# References

1 Moyer VA. Screening for glaucoma: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013 Oct 1;159(7):484–9. doi: 10.7326/0003-4819-159-6-201309170-00686. PMID: 24325017.24325017
2 Ervin A-M, Boland M, Myrowitz E, . Screening for Glaucoma: Comparative Effectiveness. Comparative Effectiveness Review No. 59. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061.) AHRQ Publication No. 12-EHC037-EF. Rockville, MD: Agency for Healthcare Research and Quality; April 2012. 2013.
3 Boland MV, Ervin AM, Friedman D, . Treatment for glaucoma: comparative effectiveness. Comparative effectiveness review no. 60. AHRQ publication No. 12-EHC038-EF. Treatment for Glaucoma: Comparative Effectiveness. 2012.
4 Boland MV, Ervin AM, Friedman DS, . Comparative effectiveness of treatments for open-angle glaucoma: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013 Feb 19;158(4):271–9. doi: 10.7326/0003-4819-158-4-201302190-00008. PMID: 23420235.23420235
5 American Academy of Ophthalmology. Primary open-angle glaucoma suspect preferred practice pattern((R)) guidelines. Ophthalmology. 2016 Jan;123(1):P112–51. doi: 10.1016/j.ophtha.2015.10.055. PMID: 26581560.26581560
6 Dielemans I, Vingerling JR, Wolfs RC, . The prevalence of primary open-angle glaucoma in a population-based study in The Netherlands. The Rotterdam Study. Ophthalmology. 1994 Nov;101(11):1851–5. doi: 10.1016/s0161-6420(94)31090-6. PMID: 7800368.7800368
7 Mitchell P, Smith W, Attebo K, . Prevalence of open-angle glaucoma in Australia. The Blue Mountains Eye Study. Ophthalmology. 1996 Oct;103(10):1661–9. doi: 10.1016/s0161-6420(96)30449-1. PMID: 8874440.8874440
8 Sommer A, Tielsch JM, Katz J, . Relationship between intraocular pressure and primary open angle glaucoma among white and black Americans: The Baltimore Eye Survey. Arch Ophthalmol. 1991;109(8):1090–5. doi: 10.1001/archopht.1991.01080080050026.1867550
9 Bathija R, Gupta N, Zangwill L, . Changing definition of glaucoma. J Glaucoma. 1998 Jun;7(3):165–9. PMID: 9627855.9627855
10 Rodriguez J, Sanchez R, Munoz B, . Causes of blindness and visual impairment in a population-based sample of U.S. Hispanics. Ophthalmology. 2002 Apr;109(4):737–43. doi: 10.1016/s0161-6420(01)01008-9. PMID: 11927431.11927431
11 Kwon M, Huisingh C, Rhodes LA, . Association between Glaucoma and At-fault Motor Vehicle Collision Involvement among Older Drivers: A Population-based Study. Ophthalmology. 2016 Jan;123(1):109–16. doi: 10.1016/j.ophtha.2015.08.043. PMID: 26459997.26459997
12 Malihi M, Moura Filho ER, Hodge DO, . Long-term trends in glaucoma-related blindness in Olmsted County, Minnesota. Ophthalmology. 2014 Jan;121(1):134–41. doi: 10.1016/j.ophtha.2013.09.003. PMID: 24823760.24823760
13 Gupta P, Zhao D, Guallar E, . Prevalence of glaucoma in the United States: The 2005-2008 National Health and Nutrition Examination Survey. Invest Ophthalmol Vis Sci. 2016 May 1;57(6):2905–13. doi: 10.1167/iovs.15-18469. PMID: 27168366.27168366
14 Klein BE, Klein R, Linton KL. Intraocular pressure in an American community. The Beaver Dam Eye Study. Invest Ophthalmol Vis Sci. 1992 Jun;33(7):2224–8. PMID: 1607232.1607232
15 Vajaranant TS, Wu S, Torres M, . The changing face of primary open-angle glaucoma in the United States: demographic and geographic changes from 2011 to 2050. Am J Ophthalmol. 2012 Aug;154(2):303–14.e3. doi: 10.1016/j.ajo.2012.02.024. PMID: 22541661.22541661
16 Varma R, Ying-Lai M, Francis BA, . Prevalence of open-angle glaucoma and ocular hypertension in Latinos: the Los Angeles Latino Eye Study. Ophthalmology. 2004 Aug;111(8):1439–48. doi: 10.1016/j.ophtha.2004.01.025. PMID: 15288969.15288969
17 Tielsch JM, Sommer A, Katz J, . Racial variations in the prevalence of primary open-angle glaucoma. The Baltimore Eye Survey. JAMA. 1991 Jul 17;266(3):369–74. PMID: 2056646.2056646
18 Stone EM, Fingert JH, Alward WL, . Identification of a gene that causes primary open angle glaucoma. Science. 1997 Jan 31;275(5300):668–70. doi: 10.1126/science.275.5300.668. PMID: 9005853.9005853
19 Kwon YH, Fingert JH, Kuehn MH, . Primary open-angle glaucoma. N Engl J Med. 2009 Mar 12;360(11):1113–24. doi: 10.1056/NEJMra0804630. PMID: 19279343.19279343
20 Heijl A, Leske MC, Bengtsson B, . Reduction of intraocular pressure and glaucoma progression: results from the Early Manifest Glaucoma Trial. Arch Ophthalmol. 2002;120(10):1268–79. doi: 10.1001/archopht.120.10.1268.12365904
21 Kass MA, Heuer DK, Higginbotham EJ, . The Ocular Hypertension Treatment Study: a randomized trial determines that topical ocular hypotensive medication delays or prevents the onset of primary open-angle glaucoma. Arch Ophthalmol. 2002;120(6):701–13. doi: 10.1001/archopht.120.6.701. PMID: 12049574.12049574
22 Kass MA, Heuer DK, Higginbotham EJ, . Assessment of Cumulative Incidence and Severity of Primary Open-Angle Glaucoma Among Participants in the Ocular Hypertension Treatment Study After 20 Years of Follow-up. JAMA Ophthalmol. 2021 Apr 15;139(5):1–9. doi: 10.1001/jamaophthalmol.2021.0341. PMID: 33856434.33856434
23 Hattenhauer MG, Johnson DH, Ing HH, . The probability of blindness from open-angle glaucoma. Ophthalmology. 1998 Nov;105(11):2099–104. doi: 10.1016/s0161-6420(98)91133-2. PMID: 9818612.9818612
24 Alward W, Feldman F, Cashwell LF. Comparison of glaucomatous progression between untreated patients with normal-tension glaucoma and patients with therapeutically reduced intraocular pressures. Collaborative Normal-Tension Glaucoma Study Group. Am J Ophthalmol. 1998 Oct;126(4):487–97. doi: 10.1016/s0002-9394(98)00223-2. PMID: 9780093.9780093
25 Gordon MO, Beiser JA, Brandt JD, . The Ocular Hypertension Treatment Study: baseline factors that predict the onset of primary open-angle glaucoma. Arch Ophthalmol. 2002 Jun;120(6):714–20; discussion 829-30. doi: 10.1001/archopht.120.6.714. PMID: 12049575.12049575
26 Le A, Mukesh BN, McCarty CA, . Risk factors associated with the incidence of open-angle glaucoma: the visual impairment project. Invest Ophthalmol Vis Sci. 2003 Sep;44(9):3783–9. doi: 10.1167/iovs.03-0077. PMID: 12939292.12939292
27 Quigley HA, West SK, Rodriguez J, . The prevalence of glaucoma in a population-based study of Hispanic subjects: proyecto VER. Arch Ophthalmol. 2001 Dec;119(12):1819–26. doi: 10.1001/archopht.119.12.1819. PMID: 11735794.11735794
28 Brandt JD, Beiser JA, Kass MA, . Central corneal thickness in the Ocular Hypertension Treatment Study (OHTS). Ophthalmology. 2001 Oct;108(10):1779–88. doi: 10.1016/s0161-6420(01)00760-6. PMID: 11581049.11581049
29 McMonnies CW. Glaucoma history and risk factors. J Optom. 2017;10(2):71–8.27025415
30 Diehl DL, Quigley HA, Miller NR, . Prevalence and significance of optic disc hemorrhage in a longitudinal study of glaucoma. Arch Ophthalmol. 1990 Apr;108(4):545–50. doi: 10.1001/archopht.1990.01070060093056. PMID: 2322157.2322157
31 Tielsch JM, Katz J, Sommer A, . Hypertension, perfusion pressure, and primary open-angle glaucoma. A population-based assessment. Arch Ophthalmol. 1995 Feb;113(2):216–21. doi: 10.1001/archopht.1995.01100020100038. PMID: 7864755.7864755
32 Crabb DP, Smith ND, Glen FC, . How does glaucoma look?: patient perception of visual field loss. Ophthalmology. 2013 Jun;120(6):1120–6. doi: 10.1016/j.ophtha.2012.11.043. PMID: 23415421.23415421
33 Sponsel WE, Shoemaker J, Trigo Y, . Frequency of sustained glaucomatous-type visual field loss and associated optic nerve cupping in Beaver Dam, Wisconsin. Clin Exp Ophthalmol. 2001 Dec;29(6):352–8. PMID: 11778803.11778803
34 American Academy of Ophthalmology. Primary Open-Angle Glaucoma. 2015. https://www.aaojournal.org/article/S0161-6420(15)01276-2/pdf Accessed September 9, 2020.
35 Garway-Heath DF, Crabb DP, Bunce C, . Latanoprost for open-angle glaucoma (UKGTS): a randomised, multicentre, placebo-controlled trial. Lancet. 2015 Apr 4;385(9975):1295–304. doi: 10.1016/s0140-6736(14)62111-5. PMID: 25533656.25533656
36 Garg A, Vickerstaff V, Nathwani N, . Primary selective laser trabeculoplasty for open-angle glaucoma and ocular hypertension: clinical outcomes, predictors of success, and safety from the laser in glaucoma and ocular hypertension trial. Ophthalmology. 2019 Sep;126(9):1238–48. doi: 10.1016/j.ophtha.2019.04.012. PMID: 31028768.31028768
37 Gazzard G, Konstantakopoulou E, Garway-Heath D, . Selective laser trabeculoplasty versus eye drops for first-line treatment of ocular hypertension and glaucoma (LiGHT): a multicentre randomised controlled trial. Lancet. 2019 Apr 13;393(10180):1505–16. doi: 10.1016/s0140-6736(18)32213-x. PMID: 30862377.30862377
38 Hasan S, Theilig T, Unterlauft JD. Comparing the efficacy of trabeculectomy and diode laser cyclophotocoagulation in primary open-angle glaucoma. Int Ophthalmol. 2019 Mar 4doi: 10.1007/s10792-019-01093-w. PMID: 30830546.30830546
39 Shah P, Bhakta A, Vanner EA, . Safety and efficacy of diode laser transscleral cyclophotocoagulation in eyes with good visual acuity. J Glaucoma. 2018 Oct;27(10):874–9. doi: 10.1097/ijg.0000000000001057. PMID: 30113509.30113509
40 Budenz DL, Barton K, Gedde SJ, . Five-year treatment outcomes in the Ahmed Baerveldt comparison study. Ophthalmology. 2015 Feb;122(2):308–16. doi: 10.1016/j.ophtha.2014.08.043. PMID: 25439606.25439606
41 Gedde SJ, Feuer WJ, Shi W, . Treatment outcomes in the primary tube versus trabeculectomy study after 1 year of follow-up. Ophthalmology. 2018 May;125(5):650–63. doi: 10.1016/j.ophtha.2018.02.003. PMID: 29477688.29477688
42 Washington University School of Medicine in St. Louis. Ocular Hypertension Treatment Study (OHTS) Risk Calculator. 2019. https://ohts.wustl.edu/risk/. Accessed September 16, 2020.
43 Hoy SM. Latanoprostene bunod ophthalmic solution 0.024%: a review in open-angle glaucoma and ocular hypertension. Drugs. 2018 May;78(7):773–80. doi: 10.1007/s40265-018-0914-6. PMID: 29761382.29761382
44 Kopczynski CC, Heah T. Netarsudil ophthalmic solution 0.02% for the treatment of patients with open-angle glaucoma or ocular hypertension. Drugs Today. 2018 Aug;54(8):467–78. doi: 10.1358/dot.2018.54.8.2849627. PMID: 30209441.30209441
45 Bar-David L, Blumenthal EZ. Evolution of glaucoma surgery in the last 25 years. Rambam Maimonides Med J. 2018 Jul 30;9(3)doi: 10.5041/rmmj.10345. PMID: 30089089.30089089
46 American Academy of Family Physicians. Glaucoma. 2019. https://www.aafp.org/patient-care/clinical-recommendations/all/glaucoma.html Accessed September 16. 2020.
47 Hark LA, Katz LJ, Myers JS, . Philadelphia telemedicine glaucoma detection and follow-up study: methods and screening results. Am J Ophthalmol. 2017 Sep;181:114–24. doi: 10.1016/j.ajo.2017.06.024. PMID: 28673747.28673747
48 Zheng C, Johnson TV, Garg A, . Artificial intelligence in glaucoma. Curr Opin Ophthalmol. 2019 Mar;30(2):97–103. doi: 10.1097/icu.0000000000000552. PMID: 30562242.30562242
49 U. S. Preventive Services Task Force. Procedure Manual. 2018. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed September 16, 2020.
50 Aspberg J, Heijl A, Bengtsson B. Screening for Open-Angle Glaucoma and Its Effect on Blindness. Am J Ophthalmol. 2021 Aug;228:106–16. doi: 10.1016/j.ajo.2021.03.030. PMID: 33823158.33823158
51 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529–36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
52 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002 Jun 15;21(11):1539–58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
53 Pazos M, Dyrda AA, Biarnes M, . Diagnostic accuracy of spectralis SD OCT automated macular layers segmentation to discriminate normal from early glaucomatous eyes. Ophthalmology. 2017 08;124(8):1218–28. doi: 10.1016/j.ophtha.2017.03.044. PMID: 28461015.28461015
54 Aksoy FE, Altan C, Yilmaz BS, . A comparative evaluation of segmental analysis of macular layers in patients with early glaucoma, ocular hypertension, and healthy eyes. J Fr Ophtalmol. 2020 Aug 21;43(9):869–78. doi: 10.1016/j.jfo.2019.12.020. PMID: 32839014.32839014
55 Aptel F, Sayous R, Fortoul V, . Structure-function relationships using spectral-domain optical coherence tomography: comparison with scanning laser polarimetry. Am J Ophthalmol. 2010 Dec;150(6):825–33. doi: 10.1016/j.ajo.2010.06.011. PMID: 20851372.20851372
56 Arnould L, De Lazzer A, Seydou A, . Diagnostic ability of spectral-domain optical coherence tomography peripapillary retinal nerve fiber layer thickness to discriminate glaucoma patients from controls in an elderly population (the MONTRACHET study). Acta Ophthalmol. 2020 Apr 24;98(8):e1009–e16. doi: 10.1111/aos.14448. PMID: 32333503.32333503
57 Asrani S, Bacharach J, Holland E, . Fixed-dose combination of netarsudil and latanoprost in ocular hypertension and open-angle glaucoma: pooled efficacy/safety analysis of phase 3 MERCURY-1 and -2. Adv Ther. 2020 04;37(4):1620–31. doi: 10.1007/s12325-020-01277-2. PMID: 32166538.32166538
58 Asrani S, Robin AL, Serle JB, . Netarsudil/Latanoprost fixed-dose combination for elevated intraocular pressure: three-month data from a randomized phase 3 trial. Am J Ophthalmol. 2019 Nov;207:248–57. doi: 10.1016/j.ajo.2019.06.016. PMID: 31229466.31229466
59 Azuara-Blanco A, Banister K, Boachie C, . Automated imaging technologies for the diagnosis of glaucoma: a comparative diagnostic study for the evaluation of the diagnostic accuracy, performance as triage tests and cost-effectiveness (GATE study). Health Technol Assess. 2016 Jan;20(8):1–168. doi: 10.3310/hta20080. PMID: 26822760.26822760
60 Bagga H, Feuer WJ, Greenfield DS. Detection of psychophysical and structural injury in eyes with glaucomatous optic neuropathy and normal standard automated perimetry. Arch Ophthalmol. 2006 Feb;124(2):169–76. doi: 10.1001/archopht.124.2.169. PMID: 16476885.16476885
61 Banister K, Boachie C, Bourne R, . Can automated imaging for optic disc and retinal nerve fiber layer analysis aid glaucoma detection? Ophthalmology. 2016 May;123(5):930–8. doi: 10.1016/j.ophtha.2016.01.041. PMID: 27016459.27016459
62 Bensinger RE, Keates EU, Gofman JD, . Levobunolol: a three-month efficacy study in the treatment of glaucoma and ocular hypertension. Arch Ophthalmol. 1985;103(3):375–8. PMID: 3883971.3883971
63 Bergstrand IC, Heijl A, Harris A. Dorzolamide and ocular blood flow in previously untreated glaucoma patients: a controlled double-masked study. Acta Ophthalmol Scand. 2002;80(2):176–82. PMID: 11952485.11952485
64 Blumberg DM, De Moraes CG, Liebmann JM, . Technology and the glaucoma suspect. Invest Ophthalmol Vis Sci. 2016 07 01;57(9):OCT80–5. doi: 10.1167/iovs.15-18931. PMID: 27409509.27409509
65 Bonomi L, Marchini G, Marraffa M, . The relationship between intraocular pressure and glaucoma in a defined population. Data from the Egna-Neumarkt Glaucoma Study. Ophthalmologica. 2001 Jan–Feb;215(1):34–8. doi: 10.1159/000050823. PMID: 11125267.11125267
66 Brubaker JW, Teymoorian S, Lewis RA, . One year of netarsudil and latanoprost fixed-dose combination for elevated intraocular pressure: Phase 3, randomized MERCURY-1 study. Ophthalmol Glaucoma. 2020 Jun 04;3(5):327–38. doi: 10.1016/j.ogla.2020.05.008. PMID: 32768361.32768361
67 Casado A, Cervero A, Lopez-de-Eguileta A, . Topographic correlation and asymmetry analysis of ganglion cell layer thinning and the retinal nerve fiber layer with localized visual field defects. PLoS One. 2019;14(9):e0222347. doi: 10.1371/journal.pone.0222347. PMID: 31509597.31509597
68 Chan MPY, Broadway DC, Khawaja AP, . Glaucoma and intraocular pressure in EPIC-Norfolk Eye Study: cross sectional study. BMJ. 2017 Sep 13;358:j3889. doi: 10.1136/bmj.j3889. PMID: 28903935.28903935
69 Charalel RA, Lin HS, Singh K. Glaucoma screening using relative afferent pupillary defect. J Glaucoma. 2014 Mar;23(3):169–73. doi: 10.1097/IJG.0b013e31826a9742. PMID: 23296370.23296370
70 Choudhari NS, George R, Baskaran M, . Can intraocular pressure asymmetry indicate undiagnosed primary glaucoma? The Chennai Glaucoma Study. J Glaucoma. 2013 Jan;22(1):31–5. doi: 10.1097/IJG.0b013e31822af25f. PMID: 21878819.21878819
71 Cifuentes-Canorea P, Ruiz-Medrano J, Gutierrez-Bonet R, . Analysis of inner and outer retinal layers using spectral domain optical coherence tomography automated segmentation software in ocular hypertensive and glaucoma patients. PLoS One. 2018;13(4):e0196112. doi: 10.1371/journal.pone.0196112. PMID: 29672563.29672563
72 Cumming RG, Ivers R, Clemson L, . Improving vision to prevent falls in frail older people: a randomized trial. J Am Geriatr Soc. 2007;55(2):175–81. PMID: 17302652.17302652
73 Dabasia PL, Fidalgo BR, Edgar DF, . Diagnostic accuracy of technologies for glaucoma case-finding in a community setting. Ophthalmology. 2015 Dec;122(12):2407–15. doi: 10.1016/j.ophtha.2015.08.019. PMID: 26411836.26411836
74 Danesh-Meyer HV, Gaskin BJ, Jayusundera T, . Comparison of disc damage likelihood scale, cup to disc ratio, and Heidelberg retina tomograph in the diagnosis of glaucoma. Br J Ophthalmol. 2006 Apr;90(4):437–41. doi: 10.1136/bjo.2005.077131. PMID: 16547323.16547323
75 Deshpande G, Gupta R, Bawankule P, . Structural evaluation of preperimetric and perimetric glaucoma. Indian J Ophthalmol. 2019 11;67(11):1843–9. doi: 10.4103/ijo.IJO_1955_18. PMID: 31638046.31638046
76 Deshpande GA, Bawankule PK, Raje DV, . Linear discriminant score for differentiating early primary open angle glaucoma from glaucoma suspects. Indian J Ophthalmol. 2019 Jan;67(1):75–81. doi: 10.4103/ijo.IJO_678_18. PMID: 30574897.30574897
77 Ehrlich JR, Radcliffe NM, Shimmyo M. Goldmann applanation tonometry compared with corneal-compensated intraocular pressure in the evaluation of primary open-angle glaucoma. BMC Ophthalmol. 2012 Sep 25;12:52. doi: 10.1186/1471-2415-12-52. PMID: 23009074.23009074
78 Epstein DL, Krug JH, Jr., Hertzmark E, . A long-term clinical trial of timolol therapy versus no treatment in the management of glaucoma suspects. Ophthalmology. 1989 Oct;96(10):1460–7. doi: 10.1016/s0161-6420(89)32688-1. PMID: 2685707.2685707
79 Field MG, Alasil T, Baniasadi N, . Facilitating glaucoma diagnosis with intereye retinal nerve fiber layer asymmetry using spectral-domain optical coherence tomography. J Glaucoma. 2016 Feb;25(2):167–76. doi: 10.1097/IJG.0000000000000080. PMID: 24921896.24921896
80 Francis BA, Varma R, Vigen C, . Population and high-risk group screening for glaucoma: the Los Angeles Latino Eye Study. Invest Ophthalmol Vis Sci. 2011 Aug 05;52(9):6257–64. doi: 10.1167/iovs.09-5126. PMID: 21245400.21245400
81 Garas A, Vargha P, Hollo G. Diagnostic accuracy of nerve fibre layer, macular thickness and optic disc measurements made with the RTVue-100 optical coherence tomograph to detect glaucoma. Eye. 2011 Jan;25(1):57–65. doi: 10.1038/eye.2010.139. PMID: 20930859.20930859
82 Gazzard G, Konstantakopoulou E, Garway-Heath D, . Selective laser trabeculoplasty versus drops for newly diagnosed ocular hypertension and glaucoma: the LiGHT RCT. Health Technol Assess. 2019 Jun;23(31):1–102. doi: 10.3310/hta23310. PMID: 31264958.31264958
83 Gordon MO, Kass MA. The Ocular Hypertension Treatment Study: design and baseline description of the participants. Arch Ophthalmol. 1999 May;117(5):573–83. doi: 10.1001/archopht.117.5.573. PMID: 10326953.10326953
84 Hammond EA, Begley PK. Screening for glaucoma: a comparison of ophthalmoscopy and tonometry. Nurs Res. 1979 Nov–Dec;28(6):371–2. PMID: 258807.258807
85 Hark LA, Myers JS, Ines A, . Philadelphia telemedicine glaucoma detection and follow-up study: confirmation between eye screening and comprehensive eye examination diagnoses. Br J Ophthalmol. 2019 Dec;103(12):1820–6. doi: 10.1136/bjophthalmol-2018-313451. PMID: 30770354.30770354
86 Hark LA, Myers JS, Pasquale LR, . Philadelphia telemedicine glaucoma detection and follow-up study: intraocular pressure measurements found in a population at high risk for glaucoma. J Glaucoma. 2019;28(4):294–301. PMID: 30946709.30946709
87 Heijl A, Bengtsson B. Long-term effects of timolol therapy in ocular hypertension: a double-masked, randomised trial. Graefes Arch Clin Exp Ophthalmol. 2000 Nov;238(11):877–83. doi: 10.1007/s004170000189. PMID: 11148810.11148810
88 Hong S, Ahn H, Ha SJ, . Early glaucoma detection using the Humphrey Matrix Perimeter, GDx VCC, Stratus OCT, and retinal nerve fiber layer photography. Ophthalmology. 2007 Feb;114(2):210–5. doi: 10.1016/j.ophtha.2006.09.021. PMID: 17270671.17270671
89 Ivers RQ, Optom B, Macaskill P, . Sensitivity and specificity of tests to detect eye disease in an older population. Ophthalmology. 2001;108(5):968–75. PMID: 11320029.11320029
90 Jones L, Garway-Heath DF, Azuara-Blanco A, . Are patient self-reported outcome measures sensitive enough to be used as end points in clinical trials?: Evidence from the United Kingdom Glaucoma Treatment Study. Ophthalmology. 2019 May;126(5):682–9. doi: 10.1016/j.ophtha.2018.09.034. PMID: 30273622.30273622
91 Kahook MY, Serle JB, Mah FS, . Long-term safety and ocular hypotensive efficacy evaluation of netarsudil ophthalmic solution: rho kinase elevated IOP treatment trial (ROCKET-2). Am J Ophthalmol. 2019 04;200:130–7. doi: 10.1016/j.ajo.2019.01.003. PMID: 30653957.30653957
92 Kamal D, Garway-Heath D, Ruben S, . Results of the betaxolol versus placebo treatment trial in ocular hypertension. Graefes Arch Clin Exp Ophthalmol. 2003 Mar;241(3):196–203. doi: 10.1007/s00417-002-0614-4. PMID: 12644943.12644943
93 Karvonen E, Stoor K, Luodonpaa M, . Diagnostic performance of modern imaging instruments in glaucoma screening. Br J Ophthalmol. 2020 Jan 16;104(10):1399–405. doi: 10.1136/bjophthalmol-2019-314795. PMID: 31949097.31949097
94 Kass MA, Gordon MO, Hoff MR, . Topical timolol administration reduces the incidence of glaucomatous damage in ocular hypertensive individuals. A randomized, double-masked, long-term clinical trial. Arch Ophthalmol. 1989 Nov;107(11):1590–8. doi: 10.1001/archopht.1989.01070020668025. PMID: 2818278.2818278
95 Katz J, Tielsch JM, Quigley HA, . Automated suprathreshold screening for glaucoma: the Baltimore Eye Survey. Invest Ophthalmol Vis Sci. 1993 Nov;34(12):3271–7. PMID: 8225862.8225862
96 Kaushik S, Kataria P, Jain V, . Evaluation of macular ganglion cell analysis compared to retinal nerve fiber layer thickness for preperimetric glaucoma diagnosis. Indian J Ophthalmol. 2018 04;66(4):511–6. doi: 10.4103/ijo.IJO_1039_17. PMID: 29582810.29582810
97 Kaushik S, Singh Pandav S, Ichhpujani P, . Retinal nerve fiber layer measurement and diagnostic capability of spectral-domain versus time-domain optical coherence tomography. Eur J Ophthalmol. 2011 Sep–Oct;21(5):566–72. doi: 10.5301/EJO.2011.6289. PMID: 21279977.21279977
98 Khouri AS, Serle JB, Bacharach J, . Once-daily netarsudil versus twice-daily timolol in patients with elevated intraocular pressure: the randomized phase 3 ROCKET-4 study. Am J Ophthalmol. 2019 Aug;204:97–104. doi: 10.1016/j.ajo.2019.03.002. PMID: 30862500.30862500
99 Kiddee W, Tantisarasart T, Wangsupadilok B. Performance of optical coherence tomography for distinguishing between normal eyes, glaucoma suspect and glaucomatous eyes. J Med Assoc Thai. 2013 Jun;96(6):689–95. PMID: 23951826.23951826
100 Kim SY, Park HY, Park CK. The effects of peripapillary atrophy on the diagnostic ability of stratus and cirrus OCT in the analysis of optic nerve head parameters and disc size. Invest Ophthalmol Vis Sci. 2012 Jul 03;53(8):4475–84. doi: 10.1167/iovs.12-9682. PMID: 22618588.22618588
101 Koh V, Tham YC, Cheung CY, . Diagnostic accuracy of macular ganglion cell-inner plexiform layer thickness for glaucoma detection in a population-based study: comparison with optic nerve head imaging parameters. PLoS One. 2018;13(6):e0199134. doi: 10.1371/journal.pone.0199134. PMID: 29944673.29944673
102 Kozobolis VP, Detorakis ET, Tsilimbaris M, . Crete, Greece glaucoma study. J Glaucoma. 2000 Apr;9(2):143–9. doi: 10.1097/00061198-200004000-00003. PMID: 10782623.10782623
103 Lai JS, Chua JK, Tham CC, . Five-year follow up of selective laser trabeculoplasty in Chinese eyes. Clin Exp Ophthalmol. 2004 Aug;32(4):368–72. doi: 10.1111/j.1442-9071.2004.00839.x. PMID: 15281969.15281969
104 Lee KM, Lee EJ, Kim TW, . Comparison of the abilities of SD-OCT and SS-OCT in evaluating the thickness of the macular inner retinal layer for glaucoma diagnosis. PLoS One. 2016;11(1):e0147964. doi: 10.1371/journal.pone.0147964. PMID: 26812064.26812064
105 Lee WJ, Na KI, Kim YK, . Diagnostic ability of wide-field retinal nerve fiber layer maps using swept-source optical coherence tomography for detection of preperimetric and early perimetric glaucoma. J Glaucoma. 2017 Jun;26(6):577–85. doi: 10.1097/IJG.0000000000000662. PMID: 28368998.28368998
106 Lee WJ, Oh S, Kim YK, . Comparison of glaucoma-diagnostic ability between wide-field swept-source OCT retinal nerve fiber layer maps and spectral-domain OCT. Eye. 2018 09;32(9):1483–92. doi: 10.1038/s41433-018-0104-5. PMID: 29789659.29789659
107 Leibowitz HM, Krueger DE, Maunder LR, . The Framingham Eye Study monograph: an ophthalmological and epidemiological study of cataract, glaucoma, diabetic retinopathy, macular degeneration, and visual acuity in a general population of 2631 adults, 1973-1975. Surv Ophthalmol. 1980 May–Jun;24(Suppl):335–610. PMID: 7444756.7444756
108 Liu S, Lam S, Weinreb RN, . Comparison of standard automated perimetry, frequency-doubling technology perimetry, and short-wavelength automated perimetry for detection of glaucoma. Invest Ophthalmol Vis Sci. 2011 Sep 21;52(10):7325–31. doi: 10.1167/iovs.11-7795. PMID: 21810975.21810975
109 Maa AY, Evans C, DeLaune WR, . A novel tele-eye protocol for ocular disease detection and access to eye care services. Telemed J E Health. 2014 Apr;20(4):318–23. doi: 10.1089/tmj.2013.0185. PMID: 24527668.24527668
110 Maa AY, McCord S, Lu X, . The impact of OCT on diagnostic accuracy of the technology-based eye care services protocol: Part II of the Technology-Based Eye Care Services Compare Trial. Ophthalmology. 2020 Oct 31;127(4):544–9. doi: 10.1016/j.ophtha.2019.10.025. PMID: 31791664.31791664
111 Maa AY, Medert CM, Lu X, . Diagnostic accuracy of technology-based eye care services: The Technology-Based Eye Care Services Compare Trial Part I. Ophthalmology. 2020 Aug 13;127(1):38–44. doi: 10.1016/j.ophtha.2019.07.026. PMID: 31522900.31522900
112 Marraffa M, Marchini G, Albertini R, . Comparison of different screening methods for the detection of visual field defects in early glaucoma. Int Ophthalmol. 1989 Jan;13(1–2):43–5. doi: 10.1007/bf02028636. PMID: 2744954.2744954
113 Medeiros FA, Martin KR, Peace J, . Comparison of latanoprostene bunod 0.024% and timolol maleate 0.5% in open-angle glaucoma or ocular hypertension: the LUNAR Study. Am J Ophthalmol. 2016 Aug;168:250–9. doi: 10.1016/j.ajo.2016.05.012. PMID: 27210275.27210275
114 Miglior S. Results of the European Glaucoma Prevention Study. Ophthalmology. 2005;112(3):366–75. doi: 10.1016/j.ophtha.2004.11.030. PMID: 15745761.15745761
115 Miglior S, Zeyen T, Pfeiffer N, . The European glaucoma prevention study design and baseline description of the participants. Ophthalmology. 2002 Sep;109(9):1612–21. doi: 10.1016/s0161-6420(02)01167-3. PMID: 12208707.12208707
116 Morejon A, Mayo-Iscar A, Martin R, . Development of a new algorithm based on FDT Matrix perimetry and SD-OCT to improve early glaucoma detection in primary care. Clin Ophthalmol. 2019;13:33–42. doi: 10.2147/OPTH.S177581. PMID: 30643378.30643378
117 Mundorf TK, Zimmerman TJ, Nardin GF, . Automated perimetry, tonometry, and questionnaire in glaucoma screening. Am J Ophthalmol. 1989 Nov 15;108(5):505–8. doi: 10.1016/0002-9394(89)90425-x. PMID: 2683793.2683793
118 Nagar M, Luhishi E, Shah N. Intraocular pressure control and fluctuation: the effect of treatment with selective laser trabeculoplasty. Br J Ophthalmol. 2009 Apr;93(4):497–501. doi: 10.1136/bjo.2008.148510. PMID: 19106150.19106150
119 Nagar M, Ogunyomade A, O’Brart DP, . A randomised, prospective study comparing selective laser trabeculoplasty with latanoprost for the control of intraocular pressure in ocular hypertension and open angle glaucoma. Br J Ophthalmol. 2005 Nov;89(11):1413–7. doi: 10.1136/bjo.2004.052795. PMID: 16234442.16234442
120 Park HY, Park CK. Structure-function relationship and diagnostic value of RNFL area Index compared with circumpapillary RNFL thickness by spectral-domain OCT. J Glaucoma. 2013 Feb;22(2):88–97. doi: 10.1097/IJG.0b013e318231202f. PMID: 23232911.23232911
121 Radius RL. Use of betaxolol in the reduction of elevated intraocular pressure. Arch Ophthalmol. 1983;101(6):898–900. PMID: 6860201.6860201
122 Rao HL, Yadav RK, Addepalli UK, . Comparing spectral-domain optical coherence tomography and standard automated perimetry to diagnose glaucomatous optic neuropathy. J Glaucoma. 2015 Jun–Jul;24(5):e69–74. doi: 10.1097/IJG.0000000000000048. PMID: 25144210.25144210
123 Ravalico G, Salvetat L, Toffoli G, . Ocular hypertension: a follow-up study in treated and untreated patients. New Trends in Ophthalmology. 1994;9(2):97–101.
124 Sall K. The efficacy and safety of brinzolamide 1% ophthalmic suspension (Azopt) as a primary therapy in patients with open-angle glaucoma or ocular hypertension. Brinzolamide Primary Therapy Study Group. Surv Ophthalmol. 2000 Jan;44 Suppl 2:S155–62. doi: 10.1016/s0039-6257(99)00107-1. PMID: 10665518.10665518
125 Sarigul Sezenoz A, Gur Gungor S, Akman A, . The diagnostic ability of ganglion cell complex thickness-to-total retinal thickness ratio in glaucoma in a caucasian population. Turk J Ophthalmol. 2020 Mar 05;50(1):26–30. doi: 10.4274/tjo.galenos.2019.19577. PMID: 32167260.32167260
126 Schulzer M, Drance SM, Douglas GR. A comparison of treated and untreated glaucoma suspects. Ophthalmology. 1991 Mar;98(3):301–7. doi: 10.1016/s0161-6420(91)32296-6. PMID: 2023749.2023749
127 Schwartz B, Lavin P, Takamoto T, . Decrease of optic disc cupping and pallor of ocular hypertensives with timolol therapy. Acta Ophthalmol Scand Suppl. 1995(215):5–21. doi: 10.1111/j.1600-0420.1995.tb00588.x. PMID: 8846250.8846250
128 Schweitzer C, Korobelnik JF, Le Goff M, . Diagnostic performance of peripapillary retinal nerve fiber layer thickness for detection of glaucoma in an elderly population: the ALIENOR Study. Invest Ophthalmol Vis Sci. 2016 Nov 01;57(14):5882–91. doi: 10.1167/iovs.16-20104. PMID: 27802518.27802518
129 Serle JB, Katz LJ, McLaurin E, . Two phase 3 clinical trials comparing the safety and efficacy of netarsudil to timolol in patients with elevated intraocular pressure: rho kinase elevated IOP treatment trial 1 and 2 (ROCKET-1 and ROCKET-2). Am J Ophthalmol. 2018 Feb;186:116–27. doi: 10.1016/j.ajo.2017.11.019. PMID: 29199013.29199013
130 Soh ZD, Chee ML, Thakur S, . Asian-specific vertical cup-to-disc ratio cut-off for glaucoma screening: an evidence-based recommendation from a multi-ethnic Asian population. Clin Exp Ophthalmol. 2020 Jul 30;48(9):1210–8. doi: 10.1111/ceo.13836. PMID: 32734654.32734654
131 Sung KR, Kim DY, Park SB, . Comparison of retinal nerve fiber layer thickness measured by Cirrus HD and Stratus optical coherence tomography. Ophthalmology. 2009 Jul;116(7):1264–70, 70.e1. doi: 10.1016/j.ophtha.2008.12.045. PMID: 19427696.19427696
132 Swamy B, Cumming RG, Ivers R, . Vision screening for frail older people: a randomised trial. Br J Ophthalmol. 2009 Jun;93(6):736–41. doi: 10.1136/bjo.2007.134650. PMID: 18614568.18614568
133 Tielsch JM, Katz J, Singh K, . A population-based evaluation of glaucoma screening: the Baltimore Eye Survey. Am J Epidemiol. 1991 Nov 15;134(10):1102–10. doi: 10.1093/oxfordjournals.aje.a116013. PMID: 1746520.1746520
134 Toris CB, Camras CB, Yablonski ME. Acute versus chronic effects of brimonidine on aqueous humor dynamics in ocular hypertensive patients. Am J Ophthalmol. 1999;128(1):8–14. PMID: 10482088.10482088
135 Vernon SA, Henry DJ, Cater L, . Screening for glaucoma in the community by non-ophthalmologically trained staff using semi automated equipment. Eye. 1990;4(Pt 1):89–97. PMID: 2182352.2182352
136 Vidas S, Popovic-Suic S, Novak Laus K, . Analysis of ganglion cell complex and retinal nerve fiber layer thickness in glaucoma diagnosis. Acta Clinica Croatica. 2017 Sep;56(3):382–90. doi: 10.20471/acc.2017.56.03.04. PMID: 29479903.29479903
137 Virgili G, Michelessi M, Cook J, . Diagnostic accuracy of optical coherence tomography for diagnosing glaucoma: secondary analyses of the GATE study. Br J Ophthalmol. 2018 05;102(5):604–10. doi: 10.1136/bjophthalmol-2017-310642. PMID: 28855198.28855198
138 Wahl J, Barleon L, Morfeld P, . The Evonik-Mainz Eye Care-Study (EMECS): development of an expert system for glaucoma risk detection in a working population. PLoS One. 2016;11(8):e0158824. doi: 10.1371/journal.pone.0158824. PMID: 27479301.27479301
139 Weinreb RN, Liebmann JM, Martin KR, . Latanoprostene bunod 0.024% in subjects with open-angle glaucoma or ocular hypertension: pooled phase 3 study findings. J Glaucoma. 2018 Jan;27(1):7–15. doi: 10.1097/ijg.0000000000000831. PMID: 29194198.29194198
140 Weinreb RN, Ong T, Scassellati Sforzolini B, . A randomised, controlled comparison of latanoprostene bunod and latanoprost 0.005% in the treatment of ocular hypertension and open angle glaucoma: the VOYAGER study. Br J Ophthalmol. 2015 Jun;99(6):738–45. doi: 10.1136/bjophthalmol-2014-305908. PMID: 25488946.25488946
141 Weinreb RN, Scassellati Sforzolini B, Vittitow J, . Latanoprostene bunod 0.024% versus timolol maleate 0.5% in subjects with open-angle glaucoma or ocular hypertension: the APOLLO Study. Ophthalmology. 2016 May;123(5):965–73. doi: 10.1016/j.ophtha.2016.01.019. PMID: 26875002.26875002
142 Wilkerson M, Cyrlin M, Lippa EA, . Four-week safety and efficacy study of dorzolamide, a novel, active topical carbonic anhydrase inhibitor. Arch Ophthalmol. 1993 Oct;111(10):1343–50. PMID: 8216014.8216014
143 Wishart PK, Batterbury M. Ocular hypertension: correlation of anterior chamber angle width and risk of progression to glaucoma. Eye (Lond). 1992;6 ( Pt 3):248–56. doi: 10.1038/eye.1992.48. PMID: 1446756.1446756
144 Xu X, Xiao H, Guo X, . Diagnostic ability of macular ganglion cell-inner plexiform layer thickness in glaucoma suspects. Medicine. 2017 Dec;96(51):e9182. doi: 10.1097/MD.0000000000009182. PMID: 29390457.29390457
145 Burr JM, Mowatt G, Hernandez R, . The clinical effectiveness and cost-effectiveness of screening for open angle glaucoma: a systematic review and economic evaluation. Health Technol Assess. 2007 Oct;11(41):iii–iv, ix–x, 1–190. doi: 10.3310/hta11410. PMID: 17927922.17927922
146 Fujimoto J, Swanson E. The development, commercialization, and impact of optical coherence tomography. Invest Ophthalmol Vis Sci. 2016 Jul 1;57(9):Oct1–oct13. doi: 10.1167/iovs.16-19963. PMID: 27409459.27409459
147 Vass C, Hirn C, Sycha T, . Medical interventions for primary open angle glaucoma and ocular hypertension. Cochrane Database Syst Rev. 2007(4)doi: 10.1002/14651858.CD003167.pub3.
148 Higginbotham EJ, Gordon MO, Beiser JA, . The ocular hypertension treatment study: topical medication delays or prevents primary open-angle glaucoma in African American individuals. Arch Ophthalmol. 2004 Jun;122(6):813–20. doi: 10.1001/archopht.122.6.813. PMID: 15197055.15197055
149 Patino CM, Varma R, Azen SP, . The impact of change in visual field on health-related quality of life the los angeles latino eye study. Ophthalmology. 2011 Jul;118(7):1310–7. doi: 10.1016/j.ophtha.2010.12.018. PMID: 21458074.21458074
150 Founti P, Bunce C, Khawaja AP, . Risk Factors for Visual Field Deterioration in the United Kingdom Glaucoma Treatment Study. Ophthalmology. 2020 Jun 12;127(12):1642–51. doi: 10.1016/j.ophtha.2020.06.009. PMID: 32540325.32540325
151 Tuulonen A, Koponen J, Alanko HI, . Laser trabeculoplasty versus medication treatment as primary therapy for glaucoma. Acta Ophthalmol (Copenh). 1989 Jun;67(3):275–80. doi: 10.1111/j.1755-3768.1989.tb01871.x. PMID: 2669435.2669435
152 AGIS Investigators. The Advanced Glaucoma Intervention Study (AGIS): 7. The relationship between control of intraocular pressure and visual field deterioration.The AGIS Investigators. Am J Ophthalmol. 2000 Oct;130(4):429–40. doi: 10.1016/s0002-9394(00)00538-9. PMID: 11024415.11024415
153 Leske MC, Heijl A, Hussein M, . Factors for glaucoma progression and the effect of treatment: the early manifest glaucoma trial. Arch Ophthalmol. 2003 Jan;121(1):48–56. doi: 10.1001/archopht.121.1.48. PMID: 12523884.12523884
154 Leske MC, Heijl A, Hyman L, . Predictors of long-term progression in the early manifest glaucoma trial. Ophthalmology. 2007 Nov;114(11):1965–72. doi: 10.1016/j.ophtha.2007.03.016. PMID: 17628686.17628686
155 Miglior S, Torri V, Zeyen T, . Intercurrent factors associated with the development of open-angle glaucoma in the European glaucoma prevention study. Am J Ophthalmol. 2007 Aug;144(2):266–75. PMID: 17543874.17543874
156 Kim M, Kim DM, Park KH, . Intraocular pressure reduction with topical medications and progression of normal-tension glaucoma: a 12-year mean follow-up study. Acta Ophthalmol. 2013 Jun;91(4):e270–5. doi: 10.1111/aos.12082. PMID: 23406253.23406253
157 Oie S, Ishida K, Yamamoto T. Impact of intraocular pressure reduction on visual field progression in normal-tension glaucoma followed up over 15 years. Jpn J Ophthalmol. 2017 Jul;61(4):314–23. doi: 10.1007/s10384-017-0519-8. PMID: 28550431.28550431
158 Rulli E, Quaranta L, Riva I, . Visual field loss and vision-related quality of life in the Italian Primary Open Angle Glaucoma Study. Sci Rep. 2018 Jan 12;8(1):619. doi: 10.1038/s41598-017-19113-z. PMID: 29330448.29330448
159 Jammal AA, Ogata NG, Daga FB, . What Is the amount of visual field loss associated with disability in glaucoma? Am J Ophthalmol. 2019 Jan;197:45–52. doi: 10.1016/j.ajo.2018.09.002. PMID: 30236774.30236774
160 Qiu M, Wang SY, Singh K, . Association between visual field defects and quality of life in the United States. Ophthalmology. 2014 Mar;121(3):733–40. doi: 10.1016/j.ophtha.2013.09.043. PMID: 24342021.24342021
161 Bayer A, Harasymowycz P, Henderer JD, . Validity of a new disk grading scale for estimating glaucomatous damage: correlation with visual field damage. Am J Ophthalmol. 2002 Jun;133(6):758–63. doi: 10.1016/s0002-9394(02)01422-8. PMID: 12036666.12036666
162 Guthauser U, Flammer J, Niesel P. The relationship between the visual field and the optic nerve head in glaucomas. Graefes Arch Clin Exp Ophthalmol. 1987;225(2):129–32. doi: 10.1007/bf02160344. PMID: 3582996.3582996
163 Miglior S, Brigatti L, Lonati C, . Correlation between the progression of optic disc and visual field changes in glaucoma. Curr Eye Res. 1996 Feb;15(2):145–9. doi: 10.3109/02713689608997407. PMID: 8670722.8670722
164 Lee KH, Park KH, Kim DM, . Relationship between optic nerve head parameters of Heidelberg Retina Tomograph and visual field defects in primary open-angle glaucoma. Korean J Ophthalmol. 1996 Jun;10(1):24–8. doi: 10.3341/kjo.1996.10.1.24. PMID: 8755198.8755198
165 Hitchings RA, Anderton S. Identification of glaucomatous visual field defects from examination of monocular photographs of the optic disc. Br J Ophthalmol. 1983 Dec;67(12):822–5. doi: 10.1136/bjo.67.12.822. PMID: 6671098.6671098
166 Keltner JL, Johnson CA, Anderson DR, . The association between glaucomatous visual fields and optic nerve head features in the Ocular Hypertension Treatment Study. Ophthalmology. 2006 Sep;113(9):1603–12. PMID: 16949445.16949445
167 World Health Organization. Global data on visual impairments 2010. World Health Organization; 2010. http://www.who.int/blindness/GLOBALDATAFINALforweb.pdf. Accessed September 16, 2020.
168 Colenbrander A. Visual standards: aspects and ranges of vision loss with emphasis on population surveys International Council of Ophthalmology. Sydney, Australia: 2002. http://www.icoph.org/downloads/visualstandardsreport.pdf Accessed September 16, 2020.
169 Summary of visual acuity and bioptic telescope requirements by state Macular Degeneration Support. Grandview, MO: 2014. http://www.mdsupport.org/library/summarychart.pdf. Accessed September 16, 2020.
170 Chou R, Dana T, Bougatsos C, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Screening for Impaired Visual Acuity in Older Adults: A Systematic Review to Update the 2009 U.S. Preventive Services Task Force Recommendation. Rockville (MD): Agency for Healthcare Research and Quality (US); 2016.
171 Suner IJ, Kokame GT, Yu E, . Responsiveness of NEI VFQ-25 to changes in visual acuity in neovascular AMD: validation studies from two phase 3 clinical trials. Invest Ophthalmol Vis Sci. 2009 Aug;50(8):3629–35. doi: 10.1167/iovs.08-3225. PMID: 19255158.19255158
172 Lindblad AS, Clemons TE. Responsiveness of the National Eye Institute Visual Function Questionnaire to progression to advanced age-related macular degeneration, vision loss, and lens opacity: AREDS Report no. 14. Arch Ophthalmol. 2005 Sep;123(9):1207–14. PMID: 16157800.16157800
173 Chang TS, Bressler NM, Fine JT, . Improved vision-related function after ranibizumab treatment of neovascular age-related macular degeneration: results of a randomized clinical trial. Arch Ophthalmol. 2007 Nov;125(11):1460–9. PMID: 17998507.17998507
174 Clemons TE, Chew EY, Peto T, . Responsiveness and the minimal clinically important difference for the NEI VFQ-25 in patients with Macular Telangectasia Type 2 (MacTel Type 2). Invest Ophthalmol Vis Sci. 2015;56(7):1360.
175 Gillespie BW, Musch DC, Niziol LM, . Estimating minimally important differences for two vision-specific quality of life measures. Invest Ophthalmol Vis Sci. 2014 Jun 06;55(7):4206–12. doi: 10.1167/iovs.13-13683. PMID: 24906863.24906863
176 Alibhai AY, Or C, Witkin AJ. Swept source optical coherence tomography: a review. Curr Ophthalmol Rep. 2018;6(1):7–16.
177 Kitazawa Y. The effect of timolol on topographic features of the optic disk in ocular hypertension. Chibret International Journal of Ophthalmology. 1990;7(1):14–7.
178 Kostanyan T, Wollstein G, Schuman JS. New developments in optical coherence tomography. Curr Opin Ophthalmol. 2015;26(2):110–5. doi: 10.1097/ICU.0000000000000133. PMID: 25594766.25594766
179 Bengtsson B, Andersson S, Heijl A. Performance of time-domain and spectral-domain optical coherence tomography for glaucoma screening. Acta Ophthalmol. 2012 Jun;90(4):310–5. doi: 10.1111/j.1755-3768.2010.01977.x. PMID: 20946342.20946342
180 U.S. Food and Drug Administration. Proposed Regulatory Framework for Modifications to Artificial Intelligence/Machine Learning (AI/ML) - Based Software as a Medical Device (SaMD). https://www.fda.gov/media/122535/download. Accessed September 11, 2020.
181 Sommer A, Tielsch JM, Katz J, . Racial differences in the cause-specific prevalence of blindness in east Baltimore. N Engl J Med. 1991 Nov 14;325(20):1412–7. doi: 10.1056/nejm199111143252004. PMID: 1922252.1922252
182 Elam AR, Andrews C, Musch DC, . Large disparities in receipt of glaucoma care between enrollees in medicaid and those with commercial health insurance. Ophthalmology. 2017;124(10):1442–8. doi: 10.1016/j.ophtha.2017.05.003. PMID: 28583710.28583710
183 Murakami Y, Lee BW, Duncan M, . Racial and ethnic disparities in adherence to glaucoma follow-up visits in a county hospital population. Arch Ophthalmol. 2011 Jul;129(7):872–8. doi: 10.1001/archophthalmol.2011.163. PMID: 21746977.21746977
184 Stein JD, Talwar N, Laverne AM, . Racial disparities in the use of ancillary testing to evaluate individuals with open-angle glaucoma. Arch Ophthalmol. 2012 Dec;130(12):1579–88. doi: 10.1001/archophthalmol.2012.1325. PMID: 23229700.23229700
185 The Advanced Glaucoma Intervention Study (AGIS). 4. Comparison of treatment outcomes within race. Seven-year results. Ophthalmology. 1998 Jul;105(7):1146–64. doi: 10.1016/s0161-6420(98)97013-0. PMID: 9663215.9663215
186 Lichter PR, Musch DC, Gillespie BW, . Interim clinical outcomes in the collaborative initial glaucoma treatment study comparing initial treatment randomized to medications or surgery. Ophthalmology. 2001 Nov;108(11):1943–53. doi: 10.1016/s0161-6420(01)00873-9. PMID: 11713061.11713061