# Chapter 3 Results

A total of 6,225 new references from electronic database searches and manual searches of recently published studies were reviewed and 1,003 full-text papers were evaluated for inclusion. We included a total of 83 studies (in 96 publications) with 75,887 total participants^16,21,35,37,53–144^ Sixty-seven studies were newly identified as part of this update and 16 were carried forward from the previous USPSTF reviews. Included studies and quality ratings are described in Appendix B.

## Key Question 1 What Are the Effects of Screening for OAG vs. No Screening on a) IOP, Visual Field Loss, Visual Acuity, or Optic Nerve Damage or b) Visual Impairment, Quality of Life, or Function?

### Summary

- One trial (N=616) of frail elderly persons found no difference between vision screening, including components for glaucoma, versus no screening on vision outcomes (mean logarithm of the minimum angle of resolution [logMAR] distance visual acuity scores 0.27 vs. 0.25, p=0.32, and mean logMAR near visual acuity scores −0.01 vs. −0.03, p=0.26) and vision-related quality of life (National Eye Institute Visual Function Questionnaire-25 [NEI-VFQ-25] mean composite scores 84.3 vs. 86.4, p=0.49) after 1 year.

### Evidence

The prior screening CER included no trials comparing screening with no screening.^2^ We identified one good-quality trial (n=616) conducted in Australia comparing vision screening by an optometrist with no screening that included components relevant for diagnosis of glaucoma (IOP, direct ophthalmoscopy, and visual field) as well as other visual testing (visual acuity, contrast sensitivity, and slit lamp examination; Appendix B Table 1).^132^ In the screened group, interventions for screen-positive persons included referral to an ophthalmologist or public hospital eye clinic and/or an occupational therapist (for home modifications, mobility training, or a cane); those in the control group received no vision assessment or intervention. The mean age was 81 years and 68 percent were female; race and ethnicity were not reported. Thirty-one percent of participants needed help with activities of daily living at baseline and 52 percent were taking more than four medications. At baseline, 46 percent of participants had experienced a fall in the past year. At baseline, mean visual acuity was 0.22 logMAR (Snellen 20/30), the mean NEI-VFQ-25 score was 85.5 (scale 0 to 100, higher is better), 63 percent had cataracts, 39 percent had undergone cataract surgery, and 98 percent wore glasses. Fourteen percent of patients had glaucoma at baseline and 50 percent self-reported vision as “good.” In addition to appropriate randomization, the trial blinded outcome assessors and data analysts and attrition was low (11% screening arm and 16% control arm; Appendix B Table 2). Nearly half (48.7%) of the patients in the screening arm were judged to need treatment, though only 5.5 percent of patients judged to need treatment were referred for glaucoma management. Other interventions were new glasses (29.8%), referral for cataract surgery (4.9%), referral for age-related macular degeneration (AMD) (1.6%), and referral to an occupational therapist (7.7%).

At 1 year, there were no differences in vision parameters or vision-related quality of life. Mean distance visual acuity was 0.27 vs. 0.25 logMAR (p=0.32), mean near visual acuity −0.01 vs. −0.03 logMAR (p=0.26), and NEI-VFQ-25 mean composite scores were 84.3 vs. 86.4 (p=0.49). Nearly three-quarters of patients in the control group reported having seen an eye care professional in the 12 months prior to study, which could have attenuated potential benefits of screening.

## Key Question 2 What Are the Harms of Screening for OAG vs. No Screening?

### Summary

- One trial (n=616) found screening associated with an increased risk for falls versus no screening (incidence rate ratio 1.57, 95% CI 1.20 to 2.05, and risk of one or more falls 65% vs. 50%, RR 1.31, 95% CI 1.13 to 1.50); screening was associated with increased risk for fractures that was not statistically significant (RR 1.74, 95% CI 0.97 to 3.11).

### Evidence

No trial in the prior screening CER compared harms of screening with no screening.^2^ A previously-described trial^132^ of vision screening (including components for identification of glaucoma) versus no screening in frail elderly reported risk of falls and fracture (Appendix B Table 1).^72^ In the trial, 46 percent of patients had fallen in the past year. Although the trial hypothesized that screening would reduce the risk of falls, screening was associated with increased incidence of falls (758 vs. 516 falls, incidence rate ratio 1.57, 95% CI 1.20 to 2.05), risk of one or more falls (65% vs. 50%, RR 1.31, 95% CI 1.13 to 1.50), and risk of two or more falls (38% vs. 31%, RR 1.24, 95% CI 0.99 to 1.54) versus no screening. Screening was also associated with increased risk of fracture, though the difference was just above the threshold for statistical significance (10% vs. 5.7%, RR 1.74, 95% CI 0.97 to 3.11, p=0.06).

## Key Question 3 What Are the Effects of Referral to an Eye Health Provider vs. No Referral on a) IOP, Visual Field Loss, Visual Acuity, or Optic Nerve Damage or b) Visual Impairment, Quality Of Life, or Function?

No eligible study compared effects of referral to an eye health provider for glaucoma with no referral.

## Key Question 4 What Is the Accuracy of Screening for Diagnosis of OAG?

### Summary

- Retinal nerve fiber layer thickness on spectral domain-OCT was associated with a pooled sensitivity of 0.79 (95% CI 0.75 to 0.83) and specificity of 0.92 (95% CI 0.87 to 0.96) for distinguishing between glaucomatous eyes and controls, based on 15 studies (N=4,242); the pooled AUROC curve was 0.90 (95% CI 0.86 to 0.93), based on 16 studies (N=4,060).
- Ganglion cell complex thickness on spectral domain-OCT was associated with a pooled sensitivity of 0.74 (95% CI 0.68 to 0.80) and specificity of 0.91 (95% CI 0.80 to 0.96) for distinguishing between glaucomatous eyes and controls, based on nine studies (N=1,522); the pooled AUROC curve was 0.88 (95% CI 0.84 to 0.92), based on six studies (N=765).
- Tonometry was associated with a pooled sensitivity of 0.48 (95% CI 0.31 to 0.66) and specificity of 0.94 (95% CI 0.90 to 0.96), based on 13 studies (N=32,892).
- The Humphrey Visual Field Analyzer was associated with a pooled sensitivity of 0.87 (95% CI 0.69 to 0.95) and specificity of 0.82 (95% CI 0.66 to 0.92) for distinguishing between glaucomatous eyes and controls, based on six studies (N=11,244).
- Evidence on diagnostic accuracy was limited for other screening tests: cup-to-disc ratio on spectral domain-OCT, swept source-OCT, optic disc photography, ophthalmoscopy/biomicroscopy/stereoscopy, pachymetry, and afferent papillary defect.
- One pilot study (n=56) and a followup study (n=256) found a telemedicine screening intervention performed in a primary care setting had variable sensitivity but high specificity for identifying persons with glaucoma compared with a face-to-face evaluation by an ophthalmologist.

### Evidence

The prior screening CER^2^ included a systematic review^145^ and 83 additional studies on the diagnostic accuracy of tests for glaucoma. Since the prior screening CER, several diagnostic tests have been superseded by newer technologies and are not included in this review. For example, for imaging the optic nerve and retinal structures, OCT has superseded Heidelberg retina tomography and scanning laser polarimetry; for evaluating visual field loss, the Humphrey Field Analyzer has superseded frequency doubling technology. In addition, the prior screening CER included case-control studies, which were excluded from this review, and had an emphasis on comparative diagnostic accuracy, which was not the focus of this review. The prior screening CER concluded that it was unclear whether any one test or combination of tests was suitable for glaucoma screening in the general population, due to the lack of a definitive diagnostic reference standard for glaucoma and heterogeneity in the design and conduct of the studies.

This review includes 53 diagnostic accuracy studies (sample sizes 46 to 8623, N=65,464 in 59 publications.) (Table 1; Appendix B Tables 3–4)^16,53–56,59–61,64,65,67–71,73–77,79–81,84–86,88,89,93,95–97,99–102,104–112,116,117,120,122,125,128,130,131,133,135–138,144^ The largest groups of studies evaluated spectral domain-OCT (k=29, N=11,434) and tonometry (k=17, N=49,742), followed by visual fields (k=10, N=11,633), ophthalmoscopy/biomicroscopy/stereopscopy (k=3, N=17,519), optic disc photography (k=4, N=3,133), pachymetry (k=2, N=6,129), telemedicine (k=2, N=308), and afferent pupillary defect (k=1, N=107). Most studies evaluated more than one test of diagnostic accuracy. Forty-six studies included a single eye per participant in the analysis, and six studies^75,93,101,112,116,122^ allowed two eyes per participant (the number of eyes analyzed was unclear in one study^105^). In most studies, the reference standard was based on findings related to ophthalmic structure (e.g., appearance of optic disc) as well as function (e.g., visual fields), though exact criteria differed (Appendix B Table 3).

Table 1 Diagnostic Accuracy, Pooled Analyses

Sensitivity and Specificity

Pooled analysis | # trials | N | Sensitivity (95% CI) | Specificity (95% CI)
RNFL thickness | 15 | 4242 | 0.79 (0.75 to 0.83) | 0.92 (0.87 to 0.96)
- Healthy eye controls | 9 | 2404 | 0.81 (0.74 to 0.86) | 0.96 (0.89 to 0.99)
- Glaucoma suspect controls | 3 | 1130 | Range 0.77 to 0.85 | Range 0.79 to 0.87
- Ocular hypertension + healthy controls | 1 | 81 | 0.78 (0.60 to 0.91)^*^ | 0.92 (0.80 to 0.98)^*^
- Ocular hypertension controls | 2 | 228 | 0.59 and 0.80 | 0.81 and 0.96
- Not glaucoma | 1 | 532 | 0.77 (0.62 to 0.89) | 0.88 (0.85 to 0.91)
- Restricted to overall mean RNFL | 12 | 3819 | 0.79 (0.74 to 0.84) | 0.90 (0.85 to 0.93)
- Good quality | 3 | 2400 | Range 0.65 to 0.81 | Range 0.79 to 0.90
- Fair quality | 12 | 1880 | 0.80 (0.74 to 0.85) | 0.94 (0.88 to 0.97)
GCC thickness | 9 | 1522 | 0.74 (0.68 to 0.80) | 0.91 (0.80 to 0.96)
- Healthy eye controls | 6 | 1145 | 0.76 (0.66 to 0.83) | 0.92 (0.86 to 0.96)
- Glaucoma suspect controls | 1 | 201 | 0.77 (0.66 to 0.86)^*^ | 0.76 (0.67 to 0.83)^*^
- Ocular hypertension controls | 1 | 95 | 0.75 (0.57 to 0.89)^*^ | 0.59 (0.46 to 0.71)^*^
- Healthy + ocular hypertension controls | 1 | 81 | 0.66 (0.47 to 0.81)^*^ | 1.00 (0.93 to 1.00)^*^
- Restricted to studies that utilized inner plexiform layer or ganglion cell layer | 5 | 998 | 0.73 (0.60 to 0.83) | 0.95 (0.87 to 0.98)
- Good quality | 1 | 456 | 0.62 (0.41 to 0.80)^*^ | 0.93 (0.91 to 0.96)^*^
- Fair quality | 8 | 542 | 0.75 (0.68 to 0.81) | 0.91 (0.78 to 0.97)
Intraocular pressure | 13 | 32892 | 0.48 (0.31 to 0.66) | 0.94 (0.90 to 0.96)
- Healthy or non-glaucoma controls | 12 | 28726 | 0.47 (0.29 to 0.66) | 0.94 (0.90 to 0.97)
- Probable glaucoma vs. not probable glaucoma | 1 | 4166 | 0.61 (0.56 to 0.67)^*^ | 0.92 (0.91 to 0.92)^*^
- Goldmann tonometry | 4 | 11690 | 0.66 (0.36 to 0.87) | 0.95 (0.92 to 0.98)
- Other tonometry methods | 9 | 21202 | 0.39 (0.22 to 0.58) | 0.93 (0.87 to 0.97)
- Good quality | 2 | 6587 | 0.24 (0.19 to 0.30); 0.19 (0.07 to 0.39) | 0.97 (0.97 to 0.97); 0.89 (0.86 to 0.92)
- Fair quality | 11 | 26305 | 0.54 (0.34 to 0.72) | 0.94 (0.89 to 0.97)
HFA visual fields | 6 | 11244 | 0.87 (0.69 to 0.95) | 0.82 (0.66 to 0.92)
- Good quality | 2 | 6082 | 0.88 (0.83 to 0.92)^*^ | 0.64 (0.64 to 0.65)^*^
- Fair quality | 5 | 5162 | Range 0.65 to 1.00^†^ | Range 0.64 to 1.00^†^

AUROC

Pooled analysis | # trials | N | AUROC (95% CI)
RNFL thickness | 16 | 4060 | 0.90 (0.86 to 0.93)
- Healthy eye controls | 10 | 2262 | 0.92 (0.89 to 0.94)
- Glaucoma suspect controls | 4 | 496 | 0.90 (0.86 to 0.94)
- Ocular hypertension controls | 3 | 319 | 0.80 (0.71 to 0.89)
- Glaucoma suspect + healthy controls | 1 | 91 | 0.91 (0.81 to 1.00)^*^
- Glaucoma suspect + ocular hypertension controls | 1 | 883 | 0.83 (0.79 to 0.87)^*^
- Not glaucoma | 1 | 532 | 0.89 (0.85 to 0.94)^*^
- Overall mean RNFL | 12 | 3634 | 0.92 (0.89 to 0.94)
- Good quality | 2 | 1944 | 0.87 (0.80 to 0.94)
- Fair quality | 14 | 2116 | 0.90 (0.86 to 0.94)
Ganglion cell analysis | 6 | 765 | 0.88 (0.84 to 0.92)
- Healthy eye controls | 5 | 564 | 0.87 (0.82 to 0.92)
- Glaucoma suspect | 2 | 354 | 0.84 (0.69 to 1.00)
- Ocular hypertension | 2 | 224 | 0.76 (0.70 to 0.82)
- Restricted to studies of ganglion cell complex | 2 | 211 | 0.87 (0.72 to 1.00)
HFA visual fields
- HFA SITA-Standard 24-2 mean deviation | 3 | 288 | 0.830.70 to 0.97)
- HFA SITA-Standard 24-2 pattern standard deviation | 2 | 242 | 0.87 (0.76 to 0.99)

Abbreviations: AUROC = area under the receiver operating characteristic curve; CI = confidence interval; GCC = ganglion cell complex; HFA = Humphrey Field Analyzer; IOP = intraocular pressure; MD = mean deviation; PSD = pattern standard deviation; RNFL = retinal nerve fiber layer; SITA = Swedish Interactive Thresholding Algorithm.

* Estimate from a single study (not pooled).

† Pooled estimate was not produced because the model did not converge.

Mean age ranged from 38.2 years to 82.2 years (median 58 years). The proportion of females enrolled ranged from 13.3 to 72.3 percent (median 55%) in studies that reported gender. Twelve studies reported race/ethnicity. Two studies restricted enrollment to Asian persons,^130,131^ one study restricted enrollment to Latino persons,^80^ and one study restricted enrollment to White persons.^81^ In the other studies, the proportion of White participants ranged from 17 to 99 percent. In two of the studies, the majority of participants (61% and 62%) were Black.^86,110^ Studies were conducted in Western Europe (N=16), the U.S. (N=13), and Asia (N=18); two studies were conducted in Turkey and one study each was conducted in Hungary, Australia, New Zealand, and Croatia. The prevalence of glaucoma ranged from 1.1^93^ to 73.6^100^ percent. Seven studies were rated good quality^56,59,73,80,109,111,122^ and the remainder were rated fair quality (Appendix B Table 5). Methodological limitations in the fair-quality studies included lack of blinding and uncertain interval between index and reference tests.

### Tests of Ophthalmic Structure

The diagnosis of glaucoma is typically made by using tests of both ophthalmic structure and function together. Tests of eye structure include OCT, optic disc photography, and clinical examination with an ophthalmoscope or slit-lamp (biomicroscopy). Thirty studies (N=11,618) evaluated OCT (Appendix B Tables 3–4). Four studies were rated good quality (N=2,575)^56,59,73,122^ and 27 were rated fair quality (N=8,859)^53–55,64,67,71,75,76,79,81,93,96,97,99–101,104–106,116,120,125,128,131,136,144^ (Appendix B Table 5).

#### Optical Coherence Tomography

There are three types of OCT: time domain, spectral domain, and swept source. Time domain-OCT represents the earliest technology and became commercially available in 1996.^146^ Time domain-OCTs have a movable reference light and can produce 400 axial scans of the eye per second. Time domain-OCT was not included in this review as it has been superseded by spectral domain-OCT, which entered the market in 2006, uses a fixed reference light, and can produce 50,000 axial scans per second, resulting in images with greater resolution.^146^ Swept source is the latest OCT technology and is even faster than spectral domain-OCT (200,000 or more axial scans per second), but is not yet in widespread use. The primary parameters used on OCT are the thickness of the retinal nerve fiber layer and the ganglion cell complex.

The prior screening CER included 48 studies of OCT. Based on average retinal nerve fiber layer estimates on OCT, sensitivity ranged from 24 to 96 percent and specificity ranged from 66 to 100 percent. Many studies (k=34) in the prior screening CER used time domain-OCT and are not included in this review. Two studies of spectral domain-OCT were carried forward from the prior USPSTF report (k=2, n=283),^55,131^ and we identified 27 new studies (N=14,199). Twenty-nine studies (N=14,482) evaluated spectral domain-OCT^53–56,59,64,67,71,73,75,76,79,81,93,96,97,99–101,104,106,116,120,122,125,128,136,144^ and three studies (n=120, 145, and not reported) assessed swept source-OCT.^104–106^

##### Retinal Nerve Fiber Layer Thickness

Retinal nerve fiber layer thickness on spectral domain-OCT was associated with a pooled sensitivity of 0.79 (95% CI 0.75 to 0.83) and specificity of 0.92 (95% CI 0.87 to 0.96) for diagnosing eyes with glaucoma versus no glaucoma (healthy eyes, glaucoma suspect, and/or ocular hypertension), based on 15 studies (N=4,242)^53,54,56,59,64,71,73,76,81,99,104,106,128,131,136^ (Table 2, Figures 2–3). Pooled estimates were similar when the analysis was limited to studies in which the control group was healthy eyes (9 studies, N=2,404, sensitivity 0.81, 95% CI 0.74 to 0.86 and specificity 0.96, 95% CI 0.89 to 0.99).^53,54,56,73,81,99,104,106,131^ Pooled estimates were also similar when the analysis was limited to studies that measured retinal nerve fiber layer based on the mean overall thickness as opposed to mean inferior,^81^ mean outer/inferior,^71,104^ or mean temporal/inferior retinal nerve fiber layer thickness^53,54^ (12 studies, N=3,819, sensitivity 0.79, 95% CI 0.74 to 0.84 and specificity 0.90, 95% CI 0.85 to 0.93),^56,59,64,71,73,76,99,104,106,128,131,136^ and when results were limited to the 12 fair-quality studies (N=1,880, sensitivity 0.80, 95% CI 0.74 to 0.85; specificity 0.94, 95% CI 0.88 to 0.97).^53,54,64,71,76,81,99,104,106,128,131,136^ In three good-quality studies (N=2,400),^56,59,73^ sensitivity ranged from 0.69 to 0.81 and specificity ranged from 0.79 to 0.94. One study (n=129) also reported accuracy of retinal nerve fiber layer thickness for diagnosing ocular hypertension versus healthy eyes (sensitivity 0.08, 95% CI 0.005 to 0.63; specificity 1.00, 95% CI 0.96 to 1.00).^81^

Table 2 Sensitivity and Specificity, Spectral Domain-OCT Retinal Nerve Fiber Layer Thickness

Author, year | N | Glaucoma | Control | Sensitivity (95% CI) | Specificity (95% CI)
Aksoy, 2020^54^ | 131 | Early glaucoma | Healthy | 0.81 (0.70 to 0.90) | 0.96 (0.87 to 0.99)
Aksoy, 2020^54^ | 133 | Early glaucoma | OHT | 0.80 (0.68 to 0.89) | 0.96 (0.88 to 0.99)
Arnould, 2020^56^ | 1061 | Glaucoma | Healthy | 0.81 (0.71 to 0.88) | 0.87 (0.85 to 0.89)
Azuara-Blanco, 2016^59^ | 883 | Glaucoma | Glaucoma Suspect + OHT | 0.77 (0.69 to 0.83) | 0.79 (0.75 to 0.81)
Blumberg, 2016^64^ | 46 | Glaucoma | Glaucoma Suspect | 0.81 (0.63 to 0.93) | 0.87 (0.60 to 0.98)
Cifuentes-Canorea, 2018^71^ | 95 | Early glaucoma | OHT | 0.59 (0.41 to 0.76) | 0.81 (0.69 to 0.90)
Dabasia, 2015^73^ | 456 | POAG | Healthy | 0.69 (0.48 to 0.86) | 0.94 (0.92 to 0.96)
Deshpande, 2019^76^ | 201 | Early glaucoma | Glaucoma suspect | 0.85 (0.75 to 0.92) | 0.84 (0.77 to 0.90)
Garas, 2011^81^ | 250 | Perimetric + PPG | Healthy | 0.69 (0.62 to 0.77) | 1.00 (0.96 to 1.00)
Kiddee, 2013 | 83 | Glaucoma | Healthy | 0.90 (0.77 to 0.97 | 1.00 (0.90 to 1.00)
Lee, 2016^164^ | 120 | POAG | Healthy | 0.82 (0.70 to 0.90) | 0.82 (0.70 to 0.90)
Lee, 2018a^106^ | 146^*^ | Early glaucoma | Healthy | 0.93 (0.84 to 0.98) | 0.92 (0.78 to 0.98)
Pazos, 2017^53^ | 80 | Early glaucoma | Healthy | 0.88 (0.73 to 0.96) | 0.95 (0.83 to 0.99)
Schweitzer, 2016^128^ | 532 | Glaucoma | Nonglaucoma | 0.77 (0.62 to 0.89) | 0.88 (0.85 to 0.91)
Sung, 2009^131^ | 115 | Glaucoma | Healthy | 0.64 (0.50 to 0.76) | 1.00 (0.94 to 1.00
Vidas, 2017^136^ | 81 | Glaucoma | No glaucoma | 0.78 (0.60 to 0.91) | 0.92 (0.80 to 0.98)

Abbreviations: CI = confidence interval; OCT = optical coherence tomography; OHT = ocular hypertension; POAG = primary open angle glaucoma; PPG = preperimetric glaucoma (no visual field defects).

* Includes 36 patients with preperimetric glaucoma; n=108 in the analysis.

Figure 2 Glaucoma vs. Control, Spectral Domain-OCT Sensitivity and Specificity for Retinal Nerve Fiber Layer Thickness

Abbreviations: CI = confidence interval; df = degrees of freedom; OCT = optical coherence tomography.

Figure 2 is a forest plot examining Glaucoma vs. Control, Spectral Domain-OCT Sensitivity and Specificity for Retinal Nerve Fiber Layer Thickness. The pooled sensitivity is 0.79 (95% CI 0.75 to 0.83) with an I-squared value of 70%. The pooled specificity is 0.92 (95% CI 0.87 to 0.96) with an I-squared value of 91%.

Figure 3 Glaucoma vs. Control, Spectral Domain-OCT Retinal Nerve Fiber Layer Thickness

Abbreviations: HSROC = hierarchical summary receiver operating characteristic; OCT = optical coherence tomography.

Figure 3 is a visual representation of the hierarchical summary receiver operating characteristic curve for Glaucoma vs. Control, Spectral Domain-OCT Retinal Nerve Fiber Layer Thickness.

Five studies on diagnostic accuracy of retinal nerve fiber layer thickness on spectral domain-OCT were not pooled because they were based on the inter-eye retinal nerve fiber layer thickness asymmetry^79^ or because they evaluated more than one eye per participant.^75,93,101,122^ Details of these studies are shown in Appendix B Tables 3 and 4.

Retinal nerve fiber layer on spectral domain-OCT was associated with high discrimination for distinguishing glaucomatous eyes from non-glaucoma, with a pooled AUROC curve of 0.90 (95% CI 0.86 to 0.93, I^2^=96%), based on 16 studies (N=4,060)^53–56,59,64,71,76,96,97,99,100,104,106,120,128^ (Figure 4). Discrimination was similar for the two good-quality studies (N=1,944, pooled AUROC 0.87, 95% CI 0.80 to 0.94, I^2^=86%)^56,59^ and 14 fair-quality studies (N=2,116, pooled AUROC 0.90, 95% CI 0.86 to 0.94, I^2^=97%).^53–55,64,71,76,97,99,100,104,106,120,128^ All studies reported an AUROC greater than or equal to 0.83, with the exception of two studies that reported an AUROC of 0.78.^54,71^ Results were similar in a sensitivity analysis restricted to studies that utilized overall mean retinal nerve fiber layer thickness (12 studies, N=3,634, AUROC 0.92, 95% CI 0.89 to 0.94, I^2^=80%) and in an analysis stratified according to whether the non-glaucoma group was healthy eyes (10 studies, N=2,262, AUROC 0.92, 95% CI 0.89 to 0.94, I^2^=84%),^53–56,96,99,100,104,106,120^ glaucoma suspects (4 studies, N=496, AUROC, 0.90, 95% CI 0.86 to 0.94, I^2^=51%),^64,76,96,99^ or ocular hypertension (3 studies, N=319, AUROC 0.80, 95% CI 0.71 to 0.89, I^2^=87%)^54,71,96^ (Figure 5).

Figure 4 AUROC, Spectral Domain-OCT Retinal Nerve Fiber Layer Thickness by Comparison

Abbreviations: AUROC = area under the receiver operating characteristic curve; CI = confidence interval; ES = estimate; OCT = optical coherence tomography.

Figure 4 is a forest plot examining AUROC, Spectral Domain-OCT Retinal Nerve Fiber Layer Thickness by Comparison. The pooled AUROC is 0.90 (95% CI 0.86 to 0.93) with an I-squared value of 96.3%.

Figure 5 AUROC Curves, Spectral Domain-OCT Retinal Nerve Fiber Layer Thickness

Abbreviations: AUROC = area under the receiver operating characteristic curve; CI = confidence interval; ES = estimate; OCT = optical coherence tomography.

Figure 5 is a forest plot examining AUROC, Spectral Domain-OCT Retinal Nerve Fiber Layer Thickness. The subtotal estimate is 0.92 (0.89 to 0.94) for the glaucoma vs. healthy comparison. The subtotal estimate is 0.83 (0.79 to 0.87) for the glaucoma vs. glaucoma suspect/OHT comparison. The subtotal estimate is 0.90 (0.86 to 0.87) for the glaucoma vs. glaucoma suspect comparison. The subtotal estimate is 0.80 (0.71 to 0.89) for the glaucoma vs. OHT comparison. The subtotal estimate is 0.91 (0.81 to 1.00) for the glaucoma vs. glaucoma suspect/healthy comparison. The subtotal estimate is 0.89 (0.84 to 0.94) for the glaucoma vs. not glaucoma comparison.

Three studies (N=364) of retinal nerve fiber layer reported a pooled AUROC of 0.76 (95% 0.63 to 0.90, I^2^=83%) for discrimination of glaucoma suspect from healthy eyes.^55,96,97^ One study (n=122) of retinal nerve fiber layer reported an AUROC of 0.64 (95% CI 0.54 to 0.75) for discrimination of ocular hypertension from healthy eyes.^96^ Four other studies reported discrimination of retinal nerve fiber layer but were not pooled due to inadequate data (N=1,335)^73,125,136,144^ or because they enrolled more than one eye in some participants (N=659).^67,75,116^ Details are shown in Appendix B Tables 3 and 4.

##### Ganglion Cell Complex

The ganglion cell complex is composed of three thickness areas which can be imaged using OCT: the retinal nerve fiber layer, the inner plexiform layer, and the ganglion cell layer. Ganglion cell complex on spectral domain-OCT was associated with a pooled sensitivity of 0.74 (95% CI 0.68 to 0.80) and pooled specificity of 0.91 (95% CI 0.80 to 0.96) for identifying individuals with glaucoma, based on nine studies (N=1,522)^53,54,71,73,76,81,104,106,136^ (Table 3; Figures 6 and 7). Estimates were similar when three studies^71,76,136^ in which persons with ocular hypertension or glaucoma suspects were excluded from the analysis (6 studies, N=1,145, sensitivity 0.76, 95% CI 0.66 to 0.83 and specificity 0.92, 95% CI 0.86 to 0.96). Estimates were also similar when studies that reported only the ganglion cell layer or inner plexiform layer^71,76,104,106^ were excluded (5 studies, N=998, pooled sensitivity 0.73, 95% CI 0.60 to 0.83 and pooled specificity 0.95, 95% CI 0.87 to 0.98). One good-quality study (n=456) reported sensitivity of 0.62 (95% CI 0.41 to 0.80) and specificity of 0.93 (95% CI 0.91 to 0.96);^73^ in eight fair-quality studies (N=542) pooled sensitivity was 0.75 (95% CI 0.68 to 0.81) and pooled specificity was 0.91 (95% CI 0.78 to 0.97).^53,54,71,76,81,104,106,136^

Table 3 Sensitivity and Specificity, Spectral Domain-OCT Ganglion Cell Complex Thickness

Author, year | N | Glaucoma | Control | Sensitivity (95% CI) | Specificity (95% CI)
Aksoy, 2020^54^ | 131 | Early glaucoma | Healthy | 0.80 (0.68 to 0.89) | 0.96 (0.87 to 0.99)
Aksoy, 2020^54^ | 133 | Early glaucoma | OHT | 0.82 (0.71 to 0.90) | 0.96 (0.88 to 0.99)
Cifuentes-Canorea, 2018^71^ | 95 | Early glaucoma | OHT | 0.75 (0.57 to 0.89) | 0.59 (0.46 to 0.71)
Dabasia, 2015^73^ | 456 | POAG | Healthy | 0.62 (0.41 to 0.80) | 0.93 (0.91 to 0.96)
Deshpande, 2019^76^ | 201 | Early glaucoma | Glaucoma suspect | 0.77 (0.66 to 0.86) | 0.76 (0.67 to 0.83)
Garas, 2011^81^ | 250 | Perimetric + PPG | Healthy | 0.57 (0.49 to 0.65) | 0.99 (0.94 to 1.00)
Lee, 2016^104^ | 120 | POAG | Healthy | 0.75 (0.62 to 0.85) | 0.90 (0.79 to 0.96)
Lee, 2018^106^ | 108 | Early glaucoma | Healthy | 0.80 (0.69 to 0.89) | 0.86 (0.71 to 0.95)
Pazos, 2017^53^ | 80 | Early glaucoma | Healthy | 0.90 (0.76 to 0.97) | 0.80 (0.64 to 0.91)
Vidas, 2017^136^ | 81 | Glaucoma | OHT + Healthy | 0.66 (0.47 to 0.81) | 1.00 (0.93 to 1.00)

Abbreviations: CI = confidence interval; OCT = optical coherence tomography; OHT = ocular hypertension; POAG = primary open angle glaucoma; PPG = preperimetric glaucoma (no visual field defects).

Figure 6 Glaucoma vs. Control, Spectral Domain-OCT Sensitivity and Specificity for Ganglion Cell Complex Thickness

Abbreviations: CI = confidence interval; df = degrees of freedom; OCT = optical coherence tomography.

Figure 6 is a forest plot examining Glaucoma vs. Control, Spectral Domain-OCT Sensitivity and Specificity for Ganglion Cell Complex Thickness. The pooled sensitivity is 0.74 (95% CI 0.68 to 0.80) with an I-squared value of 75.45%. The pooled specificity is 0.91 (95% CI 0.80 to 0.96) with an I-squared value of 92.67%.

Figure 7 Glaucoma vs. Control, Spectral Domain-OCT Ganglion Cell Complex Thickness

Abbreviations: HSROC = hierarchical summary receiver operating characteristic; OCT = optical coherence tomography.

Figure 7 is a visual representation of the hierarchical summary receiver operating characteristic curve for Glaucoma vs. Control, Spectral Domain-OCT Ganglion Cell Complex Thickness.

Six fair-quality studies found ganglion cell complex, ganglion cell layer, and inner plexiform layer associated with high discrimination for distinguishing glaucoma from non-glaucoma (N=765, AUROC 0.88, 95% CI 0.84 to 0.92, I^2^=68%)^53,54,75,96,104,106^ (Figure 8). Results were similar when the non-glaucoma groups were stratified as healthy eyes (5 studies, N=564, AUROC 0.87, 95% CI 0.82 to 0.92, I^2^=70%),^53,54,96,104,106^ glaucoma-suspect eyes (2 studies, N=354, AUROC 0.84, 95% CI 0.69 to 1.00, I^2^=92%),^75,96^ or eyes with ocular hypertension (2 studies, N=224, AUROC 0.76, 95% CI 0.70 to 0.82, I^2^=0%)^54,96^ (Figure 9). Results were also similar when the analysis was restricted to two studies that assessed the ganglion cell complex (N=211, AUROC 0.87, 95% CI 0.73 to 1.00, I^2^=89%).^53,54^ Five studies could not be pooled due to inadequate data (e.g., reported sensitivity, specificity and/or AUROC without confidence intervals, only reported odds ratios),^71,122,125,136^ or did not report standard AUROC.^73^ Four studies were not pooled because they enrolled more than one eye in some participants.^67,75,93,101^ Details are provided in Appendix B Tables 3–4.

Figure 8 Ganglion Cell Analysis

Figure 8 is a forest plot examining Ganglion Cell Analysis. The pooled estimate is 0.88 (95% CI 0.84 to 0.92) with an I-squared value of 68.0%.

Figure 9 Ganglion Cell Analysis by Control Group

Figure 9 is a forest plot examining Ganglion Cell Analysis by Control Group. The subtotal estimate is 0.87 (0.82 to 0.92) for the glaucoma vs. healthy comparison. The subtotal estimate is 0.84 (0.69 to 1.0) for the glaucoma vs. glaucoma comparison. The subtotal estimate is 0.76 (0.70 to 0.82) for the glaucoma vs. OHT comparison.

##### Cup-to-Disc Ratio

One study (N=286) found the cup-to-disc ratio on spectral domain-OCT associated with sensitivity of 0.84 (95% CI 0.77 to 0.89) and specificity of 0.72 (95% CI 0.60 to 0.81) for identifying persons with glaucoma versus healthy eyes. The cup-to-disc ratio threshold for a positive test was not specified.^81^

Three studies (n=1,870) found the spectral domain-OCT vertical cup-to-disc ratio associated with an AUROC that ranged from 0.74 to 0.94^100,101,144^ (Table 4). These studies were not pooled because they enrolled more than one eye in some participants^101,144^ and one did not report SD.^144^

Table 4 Glaucoma vs. Control, Spectral Domain-OCT Cup-to-Disc Ratio

Author, year | N | Control | AUROC (95% CI)
Kim, 2012^100^ | 106 | Healthy | 0.74 (0.72 to 0.83)
Koh, 2018^101^ | 1061^*^ | Healthy | 0.94 (0.91 to 0.98)
Xu, 2017^144^ | 703^*^ | Healthy | 0.91 (not reported)

Abbreviations: AUROC = area under the receiver operating characteristic curve; CI = confidence interval; OCT = optical coherence tomography.

* These studies enrolled one or more eyes per participant, n=number of participants.

##### Swept Source–OCT

Swept source-OCT utilizes a longer wavelength than spectral domain-OCT to visualize deeper structures and is faster than spectral domain-OCT.

Two studies (reported in 3 publications, N=266) assessed the diagnostic accuracy of swept-source OCT using retinal nerve fiber layer thickness.^104–106^ One study found wide-field retinal nerve fiber layer thickness map associated with sensitivity of 0.95 (95% CI 0.90 to 0.98) and specificity of 0.89 (95% CI 0.75 to 0.97) for distinguishing between participants with glaucoma and participants with healthy eyes.^106^ The other study reported an AUROC for distinguishing persons with glaucoma from those with healthy eyes of 0.85 (95% CI 0.78 to 0.92) for the retinal nerve fiber layer outer/inferior sector and 0.83 (95% CI 0.75 to 0.90) for the outer/temporal sector of the ganglion cell inner plexiform layer.^104^ Another article (n=not reported; 184 eyes)^105^ reported an AUROC of 0.85 (95% CI 0.78 to 0.91) for discriminating between early perimetric glaucoma and healthy eyes of 0.85 (95% CI 0.78 to 0.91) for the retinal nerve fiber layer thickness and 0.87 (95% CI 0.80 to 0.92) for the ganglion cell inner plexiform layer (inferior temporal).

#### Optic Disc Photography

Four studies (N=3,133) reported diagnostic accuracy of cup-to-disc ratio on optic disc photography, separate from OCT.^64,74,86,107^ One study (n=2,631) screened participants with indirect ophthalmoscopy as well as disc photographs to assess the optic disc^107^ (Table 5).

Table 5 Glaucoma vs. Control, Optic Disc Photography Cup-to-Disc Ratio

Author, year | N | Control | AUROC (95% CI) | Sensitivity (95% CI) | Specificity (95% CI)
Blumberg, 2016^64^ | 46 | Glaucoma suspect | 0.85 (0.74 to 0.96) | 0.64 (0.45 to 0.81) | 0.73 (0.45 to 0.92)
Danesh-Meyer, 2006^74^ | 110 | Non-glaucoma | 0.81 (0.74 to 0.92) | --- | ---
Hark, 2019^86^ | 345 | Non-glaucoma CDR>0.65 medium and large discs, >0.5 for small discs | --- | 0.71 | 0.51
Leibowitz, 1980^107^ | 2631 | Non-glaucoma CDR>0.4 | --- | 0.18 (0.09 to 0.31) | 0.67 (0.62 to 0.71)

Abbreviations: AUROC = area under the receiver operating characteristic curve; CDR = cup-to-disc ratio; CI = confidence interval.

Two studies reported similar discrimination of cup-to-disc ratio on optic disc photography, with AUROCs of 0.85 (95% CI 0.74 to 0.96) and 0.81 (95% CI 0.74 to 0.92).^64,74^ In one of these studies, sensitivity was 0.64 (95% CI 0.45 to 0.81) and specificity was 0.73 (95% CI 0.45 to 0.92) for distinguishing persons with glaucoma from glaucoma suspects; the cup-to-disc ratio threshold was not reported.^64^ Two studies did not report discrimination; in one study sensitivity was 0.18 (95% CI 0.09 to 0.31) and specificity was 0.67 (95% CI 0.62 to 0.71) based on a cup-to-disc ratio threshold of 0.4.^107^ In the other study, sensitivity was 0.71 (95% CI 0.54 to 0.85) and specificity was 0.49 (95% CI 0.44 to 0.55) for distinguishing between glaucoma and nonglaucoma, based on a cup-to-disc ratio of 0.65 for average-sized or large discs and 0.5 for small discs.^86^

#### Ophthalmoscopy, Biomicroscopy, and Stereoscopy

Five studies reported accuracy of cup-to-disc ratio on ophthalmoscopy, biomicroscopy, and stereoscopy (N=17,519)^80,84,107,130,135^ (Table 6). Studies were not pooled because the methods used to determine cup-to-disc ratio as well as the cutoffs to define a positive screen varied. Although specificity was high in all studies, sensitivity varied widely (range 0.18 to 0.92).

Table 6 Ophthalmoscopy/Biomicroscopy/Stereoscopy Cup-to-Disc Ratio

Author, year | N | Method; CDR Cutoff | Control | Sensitivity (95% CI) | Specificity (95% CI)
Vernon, 1990^135^ | 854 | Ophthalmoscopy CDR >0.7 | Glaucoma Suspect | 0.56 (0.31 to 0.78) | 0.99 (0.98 to 0.99)
Liebowitz, 1980^107^ | 2631 | Ophthalmoscopy + disc photos; CDR>0.4 | Non-glaucoma | 0.18 (0.09 to 0.31) | 0.67 (0.62 to 0.71)
Francis, 2011^80^ | 5749 | Biomicroscopy CDR≥0.8 | Non-glaucoma | 0.60 (0.54 to 0.67) | 0.98 (0.975 to 0.982)
Hammond, 1979^84^ | 188 | Ophthalmoscopy CDR≥0.5 | Non-glaucoma | 0.86 (0.42 to 1.00) | 0.95 (0.91 to 0.98)
Soh, 2020^130^ | 8097 | Stereoscopy + disc photos; CDR>0.6 or CDR asymmetry>0.2 | Healthy eyes | 0.91; 0.95 (CDR asymmetry) | 0.92; 0.91 (CDR asymmetry)

Abbreviations: CDR = cup to disc ratio; CI = confidence interval.

#### Pachymetry

Two studies (N=6,129) reported the diagnostic accuracy of corneal thickness on pachymetry.^60,80^ One study (n=6,082) reported a sensitivity of 0.16 (95% CI 0.11 to 0.21) and specificity of 0.91 (95% CI 0.90 to 0.92) for distinguishing between glaucoma and non-glaucoma within a Latino population using a central corneal thickness of less than or equal to 504µm.^80^ The other study (n=47) reported an AUROC of 0.55 (standard error [SE] 0.08) for pachymetry; sensitivity and specificity were not reported.^60^

### Tests of Ophthalmic Function

Tests of optic nerve function include measurements of IOP through tonometry and visual field assessment.

#### Visual Fields

The Humphrey Field Analyzer has superseded frequency doubling technology as standard of care for the assessment of visual fields. Although the Humphrey Field Analyzer was often used as part of the reference standard for the diagnosis of glaucoma, 10 studies (N=11,633) reported diagnostic accuracy of the Humphrey Field Analyzer against a reference standard.^64,74,80,88,89,95,108,112,117,122^ In these studies, Humphrey Field Analyzer methods varied: five studies used the Swedish Interactive Threshold Algorithm-Standard 24-2,^64,74,80,108,122^ two use the 76-point 30 degree suprathreshold,^88,89^ and one study each used the Full Field 120 Protocol,^95^ the 630 Armaly Full Field Test,^112^ and the Central 30-2 (Goldmann III stimulus).^117^

The Humphrey Field Analyzer was associated with pooled sensitivity of 0.87 (95% CI 0.69 to 0.95) and pooled specificity of 0.82 (95% CI 0.66 to 0.92), based on six studies (N=11,244)^64,80,88,95,108,117^ (Figures 10 and 11). There were too few studies of specific Humphrey Field Analyzer methods to conduct a meaningful analysis stratified by method (Table 7). One good-quality study (N=6,082)^80^ reported a sensitivity of 0.88 (95% CI 0.83 to 0.92) and specificity of 0.64 (95% CI 0.63 to 0.65) using SITA-Standard 24-2.

Figure 10 Glaucoma vs. Control, Humphrey Field Analyzer Visual Field

Abbreviation: HSROC = hierarchical summary receiver operating characteristic.

Figure 10 is a visual representation of the hierarchical summary receiver operating characteristic curve for Glaucoma vs. Control, Humphrey Field Analyzer Visual Field.

Figure 11 Glaucoma vs. Control, Visual Field Sensitivity and Specificity

Abbreviations: CI = confidence interval; df = degrees of freedom.

Figure 11 is a forest plot examining Glaucoma vs. Control, Visual Field Sensitivity and Specificity. The pooled sensitivity is 0.87 (95% CI 0.69 to 0.95) with an I-squared value of 89.94%. The pooled specificity is 0.82 (95% CI 0.66 to 0.92) with an I-squared value of 98.37%.

Table 7 Glaucoma vs. Control, Humphrey Field Analyzer Sensitivity and Specificity

Author, Year | N | Method; Threshold | Control | Sensitivity (95% CI) | Specificity (95% CI)
Francis, 2011^80^ | 6082 | SITA-Standard 24-2; GHT abnormal; MD, PSD < 5% | Non-glaucoma | MD; 0.88 (0.83 to 0.92; PSD; 0.76 (0.70 to 0.81) | MD; 0.64 (0.63 to 0.65); PSD; 0.78 (0.77 to 0.79)
Hong, 2007^88^ | 120 | 30-2 Swedish interactive threshold GHT abnormal; PDP <5%; PSD<5% | Healthy | 1.00 (0.95 to 1.00) | 0.92 (0.80 to 0.98)
Tielsch 1991^133^; Katz, 1993^95^ | 4733 | Full Field 120 Protocol; ≥17 defects or ≥8 defects in any quadrant | Non-glaucoma | 0.84 (0.77 to 0.89) | 0.75 (0.91 to 1.00)
Liu, 2011^108^ | 132 | SITA-Standard 24-2; ≥3 non-edge-contiguous point defects with ≥1 on side of horizontal meridian in PDP | Healthy | 0.68 (0.58 to 0.78) | 1.00 (0.91 to 1.00)
Mundorf, 1989^117^ | 131 | Central 30-2 (Goldman III Stimulus); ≥4 defects in any quadrant or defect pattern consistent with glaucoma | Healthy | 0.90 (0.55 to 1.00) | 0.79 (0.58 to 0.91)

Abbreviations: CI = confidence interval; GHT = global hemifield test; MD = mean deviation; PDP = pattern deviation plot; PSD = pattern standard deviation; SITA = Swedish Interactive Thresholding Algorithm.

The mean deviation on the SITA-Standard 24-2 was associated with a pooled AUROC (0.83, 95% CI 0.70 to 0.97, I^2^=88%), based on three studies (N=288).^64,74,108^ (Figure 12) and the pattern standard deviation was associated with an AUROC of 0.87 (95% CI 0.76 to 0.99), based on two studies (N=242)^74,108^ (Figure 13). One other study found the 76-point 30 degree suprathreshold associated with an AUROC of 0.87 (CI not reported).^89^

Figure 12 Glaucoma vs. Control, AUROC Humphrey Field Analyzer Visual Field Mean Deviation

Abbreviations: AUROC = area under the receiver operating characteristic curve; CI = confidence interval; ES = estimate.

Figure 12 is a forest plot examining Glaucoma vs. Control, AUROC Humphrey Visual Field Analyzer Visual Field Mean Deviation. The pooled estimate is 0.83 (0.70 to 0.97) with an I-squared value of 87.6.

Figure 13 Glaucoma vs. Control, AUROC Humphrey Field Analyzer Visual Field Pattern Standard Deviation

Abbreviations: AUROC = area under the receiver operating characteristic curve; CI = confidence interval; ES = estimate.

Figure 13 is a forest plot examining Glaucoma vs. Control, AUROC Humphrey Visual Field Pattern Standard Deviation. The pooled estimate is 0.87 (0.76 to 0.99) with an I-squared value of 73.2%.

One study (n=175; 280 eyes) found the Humphrey Field Analyzer, Swedish Interactive Threshold associated with sensitivity of 0.70 (95% CI 0.63 to 0.77) and specificity of 0.95 (95% CI 0.89 to 0.98).^122^ Another study (n=104; 182 eyes) found the Humphrey Field Analyzer, Armaly full field test associated with a sensitivity of 0.64 (95% CI 0.56 to 0.72) and specificity of 0.64 (95% CI 0.48 to 0.78).^112^ Because these studies included more than one eye of some participants, they were not included in pooled analysis.

#### Afferent Pupillary Defect

One study (N=107) tested afferent pupillary defect using the swinging flashlight test.^69^ Sensitivity was 0.67 (95% CI 0.54 to 0.78) and specificity was 0.83 (95% CI 0.67 to 0.92). Sensitivity and specificity were similar when 40 participants without prior cataract surgery were excluded from the analysis (sensitivity 0.69, 95% CI 0.50 to 0.83; specificity 0.89, 95% CI 0.72 to 0.96).

### Tests of IOP Measurement

#### Tonometry

Seventeen studies (n=49,742) evaluated the accuracy of tonometry for identifying glaucoma.^60,65,68,70,73,77,80,84,86,89,93,102,107,117,133,135,138^ Tonometry was associated with a pooled sensitivity of 0.48 (95% CI 0.31 to 0.66) and pooled specificity of 0.94 (95% CI 0.90 to 0.96) for diagnosing glaucoma from non-glaucomatous or healthy eyes, based on 13 studies (N=32,892)^65,68,73,77,80,84,86,102,107,117,133,135,138^ (Figures 14 and 15; Table 8). The IOP cutoff was 21 to 22 mm Hg in all studies except for two, which used cutoffs of 22.6^84^ and 25 mm Hg.^93^ Results were similar when one study^138^ that compared diagnostic accuracy for probable glaucoma with not probable glaucoma was excluded from the analysis (12 studies, N=28,726, pooled sensitivity 0.47, 95% CI 0.29 to 0.66 and pooled specificity 0.94, 95% CI 0.90 to 0.97). When stratified by tonometry method, sensitivity was higher for Goldmann tonometry (4 studies, N=11,690; sensitivity 0.66, 95% CI 0.36 to 0.87)^65,77,80,102^ than for other methods (9 studies, N=21,202, sensitivity 0.39, 95% CI 0.22 to 0.58) (Table 8). However, the sensitivity estimate for Goldmann tonometry was imprecise. Specificity was similar regardless of tonometry technique. Results were also similar when the analysis was limited to fair-quality studies (11 studies, N=26,305, pooled sensitivity 0.54, 95% CI 0.34 to 0.72 and specificity 0.94, 95% CI 0.89 to 0.97).^65,68,77,84,86,95,102,107,117,135,138^ Only two studies were rated good quality^73,80^ (sensitivity 0.24, 95% CI 0.19 to 0.30 and 0.19, 95% CI 0.07 to 0.39 and specificity 0.97, 95% CI 0.97 to 0.97 and 0.89, 95% CI 0.86 to 0.92). One study that included more than one eye per individual (n=3,039, eyes=6,060) reported a sensitivity of 0.07 (95% CI 0.01 to 0.19) and specificity of 0.99 (95% CI 0.99 to 0.99) for glaucoma versus non-glaucoma, based on an IOP threshold of >25 mm Hg using a rebound tonometer.^93^ Two studies (N=418) found tonometry associated with low sensitivity (0.01, 95% CI 0.00 to 0.05 and 0.27, 95% CI 0.20 to 0.36) and high specificity (0.98, 95% CI 0.94 to 1.00 and 0.81, 95% CI 0.73 to 0.88) for distinguishing glaucoma suspects versus healthy controls.^86,117^

Table 8 Tonometry Sensitivity and Specificity Glaucoma vs. Control

Author, year | N | Method | Control | Sensitivity (95% CI) | Specificity (95% CI)
Mundorf, 1989^117^ | 131 | Schiotz tonometer | Healthy | 0.20 (0.03 to 0.56) | 0.98 (0.94 to 1.00)
Kozobolis, 2000^102^ | 1107 | GAT | Non-glaucoma | 0.90 (0.74 to 0.98) | 0.93 (0.92 to 0.95)
Hark, 2019^85^ | 887 | Rebound tonometry | Non-glaucoma | 0.61 (0.48 to 0.73) | 0.77 (0.70 to 0.84)
Dabasia, 2015^73^ | 505 | Ocular Response Analyzer | Non-glaucoma | 0.19 (0.07 to 0.39) | 0.89 (0.86 to 0.92)
Tielsch, 1991^133^; Katz, 1993^95^ | 4735 | Not Reported | Non-glaucoma | 0.47 (0.40 to 0.54) | 0.92 (0.91 to 0.94)
Wahl, 2016^138^ | 4166 | Noncontact AT555 | Not probable glaucoma | 0.62 (0.32 to 0.86) | 0.92 (0.91 to 0.92)
Vernon, 1990^135^ | 874 | Pulsair noncontact | Non-glaucoma | 0.92 (0.64 to 1.00) | 0.96 (0.94 to 0.97)
Leibowitz, 1980^107^ | 2631 | Schiotz tonometer | Non-glaucoma | 0.10 (0.03 to 0.22) | 0.86 (0.83 to 0.88)
Hammond, 1979^84^ | 197 | Schiotz tonometer | Non-glaucoma | 0.29 (0.11 to 0.52) | 1.00 (0.98 to 1.00)
Francis, 2011^80^ | 6082 | GAT | Non-glaucoma | 0.24 (0.19 to 0.30) | 0.97 (0.97 to 0.97)
Ehrlich, 2012^77^ | 204 | GAT | Healthy | 0.59 (0.53 to 0.65) | 0.90 (0.86 to 0.93)
Chan, 2017^68^ | 7076 | Ocular Response Analyzer | Healthy | 0.30 (0.25 to 0.35) | 0.87 (0.86 to 0.88)
Bonomi, 2001^65^ | 4297 | GAT | Healthy | 0.80 (0.72 to 0.87) | 0.98 (0.97 to 0.98)

Abbreviations: AT555 = autotonometer model 555; CI = confidence interval; GAT = Goldmann applanation tonometry.

Figure 14 Glaucoma vs. Control Tonometry

Abbreviation: HSROC = hierarchical summary receiver operating characteristic.

Figure 14 is a visual representation of the hierarchical summary receiver operating characteristic curve for Glaucoma vs. Control Tonometry.

Figure 15 Glaucoma vs. Control Tonometry Sensitivity and Specificity

Abbreviations: CI = confidence interval; df = degrees of freedom.

Figure 15 is a forest plot examining Glaucoma vs. Control Tonometry Sensitivity and Specificity. The pooled sensitivity is 0.48 (95% CI 0.31 to 0.66) with an I-squared value of 95.13%. The pooled specificity is 0.94 (95% CI 0.90 to 0.96) with an I-squared value of 98.79%.

In three studies (N=4,684), discrimination of tonometry based on the AUROC ranged from 0.66 to 0.78.^60,77,89^ All three studies used Goldmann applanation tonometry (Figures 16 and 17).

Figure 16 Glaucoma vs. Control, Goldman Applanation Tonometry

Abbreviations: HSROC = hierarchical summary receiver operating characteristic.

Figure 16 is a visual representation of the hierarchical summary receiver operating characteristic curve for Glaucoma vs. Control, Goldman Applanation Tonometry.

Figure 17 Glaucoma vs. Control, Other Tonometry Techniques

Abbreviations: HSROC = hierarchical summary receiver operating characteristic.

Figure 17 is a visual representation of the hierarchical summary receiver operating characteristic curve for Glaucoma vs. Control, Other Tonometry Techniques.

One study (N=6,310) that evaluated intereye IOP asymmetry on tonometry^70^ was not pooled; details are shown in Appendix B Tables 3 and 4.

### Other

#### Telemedicine Screening

Two studies examined the diagnostic accuracy of a telemedicine screening intervention called Technology-based Eye Care Services used in the Veteran Affairs Healthcare System.^109–111^ The first was a small pilot study (n=52) where screening was conducted in primary care clinics and consisted of distance auto-refraction, visual acuity, tonometry, pachymetry, and a pupil exam for depth, reactivity, afferent papillary defect, and fundus. A blinded ophthalmologist reviewed screening findings and made recommendations for the participant. These recommendations were compared with the diagnosis and recommendations of a physician who conducted a face-to-face exam, which was considered the reference standard. In the pilot study, the technology-based exam was associated with sensitivity of 0.64 (95% CI 0.35 to 0.87) and specificity of 0.95 (95% CI 0.82 to 0.99).

A subsequent, larger (n=256) followup study followed a similar protocol as the pilot study.^111^ Most participants were male (87%) and Black (61%) and over a quarter of participants had a history of eye trauma (28%) or a family history of eye diagnosis or blindness (25%). Participants had no known ocular disease; those with “glaucoma suspect” history and documented visual field changes or prior treatment were excluded. Two ophthalmologists reviewed the screening findings and accuracy was compared against a face-to-face exam. On the face-to-face exam, 26.6% (68/256) were diagnosed with glaucoma or glaucoma suspect; other conditions diagnosed were cataracts referred for surgery (3.9%), macular degeneration (2.3%), diabetic retinopathy (3.1%), and other diagnoses resulting in referral (43.8%). Compared with a face-to-face exam, the sensitivity of the technology-based exam to identify persons with glaucoma varied between readers (0.72, 95% CI 0.60 to 0.82 and 0.47, 95% CI 0.35 to 0.6), though specificity was high with both readers (0.91, 95% CI 0.87 to 0.95 and 0.97, 95% CI 0.94 to 0.99). The addition of spectral domain-OCT to the screening protocol did not improve diagnostic accuracy.^110^

## Key Question 5 What Is the Accuracy of Instruments for Identifying Patients at Higher Risk of OAG?

### Summary

- One cross-sectional study (n=145) that was not in the prior CER found a questionnaire associated with low sensitivity (0.20, 95% CI 0.03 to 0.56) but high specificity (0.96, 95% CI 0.91 to 0.99) for identifying persons with glaucoma.

### Evidence

One fair-quality, cross-sectional study (n=145) not in the prior screening CER^2^ reported the diagnostic accuracy of a weighted screening questionnaire for identifying persons with glaucoma (Appendix B Tables 6–8).^117^ In the instrument, the highest weights were assigned for taking steroid medication and having a previous glaucoma diagnosis; less highly weighted risk factors were previous eye injury or stroke, age, race, prior eye surgery, high blood pressure, being nearsighted, and family history of diabetes or glaucoma. Two out of ten participants with glaucoma were correctly identified as having glaucoma based on the questionnaire alone (sensitivity 0.20, 95% CI 0.03 to 0.56), and 116 out of 121 correctly identified as not having glaucoma (specificity 0.96, 95% CI 0.91 to 0.99). The study was conducted in the U.S., but applicability to screening was likely limited because previous glaucoma diagnosis was one of the most heavily weighted risk factors.

## Key Question 6 What Are the Effects of Medical Treatments for OAG vs. Placebo or No Treatments on a) IOP, Visual Field Loss, Visual Acuity, or Optic Nerve Damage or b) Visual Impairment, Quality of Life, or Function?

### Summary

- Treatment was associated with greater reduction in IOP compared with placebo or no treatment (16 trials, N=3,706, mean difference −3.14 mm Hg, 95% CI −4.19 to −2.08, I^2^=95%); there was an interaction between drug class and effects of medical therapy on IOP (p for interaction <0.0005), though estimates favored treatment for all drug classes.
- Treatment with topical therapy decreased risk of glaucoma progression compared with placebo or no treatment at 24 to 120 months (7 trials, N=3,771, RR 0.68; 95% CI 0.49 to 0.96, I^2^=53%; absolute risk difference [ARD] −4.8%, 95% CI −8.5 to −1.0).
- Evidence on effects of medical therapy on quality of life was very limited, with one trial (n=461) reporting no differences between latanoprost and placebo in general or vision-related quality of life measured using the EuroQol-5D (EQ-5D) (1.7 vs. 1.7, p=0.98), Short Form Health Survey-36 (SF-36) (4.8 vs. 5.0, p=0.94), Glaucoma Quality of Life-15 (GQL-15) (2.7 vs. 3.2 p=0.66), or Glaucoma Activity Limitation-9 (GAL-9) (3.0 vs. 3.2 p=0.87) scales at 24 months.

### Evidence

The prior treatment CER^3^ primarily focused on head-to-head comparisons of glaucoma treatment, but included a systematic review that found medical (topical) therapy for ocular hypertension associated with reduced risk of onset of visual field defects compared with placebo or no treatment (10 trials, N=3,648, odds ratio [OR] 0.62, 95% CI 0.47 to 0.81).^147^ For this review, we included 13 placebo-controlled trials and four trials of medical therapy compared with no treatment^21,123,126,143^ in patients with OAG or ocular hypertension. Nine trials^21,78,87,92,94,114,126,127,143^ were in the systematic review utilized in the prior treatment CER and we identified eight additional trials,^35,62,63,121,123,124,134,142^ including the U.K. Glaucoma Treatment Study^35^ (UKGTS), which reported effects on quality of life and visual acuity in addition to IOP and visual field progression (Appendix B Table 9).

Across trials, sample sizes ranged from 20 to 1,636 participants (N=4,665). Mean age ranged from 55 to 74 years and 34 to 75 percent of participants were female. In 10 trials that reported race/ethnicity, the proportion of White participants ranged from 68 to 100 percent. Two trials enrolled patients with untreated, newly diagnosed OAG (excluding advanced disease and pigment dispersion),^35,63^ three trials enrolled mixed populations with OAG or ocular hypertension (proportion with OAG 40%, 76%, and not reported),^62,124,142^ and 12 trials enrolled patients with ocular hypertension (elevated IOP but normal visual fields; often also normal optic discs). OAG or ocular hypertension was diagnosed using a variety of tests, including perimetry, tonometry, gonioscopy, and visualization of the optic nerve by ophthalmoscopic examination and/or imaging; only the UKGTS^35^ utilized OCT (primarily time domain-OCT) as part of the diagnostic evaluation. Mean baseline IOP ranged from 19.6 to 27.3 mm Hg; mean baseline IOP was <22 mm Hg in the two trials^35,63^ of patients with early untreated OAG and ≥22 mm Hg in the other trials. Treatment was a beta-blocker in 10 trials (timorol in 6 trials,^78,87,121,126,143^ levobunolol in 2 trials,^62,123^ and betaxolol in 2 trials^92,121^) a carbonic anhydrase inhibitor in five trials (dorzolamide in 4 trials,^63,114,115,124,142^ and brinzolamide in 1 trial^124^), a prostaglandin analogue (latanaprost) in one trial,^35^ and an alpha agonist (brimonidine) in one trial.^134^ One trial did not evaluate a specific drug but allowed various topical therapies, with a target IOP ≤24 mm Hg or ≥20 percent IOP reduction.^21^ The duration of followup ranged from 1.5 months^63,121^ to 120 months,^87^ with followup >1 year in 10 trials. One study was multinational,^114,115^ and the others were conducted in the U.S.,^21,62,78,94,121,124,127,134,142^ U.K.,^35,92,143^ Sweden,^63,87^ Italy,^123^ and Canada.^126^

In 12 trials,^21,35,62,63,78,87,92,114,115,121,124,126,142^ randomization and analysis was per individual (2 of which enrolled only one eye^63,92^); one trial^127^ randomized by individual but reported a per-eye analysis; and three trials^94,134,143^ randomized one eye in each individual (with the other eye serving as the control). One trial^123^ reported a per-eye analysis, but randomization by eye or individual was unclear. Four trials were rated good quality,^35,92,115,127^ and 12 were rated fair quality^21,62,78,87,94,121,123,124,126,134,142,143^ (Appendix B Table 10). Methodological limitations in the fair-quality trials included unclear reporting of randomization, allocation concealment, and blinding methods, and high attrition in some studies.

#### Intraocular Pressure

Mean IOP was the most commonly reported outcome, reported in all but two trials.^21,35,62,63,87,92,94,115,121,123,126,127,134,142,143^ Overall, treatment was associated with greater reduction in IOP compared with placebo or no treatment (16 studies, N=3,706, mean difference −3.14 mm Hg, 95% CI −4.19 to −2.08, I^2^=95%) (Figure 18). Statistical heterogeneity was substantial, though inconsistency was in the magnitude of effect but not the direction of effect, with all trials reporting effects on IOP that favored treatment (range −0.70 to −7.00 mm Hg). A funnel plot did not indicate small sample effects (Egger’s test p=0.16) (Figure 19), but results were difficult to interpret due to statistical heterogeneity. There was an interaction between drug class and effects of medical therapy on IOP (p for interaction <0.0005), though estimates favored treatment for all drug classes. Beta blockers were associated with a pooled mean difference of −3.75 mm Hg (95% CI −5.43 to −2.06; I^2^=92%), based on nine trials (N=455); prostaglandin analogues with a mean difference of −2.70 mm Hg (95% CI −3.34 to −2.06), based on one trial (n=516); alpha agonists with a mean difference of −2.30 mm Hg (95% CI −3.52 to −1.08), based on one trial (n=30); and carbonic anhydrase inhibitors with a mean difference of −1.20 mm Hg (95% CI −2.30 to −0.61), based on four trials (N=1,635). One trial (n=1,636) found treatment to target using various medications associated with a mean difference of −4.60 mm Hg (95% CI −4.85 to −4.35). Estimates also consistently favored medical therapy, with differences ranging from −2 to −4 mm Hg, when analyses were stratified according to ocular hypertension, untreated OAG, or mixed status at baseline (Figure 20), baseline IOP (<20 mm Hg vs. ≥20 mm Hg) (Figure 21), and quality (fair vs. good) (Figure 22), or duration (<1 year vs. ≥1 year) (Figure 23), though statistically significant interactions were present (Table 9). In the OHTS, effects of medication compared with placebo on IOP were almost identical in Black persons and persons of other races.^148^

Figure 18 Medical Treatment vs. Placebo/No Treatment on IOP, by Drug Class

Abbreviations: CI = confidence interval; IOP = intraocular pressure; NR = not reported; OAG = open angle glaucoma; OHT = ocular hypertension; SD = standard deviation.

Figure 18 is a forest plot examining Medical Treatment vs. Placebo/No Treatment on IOP, by Drug Class. The subgroup mean difference is −2.30 (−3.52 to −1.08) for the Alpha Agonist Class. The subgroup mean difference is −3.75 (−5.43 to −2.06) for the Beta Blocker Class. The subgroup mean difference is −1.20 (−2.30 to −0.61) for the Carbonic Anhydrase Inhibitor Class. The subgroup mean difference is −4.60 (−4.85 to −4.35) for the Mixed Class. The subgroup mean difference is −2.70 (−4.19 to −2.06) for the Prostaglandin Analogue Class. The pooled mean difference is −3.14 (−4.19 to −2.08) with an I-squared value of 94.5%.

Figure 19 IOP Funnel Plot

Abbreviations: IOP = intraocular pressure; s.e. = standard error.

Figure 19 is a funnel plot for Intraocular Pressure. The mean difference ranges from approximately −8 to approximately −1. The standard error of mean difference ranges from approximately 0.1 to approximately 1.5.

Figure 20 Medical Treatment vs. Placebo/No Treatment on IOP, by Population

Abbreviations: CI = confidence interval; IOP = intraocular pressure; NR = not reported; OAG = open angle glaucoma; OHT = ocular hypertension; SD = standard deviation.

Figure 20 is a forest plot of Medical Treatment vs. Placebo/No Treatment on IOP, by Population. The subgroup mean difference is −3.70 (−7.52 to −0.08) for the Mixed population. The subgroup mean difference is −2.63 (−3.47 to −1.04) for the OAG population. The subgroup mean difference is −3.18 (−4.48 to −1.85) for the OHT population. The pooled mean difference is −3.14 (−4.19 to −2.08) with an I-squared value of 94.5%.

Figure 21 Medical Treatment vs. Placebo/No Treatment on IOP, by Baseline IOP

Abbreviations: BLIOP = baseline intraocular pressure; CI = confidence interval; IOP = intraocular pressure; mm Hg = millimeters mercury; NR = not reported; OAG = open angle glaucoma; OHT = ocular hypertension; SD = standard deviation.

Figure 21 is a forest plot of Medical Treatment vs. Placebo/No Treatment on IOP, by Baseline IOP. The subgroup mean difference is −2.70 (−3.34 to −2.06) for the <20 mmHg group. The subgroup mean difference is −3.17 (−4.30 to −2.03) for the >=20 mmHg group. The pooled mean difference is −3.14 (−4.19 to −2.08) with an I-squared value of 94.5%.

Figure 22 Medical Treatment vs. Placebo/No Treatment on IOP, by Quality

Abbreviations: CI = confidence interval; IOP = intraocular pressure; NR = not reported; OAG = open angle glaucoma; OHT = ocular hypertension; SD = standard deviation.

Figure 22 is a forest plot of Medical Treatment vs. Placebo/No Treatment on IOP, by Quality. The subgroup mean difference is −2.09 (−3.19 to −1.10) for the Good group. The subgroup mean difference is −3.49 (−4.83 to −2.11) for the Fair group. The pooled mean difference is −3.14 (−4.19 to −2.08) with an I-squared value of 94.5%.

Figure 23 Medical Treatment vs. Placebo/No Treatment on IOP, by Duration

Abbreviations: CI = confidence interval; IOP = intraocular pressure; NR = not reported; OAG = open angle glaucoma; OHT = ocular hypertension; SD = standard deviation.

Figure 23 is a forest plot of Medical Treatment vs. Placebo/No Treatment on IOP, by Quality. The subgroup mean difference is −2.66 (−4.52 to −0.86) for the <1 year group. The subgroup mean difference is −3.38 (−4.75 to −2.00) for the >=1 year group. The pooled mean difference is −3.14 (−4.19 to −2.08) with an I-squared value of 94.5%.

Table 9 Medical Treatment vs. Placebo/No Treatment, Pooled Analyses

Analysis | Number of trials | N | Estimate (95% CI) | I^2^
Intraocular Pressure | 16 | 3,706 | MD −3.14 (−4.19 to −2.08) | 95%
Drug class (P_interaction_<0.0005)
- Beta-blockers | 9 | 455 | MD −3.75 (−5.43 to −2.06) | 92%
- Prostaglandin | 1 | 516 | MD −2.70 (−3.34 to −2.06) | NA
- Alpha agonists | 1 | 30 | MD −2.30 (−3.52 to −1.08) | NA
- Carbonic anhydrase inhibitors | 4 | 1,635 | MD −1.20 (−2.30 to −0.61) | 0%
- Mixed/various medications | 1 | 817 | MD −4.60 (−4.85 to −4.35) | NA
Baseline population (P_interaction_<0.0005)
- OHT | 11 | 2,745 | MD −3.178 (−4.48 to −1.85) | 95%
- Untreated OAG | 2 | 506 | MD −2.63 (−3.47 to −1.04) | 0%
- Mixed status | 3 | 455 | MD −3.704 (−7.515 to −0.083) | 83%
Baseline IOP (P_interaction_<0.001)
- <20 mm Hg | 1 | 461 | MD −2.70 (−3.34 to −2.06) | NA
- ≥20 mm Hg | 15 | 3,245 | MD −3.17 (−4.30 to −2.03) | 94%
Quality (P_interaction_<0.0005)
- Fair | 12 | 2,555 | MD −3.49 (−4.83 to −2.11) | 94%
- Good | 4 | 1,151 | MD −2.09 (−3.19 to −1.10) | 74%
Duration (P_interaction_<0.0005)
- <1 year | 6 | 576 | MD −2.66 (−4.52 to −0.86) | 77%
- ≥1 year | 10 | 3,130 | MD −3.38 (−4.75 to −2.00) | 96%
Progression | 7 | 3,771 | RR 0.68 (0.49 to 0.96) | 53%
Population (P_interaction_=0.71)
- OAG | 1 | 461 | RR 0.59 (0.41 to 0.86) | 0%
- OHT | 6 | 3,310 | RR 0.71 (0.46 to 1.08) | 57%
Quality (P_interaction_=0.36)
- Fair | 4 | 1,978 | RR 0.59 (0.31 to 1.20) | 54%
- Good | 3 | 1,793 | RR 0.76 (0.52 to 1.30) | 15%
Progression of visual field defects | 6 | 3,679 | RR 0.73 (0.53 to 1.05) | 25%
Adverse Effects
Serious adverse events | 3 | 3,140 | RR 1.14 (0.60 to 1.99) | 32%
Withdrawal due to adverse events | 5 | 648 | RR 2.40 (0.71 to 19.32) | 0%

Abbreviations: CI = confidence interval; MD = mean difference; mm HG = millimeters mercury; NA = not applicable; OAG = open angle glaucoma; OHT = ocular hypertension; RR = risk ratio.

#### Progression of Glaucomatous Changes

Nine trials reported effects of topical medical therapies compared with placebo or no treatment on risk of glaucoma progression (Appendix B Table 9).^21,35,78,87,92,94,114,115,126,143^ Glaucoma progression was defined as progression of visual field defects,^35,78^ progression to a glaucoma diagnosis (among those with ocular hypertension, based on visual field defects or optic disc changes),^87,92,126^ or progression of visual field defects or optic disc changes.^21,114,115^ Definitions and measurement methods for progression of visual field loss varied, but were based on the development of focal or reproducible visual field defects or by the development of any reproducible visual field defect (Appendix B Table 9). No trial reported the proportion of patients with overall visual field loss exceeding a minimum clinically important threshold such as a change in mean deviation of >3 to 5 decibels (dB, a measure of light intensity when testing visual fields).^149^

Treatment with topical therapy decreased risk of glaucoma progression compared with placebo or no treatment (seven trials, N=3,771, RR 0.68; 95% CI 0.49 to 0.96, I^2^=53%; ARD −4.8%, 95% CI −8.5% to −1.0%; Figure 24) at 24 to 120 months. Estimates were similar in the new UKGTS trial,^150^ which evaluated patients with untreated OAG (n=461, RR 0.59, 95% CI 0.41 to 0.86), and trials included in the prior treatment CER of patients with ocular hypertension (6 trials, N=3,310, RR 0.71, 95% CI 0.46 to 1.08; I^2^=57%) (Figure 25). Results were also similar in fair-quality studies (4 trials, N=1,978, RR 0.57, 95% CI 0.33 to 1.00, I^2^=44%) and good-quality studies (3 trials, N=1,793, RR 0.76, 95% CI 0.52 to 1.30, I^2^=15%; Figure 26). There was no interaction between medication type (p for interaction=0.30) or study quality (p for interaction=0.36) and effects on risk of glaucoma progression. Two trials^94,143^ (ns=34 and 62) were not included in the meta-analysis because they randomized one eye in each individual and reported a per-eye analysis, but both found treatment associated with decreased risk of progression (RR 0.63, 95% CI 0.17 to 2.39 and RR 0.38, 95% CI 0.13 to 1.16). An analysis restricted to progression of visual field defects (excluding optic disc changes as a criterion for progression) produced similar results (6 trials, N=3,679, RR 0.73, 95% CI 0.53 to 1.05, I^2^=25%); Figure 27).^21,35,78,92,114,126^ In the UKGTS, latanaprost was associated with a small and non-statistically significant difference in overall visual field loss, measured by the mean deviation (−0.23 vs. 0.14 dB, p=0.07); there was no difference in visual acuity (−0.01 vs. −0.02 logMAR, p=0.9).^35^ In the OHTS, there was no interaction between race and risk of progression from ocular hypertension to OAG (hazard ratio [HR] 0.50, 95% CI 0.28 to 0.90 for Black patients, and HR 0.36, 95% CI 0.23 to 0.57 for other races; p for interaction=0.40).^148^

Figure 24 Medical Treatment vs. Placebo/No Treatment on Progression to Glaucoma

Abbreviations: CI = confidence interval; OAG = open angle glaucoma; OHT = ocular hypertension.

Figure 24 is a forest plot of Medical Treatment vs. Placebo/No Treatment on Progression to Glaucoma. The pooled Risk Ratio is 0.68 (0.49 to 0.96) with an I-squared value of 53.0%.

Figure 25 Medical Treatment vs. Placebo/No Treatment on Progression to Glaucoma, by Population

Abbreviation: CI = confidence interval.

Figure 25 is a forest plot of Medical Treatment vs. Placebo/No Treatment on Progression to Glaucoma, by Population. The subgroup Risk Ratio is 0.59 (0.41 to 0.86) for the open angle glaucoma population. The subgroup risk ratio is 0.71 (0.46 to 1.08) for the ocular hypertension population. The pooled Risk Ratio is 0.68 (0.49 to 0.96) with an I-squared value of 53.0%.

Figure 26 Medical Treatment vs. Placebo/No Treatment on Progression to Glaucoma, by Quality

Abbreviations: CI = confidence interval; OAG = open angle glaucoma; OHT = ocular hypertension.

Figure 26 is a forest plot of Medical Treatment vs. Placebo/No Treatment on Progression to Glaucoma, by Quality. The subgroup risk ratio is 0.57 (0.33 to 1.00) for the Fair group. The subgroup risk ratio is 0.76 (0.52 to 1.300 for the Good group. The pooled Risk Ratio is 0.68 (0.49 to 0.96) with an I-squared value of 53.0%.

Figure 27 Medical Treatment vs. Placebo/No Treatment on Progression of Visual Field Defects

Abbreviations: CI = confidence interval; OAG = open angle glaucoma; OHT = ocular hypertension.

Figure 27 is a forest plot of Medical Treatment vs. Placebo/No Treatment on Progression of Visual Field Defects. The pooled risk ratio is 0.73 (0.53 to 1.05) with an I-squared value of 25.0%.

#### Quality of Life

Evidence on effects of medical therapy on quality of life was very limited. In the UKGTS (n=461),^90^ there were no differences between latanoprost and placebo in general or vision-related quality of life measured using the EQ-5D (1.7 vs. 1.7, p=0.98), SF-36 (4.8 vs. 5.0, p=0.94), GQL-15 (2.7 vs. 3.2 p=0.66), or GAL-9 scales (3.0 vs. 3.2 p=0.87) at 24 months followup.

## Key Question 7 What Are the Harms of Medical Treatments for OAG vs. Placebo or No Treatments?

### Summary

- There were no significant differences in risk of serious adverse events (3 trials, N=3,140, RR 1.14, 95% CI 0.60 to 1.99; I^2^=32%), withdrawal due to adverse events (5 trials, N=648, RR 2.40, 95% CI 0.71 to 19.32; I^2^=0%), or any adverse event (2 trials, N=1,538, RR 1.56, 95% CI 0.59 to 4.03; I^2^=82%).
- Two trials found treatment associated with increased risk of ocular adverse events (primarily itching, irritation, tearing, dryness, or taste issues) compared with placebo (RR 1.21, 95% CI 1.10 to 1.33 in a trial of various treatments and RR 3.52, 95% CI 2.46 to 5.02 in a trial of dorzolamide).

### Evidence

Eight trials (in 9 publications) of medical treatments compared with placebo or no treatment reported harms (Appendix B Table 9).^21,35,62,78,114,115,124,127,142^ There were no statistically significant differences in risk of serious adverse events (three trials, N=3,140, RR 1.14, 95% CI 0.60 to 1.99; I^2^=32%; Figure 28),^21,35,114,115^ withdrawal due to adverse events (five trials, N=648, RR 2.40, 95% CI 0.71 to 19.32; I^2^=0%; Figure 29),^35,62,78,127,142^ or any adverse event (two trials, N=1,538, RR 1.56, 95% CI 0.59 to 4.03; I^2^=82%).^35,114,115^ However, estimates were imprecise and the estimate for any adverse event was based on two trials, with substantial statistical heterogeneity (RR 1.04; 95% CI 0.73 to 1.47 in a trial of latanaprost^35^ and RR 2.30, 95% CI 1.69 to 3.12 in a trial of dorzolamide^114,115^). Two trials found treatment associated with increased risk of ocular adverse events compared with placebo (RR 1.21, 95% CI 1.10 to 1.33 in a trial of various treatments^114,115^ and RR 3.52, 95% CI 2.46 to 5.02^21^ in a trial of dorzolamide). The most common ocular adverse events were localized itching, irritation, tearing, dryness, or taste issues. Because of extreme statistical heterogeneity (I^2^=94%), the pooled estimate was unreliable and not reported. The OHTS found no interaction between race and likelihood of experiencing one or more serious adverse events (p for interaction=0.16) or any adverse event (p for interaction=0.58) with medical treatment compared with placebo.^148^

Figure 28 Medical Treatment vs. Placebo/No Treatment on Serious Adverse Effects

Abbreviations: CI = confidence interval; OAG = open angle glaucoma; OHT = ocular hypertension.

Figure 28 is a forest plot of Medical Treatment vs. Placebo/No Treatment on Serious Adverse Effects. The pooled risk ratio is 1.14 (0.60 to 1.99) with an I-squared value of 31.6%.

Figure 29 Medical Treatment vs. Placebo/No Treatment on IOP Withdrawals Due to Adverse Effects

Abbreviations: CI = confidence interval; IOP = intraocular pressure; OAG = open angle glaucoma; OHT = ocular hypertension.

Figure 29 is a forest plot of Medical Treatment vs. Placebo/No Treatment on IOP Withdrawals Due to Adverse. The pooled risk ratio is 2.40 (0.71 to 19.32) with an I-squared value of 0.0%.

## Key Question 8 What Are the Effects of Newly FDA-Approved Medical Treatments (Latanoprostene Bunod and Netarsudil) vs. Older Medical Treatments on a) IOP, Visual Field Loss, Visual Acuity, or Optic Nerve Damage or b) Visual Impairment, Quality of Life, or Function?

### Summary

- Three trials (N=1,875) found netarsudil to be noninferior to timolol for IOP lowering at 3 to 12 months.
- A pooled analysis of two trials (N=985) found netarsudil and latanaprost to be associated with similar effects on IOP (mean diference 0.3 mm Hg) and likelihood of IOP ≤18 mm Hg 57.4% vs. 65.5%) at 12 months.
- One trial (N=413) found latanoprostene bunod 0.024 or 0.040 percent associated with slightly greater effects on IOP (difference 1.2 mm) compared with latanoprost at short-term (1 month) followup.
- Two trials (N=840) found latanoprostene bunod associated with slightly greater IOP reduction compared with timolol at 3 months (difference −1.0 to −1.3 mm Hg).
- A pooled analysis of two trials (N=840) found latanoprostene bunod associated with increased likelihood of IOP ≤18 (20.2% vs. 11.2%; p=0.001) and IOP reduction ≥25 percent (22.9% vs. 19.0%; p<0.001) at 3 months.

### Evidence

Eight trials and two meta-analyses evaluated the effects of latanaprostene bunod or netarsudil compared with an older glaucoma medication (Appendix B Table 11).^57,58,66,91,98,113,129,139–141^ The Rho Kinase Elevated IOP Treatment (ROCKET) trials compared netarsudil with timolol (ROCKET-1 and ROCKET-2^129^ and ROCKET-4^98^ trials); the VOYAGER study compared different doses of latanaprostene bunod with latanaprost;^140^ the LUNAR^113^ and APOLLO^139,141^ trials (acronyms not defined) compared latanaprostene bunod with timolol; and the MERCURY-1^58,66^ and MERCURY-2^57^ trials (acronym not defined) compared netarsudil with latanaprost.

Sample sizes ranged from 411 to 985 (N=4,113). The mean age ranged from 61 to 66 years and 50 to 68 percent of participants were female. All trials enrolled mixed populations of patients with OAG or ocular hypertension. The proportion of patients with OAG in the ROCKET trials ranged from 62 to 68 percent and in the MERCURY-1 and MERCURY-2 trials ranged from 72 to 77 percent; the three trials of latanaprostene bunod did not report the proportion of patients with OAG. Mean baseline IOP ranged from 20.7 to 26.7 mm Hg. The duration of followup was 3 months in all trials except for three, which had 1-^140^ or 12-month followup.^66,91^ All trials were multinational except for the MERCURY trials, which were conducted in the U.S. Three trials (LUNAR, APOLLO, and MERCURY-2)^57,113,141^ were rated good quality and five trials were rated fair quality.^66,91,98,129,140^ Methodological limitations in the fair-quality trials included unclear reporting of randomization, allocation concealment, and blinding of outcome assessors; the ROCKET and MERCURY-1 trials also had high and differential attrition (Appendix B Table 12).^91,98,129^ All of the trials focused on the outcome of IOP.

The ROCKET trials (N=1,875) found netarsudil to be noninferior to timolol in mean IOP reduction at 3 months (3 trials) and 12 months (1 trial).^91^ The MERCURY-1 trial (N=480) found netarsudil and latanaprost associated with similar reduction in IOP (mean difference 0.3 mm Hg for netarsudil vs. latanaprost) and likelihood of achieving IOP ≤18 mm Hg RR (57.4% vs. 65.5%, RR 0.73; 95% CI 0.61 to 0.88) at 12 months.^66^

The short-term (1 month) VOYAGER trial (n=413) found latanaprostene bunod 0.024% and 0.04% associated with greater reduction in IOP compared with latanaprost (mean differences 1.23 mm Hg, 95% CI 0.37 to 2.10; 0.04% and 1.16 mm Hg, 95% CI 0.29 to 2.03, respectively) and increased likelihood of IOP ≤18 (68% vs. 64% vs. 47%, p<0.05 for both latanaprostene bunod doses vs. latanaprost).^140^ Two trials (LUNAR and APOLLO, N=840) found latanaprostene bunod associated with greater IOP reductions than timolol.^113,141^ In a pre-planned pooled analysis, mean differences in IOP ranged from −1.0 to −1.3 mm Hg at 3 months (p<0.001).^139^ Latanaprostene was also associated with a higher likelihood of IOP ≤18 at week 2, week 6, and 3-month timepoints (20.2% vs. 11.2%; p=0.001) and IOP reduction ≥25 percent at all timepoints (2.9% vs. 19.0%; p<0.001).

## Key Question 9 What Are the Harms of Newly FDA-Approved Medical Treatments vs. Older Medical Treatments?

### Summary

- Netarsudil was associated with increased risk of ocular adverse events (3 trials, N=1,875, RRs ranged from 1.69 to 2.07), withdrawal due to adverse events (3 trials, N=1,875, RRs ranged from 4.73 to 38.20), and any adverse event (1 trial, n=708, 80% vs. 60%, RR 1.33, 95% CI 1.20 to 1.47) compared with timolol.
- Netarsudil also associated with increased risk of any adverse event (1 trial, n=480, RR 1.45, 95% CI 1.27 to 1.66), ocular adverse events (1 trial, n=480, RR 1.76, 95% CI 1.50 to 2.07) and withdrawal due to adverse events (1 trial, n=480, RR 12.82, 95% CI 4.71 to 34.85) compared with latanaprost at 12 months.
- One trial (n=413) found latanaprostene bunod and latanaprost associated with similar likelihood of any adverse events and withdrawals due to adverse events.
- Two trials (N=840) found latanaprostene bunod associated with increased risk of ocular adverse events compared with timolol (pooled RR 1.72; 95% CI 1.22 to 2.42); estimates for withdrawal due to adverse events were imprecise.

### Evidence

Eight head-to-head trials and two meta-analyses reported adverse events associated with newly approved glaucoma medications compared with older medications (Appendix B Table 11).^57,58,66,91,98,113,129,139–141^ In the ROCKET trials (k=3, N=1,875), netarsudil was associated with increased risk of ocular adverse events compared with timolol.^91,98,129^ The most common ocular adverse events were conjunctival redness or hemorrhage, corneal deposits (cornea verticillata, typically asymptomatic and without effects on vision), blurry vision, tearing, and itching. The proportion of patients with ocular adverse events ranged from 73 to 88 percent with netarsudil and from 41 to 50 percent with timolol; RRs ranged from 1.51 to 2.07 at 3 to 12 months (ARDs ranged from 26% to 38%). Netarsudil was also associated with increased likelihood of withdrawal due to adverse events (RRs ranged from 4.73 to 38.20; ARDs ranged from 8% to 34%), though estimates were imprecise. One trial found netarsudil associated with increased likelihood of any adverse event compared with timolol (80% vs. 60%, RR 1.33, 95% CI 1.20 to 1.47).^98^

Netarsudil was also associated with increased risk of any adverse event (RR 1.45, 95% CI 1.27 to 1.66) and ocular adverse events (RR 1.76, 95% CI 1.50 to 2.07) at 12 months compared with latanaprost, based on one trial (n=480).^66^ Netarsudil was also associated with increased risk of withdrawal due to adverse events compared with latanaprost at 3 months (2 trials, N=986, RR 7.40, 95% CI 2.94 to 18.65)^57^ and 12 months (one trial, n=480, RR 12.82, 95% CI 4.71 to 34.85).^66^

One short-term (1 month) trial (n=413) found no differences between latanaprostene bunod and latanaprost in risk of any adverse event or withdrawal due to adverse events.^140^ Two trials (N=840) found latanaprostene bunod associated with increased risk of ocular adverse events compared with timolol (pooled RR 1.72, 95% CI 1.22 to 2.42).^139^ Estimates for withdrawal due to adverse events were imprecise (RR 1.96; 95% CI 0.22 to 17.40 and RR 0.48, 95% CI 0.12 to 1.88).

## Key Question 10 What Are the Effects of Laser Trabeculoplasty for OAG vs. No Trabeculoplasty or Medical Treatment on a) IOP, Visual Field Loss, Visual Acuity, or Optic Nerve Damage or b) Visual Impairment, Quality of Life, or Function?

### Summary

- The large (n=718), good-quality Laser in Glaucoma and Ocular Hypertension (LiGHT) trial reported SLT and medical therapy were associated with similar effects on IOP, visual acuity, visual field, general quality of life, and glaucoma-specific utility, symptoms, and quality of life at 3 years.
- Three smaller, fair-quality trials found SLT and medical therapy similar for IOP at 4 to 12 months and 5 years; the trials did not evaluate other ocular and health outcomes.

### Evidence

The prior treatment CER^3^ included two trials^103,151^ (N=220) comparing SLT with medical therapy. One trial^103^ was carried forward for this update but the other^151^ was ineligible because a high proportion of patients had capsular glaucoma and use of an outdated intervention (argon laser). Three additional trials (in four publications; N=925) not included in the prior treatment CER of SLT compared with a topical prostaglandin analogue were added for this update (Appendix B Table 13).^37,82,118,119^

The largest study was the LiGHT trial, which enrolled 718 participants with OAG or ocular hypertension and visual acuity ~20/120 or better.^37,82^ In the medical therapy arm of LiGHT, patients received stepped therapy with prostaglandins as initial therapy, followed by beta blockers, topical carbonic anhydrase inhibitors, or alpha agonists. Patients were excluded if they had prior surgery or were currently on or had prior exposure to glaucoma medical therapy. Forty-five percent of patients were female and mean age was 63 years. Seventy percent of patients were White, 20 percent Black, and 7.1 percent Asian. Mean baseline IOP was 24.5 mm Hg; the majority of randomized patients were diagnosed with OAG (77.3%) compared with ocular hypertension (22.7%). Of those with OAG, disease severity was most commonly assessed as mild (88.6%), followed by moderate (20.1%) and severe (10.4%).

The sample sizes in three smaller trials (including the trial in the prior treatment CER)^103^ ranged from 32 to 167 participants; 48 percent to 55 percent were female.^103,118,119^ Mean ages ranged from 52 years to 66 years and mean baseline IOP ranged from 22.8 mm Hg to 29.3 mm Hg. The proportion of patients with OAG ranged from 43 to 59 percent and the proportion with ocular hypertension ranged from 41 to 57 percent. All studies excluded patients with prior laser or glaucoma surgery. In two trials,^103,118^ patients were randomized to 360° SLT; in the other trial,^119^ patients were randomized to 90°, 180°, or 360° SLT. The duration of followup ranged from 4 months to 5 years. Three trials were conducted in the United Kingdom (U.K.)^37,82,118,119^ and one in Hong Kong.^103^

One RCT^37,82^ was rated good quality; the remaining three were rated fair quality (Appendix B Table 14).^103,118,119^ Methodological limitations in the fair-quality trials included unclear reporting of randomization, allocation concealment, and blinding methods.

#### IOP

The good-quality, large (n=718) LiGHT trial found 360° SLT and medical therapy associated with very similar mean IOP at 3 years (16.6 [SD 3.62] vs. 16.3 [SD 3.87] mm Hg).^37,82^ Among those randomized to SLT, 74.1 percent received one treatment per eye, 25.7 percent received two treatments, and 0.2 percent received three treatments. Medical therapy was associated with more treatment escalations than SLT. SLT and medical therapy were also associated with very similar proportions of eyes at target IOP, based on Canadian Target IOP Workshop criteria (95.0% vs. 93.1%). Among those who achieved target IOP at 3 years, 78.2 percent of eyes randomized to SLT did not require medication compared with 3 percent of patients randomized to medical therapy.^37,82^ Race/ethnicity was not a predictor of response to SLT (22% of participants were Black, 6.5% were Asian, and 68% were White).^36^

Three smaller trials (n=32, 40, and 167) reported results for IOP that were consistent with LiGHT.^103,118,119^ One trial^118^ (n=40) found 360° SLT and medical therapy associated with similar mean reduction from baseline in IOP at 4 to 6 months (6.2 [SE 0.8] vs. 7.8 [SE 0.8] mm Hg, p>0.05). Similar results were reported in a trial^103^ (n=32) comparing mean IOP reduction in SLT with medical therapy at 5 years (8.6 [SD 6.7] vs. 8.7 [SD 6.6] mm Hg, p>0.05). Two trials found 360° SLT and medical therapy associated with similar likelihood of ≥20 percent reduction in IOP from baseline at 4 to 6 months (75% vs. 73%; adjusted OR, 1.65, 95% CI 0.52 to 6.07)^118^ or 12 months (82% vs. 90%).^119^ In one trial (n=167),^119^ there was no difference between 360° SLT and medical therapy in likelihood of achieving ≥20 percent IOP reduction (82% vs. 90%). However, 90° and 180° SLT were both associated with decreased likelihood of ≥20 percent IOP reduction compared with medical therapy (34% vs. 65% vs. 90%, respectively, p<0.001 for 90° vs. medical therapy and p<0.01 for 180° vs. medical therapy).^119^

#### Other Ocular Outcomes

The LiGHT trial found 360° SLT and medical therapy associated with similar mean visual acuity at 3 years (0.07 [SD 0.18] vs. 0.08 [SD 0.17] logMAR).^37,82^ SLT and medical therapy were also associated with similar visual field mean deviation (−3.21 [SD 3.76] vs. −3.19 [SD 3.92] dB). Effects on visual acuity and visual fields were similar when patients stratified according to whether they had ocular hypertension or mild, moderate, or severe OAG at baseline. The other trials did not report visual acuity or other visual outcomes.

#### Quality of Life and Function

The LiGHT trial found SLT and medical therapy associated with similar quality of life at 3 years, as measured using the EQ-5D-5 (0.90 [SD 0.16] vs. 0.89 [SD 0.18]; adjusted mean difference 0.02, 95% CI −0.00 to 0.03).^37,82^ SLT and medical therapy were also associated with very similar glaucoma-specific utility, symptoms, and quality of life, based on the Glaucoma Utility Index (GUI) (0.89 [SD 0.13] vs. 0.89 [SD 0.13]), Glaucoma Symptom Scale (GSS) (83.1 [SD 17.7] vs. 83.3 [SD 17.3]), and the GQL-15 (19.8 [SD 7.2] vs. 19.8 [SD 7.8]).^37,82^ The other trials did not report visual acuity or other visual outcomes.

## Key Question 11 What Are the Harms of Laser Trabeculoplasty for OAG vs. No Trabeculoplasty or Medical Treatment?

### Summary

- The LiGHT trial reported similar adverse and serious adverse event rates between SLT and medical therapy; evidence on harms from three smaller trials was limited.

### Evidence

The LiGHT trial found no differences between SLT and medical therapy in patients experiencing any adverse event (73.3% vs. 71.8%) or any serious adverse event (18.0% vs. 18.8%) (Appendix B Table 13).^37,82^ SLT and medical therapy were associated with similar risk of ocular adverse events such as ocular irritation, retinal hemorrhage, or floaters (52% vs. 61%) and serious ocular adverse events such as trauma, central retinal artery occlusion, or choroidal neovascularization (2.2% vs. 1.7%). In the SLT group, 34.4 percent of patients experienced SLT-related transient adverse events, including discomfort, transient blurred vision, transient photophobia, and hyperemia. Evidence on harms of SLT compared with medical therapy from other trials was limited, due to suboptimal reporting and imprecision.^103,118,119^

## Contextual Question 1 What Is the Association Between Changes in IOP, Visual Field Loss, Visual Acuity, or Optic Nerve Damage Following Treatment for OAG and Improvement in Visual Impairment, Quality of Life, or Function, and What Is the Association Between Changes in IOP and Visual Field Loss?

As described in the prior treatment CER,^3^ evidence is available on the association between decreased IOP following treatment and decreased visual field loss. However, evidence on the association between changes in intermediate outcomes (IOP, visual field loss, visual acuity, or optic nerve damage) following treatment for OAG and improvement in health outcomes remains limited. Other information that may aid in interpreting intermediate outcomes include standards for classifying the severity of impaired visual acuity; limited evidence is available on minimum clinically important differences for visual acuity and visual field loss.

As described in the Results, there was direct evidence that treatment for OAG or ocular hypertension compared with placebo or no treatment is associated with decreased risk of progression of (variably defined) visual field loss (see Key Question 6). Studies have also evaluated the association between the degree of IOP lowering following treatment for POAG or ocular hypertension and decreased visual field loss. In these analyses, greater IOP reduction or lower IOP has consistently been associated with reduced likelihood of visual field or glaucoma progression. Several studies have focused on cohorts of patients enrolled in RCTs of glaucoma treatment. One analysis evaluated patients (n=738) in the Advanced Glaucoma Intervention Study (AGIS), which enrolled patients with OAG that could not be adequately controlled by medications alone. Patients had baseline visual acuity of 20/80 or better and the minimum Visual Field Defect Score ranged from 1 to 16 (0 to 20 scale, 20 indicates insufficient vision to count fingers at 30 cm). Patient eyes were randomized to argon laser trabeculoplasty or trabeculectomy.^152^ The analysis found higher average IOP associated with greater visual field loss at 24, 60, and 84 months, with a 1 mm Hg increase in average IOP associated with an increase in the Visual Field Defect Score of 0.08 to 0.18, after adjusting for age, intervention sequence, age, diabetes, gender, baseline IOP, and baseline Visual Field Defect Score.

Subsequent studies also found an association between degree of IOP lowering following treatment and decreased visual field loss in less advanced glaucoma. The Early Manifest Glaucoma Trial (EMGT) enrolled persons (n=255) with previously untreated glaucoma.^153^ Patients with advanced visual field defects, visual acuity worse than 0.5 (20/40), or mean IOP greater than 30 mm Hg were excluded. Patients were randomized to argon laser trabeculoplasty plus topical betaxolol or no immediate treatment. The outcome was glaucoma progression, defined as a composite outcomes based on perimetric criteria for visual field loss or photographic criteria for optic disc progression. At 6 years, greater decrease in IOP from baseline to 3 months was associated with decreased risk of glaucoma progression (per 1 mm Hg, HR 0.90, 95% CI 0.86 to 0.94) and higher mean IOP at followup was associated with increased risk of glaucoma progression (per 1 mm Hg, HR 1.13, 95% CI 1.07 to 1.19), after adjusting for baseline IOP, presence of exfoliation, baseline visual field loss, and age. Similar results were found at longer (up to 11 years) followup.^154^ The European Glaucoma Prevention Study (EGPS), which randomized persons (n=1,077) with ocular hypertension to dorzolamide or placebo, found greater reduction in mean followup IOP associated with decreased risk of progression to OAG during 5-year followup (per 1 mm Hg, HR 0.89, 95% CI 0.80 to 0.98), after adjusting for treatment arms and baseline predictive factors.^155^ Greater increase in mean followup IOP (per 1 mm Hg, HR 1.12, 95% CI 1.03 to 1.22) and area under the curve of IOP (mm Hg per year, HR 1.09, 95% CI 1.06 to 1.12) were associated with increased risk of progression to OAG. A limitation of the analyses from EGPS and EMGT is that they did not exclude patients randomized to placebo or no immediate treatment, potentially reducing the directness of findings to treated patients, though both reported estimates adjusted for treatment arm. Long-term (12 to 15 year) analyses from cohort studies of treated patients with normal tension glaucoma also found an association between greater IOP reduction and risk of glaucoma progression.^156,157^

The prior treatment CER found no direct evidence on the association between improvements in intermediate outcomes (IOP, visual fields, visual acuity, or optic nerve damage) following treatment for OAG or ocular hypertension and improvement in visual impairment, quality of life, or function.^3^ However, the prior treatment CER noted that cross-sectional studies not meeting inclusion criteria indicated an association between more severe visual field loss with more visual impairment and worse patient reported outcomes. Although such studies can evaluate correlations between intermediate and health outcomes, they cannot demonstrate causality or the association between changes in IOP following treatment and subsequent outcomes, due to the lack of longitudinal followup.

As in the prior treatment CER, we identified no studies on the association between improvements in intermediate outcomes and health outcomes. Studies published since the prior USPSTF review were consistent with previous findings with regard to the association between greater visual field loss and reduced vision-related quality of life or function, but were cross-sectional or did not evaluate the association between treatment-related changed in visual fields and function.^158–160^

We identified no studies on the association between improvements in optic nerve damage following treatment and health outcomes. The association between increased optic nerve damage and greater visual field loss has been described in numerous articles, but this represents an association between two intermediate outcomes.^161–166^

Evidence on minimum clinically important differences for visual field loss is limited. One longitudinal study found a mean deviation >5 dB visual field loss or >3 dB visual field gain associated with clinically meaningful losses or gains in vision-specific quality of life (defined as a change of ≥5 points on the 0 to 100 composite NEI-VFQ).^149^ Effects of visual field changes varied according to baseline vision status, with similar levels of visual field change associated with greater impact on quality of life in persons with pre-existing vision loss.

As noted in the 2016 USPSTF review on screening for impaired visual acuity, standards for classifying severity of impaired visual acuity are available. For example, visual acuity of 20/70 or better is classified as mild or no impairment by the World Health Organization.^167^ The International Council of Ophthalmology uses a slightly lower (20/63 or better) threshold for mildly impaired visual acuity.^168^ However, effects of even mildly impaired visual acuity are variable and can have a significant impact on quality of life. The best-corrected visual acuity acceptable for driving in most U.S. states is 20/40.^169^ Therefore, even relatively small changes in even “mild” impaired visual acuity could have a clinically important impact, depending on baseline visual acuity and type of work or other activities in which an individual is engaged.

As described in the 2016 USPSTF review on screening for impaired visual acuity,^170^ minimum clinically important differences for visual acuity have been described. Although definitions for a clinically important change in visual acuity vary across studies, a difference of at least 15 letters (equivalent to 3 lines on the Early Treatment Diabetic Retinopathy Study [ETDRS]), representing a doubling of the visual angle, is a commonly reported outcome in studies assessing visual acuity, and has been used to indicate a clinically meaningful difference.^171,172^ This threshold is based primarily on studies that evaluate effects of changes in visual acuity on vision-related function. Studies using the NEI-VFQ to assess vision-related function, though not necessarily in patients with glaucoma, found a difference of 4 to 10 points to be clinically meaningful to patients, corresponding to a 10- to 15-letter change in visual acuity.^172–175^