# Appendix B Evidence Tables and Quality Tables

Appendix B Table 1 Trial of Glaucoma Screening

Appendix B Table 2 Trial of Glaucoma Screening, Quality Assessment

Appendix B Table 3 Diagnostic Accuracy of Glaucoma Screening Tests, Study Characteristics

Appendix B Table 4 Diagnostic Accuracy of Glaucoma Screening Tests, Results

Appendix B Table 5 Diagnostic Accuracy of Glaucoma Screening Tests, Quality Assessment

Appendix B Table 6 Diagnostic Accuracy of Glaucoma Screening Instrument, Study Characteristics

Appendix B Table 7 Diagnostic Accuracy of Glaucoma Screening Instrument, Results

Appendix B Table 8 Diagnostic Accuracy of Screening Instrument, Quality Assessment

Appendix B Table 9 Placebo-Controlled Trials of Glaucoma Medical Treatments

Appendix B Table 10 Placebo-Controlled Trials of Glaucoma Medical Treatments, Quality Assessment

Appendix B Table 11 Newer vs. Older Trials of Glaucoma Medical Treatments

Appendix B Table 12 Newer vs. Older Trials of Glaucoma Medical Treatments, Quality Assessment

Appendix B Table 13 Trials of Selective Laser Trabeculoplasty vs. Medical Treatments

Appendix B Table 14 Trials of Selective Laser Trabeculoplasty vs. Medical Treatments, Quality Assessment