# References

1 Chou R, Dana T, Bougatsos C, . Screening for impaired visual acuity in older adults: updated evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2016 Mar 01;315(9):915–33. doi: 10.1001/jama.2016.0783. PMID: 26934261.26934261
2 Chou R, Dana T, Bougatsos C, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Screening for Impaired Visual Acuity in Older Adults: A Systematic Review to Update the 2009 U.S. Preventive Services Task Force Recommendation. Rockville (MD): Agency for Healthcare Research and Quality (US); 2016.
3 Siu AL, Bibbins-Domingo K, Grossman DC, . Screening for impaired visual acuity in older adults: US Preventive Services Task Force recommendation statement. JAMA. 2016 Mar 1;315(9):908–14. doi: 10.1001/jama.2016.0763. PMID: 26934260.26934260
4 Selph S, Dana T, Bougatsos C, . Screening for Abnormal Glucose and Type 2 Diabetes Mellitus: A Systematic Review to Update the 2008 U.S. Preventive Services Task Force Recommendation. Evidence Synthesis No. 117 Agency for Healthcare Research & Quality. Rockville, MD: 2015.
5 Munoz B, West SK, Rubin GS, . Causes of blindness and visual impairment in a population of older Americans: The Salisbury Eye Evaluation Study. Arch Ophthalmol. 2000;118(6):819–25.10865321
6 Vitale S, Cotch MF, Sperduto RD. Prevalence of visual impairment in the United States. JAMA. 2006;295:2158–63. doi: 10.1001/jama.295.18.2158. PMID: 16684986.16684986
7 International Council for Ophthalmology. Visual standards: aspects and ranges of vision loss with emphasis on populations surveys International Council of Ophthalmology. Sydney, Australia: 2002.
8 Fisher JB, Jacobs DA, Markowitz CE, . Relation of visual function to retinal nerve fiber layer thickness in multiple sclerosis. Ophthalmology. 2006 Feb;113(2):324–32. doi: 10.1016/j.ophtha.2005.10.040. PMID: 16406539.16406539
9 Suner IJ, Kokame GT, Yu E, . Responsiveness of NEI VFQ-25 to changes in visual acuity in neovascular AMD: validation studies from two phase 3 clinical trials. Invest Ophthalmol Vis Sci. 2009 Aug;50(8):3629–35. doi: 10.1167/iovs.08-3225. PMID: 19255158.19255158
10 Lindblad AS, Clemons TE. Responsiveness of the National Eye Institute Visual Function Questionnaire to progression to advanced age-related macular degeneration, vision loss, and lens opacity: AREDS Report no. 14. Arch Ophthalmol. 2005 Sep;123(9):1207–14. PMID: 16157800.16157800
11 Jager RD, Mieler WF, Miller JW. Age-related macular degeneration. N Engl J Med. 2008 Jun 12;358(24):2606–17. doi: 10.1056/NEJMra0801537. PMID: 18550876.18550876
12 The Eye Diseases Prevalence Research Group. The prevalence of refractive errors among adults in the United States, Western Europe, and Australia. Arch Ophthalmol. 2004 April 1, 2004;122(4):495–505. doi: 10.1001/archopht.122.4.495.15078666
13 Varma R, Vajaranant TS, Burkemper B, . Visual impairment and blindness in adults in the United States: demographic and geographic variations from 2015 to 2050. JAMA Ophthalmol. 2016 Jul 1;134(7):802–9. doi: 10.1001/jamaophthalmol.2016.1284. PMID: 27197072.27197072
14 The Eye Diseases Prevalence Research Group. Causes and prevalence of visual impairment among adults in the United States. Arch Ophthalmol. 2004;122:477–85.15078664
15 Centers for Disease Control and Prevention National Center for Chronic Disease Prevention and Health Promotion. The State of Vision, Aging, and Public Health in America. Atlanta GA; 2011. https://www.preventblindness.org/sites/default/files/national/documents/vision_brief.pdf. Accessed December 16, 2019.
16 Frick KD, Gower EW, Kempen JH, . Economic impact of visual impairment and blindness in the United States. Arch Ophthalmol. 2007 Apr;125(4):544–50. doi: 10.1001/archopht.125.4.544. PMID: 17420375.17420375
17 Rein DB, Zhang P, Wirth KE, . The economic burden of major adult visual disorders in the United States. Arch Ophthalmol. 2006 Dec;124(12):1754–60. doi: 10.1001/archopht.124.12.1754. PMID: 17159036.17159036
18 Klein R, Chou CF, Klein BE, . Prevalence of age-related macular degeneration in the US population. Arch Ophthalmol. 2011 Jan;129(1):75–80. doi: 10.1001/archophthalmol.2010.318. PMID: 21220632.21220632
19 Zambelli-Weiner A, Crews JE, Friedman DS. Disparities in adult vision health in the United States. Am J Ophthalmol. 2012 Dec;154(6 Suppl):S23–30 e1. doi: 10.1016/j.ajo.2012.03.018. PMID: 22633355.22633355
20 Congdon N, O’Colmain B, Klaver CC, . Causes and prevalence of visual impairment among adults in the United States. Arch Ophthalmol. 2004 Apr;122(4):477–85. doi: 10.1001/archopht.122.4.477. PMID: 15078664.15078664
21 American Academy of Ophthalmology. Eye health statistics at a glance. 2011. http://www.aao.org/newsroom/upload/Eye-Health-Statistics-April-2011.pdf. Accessed September 16, 2020.
22 Weale RA. Epidemiology of refractive errors and presbyopia. Surv Ophthalmol. 2003 9//;48(5):515–43. doi: 10.1016/S0039-6257(03)00086-9.14499819
23 Tanna AP, Kaye HS, Tanna AP, . Trends in self-reported visual impairment in the United States: 1984 to 2010. Ophthalmology. 2012 Oct;119(10):2028–32. doi: 10.1016/j.ophtha.2012.04.018. PMID: 22683061.22683061
24 National Eye Institute. The eye health needs of older adults. Bethesda MD: National Institutes of Health; 2013. http://www.nei.nih.gov/nehep/research/The_Eye_Health_needs_of_Older_Adults_Literature_Review.pdf. Accessed October 15th, 2014.
25 Rubin G, Roche KB, Prasada-Rao P, . Visual impairment and disability in older adults. Optom Vis Sci. 1994;71:750–60. doi: 10.1097/00006324-199412000-00005. PMID: 7898882.7898882
26 Klein BEK, Moss SE, Klein R, . Associations of visual function with physical outcomes and limitations 5 years later in an older population: The Beaver Dam eye study. Ophthalmology. 2003;110(4):644–50.12689880
27 Haymes SA, Johnston AW, Heyes AD. Relationship between vision impairment and ability to perform activities of daily living. Ophthalmic Physiol Opt. 2002;22(2):79–91. PMID: 12014491.12014491
28 Sims RV, Owsley C, Allman RM, . A preliminary assessment of the medical and functional factors associated with vehicle crashes by older adults. J Am Geratr Soc. 1998;46:556–61.
29 Owsley C, Stalvey B, Wells J, . Older drivers and cataract. Driving habits and crash risk. J Gerontol A Biol Sci Med Sci. 1999 05.29.08;54:M203–11.10219012
30 McGwin G, Jr., Chapman V, Owsley C. Visual risk factors for driving difficulty among older drivers. Accid Anal Prev. 2000;32(6):735–44. PMID: 10994600.10994600
31 Lord SR, Dayhew J. Visual risk factors for falls in older people. J Am Geriatr Soc. 2001;49(5):508–15.11380741
32 Ivers RQ, Cumming RG, Mitchell P, . Visual impairment and falls in older adults: the Blue Mountains Eye Study. J Am Geriatr Soc. 1998;46:58–64.9434666
33 Chou CF, Cotch MF, Vitale S, . Age-related eye diseases and visual impairment among U.S. adults. Am J Prev Med. 2013 Jul;45(1):29–35. doi: 10.1016/j.amepre.2013.02.018. PMID: 23790986.23790986
34 American Foundation for the Blind. Aging and vision loss fact sheet. New York NY: American Foundation for the Blind; 2013. http://www.afb.org/info/programs-and-services/professional-development/experts-guide/aging-and-vision-loss/1235. Accessed October 15th, 2014.
35 Centers for Disease Control and Prevention. Vision Health Initiative (VHI). Atlanta GA; 2013. http://www.cdc.gov/visionhealth/index.htm. Accessed December 13, 2019.
36 American Foundation for the Blind. Special report on aging and vision loss. 2013(October 15th, 2014).
37 Administration on Aging, Administration for Community Living, U.S. Department of Health and Human Services. 2012 profile of older Americans 2012;2014(October 15th, 2014).
38 Swenor BK, Ehrlich JR. Ageing and vision loss: looking to the future. Lancet Glob Health. 2021 Apr;9(4):e385–e6. doi: 10.1016/s2214-109x(21)00031-0. PMID: 33607013.33607013
39 American Academy of Ophthalmology. Comprehensive adult medical eye evaluation - 2010. American Academy of Ophthalmology; 2010. http://one.aao.org/preferred-practice-pattern/comprehensive-adult-medical-eye-evaluation-octobe. Accessed October 28th, 2014.
40 Hyman L. Myopic and hyperopic refractive error in adults: an overview. Ophthalmic Epidemiol. 2007;14(4):192–7.17896297
41 Asbell PA, Dualan I, Mindel J, . Age-related cataract. Lancet. 2005;365:599–609.15708105
42 de Jong PTVM. Age-related macular degeneration. N Engl J Med. 2006;355:1474–85.17021323
43 InformedHealth.org. Age-related macular degeneration (AMD): Overview. https://www.ncbi.nlm.nih.gov/books/NBK315804/#_NBK315804_pubdet_. Accessed September 9, 2020.
44 Congdon NG. Prevention strategies for age related cataract. Br J Ophthalmol. 2001;85:516–20.11316704
45 West SK, Valmadrid CT. Epidemiology of risk factors for age-related cataracts. Surv Ophthalmol. 1995;39:323–34. doi: 10.1016/S0039-6257(05)80110-9.7725232
46 Sommer A, Tielsch JM, Katz J, . Racial differences in the cause-specific prevalence of blindness in east Baltimore. N Engl J Med. 1991 Nov 14;325(20):1412–7. doi: 10.1056/nejm199111143252004. PMID: 1922252.1922252
47 Smith W, Assink J, Klein R, . Risk factors for age-related macular degeneration. Pooled findings from three continents. Ophthalmology. 2001;108:697–704.11297486
48 National Eye Institute. News brief: three studies point to same risk gene for age-related macular degeneration. National Eye Institute; 2013. http://www.nei.nih.gov/news/briefs/risk_gene_amd.asp?nav=rss. Accessed October 15th, 2014.
49 Centers for Disease Control and Prevention. Improving the nation’s vision health. A coordinated public health approach. Atlanta GA: Centers for Disease Control; 2010. http://www.cdc.gov/visionhealth/pdf/improving_nations_vision_health.pdf. Accessed October 15th, 2014.
50 The Eye Diseases Prevalence Research Group. Prevalence of cataract and pseudophakia/aphakia among adults in the United States. Arch Ophthalmol. 2004;122:487–94.15078665
51 The Eye Diseases Prevalence Research Group. Prevalence of age-related macular degeneration in the United States. Arch Ophthalmol. 2004 Apr;122(4):564–72. doi: 10.1001/archopht.122.4.564. PMID: 15078675.15078675
52 Ghanem RC, de la Cruz J, Tobaigy FM, . LASIK in the presbyopic age group: safety, efficacy, and predictability in 40- to 69-year-old patients. Ophthalmology. 2007 Jul;114(7):1303–10. PMID: 17382397.17382397
53 Macular Photocoagulation Study Group. Argon laser photocoagulation for senile macular degeneration. Results of a randomized clinical trial. Arch Ophthalmol. 1982;100(6):912–8.7046707
54 Riaz Y, Mehta JS, Wormald R, . Surgical interventions for age-related cataract. Cochrane Database Syst Rev. 2006;1(4. Art. No.: CD001323. DOI: 10.1002/14651858.CD001323.pub2).
55 Rosenthal BP. Ophthalmology. Screening and treatment of age-related and pathologic vision changes. Geriatrics. 2001;56(12):27–31. PMID: 11766560.11766560
56 Evans JR, Henshaw KS. Antioxidant vitamin and mineral supplements for slowing the progression of age-related macular degeneration. Cochrane Database Syst Rev. 2008;Issue 1. Art. No.: CD000253. DOI: 10.1002/14651858.CD0000253.pub2.18253971
57 McNeil JJ, Robman L, Tikellis G, . Vitamin E supplementation and cataract: randomized controlled trial. Ophthalmology. 2004;111(1):75–84. PMID: 14711717.14711717
58 Christen WG, Manson JE, Glynn RJ, . A randomized trial of beta carotene and age-related cataract in US physicians. Arch Ophthalmol. 2003;121(3):372–8. PMID: 12617708.12617708
59 Christen W, Glynn R, Sperduto R, . Age-related cataract in a randomized trial of beta-carotene in women. Ophthalmic Epidemiol. 2004;11(5):401–12.15590586
60 Loewenstein JI, Palmberg PF, Connett JE, . Effectiveness of a pinhole method for visual acuity screening. Arch Ophthamol. 1985;103:222–3.
61 Melki SA, Safar A, Martin J, . Potential acuity pinhole: a simple method to measure potential visual acuity in patients with cataracts, comparison to potential acuity meter. Ophthalmology. 1999;106(7):1262–7. PMID: 10406603.10406603
62 Amsler M. Earliest symptoms of diseases of the macula. Br J Ophthalmol. 1953;37:521–37.13081950
63 Fine AM. Earliest symptoms caused by neovascular membranes in the macula. Arch Ophthalmol. 1986;104:513–4.2420316
64 Fine SL. Early detection of extrafoveal neovascular membranes by daily central field evaluation. Ophthalmology. 1985;92:603–9.2409502
65 Haase KW, Bryant EE. Development of a scale designed to measure functional distance vision loss using an interview technique. Porc Am Stat Assoc. 1973(SS):274–9.
66 Chou R, Dana T, Bougatsos C. Screening for visual impairment in older adults: systematic review to update the 1996 U.S. preventive services task force recommendation. Evidence synthesis no. 71. AHRQ publication no. 09-05135-EF-1. Rockville, MD: Agency for Healthcare Research and Quality. 2009.
67 Zheng X, Saaddine JB, Lee PP, . Eye care in the United States. Do we deliver to high-risk people who can benefit most from it? Arch Ophthalmol. 2007;125:411–8. doi: 10.1001/archopht.125.3.411. PMID: 17353417.17353417
68 AAO Hoskins Centre for Quality Eye Care. Frequency of Ocular Examinations - 2015. 2015(December 13, 2019).
69 American Optometric Association. Comprehensive adult eye and vision examination. 2015(December 13, 2019).
70 American Family Physician. Screening for impaired visual acuity in older adults: recommendation statement. 2016(December 13, 2019).
71 U. S. Preventive Services Task Force. Procedure Manual. 2018. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed September 16, 2020.
72 Evans JR, Lawrenson JG. Antioxidant vitamin and mineral supplements for slowing the progression of age-related macular degeneration. Cochrane Database Syst Rev. 2017 Jul 30;7:Cd000253. doi: 10.1002/14651858.CD000253.pub4. PMID: 28756617.28756617
73 Evans JR, Lawrenson JG. Antioxidant vitamin and mineral supplements for slowing the progression of age-related macular degeneration. Cochrane Database Syst Rev. 2012;11. Art. No.: CD000254. DOI: 10.1002/14651858.CD000254.pub3:CD000254. doi: 10.1002/14651858.CD000254.pub3. PMID: 23152201.23152201
74 Ivers RQ, Optom B, Macaskill P, . Sensitivity and specificity of tests to detect eye disease in an older population. Ophthalmology. 2001;108(5):968–75. PMID: 11320029.11320029
75 Yaffe K, Clemons TE, McBee WL, . Impact of antioxidants, zinc, and copper on cognition in the elderly: a randomized, controlled trial. Neurology. 2004 Nov 9;63(9):1705–7. doi: 10.1212/01.wnl.0000142969.19465.8f. PMID: 15534261.15534261
76 Woods RL, Tregear SJ, Mitchell RA. Screening for ophthalmic disease in older subjects using visual acuity and contrast sensitivity. Ophthalmology. 1998;105(12):2318–26. doi: 10.1016/S0161-6420(98)91235-0. PMID: 9855166.9855166
77 Weigert G, Kaya S, Pemp B, . Effects of lutein supplementation on macular pigment optical density and visual acuity in patients with age-related macular degeneration. Invest Ophthalmol Vis Sci. 2011;52(11):8174–8. doi: 10.1167/iovs.11-7522. PMID: 21873668.21873668
78 Wang H, Li R, Wang M. Effects of zinc and antioxidant on visual function of patients with age-related macular degeneration. Zhongguo Linchuant Kangfu. 2004;8:1290–1.
79 Waldstein SM, Simader C, Staurenghi G, . Morphology and visual acuity in aflibercept and ranibizumab therapy for neovascular age-related macular degeneration in the VIEW trials. Ophthalmology. 2016 07;123(7):1521–9. doi: 10.1016/j.ophtha.2016.03.037. PMID: 27157149.27157149
80 Taylor HR, Tikellis G, Robman LD, . Vitamin E supplementation and macular degeneration: randomised controlled trial. BMJ. 2002 Jul 6;325(7354):11. doi: 10.1136/bmj.325.7354.11. PMID: 12098721.12098721
81 Tay T, Rochtchina E, Mitchell P, . Eye care service utilization in older people seeking aged care. Clin Exp Ophthalmol. 2006 Mar;34(2):141–5. doi: 10.1111/j.1442-9071.2006.01139.x. PMID: 16626428.16626428
82 Jee J, Wang JJ, Rose K, . Incorporating vision and hearing tests into aged care assessment: methods and the pilot study. Ophthalmic Epidemiol. 2004 Dec;11(5):427–36. doi: 10.1080/09286580490888807. PMID: 15590588.15590588
83 Tao Y, Jiang P, Wei Y, . alpha-lipoic acid treatment improves vision-related quality of life in patients with dry age-related macular degeneration. Tohoku J Exp Med. 2016 11;240(3):209–14. PMID: 27840374.27840374
84 Swanson MW, McGwin G, Jr., Elliott AF, . The nursing home minimum data set for vision and its association with visual acuity and contrast sensitivity. J Am Geriatr Soc. 2009 Mar;57(3):486–91. doi: 10.1111/j.1532-5415.2008.02144.x. PMID: 19187419.19187419
85 Stur M, Tittl M, Reitner A, . Oral zinc and the second eye in age-related macular degeneration. Invest Ophthalmol Vis Sci. 1996 Jun;37(7):1225–35. PMID: 8641826.8641826
86 Smeeth L, Fletcher AE, Hanciles S, . Screening older people for impaired vision in primary care: cluster randomised trial. BMJ. 2003 November 1, 2003;327(7422):1027–31. doi: 10.1136/bmj.327.7422.1027. PMID: 14593039.14593039
87 Rosenfeld PJ, Brown DM, Heier JS, . Ranibizumab for neovascular age-related macular degeneration. N Engl J Med. 2006;355(14):1419–31. PMID: 17021318.17021318
88 Richer S, Stiles W, Statkute L, . Double-masked, placebo-controlled, randomized trial of lutein and antioxidant supplementation in the intervention of atrophic age-related macular degeneration: the Veterans LAST study (Lutein Antioxidant Supplementation Trial). Optometry. 2004 Apr;75(4):216–30. doi: 10.1016/s1529-1839(04)70049-4. PMID: 15117055.15117055
89 Richer S. Multicenter ophthalmic and nutritional age-related macular degeneration study-part 2: antioxidant intervention and conclusions. J Am Optom Assoc. 1996 Jan;67(1):30–49. PMID: 8825017.8825017
90 Regillo CD, Brown DM, Abraham P, . Randomized, double-masked, sham-controlled trial of ranibizumab for neovascular age-related macular degeneration: PIER Study year 1. Am J Ophthalmol. 2008;145(2):239–48. PMID: 18222192.18222192
91 Piermarocchi S, Saviano S, Parisi V, . Carotenoids in Age-related Maculopathy Italian Study (CARMIS): two-year results of a randomized study. Eur J Ophthalmol. 2012 Mar–Apr;22(2):216–25. doi: 10.5301/ejo.5000069. PMID: 22009916.22009916
92 Piatti A, Croce A, Mazzacane D, . Effect of 2-year nutritional supplementation on progression of age-related macular degeneration. Eur J Ophthalmol. 2020 Mar 18;30(2):376–81. doi: 10.1177/1120672119836007. PMID: 30880442.30880442
93 Newsome DA, Swartz M, Leone NC, . Oral zinc in macular degeneration. Arch Ophthalmol. 1988 Feb;106(2):192–8. doi: 10.1001/archopht.1988.01060130202026. PMID: 3277606.3277606
94 Newsome DA. A randomized, prospective, placebo-controlled clinical trial of a novel zinc-monocysteine compound in age-related macular degeneration. Curr Eye Res. 2008 Jul;33(7):591–8. doi: 10.1080/02713680802178437. PMID: 18600492.18600492
95 Murray IJ, Makridaki M, van der Veen RLP, . Lutein supplementation over a one-year period in early AMD might have a mild beneficial effect on visual acuity: the CLEAR study. Invest Ophthalmol Vis Sci. 2013 Mar;54(3):1781–8. doi: 10.1167/iovs.12-10715. PMID: 23385792.23385792
96 Mueller YK, Monod S, Locatelli I, . Performance of a brief geriatric evaluation compared to a comprehensive geriatric assessment for detection of geriatric syndromes in family medicine: a prospective diagnostic study. BMC Geriatr. 2018 03 13;18(1):72. doi: 10.1186/s12877-018-0761-z. PMID: 29534680.29534680
97 Moore AA, Siu A, Partridge JM, . A randomized trial of office-based screening for common problems in older persons. Am J Med. 1997;102(4):371–8. PMID: 9217619.9217619
98 McMurdo M, Baines P. The detection of visual disability in the elderly. Health Bull (Edinb). 1988;46(6):327–9. PMID: 3240947.3240947
99 Ma L, Yan SF, Huang YM, . Effect of lutein and zeaxanthin on macular pigment and visual function in patients with early age-related macular degeneration. Ophthalmology. 2012 Nov;119(11):2290–7. doi: 10.1016/j.ophtha.2012.06.014. PMID: 22858124.22858124
100 Kaiser HJ, Flammer J, Stumpfig D, . Visaline in the treatment of age-related macular degeneration: a pilot study. Ophthalmologica. 1995;209(6):302–5. doi: 10.1159/000310646. PMID: 8751336.8751336
101 Johnson AR, Munoz A, Gottlieb JL, . High dose zinc increases hospital admissions due to genitourinary complications. J Urol. 2007 Feb;177(2):639–43. PMID: 17222649.17222649
102 Jessa Z, Evans BJW, Thomson DW. The development & evaluation of two vision screening tools for correctable visual loss in older people. Ophthalmic Physiol Opt. 2012 Jul;32(4):332–48. doi: 10.1111/j.1475-1313.2012.00919.x. PMID: 22670892.22670892
103 Holz F, Wolfensberger T, Piguet B, . Oral zinc-therapy in age-related macular degeneration: a double blind study. Germ J Ophthalmol. 1993;2(Suppl):391.
104 Ho AC, Saroj N, Baker K, . Impact of baseline characteristics on treatment response to intravitreal aflibercept injection for wet age-related macular degeneration. Ophthalmol Retina. 2018 07;2(7):676–83. doi: 10.1016/j.oret.2017.10.017. PMID: 31047376.31047376
105 Hiller R, Krueger DE. Validity of a survey question as a measure of visual acuity impairment. Am J Public Health. 1983;73:93–6. PMID: 6848004.6848004
106 Heier JS, Brown DM, Chong V, . Intravitreal aflibercept (VEGF trap-eye) in wet age-related macular degeneration. Ophthalmology. 2012 Dec;119(12):2537–48. doi: 10.1016/j.ophtha.2012.09.006. PMID: 23084240.23084240
107 Gragoudas ES, Adamis AP, Cunningham ET, . Pegaptanib for neovascular age-related macular degeneration. N Engl J Med. 2004;351(27):2805–16. PMID: 15625332.15625332
108 Gillies MC, Hunyor AP, Arnold JJ, . Macular Atrophy in Neovascular Age-Related Macular Degeneration: A Randomized Clinical Trial Comparing Ranibizumab and Aflibercept (RIVAL Study). Ophthalmology. 2020 Feb;127(2):198–210. doi: 10.1016/j.ophtha.2019.08.023. PMID: 31619357.31619357
109 Gillies MC, Hunyor AP, Arnold JJ, . Effect of ranibizumab and aflibercept on best-corrected visual acuity in treat-and-extend for neovascular age-related macular degeneration: a randomized clinical trial. JAMA Ophthalmol. 2019 Apr 01;137(4):372–9. doi: 10.1001/jamaophthalmol.2018.6776. PMID: 30676617.30676617
110 Eekhof JA, De Bock GH, Schaapveld K, . Screening for hearing and visual loss among elderly with questionnaires and tests: which method is the most convincing for action? Scand J Prim Health Care. 2000;18(4):203–7. PMID: 11205087.11205087
111 Eekhof J, De Bock G, Schaapveld K, . Effects of screening for disorders among the elderly: an intervention study in general practice. Fam Pract. 2000;17(4):329–33. PMID: 10934182.10934182
112 Chew EY, Sperduto RD, Milton RC, . Risk of advanced age-related macular degeneration after cataract surgery in the Age-Related Eye Disease Study: AREDS report 25. Ophthalmology. 2009 Feb;116(2):297–303. doi: 10.1016/j.ophtha.2008.09.019. PMID: 19091420.19091420
113 Chew EY, Clemons TE, Agron E, . Long-term effects of vitamins C and E, beta-carotene, and zinc on age-related macular degeneration: AREDS report no. 35. Ophthalmology. 2013 Aug;120(8):1604–11.e4. doi: 10.1016/j.ophtha.2013.01.021. PMID: 23582353.23582353
114 Chew EY, Clemons TE, Agron E, . Effect of omega-3 fatty acids, lutein/zeaxanthin, or other nutrient supplementation on cognitive function: the AREDS2 Randomized Clinical Trial. JAMA. 2015 Aug 25;314(8):791–801. doi: 10.1001/jama.2015.9677. PMID: 26305649.26305649
115 Chew EY, Clemons T, SanGiovanni JP, . The Age-Related Eye Disease Study 2 (AREDS2): study design and baseline characteristics (AREDS2 report number 1). Ophthalmology. 2012 Nov;119(11):2282–9. doi: 10.1016/j.ophtha.2012.05.027. PMID: 22840421.22840421
116 Chang TS, Bressler NM, Fine JT, . Improved vision-related function after ranibizumab treatment of neovascular age-related macular degeneration: results of a randomized clinical trial. Arch Ophthalmol. 2007 Nov;125(11):1460–9. PMID: 17998507.17998507
117 Bressler NM, Chang TS, Varma R, . Driving ability reported by neovascular age-related macular degeneration patients after treatment with ranibizumab. Ophthalmology. 2013 Jan;120(1):160–8. doi: 10.1016/j.ophtha.2012.07.027. PMID: 23009891.23009891
118 Berrow EJ, Bartlett HE, Eperjesi F, . The effects of a lutein-based supplement on objective and subjective measures of retinal and visual function in eyes with age-related maculopathy - a randomised controlled trial. Br J Nutr. 2013 Jun;109(11):2008–14. doi: 10.1017/s0007114512004187. PMID: 23084077.23084077
119 Beatty S, Chakravarthy U, Nolan JM, . Secondary outcomes in a clinical trial of carotenoids with coantioxidants versus placebo in early age-related macular degeneration. Ophthalmology. 2013 Mar;120(3):600–6. doi: 10.1016/j.ophtha.2012.08.040. PMID: 23218821.23218821
120 Bartlett HE, F.A. E. Effect of lutein and antioxidant dietary supplementation on contrast sensitivity in age-related macular degeneration: a randomized controlled trial. Eur J Clin Nutr. 2007;61(9):1121–7. PMID: 17268417.17268417
121 Arora KS, Chang DS, Supakontanasan W, . Assessment of a rapid method to determine approximate visual acuity in large surveys and other such settings. Am J Ophthalmol. 2014 Jun;157(6):1315–21.e1. doi: 10.1016/j.ajo.2014.02.031. PMID: 24548874.24548874
122 Ariyasu RG, Lee PP, Linton KP, . Sensitivity, specificity, and predictive values of screening tests for eye conditions in a clinic-based population. Ophthalmology. 1996;103(11):1751–60. PMID: 8942866.8942866
123 AREDS Research Group. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E, beta carotene, and zinc for age-related macular degeneration and vision loss: AREDS report no. 8. Arch Ophthalmol. 2001 Oct;119(10):1417–36. PMID: 11594942.11594942
124 Age-Related Eye Disease Study 2 Research Group. Lutein + zeaxanthin and omega-3 fatty acids for age-related macular degeneration: the Age-Related Eye Disease Study 2 (AREDS2) randomized clinical trial. JAMA. 2013 May 15;309(19):2005–15. doi: 10.1001/jama.2013.4997. PMID: 23644932.23644932
125 Wang F, Tielsch JM, Ford DE, . Evaluation of screening schemes for eye disease in a primary care setting. Ophthalmic Epidemiol. 1998;5(2):69–82. PMID: 9672907.9672907
126 Teh RC, Lim WS. Utility of a patient-response screening question for visual impairment. J Am Geriatr Soc. 2006;54(2):370–2. PMID: 16460398.16460398
127 Clemons TE, Chew EY, Peto T, . Responsiveness and the minimal clinically important difference for the NEI VFQ-25 in patients with Macular Telangectasia Type 2 (MacTel Type 2). Invest Ophthalmol Vis Sci. 2015;56(7):1360.
128 Evans JR. Ginkgo biloba extract for age-related macular degeneration. Cochrane Database Syst Rev. 2013(1).
129 Souied EH, Delcourt C, Querques G, . Oral docosahexaenoic acid in the prevention of exudative age-related macular degeneration: the Nutritional AMD Treatment 2 study. Ophthalmology. 2013 Aug;120(8):1619–31. doi: 10.1016/j.ophtha.2013.01.005. PMID: 23395546.23395546
130 Chew EY, Clemons TE, Agron E, . Ten-year follow-up of age-related macular degeneration in the age-related eye disease study: AREDS report no. 36. JAMA Ophthalmol. 2014 Mar;132(3):272–7. doi: 10.1001/jamaophthalmol.2013.6636. PMID: 24385141.24385141
131 France. Professor Soubrane. Zinc Supplementation. Universitaire de Creteil, France. Unpublished data only. 1998.
132 Huang YM, Dou HL, Huang FF, . Effect of supplemental lutein and zeaxanthin on serum, macular pigmentation, and visual performance in patients with early age-related macular degeneration. Biomed Res Int. 2015;2015(564738) PMID: 25815324.25815324
133 D’Amico DJ, Masonson HN, Patel M, . Pegaptanib sodium for neovascular age-related macular degeneration: two-year safety results of the two prospective, multicenter, controlled clinical trials. Ophthalmology. 2006 Jun;113(6):992–1001.e6. doi: 10.1016/j.ophtha.2006.02.027. PMID: 16647134.16647134
134 Clarke EL, Evans JR, Smeeth L. Community screening for visual impairment in older people. Cochrane Database Syst Rev. 2018 02 20;2:CD001054. doi: 10.1002/14651858.CD001054.pub3. PMID: 29460275.29460275
135 Pillay J, Freeman EE, Hodge W, . Screening for impaired visual acuity and vision-related functional limitations in adults 65 years and older in primary health care: systematic review. Edmonton, AB; Evidence Review Synthesis Centre. 2017. http://canadiantaskforce.ca/ctfphc-guidelines/overview/ Accessed May 8, 2020.
136 Swamy B, Cumming RG, Ivers R, . Vision screening for frail older people: a randomised trial. Br J Ophthalmol. 2009 Jun;93(6):736–41. doi: 10.1136/bjo.2007.134650. PMID: 18614568.18614568
137 Cumming RG, Ivers R, Clemson L, . Improving vision to prevent falls in frail older people: a randomized trial. J Am Geriatr Soc. 2007;55(2):175–81. PMID: 17302652.17302652
138 Stone DH, Shannon DJ. Screening for impaired visual acuity in middle age in general practice. Br Med J. 1978;2(6141):859–61.709095
139 Powe N, Schein O, Gieser S, . Synthesis of the literature on visual acuity and complications following cataract extraction with intraocular lens implantation. Arch Ophthalmol. 1994 06.03.08;112(2):239–52.8037792
140 Coleman AL, Yu F, Keeler E, . Treatment of uncorrected refractive error improves vision-specific quality of life. J Am Geriatr Soc. 2006;54(6):883–90. PMID: 16776781.16776781
141 Elliott AF, McGwin G, Jr., Owsley C. Vision-enhancing interventions in nursing home residents and their short-term effect on physical and cognitive function. J Am Geriatr Soc. 2009 Feb;57(2):202–8. doi: 10.1111/j.1532-5415.2008.02099.x. PMID: 19170783.19170783
142 Hall TA, McGwin G, Jr., Owsley C. Effect of cataract surgery on cognitive function in older adults. J Am Geriatr Soc. 2005 Dec;53(12):2140–4. doi: 10.1111/j.1532-5415.2005.00499.x. PMID: 16398899.16398899
143 Owsley C, McGwin G, Jr., Scilley K, . Effect of refractive error correction on health-related quality of life and depression in older nursing home residents. Arch Ophthalmol. 2007;125(11):1471–7. PMID: 17998508.17998508
144 Owsley C, McGwin G, Jr., Scilley K, . Impact of cataract surgery on health-related quality of life in nursing home residents. Br J Ophthalmol. 2007;91(10):1359–63. PMID: 17522143.17522143
145 Tanvetyanon T, Bepler G. Beta-carotene in multivitamins and the possible risk of lung cancer among smokers versus former smokers: a meta-analysis and evaluation of national brands. Cancer. 2008 Jul 1;113(1):150–7. doi: 10.1002/cncr.23527. PMID: 18429004.18429004
146 National Eye Institute. AREDS/AREDS2 Clinical Trials. 2020. https://www.nei.nih.gov/research/clinical-trials/age-related-eye-disease-studies-aredsareds2/about-areds-and-areds2. Accessed September 5, 2020.
147 Yashkin AP, Hahn P, Sloan FA. Introducing anti-vascular endothelial growth factor therapies for AMD did not raise risk of myocardial infarction, stroke, and death. Ophthalmology. 2016 10;123(10):2225–31. doi: 10.1016/j.ophtha.2016.06.053. PMID: 27523614.27523614
148 Dalvin LA, Starr MR, AbouChehade JE, . Association of intravitreal anti-vascular endothelial growth factor therapy with risk of stroke, myocardial infarction, and death in patients with exudative age-related macular degeneration. JAMA Ophthalmol. 2019 May 1;137(5):483–90. doi: 10.1001/jamaophthalmol.2018.6891. PMID: 30703203.30703203
149 Ng WY, Tan GS, Ong PG, . Incidence of myocardial infarction, stroke, and death in patients with age-related macular degeneration treated with intravitreal anti-vascular endothelial growth factor therapy. Am J Ophthalmol. 2015 Mar;159(3):557–64.e1. doi: 10.1016/j.ajo.2014.12.005. PMID: 25497143.25497143
150 Whitlock EP, Lin JS, Chou R, . Using existing systematic reviews in complex systematic reviews. Ann Intern Med. 2008;148(10):776–82. doi: 10.7326/0003-4819-148-10-200805200-00010. PMID: 18490690.18490690
151 Zhang J, Liang Y, Xie J, . Conbercept for patients with age-related macular degeneration: a systematic review. BMC Ophthalmol. 2018 Jun 15;18(1):142. doi: 10.1186/s12886-018-0807-1. PMID: 29902977.29902977
152 Guymer RH, Baird PN, Varsamidis M, . Proof of concept, randomized, placebo-controlled study of the effect of simvastatin on the course of age-related macular degeneration. PLoS One. 2013;8(12):e83759. doi: 10.1371/journal.pone.0083759. PMID: 24391822.24391822
153 Roizenblatt M, Naranjit N, Maia M, . The question of a role for statins in age-related macular degeneration. Int J Mol Sci. 2018 Nov 21;19(11)doi: 10.3390/ijms19113688. PMID: 30469381.30469381
154 Williams MA, McKay GJ, Chakravarthy U. Complement inhibitors for age-related macular degeneration. Cochrane Database Syst Rev. 2014;Issue 1. Art. No.: CD009300. DOi:. 10.1002/14651858.CD009300.pub2doi: 10.1002/14651858.CD009300.pub2.24431152
155 Singh R. Complement inhibitors for treatment of geographic atrophy and advanced nonexudative AMD.
156 AAO Telemedicine Task Force. Telemedicine for Opthalmology Information Statement - 2018. Clinical Statements. 2018.
157 Holladay JT. Visual acuity measurements. J Cataract Refract Surg. 2004 Feb;30(2):287–90. doi: 10.1016/j.jcrs.2004.01.014. PMID: 15030802.15030802
158 Mitchell RA. Prevalence of age related macular degeneration in persons aged 50 years and over resident in Australia. J Epidemiol Community Health. 1993 Feb;47(1):42–5. doi: 10.1136/jech.47.1.42. PMID: 8436893.8436893