# Acknowledgments

The authors thank research librarian, Tracy Dana, MLS, for conducting the searches; AHRQ Medical Officer, Justin Mills, MD, MPH; as well as the U.S. Preventive Services Task Force.