# Chapter 4 Discussion

## Summary of Review Findings

Table 4 summarizes the evidence reviewed for this update. As in the prior review for the USPSTF, direct evidence on screening for impaired visual acuity compared with no screening, delayed screening, or usual care found no benefits on vision-related or other outcomes. Three fair- to good-quality cluster-randomized trials included in the prior review for the USPSTF^66^ with more than 4,700 patients found vision screening in older adults as part of a multicomponent screening intervention in primary care settings to be no more effective than no vision screening, delayed screening, or usual care.^86,97,111^ One additional, smaller trial (n=188) added for this update also found screening associated with no statistical significant improvement in vision-related outcomes compared with no screening.^81^ Potential reasons for lack of benefit in the screening trials may include high attrition, use of suboptimal screening interventions, low uptake of recommended interventions, or high rates of antecedent eye professional care.

Table 4 Summary of Evidence

Key Question | Studies (k); Observations (n); Study Designs | Summary of Findings | Consistency and Precision | Other Limitations | Strength of evidence | Applicability
KQ 1 . Benefits of screening | k=4 trials (3 in prior USPSTF review, 1 new); N=4,819 | Four trials of screening versus no screening, usual care, or delayed screening in older adults found no difference on vision or other clinical outcomes in older adults. | Evidence was consistent and reasonably precise | All studies rated fair quality; interventions and comparators differed across studies; adherence with recommended follow-up and interventions was low in some trials; attrition high in some trials; Reporting bias not detected. | Moderate for no benefit | Screening tests feasible for primary care; the studies were conducted in the United States., Europe, and Australia; screening conducted in community or general practice settings or a geriatric day hospital; screening conducted by general practitioners, office staff, or trained nurses; vision screening was conducted as part of a multicomponent health screen
KQ 2 . Harms of screening | No studies | No included trials reported harms of screening. | - | - | Insufficient | -
KQ 3 . Diagnostic accuracy of screening tests | K= 8 cross-sectional studies (7 in prior USPSTF review, 1 new); N= 7,398 | Visual acuity tests (3 studies) were associated with poor diagnostic accuracy for identifying visual conditions compared with a complete examination by an ophthalmologist; evidence on other screening tests was limited. | Evidence was consistent and precise. | All studies rated fair-quality; variability in screening tests and testing thresholds; test threshold not specified in some studies; clinical relevance of visual conditions identified on ophthalmological examination but not associated with impaired visual acuity unclear; some screening tests have not been validated; Reporting bias not detected | Moderate | Screening tests were feasible for primary care; studies were conducted in the United States, United Kingdom, and Australia; variability in screening settings (primary care clinics, general eye clinics, hospitals, community day centers, and nursing homes); screener trained research staff or unclear in some studies
KQ 4 . Diagnostic accuracy of screening instruments | K= 3 cross-sectional studies (2 in prior USPSTF review, 1 new); N= 5,203 | Three studies found that a screening question was not accurate for identifying older persons with impaired visual acuity compared with a visual acuity chart | Evidence was consistent and reasonably precise. | All studies rated fair-quality; the screening question varied across studies; Reporting bias not detected | Moderate | The screening questions were highly feasible for primary care; studies were conducted in the United States and Europe.
KQ 5 . Benefits of treatment for AMD vs. placebo/no treatment; Wet AMD - VEGF Inhibitors | k= 4 trials (all in prior USPSTF review); N= 2,086 | Four trials of VEGF inhibitors were associated with greater likelihood of ≥15 letters (3 lines) of visual acuity gain (RR, 2.92, 95% CI 1.20 to 7.12; I^2^=76%; ARD10%), <15 letters (3 lines) of visual acuity loss (RR 1.46, 95% CI 1.22 to 1.75, I^2^=80%; ARD 27%), and having vision 20/200 or better (RR, 1.47, 95% CI, 1.30 to 1.66, I^2^=42%; ARD 24%) at 1 year versus sham injection. In 1 trial, VEGF inhibitors were associated with better vision-related function and quality of life measures versus sham injection at 1 and 2 years, the mean difference was above the threshold for a minimum clinically important difference | Consistent (statistical heterogeneity present in pooled analyses, but inconsistency was in magnitude of effect, not direction of effect); Precise | Data on function or quality of life limited to 1 trial; studies not designed to evaluate mortality or other health outcomes; Reporting bias was not detected | Moderate for benefit | VEGF inhibitors are considered first-line therapy in the United States; baseline visual acuity 20/80 in 3 studies and ranged from 20/40 to 20/200 in 1 study; studies were conducted in the United States in 2 trials, and the others had various sites (United States, Canada, Europe, Israel, Australia, South America).
KQ 5 . Benefits of treatment for AMD vs. placebo/no treatment; Dry AMD – Vitamin and Mineral Supplements | k=1 systematic review of 19 trials (N=11,162) and 2 additional trials; N=180; The prior USPSTF review included a prior version of the SR with 13 trials | Antioxidant multivitamins associated with decreased risk of progression to late AMD (3 trials, N=2,445 people, OR 0.72 [95% CI 0.58 to 0.90]) and ≥3 lines visual acuity loss (1 trial, N=1,791 people, OR 0.77 [95% CI 0.62 to 0.96]) versus placebo. Zinc was associated with decreased risk of progression to late AMD versus placebo (3 trials, N=3,790 people, OR 0.83 [95% CI 0.70 to 0.98]; 96% of patients from AREDS) and decreased risk of visual acuity loss ≥3 lines that was of borderline statistical significance (2 trials, 3,791 people, RR 0.87 [95% CI 0.75 to 1.00]). | Evidence was consistent and precise. | Findings were primary based on 1 study (AREDS); heterogeneity in the interventions assessed | Moderate for benefit | AREDS was conducted in the United States and the AREDS and AREDS 2 formulations are widely used in clinical practice; baseline visual acuity was 20/32 or better in AREDS; ~75% of patients in AREDS had mild to moderate AMD at baseline
KQ 6 . Benefits of newer (aflibercept or brolucizumab-dbll) versus older VEGF inhibitors for AMD | k= 3 trials (all new); N= 2,738 | Aflibercept was noninferior to ranibizumab in likelihood of <15 ETDRS letters of visual acuity loss (3 trials), ≥15 letters of visual acuity gain (3 trials), and similar to ranibizumab for vison-related function (2 trials). | Evidence was consistent and reasonably precise | No trial of brolucizumab-dbll met inclusion criteria; trials not designed to assess mortality or other health outcomes.; Reporting bias was not detected | Moderate for similar benefit | Aflibercept was FDA approved for AMD in 2011, and with a longer dosing schedule in 2018; One trial was conducted in Australia, and the others had various sites (United States, Canada, international)
KQ 7 . Harms of treatment for AMD; Wet AMD – VEGF Inhibitors | VEGF vs. sham: k= 4 trials (all in prior USPSTF review); N= 2,086; Newer vs. older VEGF: k= 3 trials (all new); N= 2,738 | No differences between VEGF inhibitors versus sham injection in likelihood of withdrawal due to adverse events, cardiovascular events, or serious ocular adverse events; Three trials found that serious ocular adverse events were infrequent and occurred in similar proportions of patients randomized to either aflibercept or ranibizumab. | Evidence was consistent and imprecise. | Trials not powered for serious cardiovascular or ocular adverse events.; Reporting bias not detected | Moderate for no harm | VEGF vs. sham: VEGF inhibitors are considered first-line therapy in the United States; baseline visual acuity 20/80 in 3 studies and ranged from 20/40 to 20/200 in 1 study; studies were conducted in the United States in 2 trials, and the others had various sites (United States, Canada, Europe, Israel, Australia, South America); Newer vs. older VEGF: Aflibercept was FDA approved for AMD in 2011, and with a longer dosing schedule in 2018; One trial was conducted in Australia, and the others had various sites (United States, Canada, international)
KQ 7 . Harms of treatment for AMD; Dry AMD – Vitamin and Mineral Supplements | k=1 systematic review of 19 trials (N=11,162) and 2 additional trials; N=180; The prior USPSTF review included a prior version of the SR with 13 trials | The AREDS trial found zinc use associated with increased risk for hospitalization due to genitourinary causes versus nonuse (7.5% vs. 4.9%, RR, 1.47 [95% CI, 1.19 to 1.80]) and antioxidant use associated with increased risk of yellow skin compared with nonuse (8.3% vs. 6.0%, RR, 1.38 [95% CI, 1.09 to 1.75). The AREDS 2 trial found the AREDS formulation with beta carotene associated with increased risk of lung cancer versus the AREDS formulation without beta carotene (2.0% vs. 0.9%, p=0.04); almost all (91%) of the lung cancers in this analysis occurred in former smokers (current smokers were excluded from the analysis). Evidence on harms of antioxidant vitamins and minerals for dry AMD was otherwise limited, but did not indicate increased risk of serious adverse events or withdrawal due to adverse events. | Evidence was consistent. Evidence was precise for the AREDS formulation but imprecise for other antioxidant multivitamins and minerals | Trials were not designed to evaluate harms and reporting of harms from some trials was suboptimal | Moderate for harm (for AREDS formulation) | AREDS was conducted in the United States and the AREDS and AREDS 2 formulations are widely used in clinical practice; baseline visual acuity was 20/32 or better in AREDS; ~75% of patients in AREDS had mild to moderate AMD at baseline

Abbreviations: AMD = age-related macular degeneration; ARD = absolute risk difference; AREDS = Age-Related Eye Disease Studies; CI = confidence interval; ETDRS = Early Treatment Diabetic Retinopathy Study; FDA = United States Food and Drug Administration; KQ = key question; OR = odds ratio; RR = risk ratio; SR = systematic review; USPSTF = United States Preventive Services Task Force; VEGF = vascular endothelial growth factor.

Recent reviews of vision screening in older adults in broader (e.g., community and home-based) settings^134,135^ also found no differences between screening and no screening in vision or vision-related outcomes. However, a number of trials in these reviews did not meet inclusion criteria for our report because they evaluated multicomponent screening interventions and did not evaluate the vision screening component separately or screening was conducted by an eye specialist.

One previously identified trial did not meet inclusion criteria because screening was performed by an optometrist and utilized methods not commonly performed in primary care (involved visual acuity, contrast sensitivity, and visual field testing; slit lamp examination; and direct ophthalmoscopy), but may provide additional information about potential harms of screening.^136,137^ It evaluated frail elderly persons (mean age 81 years) at high risk of falls (45% with fall in the last year). Like the screening trials eligible for this review, it found screening was not associated with improved visual acuity or vision-related function. However, screening was associated with increased risk of falls.^136,137^ For falls incidence, the incidence rate ratio was 1.57 (95% CI 1.20 to 2.05). For risk of one or more falls (65% vs. 50%), RR was 1.31 (95% CI 1.13 to 1.50) and for two or more falls (38% vs. 31%), RR was 1.24 (95% CI 0.99 to 1.54). Screening was also associated with an increased risk of fractures that was just above the threshold for statistical significance (10% vs. 5.7%, RR 1.74 [95% CI 0.97 to 3.11]; p=0.06). The reason for increased falls risk was unclear, but could be related to difficulty adapting to large corrections in visual acuity or use of multifocal lenses.

Conclusions regarding the suboptimal diagnostic accuracy of vision screening tests for identifying conditions associated with impaired visual acuity in primary care settings were also unchanged from the prior review for the USPSTF. The prior review for the USPSTF found that no screening question is comparable in accuracy to tests of visual acuity for identifying impaired visual acuity^105,110,125,126,138^ and that visual acuity testing with a chart is inaccurate compared with a detailed eye examination for identifying visual conditions identified on a comprehensive ophthalmological examination. Other previously reviewed studies found that the accuracy of a computer-based screening tool was limited, and that the MDS Vision Patterns section questions performed poorly as a screening test.^84,102^ One new study found visual acuity screening using a mobile application was accurate compared with a standard ETDRS chart.^121^ Studies comparing visual acuity testing to a comprehensive ophthalmological examination are difficult to interpret, as the conditions identified on examination were not necessarily associated with impaired visual acuity. For example, it is not known whether identification of cataracts or AMD prior to the development of impaired visual acuity is associated with improved clinical outcomes compared with identification after the development of early impaired visual acuity. Although visual acuity testing with a Snellen or ETDRS chart remains the most widely used tool to measure visual acuity in primary care settings, no clinically relevant reference standard exists to determine their diagnostic accuracy, in part because such tests are often considered the standard for assessing visual acuity in clinical practice. There remains insufficient evidence to assess the accuracy or utility of pinhole testing, the Amsler grid, visual acuity tests other than the Snellen or ETDRS, physical examination, or funduscopic examination performed in primary care settings.

Conclusions from the prior review for the USPSTF of strong evidence showing the effectiveness of treatments compared with no treatment for common causes of impaired visual acuity also remain unchanged. The USPSTF previously determined that a very high proportion of patients experience favorable vision-related outcomes following treatment for impaired visual acuity due to refractive error and cataracts; therefore, this evidence was not re-reviewed for this update.^66^ As noted in the prior review for the USPSTF, more than half of all older adults with impaired visual acuity achieve vision better than 20/40 with refractive correction,^6^ which can be done noninvasively in most cases with corrective lenses. In patients with cataracts, a large body of observational studies indicates that surgical extraction and intraocular lens implantation results in visual acuity of 20/40 or better in more than 90 percent of patients, and is associated with improvements in vision-related quality of life.^139^ Correction of refractive error and cataract removal are also associated with improvement in vision-related quality of life, although RCTs and cohort studies have not shown clear effects on measures of function, cognition, or depression.^140–144^

With regard to treatments for conditions associated with impaired visual acuity, this review focused on treatments for dry and wet AMD. For dry AMD, evidence showing the effectiveness of antioxidant vitamins and minerals for slowing progression of disease or improving visual acuity remains largely restricted to the large AREDS trials.^56,123^ As reported in the prior review for the USPSTF, extended (10-year) followup from AREDS indicates continued benefits beyond the originally reported (6.3-year) data.^113^ The AREDS trial found zinc use associated with increased risk for hospitalizations due to genitourinary causes compared with non-use^101^ and the AREDS 2 trial found the AREDS formulation with beta carotene associated with increased risk of lung cancer compared with the AREDS formulation without beta carotene in former smokers.^113^ Based on AREDS 2 and other evidence^145^ indicating an association between use of beta-carotene and increased risk of lung cancer in smokers, recommendations^146^ for current and former smokers are to avoid the AREDS formula with beta-carotene, using lutein and zeaxanthin in its place. For wet AMD, this update focused on VEGF inhibitors, which are first line treatment in most patients. As in the prior review for the USPSTF, intravitreal injection with VEGF inhibitors was associated with improvement in visual acuity-related outcomes with a relatively low incidence of serious harms, though data on effects of VEGF inhibitors on vision-related quality of life or function are limited and inconclusive. One area of concern with VEGF inhibitors has been a potential association with increased risk of cardiovascular events.^147^ Although RCTs of VEGF inhibitors for AMD did not report increased risk of cardiovascular events, they were not designed to evaluate these outcomes and the number of events were small. However, several recent observational studies found no association between use of VEGF inhibitors and increased risk of cardiovascular events.^147–149^ An important advantage of VEGF inhibitors compared with earlier treatments such as laser photocoagulation is that they are associated with less retinal scarring compared with laser photocoagulation, which is a particularly important consideration for patients with subfoveal (central) neovascularization, and decreased recurrence compared with photodynamic therapy with verteprofin. Although we did not identify new sham-controlled trials of VEGF inhibitors, head-to-head trials^106,108^ of recently approved FDA-approved VEGF inhibitor compared with older VEGF inhibitors indicated similar effects on visual acuity-related outcomes.

## Limitations

Our evidence review had some limitations. First, we utilized a previously published systematic review^72^ on antioxidant multivitamins and minerals for dry AMD. The reliability of systematic reviews depends on how well they are designed and conducted. Therefore, we ensured that the systematic review met a quality threshold based on predefined criteria;^150^ we also verified data abstraction of the systematic review by independently abstracting and rating the quality of trials comparing an intervention to placebo, sham treatment, or no treatment. Second, evidence on effectiveness of treatment for dry AMD relied heavily on results of a single trial—the large, well-conducted AREDS trial.^123^ Third, we excluded non-English–language studies, which could introduce language bias. However, we identified no relevant non-English–language studies in literature searches or when searching reference lists. Fourth, there were too few RCTs to perform formal assessments for publication bias with graphical or statistical methods for small sample effects. However, we did not identify unpublished trials likely to impact findings. Fifth, there was statistical heterogeneity in some pooled analyses of VEGF inhibitors compared with sham. However, inconsistency was in the magnitude of benefit, not direction of effect, which favored VEGF inhibitors across studies. Because of anticipated heterogeneity, we utilized a random effects model for pooling. Sixth, trials of screening compared with no screening had methodological limitations, including high attrition and use of a suboptimal screening test. In some trials, low uptake of recommended interventions or a high rate of eye specialist care prior to screening could have attenuated potential benefits. In addition, the screening trials were published between 1997 and 2006, and may not reflect outcomes that would be obtained in current clinical practice.

## Emerging Issues/Next Steps

Conbercept is a VEGF inhibitor developed in China that has been evaluated in a number of RCTs, but excluded from this review because it is not approved by the FDA.^151^ New therapies have been investigated for their effectiveness in the treatment of AMD. The small (n=114) Age-related Maculopathy Statin Study trial of simvastatin 40 mg daily compared with placebo found that simvastatin was associated with lower risk of AMD progression after 3 years of followup, although the difference was not statistically significant (54.4% vs. 70.2%; RR, 0.78 [95% CI 0.58 to 1.04]).^152^ Findings from other studies have also been inconclusive.^153^ Complement inhibitors (e.g., protease inhibitors) are also being investigated for their potential effects on AMD, though initial studies have failed to improve outcomes.^154,155^ In May 2021, several ongoing trials of brolucizumab were discontinued due to higher rates of intraocular inflammation, including retinal vasculitis and retinal vascular occlusion; one of the trials was a head-to-head trial of brolucizumab-dbll compared with aflibercept (both newer VEGF inhibitors) for AMD. The rate of retinal vasculitis, retinal artery occlusion, or severe vision loss was around 10 out of 10,000 injections. Implications for the role of brolucizumab-dbll in treatment for AMD are uncertain.^38^

## Relevance for Priority Populations

The focus of this review was on screening in older adults, a priority population at particular risk for impaired visual acuity as well as sequelae from impaired visual acuity. Although Black males are at higher risk of unoperated cataracts, there is no evidence to suggest that cataract surgery is less successful in this patient group. Low socioeconomic status is associated with poorer access to vision services.

## Future Research

Important gaps remain in the evidence on screening for impaired visual acuity in older adults. Direct evidence indicates that vision screening in older adults is not effective for improving visual outcomes or other clinical outcomes. However, in some screening trials, including the largest study, only half of patients received recommended interventions, which could have attenuated benefits.^86^ In addition, vision screening was evaluated as part of a multicomponent intervention. Well-designed studies in contemporary primary care settings that evaluate more focused vision screening interventions, utilize strategies to link screen-positive older adults to appropriate followup and care, address barriers to linkage to care, and target higher-risk populations would be useful for clarifying potential benefits of screening. Screening strategies targeted at identification of AMD may be particularly suitable for future studies, given the potential for irreversible effects with delayed diagnosis. Studies are needed on diagnostic accuracy and utility of funduscopic examination, pinhole testing, the Amsler grid, and nonSnellen visual acuity charts in primary care settings for supplementing or replacing standard visual acuity eye chart. Research would also be helpful for determining the feasibility and accuracy of alternative screening modalities to supplement standard visual acuity testing in primary care settings, such as tests for dark adaptation, visual contrast, or useful field of view. Telehealth approaches to screening that could potentially facilitate access are especially relevant in the post-COVID-19 era^156^ and warrant research consideration. Evidence on the effectiveness of antioxidant vitamins and minerals for the treatment of dry AMD remains largely dependent on the large AREDS trial^123^ and could be strengthened by other large, well-designed trials of alternative regimens designed to adequately evaluate benefits and harms. Research is also needed to understand the effects of treatment for wet and dry AMD on quality of life and function. More studies are needed to understand the potential association between correction of refractive errors and risk of falls,^137^ and, if an association is present, to identify methods for mitigating these risks (e.g., avoid large corrections in visual acuity, education or training with multifocal lens). Head-to-head trials of the recently FDA-approved VEGF brolucizumab-dbll compared with older VEGF inhibitors would be helpful for clarifying benefits and harms, particularly with regard to risk of adverse events related to intraocular inflammation.

## Conclusions

Impaired visual acuity is common in older adults and effective treatments are available for common causes of impaired visual acuity. Visual acuity testing is the reference standard for identifying impaired visual acuity but has low diagnostic accuracy compared with an ophthalmological exam for identifying visual conditions not necessarily associated with impaired visual acuity; screening questions have low diagnostic accuracy compared with visual acuity testing. Direct evidence found no significant difference between vision screening in older adults in primary care settings and no screening in visual acuity-related outcomes or other clinical outcomes.