# Chapter 3 Results

A total of 5,170 new references from electronic database searches and manual searches of recently-published studies were reviewed and 339 full-text papers were evaluated for inclusion. Twenty-five studies (33,586 total participants) were included in this review (13 trials, 11 diagnostic accuracy studies, and one systematic review [of 19 trials] in 51 publications.^74–124^ Sixteen studies were carried forward from the 2016 review for the USPSTF, eight studies were new, and the systematic review^73^ utilized in the 2016 review for the USPSTF was updated^72^ to include six new trials. Included studies and quality ratings are described below and in Appendix B.

## Key Question 1 What Are the Effects of Vision Screening in Asymptomatic Older Adults vs. No Screening on Visual Acuity, Morbidity or Mortality, General or Vision-Related Quality of Life, Functional Status, or Cognition?

### Summary

- Four randomized controlled trials (RCTs) (N=4,819) found no difference between vision screening in primary care-applicable settings and no screening, usual care, or delayed screening on vision and other clinical outcomes in older adults; 1 small trial (n=188) was not included in the 2016 USPSTF review.

### Evidence

The prior USPSTF review^1,2^ included three fair-quality cluster-randomized trials in four publications^86,97,110,111^ (sample sizes 261 to 3,249, N=4,631) of vision screening in older adults in primary care-applicable settings. None of the trials found beneficial effects of screening on visual acuity, likelihood of vision disorders, or functional impairment related to vision with vision screening. For this update, all three trials were carried forward, and one additional RCT (n=188) in two publications was added^81,82^ (Table 3, Appendix B Table 1).

Table 3 Screening Trials

Author, Year | Intervention | Screening Tools | Results
Eekhof, 2000^110,111^; From prior report | A. Vision screening (n=576); B. Delayed screening (n=545) | Validated diagnostic tests:; Assessment of difficulty in recognizing a face at 4 meters and/or reading normal letters in a newspaper, and/or impaired vision with both by Snellen eye chart or not being able to read normal newspaper letters at 25 centimeter distance; Vision was measured with the glasses usually worn | A vs. B; Vision disorder detected: 49% (95% CI 43% to 54%) vs. NR; Visual disorder in 2nd year: 51% (95% CI 45% to 58%) vs. 47% (95% CI 42% to 52%); p=0.68
Moore, 1997^97^; From prior report | A. Vision screening, coupled with clinical summaries (n=112); B. Usual care (n=149) | Question, “Do you have difficulty driving or watching television or reading or doing any of your daily activities because of your eyesight (even while wearing glasses)?”, followed by Snellen eye chart if positive | A vs. B; Vision problem detected: 20% vs. 19%, p=0.84; Improvement in vision at 6 months: 20% (20/99) vs. 24% (31/131); RR 0.85 (95% CI 0.52 to 1.40)
Smeeth, 2003^86^; MRC Trial; From prior report | A. Universal screening = brief health assessment plus detailed health assessment, latter of which included measurement of VA (n=1,565); B. Targeted screening = brief health assessment (n=1,684, 120 of which had a detailed assessment due to severity of problems, though 150 were eligible) | Detailed health assessment: VA measured using Glasgow acuity eye chart (Snellen equivalent provided in results), and pinhole testing if VA less than 6/18 in either eye; referral to ophthalmologist when appropriate; Brief health assessment: Covered all areas specified in the general practitioner contract, including a question about difficulty seeing, but did not include measurement of VA. Those with a specified range and level of problems were eligible to have a detailed assessment; Note: reporting difficulty seeing was not on its own sufficient to lead to a detailed assessment | A vs. B; Found to have VA <6/18 (20/60) in either eye: 29% (451/1565) vs. 3.1% (53/1684); Eligible for referral to ophthalmologist: 14% 220/1565) vs. 1.7% (29/1684); Eligible for referral to optician: 5% (79/1565) vs. 0.4% (8/1684); At followup:; VA <6/18 (20/60) in either eye at 3 years: 37% (307/829) vs. 35% (339/978), RR 1.07 (95% CI 0.84 to 1.36); VA <6/18 binocular vision: 14% (114/817) vs. 17% (160/962), RR 0.84 (95% CI 0.64 to 1.10); VA <6/12 in either eye: 59% (486/829) vs. 60% (584/978), RR 0.98 (95% CI 0.82 to 1.17); VA <6/12 binocular vision: 31% (256/817) vs. 37% (351/962), RR 0.86 (95% CI 0.65 to 1.13); NEI-VFQ mean composite score (scale 0 to 100; higher score = better quality of life): 86.0 vs. 85.6; mean difference 0.4 (95% CI −1.7 to 2.5)
Tay, 2006^81^; ACCS; Added | Routine aged care assessment and interview using a standardized questionnaire, plus:; A. Vision screening (n=96); B. No vision screening (n=92) | LogMAR chart for presenting VA for distance (with glasses, if worn) using letters read correctly using ETDRS-Fast protocol; Binocular near vision and visual field using confrontation method; Self-report questions: Did you notice any deterioration in one or both eyes? Are you able to recognize a friend across the street? Can you read the ordinary print in the newspaper reasonably well, with or without glasses? | A vs. B; Mean VA: 39 letters vs. 35 letters, p=0.25; Bilateral visual impairment: 35% vs. 47%, p=0.17

Abbreviations: ACCS = Aged Care Client pilot Study; CI = confidence interval; ETDRS = Early Treatment Diabetic Retinopathy Study; LogMAR = logarithmic minimum angle of resolution; MRC = Medical Research Counsel; NEI-VFQ = National Eye Institute Visual Function Questionnaire; NR = not reported; RR = relative risk; VA = visual acuity.

The trials from the prior report compared universal with targeted vision screening,^86^ immediate with delayed vision screening,^111^ and vision screening with usual care;^97^ the additional trial compared vision screening with no screening.^81^ In all trials, vision screening was part of a larger, multicomponent health screen for older adults including other assessments (e.g., hearing, mobility, cognition); however, effects of vision screening compared with no screening were evaluated separately. Screening methods varied: a brief screening questionnaire plus the Glasgow visual acuity chart followed by pinhole testing for persons with visual acuity worse than 6/18 (20/60),^86^ assessment of difficulty in recognizing a face and/or reading normal letters in a newspaper, along with Snellen visual acuity eye chart,^110,111^ a screening question and clinical summary followed by the Snellen eye chart,^97^ and an ETDRS visual acuity chart, measurement of binocular near vision and visual field testing, along with screening questions.^81^ The previously included trials were conducted in community or general practice settings and screening was conducted by general practitioners, office staff, or trained nurses. The additional trial^81^ was conducted in a geriatric day hospital, though screening could have been done via home visit if needed. Screening was conducted by study investigators (geriatric medicine or eye specialist) or an orthoptist, but the study was considered primary care-applicable because the screening methods consisted of visual acuity testing, binocular near vision, and visual field confrontation testing.

Across all four studies, one trial each was conducted in the U.S., the United Kingdom (U.K.), the Netherlands, and Australia; race and ethnicity were not reported. Mean ages ranged from 76 to 83 years and the proportion female ranged from 34 to 62 percent. The duration of followup ranged from 6 months to 5 years. All trials were rated fair quality (Appendix B Table 2). Methodological limitations included unclear allocation concealment and blinding methods, and high loss to followup.

None of the previously-included trials found any beneficial effects of screening on visual acuity, likelihood of vision disorders, or vision-related functional impairment. In the largest (n=3,249) trial, universal vision screening identified about 10 times as many patients with impaired visual acuity and correctable impairment compared with targeted screening, but there was no difference in the likelihood of visual acuity worse than 20/60 at 3- to 5-year followup (relative risk [RR], 1.07 [95% confidence interval [CI], 0.84 to 1.36]).^86^ There were also no differences in vision-related quality of life (National Eye Institute – Visual Function Questionnaire [NEI-VFQ] mean difference 0.4 [95% CI −1.7 to 2.5] on a 0 to 100 scale). Another trial (n=1,121) found no differences between immediate and delayed vision screening in likelihood of visual disorders in the second year of followup (51% [95% CI 45% to 58%] vs. 47% [95% CI 42% to 52%]; p=0.68).^110,111^ The third trial found no difference between screening and usual care in likelihood of improvement in vision at 6 months (20% [20/99] vs. 24% [31/131], RR 0.85 [95% CI 0.52 to 1.40]).^97^ The fourth, small trial (n=188), which was not in the prior USPSTF review, found no statistically significant differences between screening and no screening in mean visual acuity (39 letters vs. 35 letters, p=0.25) or bilateral visual impairment (35% vs. 47%, p=0.17) at 1 year.^81^

In the largest trial, only half of the patients advised to see an eye care provider after vision screening actually received new glasses, which could have attenuated potential benefits.^86^ Other reasons for lack of benefit in the screening trials may have included attrition (24% to nearly 60% in the larger trials at 2 to 5 years of followup),^86,110,111^ similar frequency of vision disorder detection and treatment in the screening and control groups in one trial,^97^ use of a screening question to identify persons for further testing in one trial,^97^ low uptake of recommended interventions in one trial,^111^ or high rates of antecedent eye professional care in screened and unscreened groups.^81^

## Key Question 2 What Are the Harms of Vision Screening in Asymptomatic Older Adults vs. No Screening?

### Summary

- No trial comparing screening with no screening, usual care, or delayed screening (including one fair quality trial added for this update) reported harms.

### Evidence

None of the three fair-quality cluster-randomized trials included in the prior USPSTF review comparing vision screening in primary care-applicable settings with no screening, usual care, or delayed screening reported harms.^86,97,111^ One additional fair-quality trial added for this update (described above) also did not report harms.^81^

## Key Question 3 What Is the Diagnostic Accuracy of Screening for Impaired Visual Acuity Due to Uncorrected Refractive Error, Cataracts, or AMD?

### Summary

- Three studies (N=6,493) in the prior USPSTF review found no visual acuity test associated with both high sensitivity and specificity for identifying visual conditions compared with a complete examination by an ophthalmologist. Based on a visual acuity threshold of <20/30 or <20/40, sensitivity ranged from 0.27 to 0.75 and specificity from 0.51 to 0.87, with positive likelihood ratios of 1.54 to 5.69 and negative likelihood ratios of 0.30 to 0.84.
- Two studies (N=380) in the prior USPSTF review on development and refinement of a computerized vision screening tool with four tests of vision function found optimal accuracy with high contrast visual acuity (threshold <20/30), which was associated with sensitivity of 0.77 (95% CI 0.69 to 0.84) and specificity of 0.73 (95% CI 0.62 to 0.82) for identification of significant acuity-impairing eye conditions.
- One study (n=371) in the prior USPSTF review found a cutoff score of the Minimum Data Set Vision Patterns section (score ≥1 on a 0 to 4 scale) associated with sensitivity of 0.52 (95% CI 0.45 to 0.59) and 0.75 (95% CI 0.68 to 0.82) for detecting visual acuity ≤20/40, for a positive likelihood ratio of 2.11 (95% CI 1.56 to 2.86) and negative likelihood ratio of 0.64 (95% CI 0.54 to 0.75).
- One study (n=50) in the prior USPSTF review found that 100 percent of cataract patients and 80 percent of AMD patients were correctly identified by a geriatrician compared with an ophthalmologist, with no false positives.
- One new, fair-quality study (n=104) found visual acuity mobile application screening associated with sensitivity of 0.98 (95% CI 0.91 to 1.00) and specificity 0.94 (95% CI 0.82 to 0.99) for identifying visual acuity ≤20/40 compared with the standard ETDRS chart, for a positive likelihood ratio of 15.07 (95% CI 5.04 to 45.03) and negative likelihood ratio of 0.02 (95% CI 0.00 to 0.13).

### Evidence

We included eight studies on the accuracy of screening tests for impaired visual acuity due to visual conditions such as cataracts, refractive error, and AMD in older adults (Appendix B Tables 3 and 4). Of these, the prior USPSTF review^2^ included seven studies (reported in six publications)^74,76,84,98,102,122^ and one study^121^ was new for this review. One additional study from the prior USPSTF report was excluded due to poor quality (only 56 percent of those screened received the reference standard).^125^

In the studies carried forward from the prior USPSTF review, screening was conducted using an eye chart (Snellen or logMAR, 3 studies),^74,76,122^ a computerized tool based on four tests of vision function (2 studies),^102^ score on the Minimum Data Set (MDS) Vision Patterns section (1 study),^84^ geriatrician examination (1 study),^98^ and the Amsler grid (1 study).^122^ The reference standard was a complete examination by an ophthalmologist in all studies, except for the study that evaluated the MDS Vision Patterns section.^84^ In that study, the reference standard was visual acuity evaluation using a chart. Two studies,^74,76^ one of which was part of the Blue Mountains Eye Study,^74^ included 3,654 and 2,522 participants. In the other studies, sample sizes ranged from 50 to 371 (total N=7,294). Studies were conducted in the U.S., Australia, and the U.K. Settings included primary care clinics, general eye clinics, hospitals, community day centers, and nursing homes. Screening was performed by primary care physicians, general practitioners, geriatricians, or trained research staff; in two studies the screener was unclear.^74,122^ The mean age of participants ranged from 77 to 81 years or enrolled persons older than 49, 50, or 64 years of age, with the exception of one study in which 21 percent of the population was at least 60 years of age (mean age 44 years).^122^ The proportion female was 54 to 81 percent in studies that reported this information. Two studies reported race/ethnicity; in one study, the majority (77%) of participants were Latino,^122^ in the other the proportion White was 73 percent and the proportion Black 26 percent.^84^ Refractive error was present in 5 to 58 percent of participants, cataracts in 17 to 70 percent, and AMD in 4 to 29 percent. Impaired visual acuity at baseline was reported in one study at 41 percent.^84^

One new study (n=104) conducted in the U.S. compared visual acuity screening using a mobile iPod application against the standard ETDRS chart^121^ (Appendix B Tables 3 and 4). Mean age was 67 years. The proportion female was 63 percent, the proportion White was 69 percent, and the proportion Black was 25 percent. The proportion of patients with visual acuity ≥20/40 was 44 percent.

All studies were rated as fair quality (Appendix B Table 5). Methodological shortcomings included unclear interpretation of the reference standard independently from the screening test, unclear methods for selecting patients for inclusion, and failure to apply the reference standard to all patients. Four studies did not pre-specify thresholds used to define an abnormal screening test,^74,102,121,122^ including two studies^102,121^ that reported on the development of a screening tool.

Three studies (N=6,493) compared diagnostic accuracy of visual acuity testing with a chart with a complete examination by an ophthalmologist (Appendix B Tables 3 and 4).^74,76,122^ One large study (n=2,522) found presenting distance visual acuity ≤20/30 associated with sensitivity of 0.74 (95% CI 0.72 to 0.76) and specificity of 0.87 (95% CI 0.84 to 0.89) for any ocular disease excluding refractive error, for a positive likelihood ratio of 5.69 and negative likelihood ratio of 0.30.^76^ Sensitivity was similar (0.77, 95% CI 0.75 to 0.79) but specificity lower (0.68, 95% CI 0.65 to 0.71) when screening was based on near visual acuity at the same visual acuity threshold. However, another large study (n=3,654) found distance visual acuity ≤20/30 associated with lower sensitivity of 0.47 (95% CI 0.44 to 0.50) for any eye disease, with specificity of 0.74 (95% CI 0.72 to 0.76), for a positive likelihood ratio of 1.81 (95% CI 1.65 to 1.98) and negative likelihood ratio of 0.72 (95% CI 0.68 to 0.76).^74^ Accuracy was similar for identification of persons with specific conditions (cataracts or early AMD). Use of alternate screening thresholds (≤20/40 or ≤20/60) or screening based on near distance, pinhole, or reading acuity also was not associated with both high sensitivity and specificity (Appendix B Tables 3 and 4). A third, smaller study (n=317) also reported suboptimal sensitivity of visual acuity screening.^122^ It found distance visual acuity ≤20/30 associated with sensitivity of 0.75 (95% CI 0.69 to 0.81) and specificity of 0.51 (95% CI 0.42 to 0.61) for any ocular disease excluding refractive error, for a positive likelihood ratio of 1.54 (95% CI 1.26 to 1.90) and negative likelihood ratio of 0.48 (95% CI 0.36 to 0.65). Higher screening thresholds (≤20/40 or ≤20/60) were associated with lower sensitivity but higher specificity; results were similar for screening based on near distance visual acuity. In the latter two studies, discrimination based on the area under the receiver operating characteristic curve (AUC) for various measures of visual acuity ranged from 0.72 and 0.83;^74,122^ the AUC was not reported in the other study.^76^ A challenge in interpreting data on diagnostic accuracy of screening is the uncertain clinical significance of visual conditions identified on full ophthalmological examination but not associated with reduced visual acuity.

Two studies (reported in one publication) evaluated a computerized vision screening tool (Computer Vision Screener).^102^ The studies (n=180 and n=200) were conducted in the U.K. in participants 65 years or older (mean age, 77 years). Of these, about 30 percent had cataracts, 30 to 39 percent had significant refractive error, and 22 to 29 percent had significant macular degeneration; 51 to 58 percent were classified as having correctable visual loss. The reference standard was a “gold standard eye exam” that included detailed history and symptoms, slit lamp and dilated funduscopic examination, tests of visual acuity, visual field, orthoptic tests, and others. The original version of the screening tool included questions on history and symptoms as well as six tests of vision function (near visual acuity, visual field, fixation disparity, stereoacuity, high contrast distance visual acuity, and low contrast distance visual acuity). The first study reported initial development and testing of the computerized vision screening tool, to inform further refinement. For high-contrast or low-contrast visual acuity, sensitivity for identifying persons with significant acuity-impairing eye conditions (correctable visual loss from cataracts or refractive error or AMD at risk of progression) ranged from 0.67 to 0.86 and specificity ranged from 0.50 to 0.60. Due to poor performance, two items (fixation disparity and stereoacuity) were dropped from the tool. In the second study, which evaluated the modified computerized vision screening tool with four items, optimal accuracy for identifying persons with significant acuity-impairing eye conditions was observed with high-contrast visual acuity (threshold >0.19 logMAR [20/30]), which had a sensitivity of 0.77, 95% CI 0.69 to 0.84), specificity of 0.73 (95% CI 0.62 to 0.82), positive likelihood ratio of 2.85, and negative likelihood ratio of 0.32. Results were similar for the combination of abnormal high-contrast visual acuity (threshold >0.19 logMAR [20/30]) or near visual acuity (threshold unclear). With this combination, sensitivity was 0.80 (95% CI 0.72 to 0.86) and specificity 0.68 (95% CI 0.57 to 0.77).

Another study (n=371) compared the scores on the MDS Patterns section against a standard visual acuity (ETDRS chart) test for detecting impaired visual acuity.^84^ Participants age 55 years or older (mean age, 81 years) were recruited from nursing homes and assessed by trained research staff (not further described). The prevalence of impaired visual acuity was about 40 percent. The MDS Visual Patterns section is scored from 0 to 4, with 0 indicating adequate vision and 4 severely impaired vision. Diagnostic accuracy was poor using any cutoff score on the MDS Visual Patterns. Using a cutoff score of 1 or greater (0 indicating adequate vision and scores of 1 to 3 indicating various degrees of impairment), sensitivity of the MDS Visual Patterns section for detecting distance visual acuity worse than 20/40 was 0.52 (95% CI 0.45 to 0.59) and specificity was 0.75 (95% CI 0.68 to 0.82), resulting in a positive likelihood ratio of 2.11 (95% CI 1.56 to 2.86) and a negative likelihood ratio of 0.64 (95% CI 0.54 to 0.75).

One study (n=104) developed and tested visual acuity screening with a mobile (iPod) ETDRS application against the standard (chart) ETDRS.^121^ The mobile application utilized randomized ETDRS letters at the Snellen equivalent of 20/40 and 20/200 visual acuity. Patients were selected from tertiary referral glaucoma and retina practices in the U.S. Mean age was 67 years and 63 percent were female. For visual acuity ≤20/40, incorrect identification of four visual acuity <20/40 images was associated with sensitivity of 0.98 (95% CI 0.91 to 1.00) and specificity of 0.94 (95% CI 0.82 to 0.99), for a positive likelihood ratio of 15.07 (95% CI 5.04 to 45.03) and negative likelihood ratio of 0.02 (95% CI 0.00 to 0.13). For visual acuity <20/200, incorrect identification of four <20/200 images was associated with sensitivity of 0.92 (95% CI 0.64 to 1.00), specificity of 0.92 (95% CI 0.85 to 0.97), positive likelihood ratio of 12.00 (95% CI 5.79 to 24.87), and negative likelihood ratio 0.08 (95% CI 0.01 to 0.55).

One study (n=317) found the Amsler grid associated with poor accuracy for identifying any ocular disease excluding refractive error, with sensitivity of 0.20 (95% CI 0.14 to 0.27), specificity of 0.88 (95% CI 0.80 to 0.94), positive likelihood ratio of 1.65 (95% CI 0.90 to 3.06), and negative likelihood ratio of 0.91 (95% CI 0.82 to 1.01) (Appendix B Tables 3 and 4).^122^ Another study in the prior USPSTF review (n=50) compared the accuracy of an examination by a geriatrician with an ophthalmologist for identifying persons with previously undiagnosed cataracts or AMD (Appendix B Tables 3 and 4).^98^ All patients were 64 years of age or older. The proportion of patients with cataracts was 18 percent and the proportion with previously undiagnosed AMD was 8 percent. The study found that 100 percent (sensitivity 1.0, 95% CI 0.69 to 1.0) of cataract patients and 80 percent (sensitivity 0.80, 95% CI 0.28 to 0.99) of AMD patients were correctly identified by a geriatrician, with no false-positives.

## Key Question 4 What Is the Accuracy of Instruments for Identifying Patients at Higher Risk of Impaired Visual Acuity Due to Uncorrected Refractive Error, Cataracts, or AMD?

### Summary

- Two studies (n=1,121 and 3,997) included in the prior USPSTF review and one new study (n=85) found that screening questions were not accurate (associated with both high sensitivity and specificity) for identifying older persons with impaired visual acuity compared with the Snellen or low vision eye chart. Sensitivities ranged from 0.17 to 0.81 and specificities from 0.19 to 0.84, resulting in positive likelihood ratios of 0.26 to 2.69 and negative likelihood ratios of 0.41 to 3.23

### Evidence

We included three studies on the diagnostic accuracy of screening questions for identifying older adults with decreased visual acuity (Appendix B Tables 6 and 7). Of these, two studies^105,110,111^ were included in the 2016 USPSTF review and one study^96^ was new for this review. Two other studies in the prior USPSTF report were excluded due to poor quality (insufficient reporting of methods and results or high proportion of patients did not undergo the reference standard).^125,126^

The sample sizes of the studies carried forward from the prior USPSTF report were 1,121 and 3,997. The mean age was 81 years in one study;^110,111^ in the other study^105^ 37 percent of patients were 65 to 74 years of age and the remainder were <65 years old. One study^105^ conducted in the U.S. reported that 61 percent of participants were female and 79 percent were White. In the other study, conducted in the Netherlands, sex and race/ethnicity were not reported.^110,111^ The studies evaluated single screening questions against the reference standard Snellen chart (Appendix B Table 6). Screening was performed by general practitioners in one study^110,111^ and by study personnel in mobile examination units in the other.^105^ Both studies were rated fair quality (Appendix B Table 8). Methodological limitations included unclear interpretation of the reference standard from the screening test, and vice versa. One study did not include all patients in the analysis.

Both studies reported poor accuracy of screening questions for identifying persons with decreased visual acuity (Appendix B Table 7). One study found a question on trouble recognizing faces associated with sensitivity of 0.40 (95% CI 0.31 to 0.49) and specificity of 0.19 (95% CI 0.16 to 0.21) for visual acuity ≤0.3 (~20/60) on the Snellen.^110,111^ The prevalence of Snellen visual acuity <0.3 was 11 percent. A question on trouble reading the newspaper was associated with a sensitivity of 0.17 (95% CI 0.12 to 0.25) and specificity of 0.33 (95% CI 0.30 to 0.36) for identifying persons with difficulty with low vision chart at reading distance, for a positive likelihood ratio of 0.26 (95% CI 0.18 to 0.37) and negative likelihood ratio of 2.47 (95% CI 2.20 to 2.78). In the other study, a question on trouble seeing was associated with sensitivity of 0.34 (95% CI 0.28 to 0.41) and specificity of 0.84 (95% CI 0.82 to 0.86) for identifying persons with visual acuity ≤20/50 on the Snellen,^105^ for a positive likelihood ratio of 2.15 (95% CI 1.72 to 2.69) and negative likelihood ratio of 0.78 (95% CI 0.71 to 0.86). Approximately two-thirds of patients had visual acuity ≤20/25. Results were similar for identifying persons with visual acuity ≤20/100.

A new, fair-quality study (Appendix B Tables 6-8) was smaller (n=85). It assessed a screening question in patients 69 years of age or older in Switzerland.^96^ About half of patients were female. The study found a question by family physicians or internists on trouble reading the newspaper associated with sensitivity of 0.81 (95% CI 0.69 to 0.90) and specificity of 0.46 (95% CI 0.26 to 0.67) for identification of persons with any visual impairment (not defined) based on a comprehensive geriatric assessment that included visual acuity (Snellen) and visual field testing. The positive likelihood ratio was 1.5 (95% CI 1.0 to 2.2) and negative likelihood ratio was 0.4 (95% CI 0.2 to 0.8).

## Key Question 5 What Are the Effects of Treatment for Wet or Dry AMD vs. Placebo or No Treatment on Visual Acuity, Morbidity, Mortality, General or Vision-Related Quality of Life, Functional Status, or Cognition?

### Summary

#### VEGF Inhibitors for Wet AMD

- No new trials compared intravitreal injection with VEGF inhibitors with sham injection.
- In four RCTs (N=2,086) included in the prior USPSTF review, intravitreal injection with VEGF inhibitors was associated with greater likelihood of ≥15 letters of visual acuity gain (RR, 2.92, 95% CI 1.20 to 7.12, I^2^=76%; absolute risk difference [ARD] 10%), <15 letters of visual acuity loss (RR, 1.46, 95% CI 1.22 to 1.75, I^2^=80%; ARD 27%), and having vision 20/200 or better (RR, 1.47, 95% CI 1.30 to 1.66, I^2^=42%; ARD 24%) at 1 year compared with sham injection.
- Based on one trial included in the prior USPSTF review, VEGF inhibitors were associated with better vision-related function and quality of life measures compared with sham injection at 1 and 2 years; the difference (~8 points on a 0 to 100 scale) was above the threshold for a clinically important difference (4 to 6 points).

#### Antioxidant Vitamins and Minerals for Dry AMD

- The large (n=3,640), good-quality Age-Related Eye Disease Study (AREDS), which was included in prior USPSTF reviews, remains the most important trial for informing treatment for dry AMD. At 6.3 years, the combination of antioxidants plus zinc was associated with decreased risk of progression to advanced AMD compared with placebo (odds ratio [OR], 0.72, 99% CI 0.52 to 0.98).^123^ In persons with more advanced (category 3 or 4) AMD, antioxidants plus zinc were associated with decreased risk of visual acuity loss ≥15 lines on the ETDRS (OR, 0.73, 99% CI 0.54 to 0.99). Ten-year followup results were consistent with the 6.3 year results.
- An updated (2017) Cochrane systematic review included 19 trials (13 trials in the 2012 Cochrane review used in the prior USPSTF review) of antioxidant multivitamins, zinc, lutein and zeaxanthin, or vitamin E for dry AMD; results were heavily influenced by AREDS.
  ○ Antioxidant multivitamins were associated with decreased risk of progression to late AMD (3 trials, N=2,445 people, OR 0.72, 95% CI 0.58 to 0.90; 73% of patients from AREDS) and ≥3 lines visual acuity loss (1 trial [AREDS], N=1,791 people, OR 0.77, 95% CI 0.62 to 0.96) compared with placebo.
  ○ Zinc was associated with decreased risk of progression to late AMD compared with placebo (3 trials, N=3,790 people, OR 0.83, 95% CI 0.70 to 0.98; 96% of patients from AREDS) and decreased risk of ≥3 visual acuity loss lines that was of borderline statistical significance (2 trials, 3,791 people, RR 0.87, 95% CI 0.75 to 1.00; 96% of patients from AREDS).
  ○ Lutein and zeaxanthin or vitamin E were associated with little or no effect on risk of AMD progression.
- Evidence on the effects of other vitamins and mineral treatments remains limited, with no clear effects on AMD progression or visual acuity.

### Evidence

#### VEGF Inhibitors for Wet AMD

No new trials of intravitreal injection with VEGF inhibitors compared with sham injection were identified. The prior USPSTF review included four RCTs (reported in five publications) of intravitreal injection with VEGF inhibitors compared with sham injection, all of which were carried forward.^87,90,107,116,117^ The trials were the Minimally Classic/Occult Trial of the Anti-VEGF Antibody Ranibizumab in the Treatment of Neovascular Age-Related Macular Degeneration (MARINA) trial,^87,116,117^ the two VEGF Inhibition Study in Ocular Neovascularization (VISION) trials (reported in one publication),^107^ and the Phase IIIB, multicenter, randomized double-masked sham Injection-controlled study of the Efficacy and safety of Ranibizumab (PIER) trial.^90^

Sample sizes ranged from 184 to 1,208 participants (N=2,086); 54 to 68 percent of participants were female (Appendix B Table 9). Mean age was 77 to 78 years in MARINA and PIER; in the VISION trials,^107^ 61 percent of the population was older than age 75 years. Studies were conducted in the U.S in two trials, and the other trials had various countries (U.S., Canada, Europe, Israel, Australia, and South America). Mean baseline visual acuity was about 20/80 in three studies; in the fourth study (PIER),^90^ 69 percent of the population had baseline visual acuity between 20/40 and 20/200. The MARINA^87^ and PIER^90^ trials evaluated ranibizumab 0.3 to 0.5 mg every 1 to 3 months and the VISION^107^ trials evaluated pegaptanib (0.3 to 3.0 mg) every 6 weeks. The proportion of patients with lesions classified as occult choroidal neovascularization ranged from 38 to 63 percent; the proportion classified as minimally classic ranged from 36 to 38 percent; and the proportion with predominantly classic ranged from 19 to 26 percent. The duration of followup ranged from 1 to 2 years. All trials were appropriately randomized, used a blinded design, and had low attrition, and were rated good quality (Appendix B Table 10).

#### AMD Progression and Changes in Visual Acuity

Pooling data from all four trials (N=2,086), VEGF inhibitor treatment was associated with greater likelihood of ≥15 ETDRS letters of visual acuity gain (RR, 2.92, 95% CI 1.20 to 7.12, I^2^=76%; ARD, 10%, 95% CI −7 to 27) (Figure 2) and <15 letters of visual acuity loss (RR, 1.46, 95% CI 1.22 to 1.75, I^2^=80%; ARD, 27%, 95% CI 12 to 42) (Figure 3) compared with sham injection at 1 year.^87,90,107^ Although statistical heterogeneity was high, estimates from all trials favored VEGF inhibitors and results were similar when they were stratified by VEGF inhibitor. For visual acuity gain ≥15 letters, estimates were similar for ranibizumab (2 trials, RR 2.86, 95% CI 0.64 to 12.73) and pegaptanib (2 VISION trials, RR 2.83, 95% CI 1.23 to 6.52). For visual acuity loss <15 letters, estimates were also similar for ranibizumab (RR 1.56, 95% CI 1.40 to 1.74) and pegaptanib (RR 1.24, 95% CI 1.11 to 1.39). Use of VEGF inhibitors was also associated with greater likelihood of vision 20/200 or better at 1 year compared with sham injection, with less statistical heterogeneity (RR 1.47, 95% CI 1.30 to 1.66, I^2^=42%; ARD, 24%, 95% CI 12 to 37) (Figure 4). Only the MARINA trial (n=716) reported effects of VEGF inhibitors compared with sham at longer (2-year) followup.^87^ It found ranibizumab associated with greater likelihood of ≥15 letters visual acuity gain (RR 7.86, 95% CI 4.08 to 15), <15 letters of visual acuity loss (RR 1.72, 95% CI 1.52 to 1.94), and having 20/200 vision or better (RR 1.63, 95% CI 1.44 to 1.86).^87^

Figure 2 ≥15 Letters of Visual Acuity Gain With Use of VEGF Inhibitors at 1-Year Followup

Abbreviations: CI = confidence interval; df = degrees of freedom; MARINA = minimally classic/occult trial of the anti-VEGF antibody ranibizumab in the treatment of neovascular age-related macular degeneration; M-H = Mantel-Haenszel; PIER = phase IIIB, multicenter, randomized double-masked sham injection-controlled study of the efficacy and safety of ranibizumab; RR = risk ratio; VEGF = vascular endothelial growth factor; VISION = VEGF inhibition study in ocular neovascularization.

Figure 2 is a forest plot examining ≥15 Letters of Visual Acuity Gain With Use of VEGF Inhibitors at 1-Year Followup. The risk ratio for the ranibizumab versus sham subgroup with 2 studies is 2.86 (95% CI 0.64 to 12.73) with an I-squared value of 87%. The risk ratio for the pegaptanib versus sham subgroup with 2 studies is 2.83 (95% CI 1.23 to 6.52); heterogeneity was not applicable. The overall risk ratio is 2.92 (95% CI 1.20 to 7.12) with an I-squared value of 76%.

Figure 3 <15 Letters of Visual Acuity Loss With Use of VEGF Inhibitors at 1-Year Followup

Abbreviations: CI = confidence interval; df = degrees of freedom; MARINA = minimally classic/occult trial of the anti-VEGF antibody ranibizumab in the treatment of neovascular age-related macular degeneration; M-H = Mantel-Haenszel; PIER = phase IIIB, multicenter, randomized double-masked sham injection-controlled study of the efficacy and safety of ranibizumab; RR = risk ratio; VEGF = vascular endothelial growth factor; VISION = VEGF inhibition study in ocular neovascularization.

Figure 3 is a forest plot examining <15 Letters of Visual Acuity Loss With Use of VEGF Inhibitors at 1-Year Followup. The risk ratio for the ranibizumab versus sham subgroup with 2 studies is 1.56 (95% CI 1.40 to 1.74) with an I-squared value of 9%. The risk ratio for the pegaptanib versus sham subgroup with 2 studies is 1.24 (95% CI 1.11 to 1.39); heterogeneity was not applicable. The overall risk ratio is 1.46 (95% CI 1.22 to 1.75) with an I-squared value of 80%.

Figure 4 Visual Acuity of 20/200 or Better With Use of VEGF Inhibitors at 1-Year Followup

Abbreviations: CI = confidence interval; df = degrees of freedom; MARINA = minimally classic/occult trial of the anti-VEGF antibody ranibizumab in the treatment of neovascular age-related macular degeneration; M-H = Mantel-Haenszel; PIER = phase IIIB, multicenter, randomized double-masked sham injection-controlled study of the efficacy and safety of ranibizumab; RR = risk ratio; VEGF = vascular endothelial growth factor; VISION = VEGF inhibition study in ocular neovascularization.

Figure 4 is a forest plot examining Visual Acuity of 20/200 or Better With Use of VEGF Inhibitors at 1-Year Followup. The risk ratio for the ranibizumab versus sham subgroup with 2 studies is 1.56 (95% CI 1.40 to 1.73) with an I-squared value of 0%. The risk ratio for the pegaptanib versus sham subgroup with 2 studies is 1.33 (95% CI 1.15 to 1.52); heterogeneity was not applicable. The overall risk ratio is 1.47 (95% CI 1.30 to 1.66) with an I-squared value of 42%.

In a posthoc analysis of the MARINA trial, beneficial effects of ranibizumab were observed in patients with intact or impaired baseline visual acuity. Among patients (n=473) with baseline visual acuity worse than 20/40 (n=473), ranibizumab was associated with greater likelihood of visual acuity improvement to 20/40 or better at 1 year compared with sham (27.9% vs. 10.6%, RR 2.64, 95% CI 1.41 to 4.92) or 2-year followup (31.9% vs. 7.7%, RR 4.13, 95% CI 2.03 to 8.42) (Appendix B Table 9).^117^ Ranibizumab was also associated with increased likelihood of maintaining good visual acuity at 2 years among patients (n=243) with baseline visual acuity better than 20/40 (77.2% vs. 56.4%, RR 1.37, 95% CI 1.14 to 1.64).

#### Vision-Related Function

As described in the prior USPSTF review, ranibizumab was associated with better vision-related function scores at both 1- and 2-year followup compared with sham, based on the MARINA trial.^116^ On the composite NEI-VFQ-25 (0 to 100 scale), mean improvement was +5.2 (95% CI 3.5 to 6.9) for ranibizumab 0.3 mg and +5.6 (95% CI 3.9 to 7.4) for ranibizumab 0.5 mg dose compared with −2.8 (95% CI −4.6 to −1.1) for sham (p<0.001 for sham vs. either dose). Findings were similar on NEI-VFQ-25 subscale scores for general vision, mental health, social functioning, and driving (Appendix B Table 9). The difference of about 8 points on the NEI-VFQ-25 was above published thresholds for minimum clinically important differences (4 to 6 points on a 0 to 100 scale).^127^

The MARINA trial found ranibizumab 0.3 and 0.5 mg associated with increased likelihood of driving at 24 months compared with sham among those who drove at baseline (81% vs. 78% vs. 67%, respectively; p<0.05 for either dose vs. sham); there was no difference in the proportion of drivers at 24 months among those who were not driving at baseline (9% for 0.5 mg dose vs. 7% for sham; p=0.65; Appendix B Table 9).^117^

#### Mortality

Trials of VEGF inhibitors were not designed to evaluate mortality and few deaths were reported, resulting in imprecise estimates. As described in the prior USPSTF review, the MARINA trial found no difference between ranibizumab and sham in all-cause (2% vs. 3%; RR 0.91, 95% CI 0.34 to 2.44) or vascular (1% vs. 2%; RR 0.74, 95% CI 0.21 to 2.60) mortality after 2 years (Appendix B Table 9).^87^ The VISION trials reported similar rates of mortality (2%) in treatment and sham groups;^107^ there were no deaths in the PIER trial.^90^

#### Antioxidant Vitamins and Minerals for Dry AMD

The prior USPSTF review^1,2^ included the large, good-quality, AREDS trial^123^ (n=3,640) with 10-year followup,^113^ a good-quality systematic review of 13 trials (N=6,150, including AREDS^73^), and two additional trials^95,99^ (N=180) not included in the systematic review on antioxidant multivitamins and minerals and other supplements for dry AMD compared with placebo. A different Cochrane systematic review^128^ and one other trial^129^ included in the prior USPSTF report were excluded from this update because they addressed ineligible interventions (ginkgo biloba and fish oil).

The AREDS trial remains the most important evidence on treatment for dry AMD (Appendix B Tables 11 and 12). AREDS was a large (n=3,640), good-quality trial conducted in the U.S. of patients with dry AMD and baseline best-corrected visual acuity of 20/32 or better. Patients were randomized to antioxidants (vitamin C 500 mg, vitamin E 400 IU, and beta carotene 15 mg), zinc (zinc oxide 80 mg and cupric oxide 2 mg), antioxidants plus zinc, or placebo. Baseline AMD severity was classified into four categories, ranging from category 1 (no existing AMD and <5 drusen [<63 µm] without pigment changes) to category 4 (advanced AMD in one eye with central geographic atrophy or neovascular AMD). The prespecified AMD analysis focused on patients in categories 2 to 4. Among this group, 29 percent were classified as category 2, 44 percent as category 3, and 26 percent as category 4. Nearly half of AREDS participants were age 70 years or older at baseline, 57 percent were women, and 97 percent were White. More than half were either current (8%) or former (49%) smokers. At 6.3 years, the combination of antioxidants plus zinc was associated with decreased risk of progression to advanced AMD (based on receipt of treatment or pre-defined photographic criteria) compared with placebo (OR 0.72, 99% CI 0.52 to 0.98).^123^ Estimates for risk of progression to advanced AMD also favored antioxidants alone (OR 0.80, 95% CI 0.59 to 1.09) and zinc alone (OR, 0.75, 99% CI 0.55 to 1.03) compared with placebo, but differences were not statistically significant. Effects on risk of visual acuity loss ≥15 lines on the ETDRS favored antioxidants plus zinc, but the difference was not statistically significant (OR 0.79, 99% CI 0.60 to 1.04) unless the analysis was restricted to persons with category 3 or 4 AMD (OR 0.73, 99% CI 0.54 to 0.99). The prior USPSTF review added 10-year results from AREDS,^130^ which were consistent with the 6.3-year results. At 10 years, the combination of antioxidants plus zinc was associated with decreased risk of progression to advanced AMD (OR 0.69, 99% CI 0.56 to 0.86) and visual acuity loss ≥15 lines (OR 0.76, 99% CI 0.63 to 0.93) compared with placebo.

The prior USPSTF review also included a Cochrane systematic review^73^ of 13 trials of antioxidant multivitamins and mineral supplements for dry AMD. The systematic review findings were heavily influenced by the AREDS trial, which had the longest duration of followup and accounted for most patients in pooled analyses; therefore, conclusions of the systematic review regarding the effectiveness of multivitamins and mineral supplements were similar to AREDS. The systematic review found evidence for vitamins and mineral supplements other than antioxidants and zinc to be too limited to determine effects.

This review includes findings from an updated (2017) version of the Cochrane systematic review^72^ with 19 trials^77,78,80,85,88,89,91,93–95,99,100,103,113,118–120,123,124,131^ (N=11,162) (Appendix B Tables 13 and 14), including AREDS and all trials in the prior USPSTF review, as well as two additional trials not included in the updated Cochrane review^83,92^ (n=80 and 100) (Appendix B Tables 15 and 16). The updated Cochrane systematic review included the large (n=4,203) AREDS 2^115,124^ trial. All patients in AREDS 2 were taking the AREDS formulation or a variation of it (elimination of beta carotene, lowering of zinc dose, or both). Therefore, although it included a comparison of lutein plus zeaxanthin with placebo, it may be considered a trial of add-on therapy with lutein plus zeaxanthin rather than a true placebo-controlled trial.

In addition to AREDS 2, the systematic review included two other large trials: AREDS^113^ (n=3,640) and the Vitamin E, Cataract, and Age-related Maculopathy (VECAT) study^80^ (n=1,193). In the other trials, sample sizes ranged from 14 to 433 (Appendix B Table 13). The interventions evaluated were zinc (six trials), lutein (with or without zeaxanthin, five trials), vitamin E (one trial), and various antioxidant multivitamin and mineral combinations (nine trials). Mean age ranged from 66 to 75 years and the percentage of females ranged from 55 to 57, however three other trials recruited mostly males. Studies were conducted in the U.S., Europe, China, and Australia. Race/ethnicity was greater than 80 percent White in the five trials that reported this information. About half of the studies reported best-corrected visual acuity at baseline, which ranged from an average of 78 to 82 letters on the ETDRS chart (approximately 20/25) or 0.05 to 0.45 logMAR (approximately 20/20 to 20/60). Two trials required patients to have visual acuity of 0.20 to 0.40 logMAR (approximately 20/30 to 20/50) for inclusion. The mean duration of followup ranged from 6 months to 6 years, with most <2 years; 6.3-year followup data from AREDS were used. Most studies were assessed as low risk of bias, including the two largest studies, AREDS and VECAT.

The two additional placebo-controlled trials not included in the updated Cochrane review were rated fair quality (Appendix B Tables 15 and 16).^83,92^ One trial (n=80) evaluated a nutritional supplement containing carotenoids, antioxidants, and omega-3 fatty acids at 2 years,^92^ and one evaluated α-lipoic acid capsules;^83^ both were compared with placebo. Mean age of participants ranged from 71 to 74 years, and percent female ranged from 44 to 77 percent. The studies were conducted in Italy^92^ and China.^83^ At baseline, studies reported best corrected visual acuity of 0.63 logMAR (20/85),^83^ and visual acuity of 48.5 ETDRS letters (approximately 20/100).^92^ The trials were rated fair quality.

#### AMD Progression and Changes in Visual Acuity

The updated (2017) Cochrane systematic review^72^ was consistent with the prior (2012) version in finding antioxidant multivitamins and zinc associated with improved outcomes compared with placebo (Appendix B Table 13). Results were largely based on the AREDS trials, which accounted for the great majority of patients in pooled analyses and had the longest duration of followup.^123^

Antioxidant vitamins were associated with decreased risk of progression to late AMD compared with placebo (3 trials,^91,119,123^ N=2,445 people [73% from AREDS], OR 0.72, 95% CI 0.58 to 0.90; I^2^=0%) and decreased risk of progression to ≥3 lines visual acuity loss (1 trial,^123^ N=1,791 people, OR 0.77, 95% CI 0.62 to 0.96). There was no difference between antioxidants and placebo in mean visual acuity (5 trials, N=595, pooled mean difference 0.02 logMAR, 95% CI −0.03 to 0.07; I^2^=38%). In AREDS, the risk of progression to advanced AMD at 5 years varied according to baseline severity: 1.3% for category 2, 18% for category 3 (extensive intermediate drusen, large drusen, or noncentral geographic atrophy), and 43% for category 4.^123^ However, results were similar for antioxidant vitamins plus zinc compared with placebo when the analysis for progression to advanced AMD was restricted to category 3 or 4 patients (adjusted OR 0.66, 95% CI 0.47 to 0.93) or when the analysis included categories 2, 3, and 4 (adjusted OR 0.68, 95% CI 0.49 to 0.93).

The review^72^ also found zinc associated with decreased risk of progression to late AMD compared with placebo (3 trials,^85,103,123^ N=3,790 people [96% from AREDS], OR 0.83, 95% CI 0.70 to 0.98; I^2^=17.5%). Zinc was associated with decreased risk of ≥3 lines visual acuity loss compared with placebo but the difference was of borderline statistical significance (2 trials,^93,123^ 3,791 people [96% from AREDS], RR 0.87, 95% CI 0.75 to 1.00; I^2^=37%).

The review found little or no effect of lutein and zeaxanthin or vitamin E on risk of progression of AMD.^72^ Based on the AREDS 2 trial,^115^ the addition of lutein plus zeaxanthin to the AREDS formulation was not associated with decreased risk of progression to advanced AMD compared with placebo (n=6,891 eyes, RR, 0.92, 98.7% CI 0.80 to 1.05). AREDS 2 also found no effects of elimination of beta carotene or use of lower-dose zinc and risk of progression to advanced AMD, compared with the AREDS formulation.

Two small (n=80 and 100) fair-quality trials not included in the updated systematic review also evaluated effects of antioxidants compared with placebo for dry AMD (Appendix B Table 15). One trial^92^ (n=80) found a combination of carotenoids (lutein 10 mg, astaxahnthin 4 mg, zeaxanthin 2 mg), antioxidants (vitamin C 90 mg, vitamin E 30 mg, zinc 22.5 mg plus copper 1 mg), and omega-3 fatty acids (fish oil 500 mg, containing eicosapentaenoic acid [EPA] 185 mg and docosahexaenoic acid [DHA] 140 mg) associated with decreased likelihood of retionography worsening (2.1% vs. 15.4%, p=0.05) compared with placebo at 2 years, but effects on risk of worsened distance visual acuity (14.6% vs. 19.2%, p=0.74) and near visual acuity (16.7% vs. 34.6%, p=0.08) were not statistically significant. The other trial^83^ (n=100) found no difference in best corrected visual acuity after 3 months between α-lipoic acid 0.2 g daily compared with placebo (logMAR 0.66 vs. 0.63, p>0.05); the placebo in this trial was low-dose vitamin C (0.2 g).

#### Mortality

Trials of antioxidant multivitamins and minerals were not designed to evaluate mortality, though several trials reported this outcome. In AREDS, the largest trial (n=3,640), there was no difference between antioxidant use compared with no antioxidant in risk of all-cause mortality (hazard ratio [HR] 1.06, 95% CI 0.93 to 1.21), cardiovascular mortality (RR 1.20, 95% CI 0.97 to 1.49), cancer mortality (RR 1.07, 95% CI 0.83 to 1.38), or mortality due to other causes (RR 0.94, 95% CI 0.74 to 1.20) after adjustment for age, sex, race, education, smoking status, body mass index, diabetes, angina, cancer, and hypertension^113^ (Appendix B Table 11). However, zinc use was associated with decreased risk of all-cause (adjusted HR 0.83, 95% CI 0.73 to 0.95) and cardiovascular mortality (adjusted RR 0.80, 95% CI 0.64 to 0.99) compared with nonuse, though effects on cancer mortality were not statistically significant (adjusted RR 0.84, 95% CI 0.65 to 1.08). Two other trials (n=90 and n=1,193) also reported mortality but reported few events and imprecise estimates.^80,89^

#### Other Outcomes

Evidence on other outcomes associated with use of antioxidant multivitamins and minerals was limited.

One trial^91^ (n=110) found multivitamins associated with better vision-related function after 2 years (NEI-VFQ-25, 0-100 scale, mean difference 12.0, 95% CI 4.24 to 20.36). However, three other trials (n=1,193, 108, and 90) found no significant differences between antioxidants or minerals and vision-related function (NEI VFQ- 25 or Visual Function Index [VF-14], also 0-100 scale),^80,88,132^ though reporting of these outcomes was limited. One trial found α-lipoic acid associated with better quality of life (Low Vision Quality of Life instrument, Chinese version, 0 to 125 scale; 82.6 vs. 72.8, p<0.05) after 3 months.^83^ Long-term (10-year) followup of AREDS participants found no significant difference in likelihood of cataract surgery in participants taking any active AREDS intervention (antioxidants, zinc, or both) compared with placebo (RR 0.99, 95% CI 0.89 to 1.10) (Appendix B Table 11).^112^ The AREDS trial also found no differences between antioxidants, zinc, both, or placebo in six cognitive tests after 6.9 years^75^ and the AREDS 2 trial found no difference between lutein/zeaxanthin compared with placebo on cognitive function among those on the AREDS formulation.^114^

## Key Question 6 What Are the Effects of Newer (Aflibercept or Brolucizumab-Dbll) vs. Older VEGF Inhibitors for Wet AMD on Visual Acuity, Morbidity, Mortality, General or Vision-Related Quality of Life, Functional Status, or Cognition?

### Summary

- In three new trials (N=2,738), aflibercept was noninferior to ranibizumab in likelihood of <15 ETDRS letters of visual acuity loss or ≥15 letters of visual acuity gain.
- Two new trials (N=2,457) found aflibercept and ranibizumab associated with similar improvements in vison-related function.

### Evidence

Two newer VEGF inhibitors (aflibercept or brolucizumab-dbll) have been approved for treatment of wet AMD. Three new trials (reported in five publications) compared aflibercept to the older VEGF inhibitor ranibizumab.^79,104,106,108,109^ No trial compared brolucizumab-dbll to an older VEGF inhibitor. Aflibercept was evaluated in the two similarly designed VEGF Trap-Eye: Investigation of Efficacy and Safety in Wet AMD trials (VIEW1 and VIEW2, reported in one publication)^106^ (n=2,457), and the Comparison of Ranibizumab and Aflibercept for the Development of Geographic Atrophy in Wet AMD Patients (RIVAL)^108^ trial (n=281). Mean ages were 73 and 79 years; 57 and 53 percent of participants were female (Appendix B Table 9). One trial was conducted in Australia, and the others had various sites (U.S., Canada, international). Mean baseline visual acuity was ~20/80 in VIEW^106^ and ~20/50 in RIVAL.^108^ In the VIEW trials, the proportion of patients with lesions classified as occult choroidal neovascularization ranged from 36 to 40 percent; the proportion classified as minimally classic ranged from 32 to 37 percent; and the proportion with predominantly classic ranged from 23 to 29 percent.^106^ In RIVAL, choroidal neovascularization subtypes were 17 percent predominantly classic and 82 percent minimally classic/occult.^108^

The VIEW trials evaluated intravitreal aflibercept injections with initial dosing of 2 mg once monthly, 2 mg every 8 weeks (after 3 initial monthly doses), or 0.5 mg monthly. The RIVAL trial evaluated intravitreal aflibercept 2 mg once monthly. The ranibizumab dose in all trials was 0.5 mg once monthly. In the VIEW trial, at week 52 patients were switched to dosing at least every 12 weeks, with the exact frequency depending on disease activity.

The duration of followup ranged from 1 year to 4 years in the VIEW^106^ trials, and 2 years in RIVAL.^108^ All trials were appropriately randomized, used a blinded design, and had low attrition, and were rated good quality (Appendix B Table 10).

#### AMD Progression and Changes in Visual Acuity

Effects of aflibercept and ranibizumab on visual outcomes were similar. The VIEW trials found intravitreal aflibercept to be noninferior to ranibizumab for likelihood of <15 ETDRS letters of visual acuity loss at 1 year (94.9% vs. 94.3%) (Appendix B Table 9).^106^ Aflibercept and ranibizumab were also associated with similar likelihood of ≥15 or more letters of visual acuity gain at 1 year (31.4% vs. 32.4%), and likelihood of improvement to 20/40 vision or better (35.2% vs. 35.1%).^106^ In post-hoc analyses of the VIEW trials, effects of aflibercept and ranibizumab were also similar when patients were stratified according to age, baseline visual acuity, baseline lesion size or type of choroidal neovascularization, and baseline central retinal thickness.^79,104^ The RIVAL trial found aflibercept and ranibizumab to be associated with similar likelihood of <15 letters of visual acuity loss (94% vs. 94%) and ≥15 or more letters gain (19% vs. 25%) after 2 years (Appendix B Table 9).^108^ Reported mean change in best corrected visual acuity was +6.6 letters (95% CI 4.7 to 8.5 letters) for the ranibizumab group and +4.6 letters (95% CI 2.7 to 6.6 letters) for the aflibercept group (p=0.15) over 2 years. Mean change in the square root area of macular atrophy was +0.36 mm (95% CI 0.27 to 0.45 mm) for ranibizumab and +0.28 mm (95% CI 0.19 to 0.37 mm) for aflibercept, a treatment difference of +0.08 mm (95% CI −0.05 to 0.21 mm, p=0.24) after 2 years. The proportion of patients with macular atrophy increased from 7 to 37 percent for ranibizumab, and from 6 to 32 percent for aflibercept.

#### Vision-Related Function

In the VIEW trials, aflibercept and ranibizumab were associated with similar improvements from baseline in composite NEI-VFQ-25 scores (Appendix B Table 9).^106^ Mean improvements averaged 4.5 to 6.7 points on a 0 to 100 scale.^106^

#### Mortality

In the VIEW trials, intravitreal aflibercept and ranibizumab were associated with low and similar rates of vascular mortality (0.5% vs. 0.3%, RR 1.47, 95% CI 0.32 to 6.78; Appendix B Table 9).^108^ Two-year followup from the RIVAL trial reports similar rates of mortality for aflibercept and ranibizumab (4.3% vs. 2.1%, RR 2.02, 95% CI 0.52 to 7.95).^108^

## Key Question 7 What Are the Harms of Treatment for Early Impaired Visual Acuity Due to Wet or Dry AMD?

### Summary

#### VEGF Inhibitors for Wet AMD

- As described in the prior USPSTF review, four trials reported no differences between VEGF inhibitors and sham injection in likelihood of withdrawal due to adverse events.
- The prior USPSTF review found no significant differences between VEGF inhibitors and sham in likelihood of ocular hemorrhage (one trial), retinal detachment (two trials), or endophthalmitis (two trials), though these events occurred infrequently and estimates were imprecise.
- Rates of cardiovascular events and other serious adverse events in the trials were low, did not differ significantly across groups, and the studies were not sufficiently powered to accurately assess these outcomes.

#### Newer Compared With Older VEGF Inhibitors for Wet AMD

- Three new trials (N=2,738) found that serious ocular adverse events and cardiovascular events were infrequent and occurred in similar proportions of patients randomized to either aflibercept or ranibizumab.

#### Antioxidant Vitamins and Minerals for Dry AMD

- The AREDS trial found zinc use associated with increased risk for hospitalization due to genitourinary causes compared with nonuse (7.5% vs. 4.9%, RR, 1.47, 95% CI 1.19 to 1.80) and antioxidant use associated with increased risk of yellow skin compared with nonuse (8.3% vs. 6.0%, RR, 1.38, 95% CI 1.09 to 1.75).
- The AREDS 2 trial found the AREDS formulation with beta carotene associated with increased risk of lung cancer compared with the AREDS formulation without beta carotene (2.0% vs. 0.9%, p=0.04) when current smokers were excluded from the analysis; almost all (91%) of the lung cancers in this analysis occurred in former smokers.
- Evidence on harms of antioxidant vitamins and minerals for dry AMD was otherwise limited due to suboptimal reporting and imprecision, but did not indicate increased risk of serious adverse events or withdrawal due to adverse events.

### Evidence

#### VEGF Inhibitors for Wet AMD

As described in the prior USPSTF review, there were no significant differences between VEGF inhibitors compared with sham treatment in likelihood of withdrawal due to adverse events in the MARINA^87^ (n=716, RR, 0.88, 95% CI 0.45 to 1.70) or VISION^107^ trials (N=1,208, RR 1.00, 95% CI 0.27 to 3.66) (Appendix B Table 9). Evidence on the effects of VEGF inhibitors on other harms was limited.^2^ Serious ocular harms were infrequent, and incidence of endophthalmitis (two trials, N=1,924; RR 5.49, 95% CI 0.30 to 99 and RR 8.33, 95% CI 0.50 to 140), ocular hemorrhage (one trial, n=184; RR 0.52, 95% CI 0.08 to 3.61), and retinal detachment (two trials, N=1,924; RR 0.17, 95% CI 0.01 to 4.07, and RR 3.67, 95% CI 0.20 to 65) were similar in VEGF and sham groups.^2,87,90,107^

Rates of cardiovascular events and other serious adverse events in the trials were low, did not differ significantly across groups, and the studies were not sufficiently powered to accurately assess these outcomes (Appendix B Table 9).^87,90,107,133^ In MARINA, there was no difference between ranibizumab and sham in risk of myocardial infarction (2% vs. 2%; RR 1.12, 95% CI 0.35 to 3.60) or cerebrovascular accident (RR 2.24, 95% CI 0.49 to 10);^87^ neither group in PIER experienced a myocardial infarction or cerebrovascular accident after 1 year, and one ischemic cardiomyopathy event occurred in the sham arm.^90^ The VISION trials reported thromboembolic events of 6 percent in all groups.^107^

#### Newer Compared With Older VEGF Inhibitors for Wet AMD

Serious treatment-emergent ocular adverse events were infrequent in the VIEW trials (Appendix B Table 9).^106^ Discontinuation due to adverse events was low in aflibercept (1.9%) and ranibizumab (1.0%) groups. Aflibercept and ranibizumab were associated with similar rates of patients with at least one ocular serious adverse event (2.0% vs. 3.2%, RR 0.62, 95% CI 0.36 to 10.7).^106^ In RIVAL, discontinuation due to adverse events was 7.9 percent for aflibercept and 7.0 percent for ranibizumab; total ocular serious adverse effects were also low and similar across groups (2.9% vs.1.4%, RR 2.02, 95% CI 0.38 to 10.9; Appendix B Table 9).^108^

In the VIEW trials, intravitreal aflibercept and ranibizumab were associated with low and similar rates of vascular mortality (0.5% vs. 0.3%, RR 1.47, 95% CI 0.32 to 6.78), myocardial infarction (0.8% vs. 1%, RR 0.76, 95% CI 0.29 to 1.97), and cerebrovascular accident (0.4% vs. 0.2%, RR 2.28, 95% CI 0.28 to 18.5) after 1-year followup (Appendix B Table 9).^108^ Two-year followup from the RIVAL trial also found low and similar rates across treatment arms for atrial fibrillation (aflibercept 0% vs. ranibizumab 5.0%, RR 0.07, 95% CI 0.004 to 1.17), and cerebrovascular accidents (aflibercept 2.2% vs. ranibizumab 0.7%, RR 3.04, 95% CI 0.32 to 29).^108^

#### Antioxidant Vitamins and Minerals for Dry AMD

The prior USPSTF review^2^ included evidence on harms of antioxidant vitamins and minerals from the AREDS trial (Appendix B Table 17). Zinc use was associated with increased risk for hospitalization due to genitourinary causes compared with nonuse (7.5% vs. 4.9%, RR 1.47, 95% CI 1.19 to 1.80)^101^ and use of antioxidants was associated with increased risk of yellow skin compared with nonuse (8.3% vs. 6.0%, RR 1.38, 95% CI 1.09 to 1.75).^123^ None of the active treatments in AREDS (antioxidants, zinc, or both) was associated with increased risk of serious adverse events, which were uncommon (Appendix B Table 17). AREDS 2 found no differences between lutein and zeaxanthin compared with placebo in risk of serious adverse events among persons on the AREDS formulation. In the secondary randomization to different AREDS formulations (original formulation, without beta carotene, with low-dose zinc, or without beta carotene and without low dose zinc), there were also no differences between groups in risk of serious adverse events.^124^ However, in an analysis in which current smokers were excluded, the AREDS formulation with beta carotene was associated with increased risk of lung cancer compared with the AREDS formulation without beta carotene (2.0% vs. 0.9%, p=0.04). In this analysis, almost all (91%) of the lung cancers occurred in former smokers.

The largest trial after AREDS and AREDS 2, VECAT (n=1,193), reported no serious adverse events with vitamin E or placebo, and no differences in risk of withdrawal due to adverse events or specific adverse events.^80^ Evidence on harms of antioxidant vitamins and minerals for dry AMD from other trials was limited, due to suboptimal reporting and imprecision as a result of small, underpowered sample sizes.^72,83,92^ Four trials reported small numbers of withdrawals due to adverse events arms^77,80,85,91^ and two trials reported few serious adverse events;^88,129^ rates for both of these outcomes were similar for treatments and controls (Appendix B Table 17). Otherwise, trials provided no information on adverse events;^78,83,119,131^ stated that no adverse events were reported;^92,99,100,120^ reported minimal harms, few adverse events, or that adverse events were well tolerated;^89,93,94,103^ or reported no or few withdrawals from treatment.^118^