# Chapter 2 Methods

## Key Questions and Analytic Framework

The scope and Key Questions were developed by the Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers using the methods developed by the USPSTF.^71^ The analytic framework and Key Questions that guided the review are shown in Figure 1. Seven Key Questions were developed for this review:

Figure 1 Analytic Framework and Key Questions – Impaired Visual Acuity

* “Asymptomatic” individuals are defined as those without known impaired visual acuity (based on current corrected vision) who have not sought care for evaluation of vision problems.

^†^Conditions of interest include impaired visual acuity due to uncorrected refractive errors, cataracts, and age-related macular degeneration.

Note: Subpopulations of interest include those defined by age, sex, race/ethnicity, setting (e.g., rural or urban), and functional and cognitive status, etc.

Abbreviation: KQ = key question.

Key Question 1 What are the effects of vision screening in asymptomatic older adults versus no screening on visual acuity, morbidity or mortality, general or vision-related quality of life, functional status, or cognition?
Key Question 2 What are the harms of vision screening in asymptomatic older adults versus no screening?
Key Question 3 What is the diagnostic accuracy of screening for impaired visual acuity due to uncorrected refractive error, cataracts, or age-related macular degeneration?
Key Question 4 What is the accuracy of instruments for identifying patients at higher risk of impaired visual acuity due to uncorrected refractive error, cataracts, or age-related macular degeneration?
Key Question 5 What are the effects of treatment for wet or dry age-related macular degeneration versus placebo or no treatment on visual acuity, morbidity, mortality, general or vision-related quality of life, functional status, or cognition?
Key Question 6 What are the effects of newer (aflibercept or brolucizumab-dbll) versus older vascular endothelial growth factor inhibitors for wet age-related macular degeneration on visual acuity, morbidity, mortality, general or vision-related quality of life, functional status, or cognition?
Key Question 7 What are the harms of treatment for early impaired visual acuity due to wet or dry age-related macular degeneration?

The analytic framework depicts the relationship between the Key Questions for the systematic review within the context of the populations, interventions, outcomes, and harms of screening and treatment for impaired visual acuity. The far left of the framework describes the target population as asymptomatic adults 65 years of age and older without known vision impairment. To the right of the population is a line representing the diagnostic accuracy of screening leading to the diagnosis of impaired visual acuity (Key Question 3) and instruments for identifying patients at higher risk of impaired visual acuity (Key Question 4), and an additional arrow indicates potential harms of screening (Key Question 2). A subsequent line and area of the framework leads from the impaired visual acuity diagnosis to outcomes from treatment (Key Questions 5 and 6), specifically improved visual acuity, morbidity, mortality, vision-related quality of life, functional status, and cognition. An additional arrow indicates potential harms of treatment (Key Question 7). An overarching arrow leading from the initial screening population to the outcomes represents the direct effects of screening on outcomes (Key Question 1).

### Key Questions

1. What are the effects of vision screening in asymptomatic older adults versus no screening on visual acuity, morbidity or mortality, general or vision-related quality of life, functional status, or cognition?
2. What are the harms of vision screening in asymptomatic older adults versus no screening?
3. What is the diagnostic accuracy of screening for impaired visual acuity due to uncorrected refractive error, cataracts, or AMD?
4. What is the accuracy of instruments for identifying patients at higher risk of impaired visual acuity due to uncorrected refractive error, cataracts, or AMD?
5. What are the effects of treatment for wet or dry AMD versus placebo or no treatment on visual acuity, morbidity, mortality, general or vision-related quality of life, functional status, or cognition?
6. What are the effects of newer (aflibercept or brolucizumab-dbll) versus older VEGF inhibitors for wet AMD on visual acuity, morbidity, mortality, general or vision-related quality of life, functional status, or cognition?
7. What are the harms of treatment for early impaired visual acuity due to wet or dry AMD?

## Search Strategies

A research librarian searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews, and Ovid MEDLINE (January 2015 to February 9, 2021) for relevant studies and systematic reviews. The search relied primarily on the previous systematic review for the USPSTF to identify potentially relevant studies published before 2015 (we reassessed all articles included in that systematic review using the eligibility criteria). Search strategies are available in Appendix A1. To supplement electronic searches, we reviewed reference lists of relevant articles. Ongoing surveillance was conducted to identify major studies published since February 2021 that may have affected the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on January 21, 2022 and identified no studies affecting review conclusions.

## Study Selection

At least two reviewers independently evaluated each study to determine eligibility. We selected studies on the basis of inclusion and exclusion criteria developed for each Key Question (Appendix A2).

This systematic review carries forward prior questions (from the 2016 review for the USPSTF) on the benefits and harms of screening compared with no screening, and diagnostic accuracy of screening. The population of interest was older adults, defined as those 65 years of age or older. Screening tests include tests of vision conducted in primary settings as well as questionnaires related to problems with vision. Multi-component screening studies were excluded if the vision component was not evaluated separately or if the intervention was not feasible to conduct in a primary care setting (e.g., required eye specialty training or equipment). Because evidence on the benefits and harms of treatment for cataracts and refractive error are well-established and unlikely to have changed, we focused on benefits and harms of treatment for wet and dry AMD. For wet AMD, we focused on intravitreal injection of VEGF inhibitors, which are considered first-line therapy and the most commonly used treatment in clinical practice. Because newer VEGF inhibitors approved by the FDA (aflibercept and brolucizumab-dbll) have not been evaluated in placebo-controlled trials, a new Key Question on the benefits and harms of these medications compared with other VEGF inhibitors was added. Second-line therapies for wet AMD such as laser photocoagulation and PDT with verteprofin were not eligible. For dry AMD, we focused on the effectiveness of vitamins and antioxidants. Like the prior review for the USPSTF, this review did not address treatments for prevention of impaired visual acuity. An updated version^72^ of a systematic review^73^ on treatment for dry AMD that was utilized in the prior USPSTF review was included. Otherwise this report utilized primary studies; systematic reviews were used to identify potentially eligible studies for inclusion. In accordance with USPSTF methods, studies rated poor quality (see below) were excluded.

The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists the included studies, and Appendix A5 lists the excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

For studies meeting inclusion criteria, we created data abstraction forms to summarize characteristics of study populations, interventions, comparators, outcomes, study designs, settings, and methods. One investigator conducted data abstraction, which was reviewed for completeness and accuracy by another team member.

Predefined criteria were used to assess the quality of individual controlled trials, systematic reviews, and observational studies by using criteria developed by the USPSTF; studies were rated as “good,” “fair,” or “poor” per USPSTF criteria, depending on the seriousness of the methodological shortcomings (Appendix A6).^71^ For each study, quality assessment was performed by two team members. Disagreements were resolved by consensus.

## Data Synthesis and Analysis

A random effects meta-analysis conducted for the prior USPTF review on the effects of VEGF inhibitors compared with sham on visual acuity outcomes (the likelihood of visual acuity gain, visual acuity loss, or having vision 20/200 or better) was carried forward for this review; there were no new trials of VEGF inhibitors compared with sham. The meta-analysis calculated pooled risk ratios (RRs) and absolute risk differences using Review Manager 5.2 (Nordic Cochrane Centre) and stratified by the VEGF inhibitor used. Results were considered statistically significant if the P value was less than 0.05 based on 2-sided testing, and statistical heterogeneity was measured using the I^2^. No new evidence suitable for meta-analysis was identified for this review, due to small numbers of studies and heterogeneity in populations, interventions, and outcomes.

For all Key Questions, the overall strength of evidence was determined using the approach described in the USPSTF Procedure Manual.^71^ The strength of evidence was rated “high”, “moderate”, “low” or “insufficient” based on study quality, consistency of results between studies, precision of estimates, study limitations, and risk of reporting bias.^71^ Additionally, the applicability of the findings to U.S. primary care populations and settings was assessed. Discrepancies were resolved through consensus discussion.

## USPSTF and AHRQ Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and Key Questions and to resolve issues around scope for the final evidence synthesis.

AHRQ staff provided oversight for the project, coordinated systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.

## Expert Review and Public Comment

The draft research plan was posted for public comment from February 13, 2020 to March 11, 2020. The comments were reviewed and no changes to the scope or Key Questions were required. A final research plan was posted on the USPSTF’s Web site on June 11, 2020.

A draft version of this report was reviewed by content experts and Federal partner representatives (Appendix A7), and minor edits were made for clarity. In addition, the draft was posted for public comment from October 26, 2021 to November 22, 2021. The comments were reviewed and minor edits were made for clarity. However, no changes to the studies or findings were required.