# Chapter 1 Introduction and Background

## Purpose

This report updates a 2016 review for the U.S. Preventive Services Task Force (USPSTF)^1,2^ on screening for impaired visual acuity in older adults (defined as persons 65 years of age or older). It will be used by the USPSTF to update its 2016 recommendation.^3^ In 2016, the Task Force concluded that the current evidence was insufficient to assess the balance of benefits and harms of screening for impaired visual acuity in older adults (I Statement). Although the prior USPSTF review found that screening can identify persons with impaired visual acuity and that effective treatments are available for common causes of impaired visual acuity, direct evidence found no significant difference between vision screening in older adults in primary care settings and no screening in visual acuity or other clinical outcomes.

This review focuses on screening for and treatment of impaired visual acuity associated with the following conditions: uncorrected refractive errors, cataracts, and age-related macular degeneration (AMD). This review does not address screening for diabetic retinopathy. Screening for diabetic retinopathy is not addressed by the USPSTF, as it is considered part of diabetes followup and management (screening for diabetes is addressed elsewhere by the USPSTF).^4^ For this review, we use the term “impaired visual acuity” rather than “vision impairment” because the latter term implies functional limitations, which may or may not be present. In addition, vision impairment can occur for reasons other than visual acuity loss. For the purposes of this review, “asymptomatic” individuals are defined as those without known impaired visual acuity (based on current corrected vision) who have not sought care for evaluation of vision problems.

## Condition Background

### Condition Definition

Impaired visual acuity refers to decreased clarity or sharpness of vision. In addition to decreased or substandard visual acuity, uncorrected impaired visual acuity can also be associated with decreases in lowlight vision, color vision, binocularity, contrast sensitivity, accommodation, or stereopsis, as well as visual field loss (areas in the field of view in which objects cannot be seen). Visual acuity is most commonly determined in primary care settings using a tool such as the Snellen or Early Treatment Diabetic Retinopathy Study (ETDRS) eye chart, which assess high contrast visual acuity based on the ability of patients to recognize letters of different sizes arranged in rows from a prespecified distance (typically 20 feet). Roughly speaking, a person with 20/100 vision according to a visual acuity chart would need to be 20 feet away to read the smallest letters that someone with “normal” (20/20) vision could read at 100 feet. Visual acuity can also be described in meters (6/6 in meters is equivalent to 20/20 in feet) or using the decimal or the logarithm of the minimum angle of resolution (logMAR) scale (Table 1). The severity of decreased visual acuity varies. Impaired visual acuity has been defined as visual acuity of worse than 20/40^5^ or 20/50^6^ but better than 20/200 (the threshold for legal blindness). This definition for impaired visual acuity was used in this report, unless otherwise noted. Visual acuity can be measured with or without refractive correction; for the purposes of this review, impaired visual acuity refers to current corrected visual acuity.

Table 1 Measurements of Visual Acuity

Snellen, Feet | Snellen, Meters | Decimal | LogMAR
20/20 | 6/6 | 1.00 | 0.00
20/30 | 6/9 | 0.67 | 0.18
20/40 | 6/12 | 0.50 | 0.30
20/60 | 6/18 | 0.33 | 0.48
20/80 | 6/24 | 0.25 | 0.60
20/100 | 6/30 | 0.20 | 0.70
20/160 | 6/48 | 0.13 | 0.90
20/200 | 6/60 | 0.10 | 1.00

Note: Visual impairment is 20/50 or worse; legal blindness is 20/200 or worse.

Abbreviation: LogMAR = logarithmic minimum angle of resolution.

Source: Holladay 2004^157^

High-contrast visual acuity worse than 20/20 but better than 20/40 is generally thought to have minimal effects on reading ability, functional capacity, or quality of life. In the United States (U.S.), the visual acuity standard for driving without restrictions is 20/40 or better. Although the International Council of Ophthalmology defined mild impaired visual acuity in 2002 as worse than 20/25 and better than 20/80,^7^ some studies have used a definition for mild impaired visual acuity of between roughly 20/40 and 20/80.^5,6^ This degree of impaired visual acuity is less likely to cause major functional limitations than more severe impairment, and may be more apt to be unidentified without screening. Although these criteria focus on findings for high-contrast visual acuity, normal high-contrast visual acuity can be associated with decreased low-contrast visual acuity and contrast sensitivity.^8^ As described in a Contextual Question in the prior USPSTF review, definitions for a clinically important change in visual acuity vary across studies. However, a difference of at least 15 letters (equivalent to 3 lines on the ETDRS), representative of a doubling of the visual angle, is a commonly reported outcome in studies assessing visual acuity.^9,10^

AMD, cataracts, refractive errors, and presbyopia are common causes of impaired visual acuity in older adults. AMD leads to blurred vision and development of scotomas that obscure central vision. AMD is the leading cause of legal blindness for persons older than age 65 years. Atrophic or “dry” (nonexudative) macular degeneration accounts for 85 to 90 percent of AMD cases. Although AMD becomes “wet” (exudative or neovascular) in only 10 to 15 percent of cases, wet AMD accounts for over 80 percent of cases of severe visual loss from AMD.^11^ Cataracts lead to blurring of vision, increased sensitivity to glare, and loss of sensitivity to differences in contrast. Refractive errors, such as myopia (nearsightedness) or hyperopia (farsightedness), occur when the eye is unable to bring parallel rays of light into focus on the fovea.^12^ Presbyopia, which occurs as part of the natural aging process of the eye, is the loss of the eye’s ability to change its focus to see objects that are near. This occurs as the lenses of the eyes begin to lose flexibility around age 45 years, and affects most people at some point in life.

### Prevalence and Burden of Disease/Illness

In 2015, of 3.22 million persons with visual impairment, approximately half were persons ages 80 years and older, 24 percent were 70 to 79 years of age, and 16 percent were 60 to 69 years of age.^13^ The prevalence of impaired visual acuity rises significantly with age in older adults, from 1.1 percent in persons ages 65 to 69 years to 16.7 percent in persons older than age 80 years,^14^ and the prevalence of both blindness and impaired visual acuity increases with age, especially among people age 80 years and older.^13,15^ The number of persons age 60 years and older with impaired visual acuity (defined as visual acuity worse than 20/40 but better than 20/200) was estimated at 2.91 million in 2015 and the number blind (defined as visual acuity 20/200 or worse) was estimated at 0.76 million.^13^ These numbers were projected to increase to 6.57 and 1.73, respectively, in 2050, due to the aging of the population. The prevalence of specific causes of impaired visual acuity (i.e., AMD, cataracts, refractive errors, and presbyopia) is described below. The cost of impaired visual acuity and blindness to the U.S. economy is estimated at $5.48 billion.^16,17^

#### Age-Related Macular Degeneration

The prevalence of AMD in the 2005 to 2008 National Health and Nutrition Examination Survey was 6.5 percent in persons older than age 40 years (estimated 7.2 million individuals in the U.S.) and increased with age (2.8% in ages 40 to 59 years and 11.1% in age ≥60 years).^18^ The prevalence of early AMD was 5.7 percent, late AMD 0.8 percent, wet (exudative) AMD 0.3 percent, and advanced dry AMD (geographic atrophy) 0.5 percent. AMD is more common among White non-Latino and Latino persons compared with Black persons, especially among the very old (≥75 years).^18,19^ The prevalence of AMD in males and females is similar.

#### Cataracts

Cataracts are the cause of low vision (defined as best-corrected visual acuity worse than 20/40) in approximately half of cases.^20^ The prevalence of cataracts increases sharply with age. Approximately 22 million U.S. adults age 40 years and older were estimated to have cataracts (not necessarily associated with vision impairment) in 2011,^21^ and 50 percent of those age 80 years and older are estimated to have cataracts. In White females, prevalence increases from 27.7 percent in ages 65 to 69 years to 76.6 percent in those age 80 years or older. In Black females, respective prevalence rates are 28.5 and 60.9 percent, in White males they are 22.4 and 71.3 percent, and in Black males they are 17.5 and 46.2 percent.

#### Refractive Errors

Refractive errors are the most common cause of impaired visual acuity in the U.S. and worldwide. In older adults with impaired visual acuity due to hyperopia or myopia (including those currently using corrective lenses), approximately 60 percent have correctable (to better than 20/40) refractive errors.^6^ In general, the prevalence of hyperopia increases sharply with age, with a prevalence that is 4.2 to 7.4 times higher in persons age 80 years or older compared with those ages 40 to 49 years.^12,19^ The prevalence of hyperopia requiring a correction of +3.0 diopters (D) or more (at least moderate severity) is about 5.9 percent in U.S. adults ages 50 to 54 years, 15.2 percent in adults ages 65 to 69 years, and 20.4 percent in adults age 80 years and older. At any age, hyperopia is more common in White non-Latino persons than Black or Latino persons, and is also more prevalent in females than males. For example, among White males, the prevalence of hyperopia of +3.0 D or more is 3.6 percent among those ages 40 to 49 years, 14.1 percent among those ages 65 to 69 years, and 23.5 percent among those older than 80 years. Respective rates for White females are 3.7, 17.8, and 27.2 percent, and for Black females they are 3.1, 10.6, and 13.5 percent. An exception to increasing prevalence of hyperopia with age is adult Black males, in whom the prevalence of hyperopia remains fairly constant across age groups, ranging from 1.5 to 3.9 percent.^12^

Among adults older than age 65 years, the prevalence of myopia is relatively stable with increasing age, though prevalence varies among different ethnic/racial groups. For example, the prevalence of myopia of at least −1.0 D in Black males ages 65 to 69 years is 8.1 percent compared with 13.1 percent in Latino males and 17.7 percent in non-Latino white males.^12^ The prevalence of myopia of at least −1.0 D tends to decrease with age from about 25.7 percent in U.S. adults ages 50 to 54 years, to 16.0 percent in adults ages 65 to 69 years and 17.5 percent in adults age 80 years and older. At any age, myopia is more prevalent in non-Latino White persons than Black or Latino persons.

It is estimated that around three-quarters of U.S. individuals with impaired visual acuity due to uncorrected refractive error could experience improvement with proper refractive correction.^13^

#### Presbyopia

The prevalence of presbyopia, or age-related loss of accommodation, increases with age and affects most people at some point in life. The onset of presbyopia generally occurs around age 45 years, though onset tends to be somewhat earlier in people who live in areas with higher ambient temperatures.^22^

Regardless of its cause, impaired visual acuity is consistently associated with decreased functional capacity and quality of life in older people, including the ability to live independently, with more severe impaired visual acuity associated with greater negative effects.^23–27^ Impaired visual acuity can affect ability to perform both basic and instrumental activities of daily living, work, drive safely, or obtain a driver’s license, as well as increase risk of falls and other accidental injuries.^28–32^ However, there is inter-individual variability in the degree of functional impairment in persons with the same degree of impaired visual acuity. Vision loss is also associated with higher prevalence of depression and social isolation.^24,33^ Of older adults experiencing impaired visual acuity, 57.2 percent are at risk for mild or moderate depression compared with 43.5 percent of those without vision loss.^34^ When combined with other chronic health conditions, vision loss is associated with overall poorer health among people age 65 years and older.^15^

According to the Centers for Disease Control and Prevention, in 2017 an estimated 53 million U.S. adults older than 65 years were at high risk for serious vision loss, which can cause a substantial social and economic toll, including disability, loss of productivity, and reduced quality of life.^35^ Experts predict that by 2030, rates of severe vision loss will double or triple as the aging population increases^34–36^ and the number of older adults (age ≥65 years) increases.^15,24,34,37,38^ Direct medical expenses for older adults with impaired visual acuity in the U.S. are $8.3 billion annually,^15^ including an estimated annual $6.8 billion for cataract treatment.^39^

### Etiology and Natural History

Refractive errors are a general term to describe conditions associated with the inability of the cornea and lens of the eye to bring parallel rays of light into sharp focus on the fovea, resulting in blurry vision. In adults, common types of refractive errors are myopia, hyperopia, and astigmatism. Myopia occurs when images are focused in front of the fovea, affecting ability to clearly view more distant objects.^40^ Hyperopia occurs when images are focused behind the fovea, which affects the ability to sharply view closer objects. Hyperopia often presents or worsens with older age due to presbyopia, which refers to age-related changes in the eye, including decreased elasticity of the lens, reducing near-focusing ability. Astigmatism is a condition in which there are two or more focal points in the eye, resulting in distortion of images at various distances. Progression of myopia in older adults can be associated with development and progression of cataracts. Cataracts are opacities in the lens of the eye, which generally progress over time and result in decreased visual acuity and glare.^41^

AMD affects the macula, the area of the retina responsible for central vision.^42^ Drusen, which are white to yellow retinal lesions, are an early sign of AMD when they occur in the macula. Early stage AMD with small to medium-sized drusen and no pigment change is not associated with vision loss. However, about one to three out of 100 people with small drusen experience vision problems within 5 years, and about 50 out of 100 people with larger drusen develop advanced AMD and vision loss within 5 years.^43^ Advanced AMD is usually classified into “wet” or “dry” forms. The dry form of advanced AMD (also referred to as “geographic atrophy”) is more common and associated with atrophy of the retinal layers and retinal pigmented epithelial cells. The wet form of AMD is associated with the development of abnormal blood vessels in the choroid layer underneath the retina (choroidal neovascularization). Both types of advanced AMD can cause blurred central vision, distorted vision, and decreased lowlight vision. Dry AMD progresses more gradually than wet AMD, and is less likely to cause vision loss or other vision problems, though dry AMD can turn into wet AMD. In severe cases, advanced AMD results in central scotomas (complete loss of central vision).

### Risk Factors

The prevalence of impaired visual acuity is higher among people of lower socioeconomic or educational status and those without private health insurance.^6,12^ Risk factors for impaired visual acuity vary depending on the specific condition. A positive family history is a major risk factor for both myopia and hyperopia.^40^ In both sexes and in various ethnic/racial groups, latent hyperopia tends to manifest with older age due to a loss in accommodation, with the exception of Black men, in whom the prevalence of hyperopia remains relatively low.^12^ Risk factors for cataracts include older age, smoking, and alcohol use, exposure to ultraviolet light, eye trauma, ocular inflammatory diseases, diabetes, and exposure to corticosteroids.^44,45^ Lower socioeconomic status and Black race are associated with higher rates of unoperated cataracts.^46^ Risk factors for AMD are not completely understood, but are thought to include older age, smoking, obesity, diet, elevated cholesterol, cardiovascular disease, and family history.^47,48^ AMD is more common in White persons compared with other races/ethnicities.^12^

The Behavioral Risk Factor Surveillance System Vision Impairment Expert Panel concluded that the most substantial barriers to vision preventive care, treatment, and rehabilitation appear to be behavioral issues, followed by cost and geographic access. Behavioral and cultural issues include patient belief systems, trust issues, education and language barriers, health literacy issues, immigration status, and concordance between doctor and patient.^49^

### Rationale for Screening/Screening Strategies

Impaired visual acuity due to uncorrected refractive error, cataracts, and AMD is common in adults and the prevalence increases with age.^12,50,51^ Impaired visual acuity in older adults may not be recognized or may remain unreported because vision changes can be relatively subtle, occur in more advanced stages of the condition, progress slowly over time, and occur in persons with cognitive dysfunction or other comorbid conditions. However, even mildly impaired visual acuity may be associated with decreased quality of life and functional capacity and increased likelihood of accidents and related injuries.^23,25–27^ In addition, vision loss due to AMD may be irreversible. Screening provides an opportunity to address disparities in detection and treatment of impaired visual acuity among racial/ethnic groups, and targeting older adults addresses the population most likely to be affected. Screening for impaired visual acuity in the primary care setting is noninvasive and could potentially identify persons without access to specialty eye services likely to benefit from referral for interventions to improve visual acuity, slow progression of ocular disease, or prevent the development of irreversible vision loss.^2^

### Interventions/Treatment

A number of interventions are available to treat common causes of impaired visual acuity. Although impaired visual acuity may be identified in the primary care setting, most interventions require the involvement of an eye care provider. Presbyopia is often corrected with prescription glasses, contact lenses, reading glasses, progressive addition lenses, or bifocals. Refractive errors may be remedied with corrective lenses, contact lenses, or refractive surgery. Photorefractive surgery (including laser in situ keratomileusis, photorefractive keratectomy, or laser epithelial keratomileusis) is associated with more upfront costs compared with corrective lenses and more commonly selected as a treatment option by younger adults. Older patients undergoing photorefractive surgery may be slightly less likely to experience optimal results and slightly more likely to need repeat treatment or enhancement compared with those younger.^52^

For patients with impaired visual acuity that is not sufficiently improved by correcting refractive error, and in whom other treatable causes cannot be identified, reading aids (such as magnifiers) are a treatment option.^53^ For cataracts causing significant impairment in visual acuity, the most common treatment is surgical cataract extraction and intraocular lens implantation.^54^ Cataract surgery is effective in improving vision in 90 percent of patients, has a low complication rate, generally can be performed as an outpatient procedure, and can restore vision even in patients with advanced cataracts.^55^

Antioxidants and vitamins are used to slow progression of dry AMD, but have no proven benefit in slowing cataract progression.^56–59^ No treatment is known to reverse the retinal damage associated with dry AMD. The wet form of AMD accounts for most of the vision loss and blindness associated with advanced AMD. For both dry and wet AMD, early identification and treatment may help to prevent permanent effects on vision. Treatments for wet AMD are aimed at the abnormal retinal vascular growth (choroidal neovascularization) associated with this condition and responsible for vision loss. Currently, the most common therapy for wet AMD is intravitreal injection of vascular endothelial growth factor (VEGF) inhibitors. Intravitreal medications approved by the U.S. Food and Drug Administration (FDA) for wet AMD are ranibizumab, pegaptanib, aflibercept, and brolucizumab-dbll. In addition, bevacizumab is a VEGF inhibitor approved for treatment of colorectal and other cancers that is used off-label for treatment of wet AMD. Laser photocoagulation, an older treatment for wet AMD, is no longer commonly used because it causes blind spots due to retinal damage in areas of treatment.^53^ Photodynamic therapy with administration of verteporfin, a photoreactive agent, followed by exposure of the eye to a low-level, non-thermal photo-activating laser light, is associated with less retinal scarring than laser photocoagulation and is an option for subfoveal neovascularization, but associated with high rates of recurrence, and is not a first-line therapy for most patients with AMD.

### Current Clinical Practice/Recommendations of Other Groups

The clinical standard for identifying presence of impaired visual acuity is by evaluation of distance visual acuity using the Snellen or ETDRS eye chart or another standardized test of visual acuity. Pinhole visual acuity testing can be used to estimate whether impaired visual acuity is due to correctable refractive error (i.e., vision corrects or improves upon pinhole testing).^60^ Reading distance testing can also be assessed using a handheld card or other screening tool.

Clinically significant cataracts can be visualized on physical examination as change of color or opacities in the lens. Impaired visual acuity due to cataracts should not completely correct with pinhole testing, though partial correction may occur due to decreased light scattering, particularly if myopia related to the cataract is present.^61^

The Amsler grid consists of evenly spaced horizontal and vertical lines (making squares) on a sheet.^62^ It is used to detect retinal defects affecting central vision, including AMD, which can be associated with distortion in the boxes on the grid or blank areas in the grid (scotomas). The Amsler grid can also be used by patients as a self-monitoring tool for early signs or progression of macular disease.^63,64^

Screening questions may be used to elicit self-perceived problems with vision.^65^ Funduscopic examination can also be performed in order to detect asymptomatic or early AMD or other retinal disease. The frequency with which nonstandard visual acuity tests, the Amsler grid, vision screening questionnaires, or funduscopic examination is used in primary care is not known.^66^ Older adults with impaired visual acuity are typically referred to an optometrist or ophthalmologist for further evaluation, correction of refractive error, and other treatments. In a study estimating the level of self-reported access to eye care services, approximately half of U.S. adults older than age 65 years reported receiving an eye examination within the last 12 months.^67^

The American Optometric Association recommends an annual comprehensive eye and vision examination for all adults older than age 65 years, and the American Academy of Ophthalmology recommends a comprehensive examination conducted by an ophthalmologist every 1 to 2 years in patients age 65 years or older (Table 2).^68,69^ The American Academy of Family Physicians’ recommendation on screening for visual acuity in older adults is in agreement with the USPSTF recommendation (insufficient evidence).^70^

Table 2 Recommendations of Other Groups

Organization | Recommendation/Clinical Guidance
American Academy of Ophthalmology^68^ | Patients age 65 years or older without risk factors for eye disease (e.g., diabetes, glaucoma) should have comprehensive medical eye evaluations every 1 to 2 years.
American Optometric Association^69^ | Annual comprehensive eye and vision examinations are recommended for persons 65 years of age or older for the diagnosis and treatment of sight-threatening eye conditions and the timely correction of refractive errors.
American Academy of Family Physicians^70^ | Links to the 2016 U.S. Preventive Services Task Force Recommendation.