# Appendix B Evidence Tables and Quality Tables

Appendix B Table 1 Trials of Vision Screening

Appendix B Table 2 Trials of Vision Screening, Quality Assessment

Appendix B Table 3 Diagnostic Accuracy of Vision Screening Tests, Study Characteristics

Appendix B Table 4 Diagnostic Accuracy of Vision Screening Tests, Results

Appendix B Table 5 Diagnostic Accuracy of Vision Screening Tests, Quality Assessment

Appendix B Table 6 Diagnostic Accuracy of Vision Screening Instruments, Study Characteristics

Appendix B Table 7 Diagnostic Accuracy of Vision Screening Instruments, Results

Appendix B Table 8 Diagnostic Accuracy of Vision Screening Instruments, Quality Assessment

Appendix B Table 9 Trials of VEGF Inhibitors

Appendix B Table 10 Trials of VEGF Inhibitors, Quality Assessment

Appendix B Table 11 AREDS Trials of Multivitamins

Appendix B Table 12 AREDS Trials of Multivitamins, Quality Assessment

Appendix B Table 13 Systematic Review of Multivitamins

Appendix B Table 14 Systematic Review of Multivitamins, Quality Assessment

Appendix B Table 15 Additional Trials of Multivitamins

Appendix B Table 16 Additional Trials of Multivitamins, Quality Assessment

Appendix B Table 17 Trials of Multivitamins, Harms