# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Database: Ovid MEDLINE(R) ALL

#### Screening

1. Vision Screening/
2. exp Vision Tests/
3. exp Refractive Errors/
4. exp Vision Disorders/
5. exp Macular Degeneration/
6. exp Cataract/
7. (vision or presbyop$ or myop$ or astigmati$ or hyperop$ or cataract$ or “macular degeneration” or “armd” or “amd”).ti,ab,kf.
8. Mass Screening/
9. screen*.ti,ab,kf.
10. or/2-7
11. or/8-9
12. 10 and 11
13. 1 or 12
14. 13 not (adolescen$ or child$ or school or pediatric$ or toddler or infant$ or newborn or neonat$ or prematur$).ti,ab.
15. 14 not “diabetic retinopathy”.ti.
16. limit 15 to yr="2015 -Current"
17. (random* or control* or trial or cohort or case* or prospective or retrospective or systematic or “meta analysis” or “metaanalysis”).ti,ab,kf,tw,pt,sh.
18. (canine or dog or dogs or mouse or mice or rat or rats).ti.
19. 16 and 17
20. 19 not 18
21. limit 20 to english language

#### Diagnostic Accuracy

1. Vision Screening/
2. exp Vision Tests/
3. exp Refractive Errors/
4. exp Vision Disorders/
5. exp Macular Degeneration/
6. exp Cataract/
7. (presbyop$ or myop$ or astigmati$ or hyperop$ or cataract$ or “macular degeneration” or “armd” or “amd”).ti,ab,kf.
8. or/1-7
9. (screen* or test*).ti,ab,kf.
10. 8 and 9
11. exp “Sensitivity and Specificity”/
12. (sensitivity or specificity or accuracy or predict*).ti,ab,kf.
13. 11 or 12
14. 10 and 13
15. 14 not (adolescen* or child* or school or preschool* or pediatric$ or paediatric* or toddler or infant* or newborn or neonat* or prematur*).ti,ab.
16. 15 not “diabetic retinopathy”.ti,ab.
17. limit 16 to yr="2015 -Current"
18. 17 not (canine or dog or dogs or mouse or mice or rat or rats).ti.
19. limit 18 to english language

#### Treatment

1. exp Macular Degeneration/dh, dt, pc
2. (“macular degeneration” or “ARMD” or “AMD”).ti,ab,kf.
3. Ranibizumab/
4. Bevacizumab/
5. (ranibizumab or pegaptanib or aflibercept or brolucizumab or bevacizumab).ti,ab,kf.
6. exp Vitamins/
7. exp Antioxidants/
8. Dietary Supplements/
9. (vitamin* or antioxidant* or zinc or “beta carotene” or copper or lutein or “eicosapentaenoic acid” or “docosahexaenoic acid” or zeaxanthin or “fish oil”).ti,ab,kf.
10. AREDS.ti,ab.
11. 1 or 2
12. or/3-10
13. 11 and 12
14. limit 13 to yr="2015 -Current"
15. (random* or control* or trial or cohort or case* or prospective or retrospective or systematic or “meta analysis” or “metaanalysis”).ti,ab,kf,tw,pt,sh.
16. 14 and 15
17. limit 16 to english language

### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

#### Screening

1. Vision Screening/
2. exp Vision Tests/
3. exp Refractive Errors/
4. exp Vision Disorders/
5. exp Macular Degeneration/
6. exp Cataract/
7. (vision or presbyop$ or myop$ or astigmati$ or hyperop$ or cataract$ or “macular degeneration” or “armd” or “amd”).ti,ab,hw.
8. Mass Screening/
9. screen*.ti,ab,hw.
10. or/2-7
11. or/8-9
12. 10 and 11
13. 1 or 12
14. 13 not (adolescen$ or child$ or school or pediatric$ or toddler or infant$ or newborn or neonat$ or prematur$).ti,ab.
15. 14 not “diabetic retinopathy”.ti.
16. limit 15 to yr="2015 -Current"
17. conference abstract.pt.
18. “journal: conference abstract”.pt.
19. “journal: conference review”.pt.
20. “http://.www.who.int/trialsearch (http://www.who.int/trialsearch)*”.so.
21. “https://clinicaltrials.gov*”.so.
22. or/17-21
23. 16 not 22

#### Diagnostic Accuracy

1. Vision Screening/
2. exp Vision Tests/
3. exp Refractive Errors/
4. exp Vision Disorders/
5. exp Macular Degeneration/
6. exp Cataract/
7. (presbyop$ or myop$ or astigmati$ or hyperop$ or cataract$ or “macular degeneration” or “armd” or “amd”).ti,ab,hw.
8. or/1-7
9. (screen* or test*).ti,ab,hw.
10. 8 and 9
11. exp “Sensitivity and Specificity”/
12. (sensitivity or specificity or accuracy or predict*).ti,ab,hw.
13. 11 or 12
14. 10 and 13
15. 14 not (adolescen* or child* or school or preschool* or pediatric$ or paediatric* or toddler or infant* or newborn or neonat* or prematur*).ti,ab.
16. 15 not “diabetic retinopathy”.ti,ab.
17. limit 16 to yr="2015 -Current"
18. 17 not (canine or dog or dogs or mouse or mice or rat or rats).ti.
19. limit 18 to english language
20. conference abstract.pt.
21. “journal: conference abstract”.pt.
22. “journal: conference review”.pt.
23. “http://.www.who.int/trialsearch (http://www.who.int/trialsearch)*”.so.
24. “https://clinicaltrials.gov*”.so.
25. 20 or 21 or 22 or 23 or 24
26. 19 not 25

#### Treatment

1. exp Macular Degeneration/dh, dt, pc
2. (“macular degeneration” or “ARMD” or “AMD”).ti,ab,hw.
3. Ranibizumab/
4. Bevacizumab/
5. (ranibizumab or pegaptanib or aflibercept or brolucizumab or bevacizumab).ti,ab,hw.
6. exp Vitamins/
7. exp Antioxidants/
8. Dietary Supplements/
9. (vitamin* or antioxidant*).ti,ab,hw.
10. (zinc or “beta carotene” or copper or lutein or “eicosapentaenoic acid” or “docosahexaenoic acid” or zeaxanthin or “fish oil”).ti,ab,hw.
11. AREDS.ti,ab.
12. 1 or 2
13. or/3-11
14. 12 and 13
15. limit 14 to yr="2015 -Current"
16. limit 15 to english language
17. conference abstract.pt.
18. “journal: conference abstract”.pt.
19. “journal: conference review”.pt.
20. “http://.www.who.int/trialsearch (http://www.who.int/trialsearch)*”.so.
21. “https://clinicaltrials.gov*”.so.
22. 17 or 18 or 19 or 20 or 21
23. 16 not 22

### Database: EBM Reviews - Cochrane Database of Systematic Reviews

#### All KQs

1. (vision or presbyop$ or myop$ or astigmati$ or hyperop$ or cataract$ or “macular degeneration” or “armd” or “amd”).ti,ab.
2. “eyes and vision”.gw.
3. 1 and 2
4. limit 3 to last 5 years
5. limit 4 to full systematic reviews
6. 5 not child*.ti.
7. screen*.ti,ab.
8. 6 and 7
9. (sensitivity or specificity or accuracy or predict*).ti,ab.
10. 6 and 9
11. (“macular degeneration” or “armd” or “amd”).ti,ab.
12. 8 or 10 or 11

## Appendix A2 Inclusion and Exclusion Criteria

| Include | Exclude
Definition of Disease | Impaired VA due to uncorrected refractive errors, cataracts, or AMD for screening and due to AMD for treatment | Impaired VA due to other conditions
Populations | KQs 1-4: Asymptomatic adults 65 years of age and older without known impaired VA (based on current corrected vision) and who have not sought care for evaluation of vision problems; KQs 5-7: Asymptomatic adults with vision impairment (current corrected VA worse than 20/40 but better than 20/200) due to uncorrected refractive errors (myopia, hyperopia, astigmatism, or presbyopia), AMD, or cataracts | KQs 1-4: Known impaired VA based on current corrected vision or who have sought care for evaluation of vision problems; KQs 5-7: VA worse than 20/200, other causes of vision loss
Interventions | KQs 1-2: Vision screening performed in primary care or community-based settings, including multi-component screening with a distinct vision screening component; KQs 3-4: Vision screening tests performed in primary care or community-based settings; questions or questionnaires for impaired VA; KQs 5-7: For wet AMD, vascular endothelial growth factor inhibitors (ranibizumab, pegaptanib, aflibercept, brolucizumab-dbll, and bevacizumab); for dry AMD, vitamins and antioxidants | KQs 1-2: Vision screening performed in eye specialty settings; KQs 3-4: Diagnostic tests for vision screening performed in eye specialty settings (including funduscopic examination performed by an eye professional and specialized diagnostic testing); KQs 5-7: Laser photocoagulation, photodynamic therapy, treatment for uncorrected refractive error and cataracts
Comparisons | KQs 1-2: No screening; KQs 3-4: Reference standard for impaired VA (as defined in the studies); KQs 5, 7: No treatment or placebo; KQ 6: Newer (aflibercept or brolucizumab-dbll) versus older vascular endothelial growth factor inhibitors
Outcomes | KQs 1-2, 5-7: VA; vision-related quality of life; functional capacity, including ability to drive and driving outcomes; other measures of morbidity; mortality; cognition; harms, including falls and fractures; other treatment-related harms; KQs 3-4: Sensitivity, specificity, positive and negative predictive values, areas under the receiver operating curve, other measures of diagnostic test accuracy | KQs 1-2, 5-7: Reading speed and other tests of vision function
Setting | United States applicable, primary care relevant | -
Study Designs | KQs 1-2: RCTs and controlled observational studies comparing vision screening to no screening, delayed screening or usual care (i.e., targeted screening); KQs 3-4: Studies evaluating diagnostic accuracy of a screening question or diagnostic test compared to a reference standard; KQs 5-7: RCTs comparing treatment to no treatment (including sham injection); controlled observational studies will be included if evidence on harms from RCTs is insufficient | -
Study Quality | Fair or good quality studies | Poor quality studies

Abbreviations: AMD = age-related macular degeneration; KQ = key question; RCTs = randomized controlled trials; VA = visual acuity.

## Appendix A3 Literature Flow Diagram

Abbreviations: AMD = Age-Related Macular Degeneration; AREDS = Age-Related Eye Disease Studies; KQ = key question; SR = systematic review; VEGF = vascular endothelial growth factor.

Note: The number of included studies does not total to the number shown, because some studies are included for more than one Key Question. The number of publications includes the studies in the systematic review.

Appendix A3 is the Literature Flow Diagram depicting the search and selection of articles for the review. The diagram shows that 5,170 citations were identified and reviewed. Three hundred and thirty-nine articles were reviewed at the full-text level after excluding 4,831 citations based on review of title and abstract. Two hundred and eighty-eight articles were excluded for the following reasons: wrong population (29), wrong intervention (72), wrong outcome (26), wrong comparator (25), wrong study design for key question (54), not a study (8), systematic review or meta-analysis used as a source document only to identify individual studies (22), study covered in a systematic review (7), wrong country (1), poor quality (2), wrong publication type (3), results not usable or fully reported (4), wrong setting (10), wrong screener (13), ancillary publication not relevant to the current systematic review (12). Twenty-four studies and 1 systematic review (of 19 studies) in 51 total publications were included that provide evidence for Key Questions as follows: Key Question 1: 4 trials (3 carried forward, 1 new) in 6 publications, Key Question 2: no studies, Key Question 3: 8 cross-sectional studies (7 carried forward, 1 new) in 7 publications, Key Question 4: 3 cross-sectional studies (2 carried forward, 1 new) in 4 publications, Key Question 5: Wet AMD VEGF inhibitors: 4 trials (all carried forward) in 5 publications, Dry AMD Vitamin and Mineral Supplements: 1 updated SR (of 19 trials) and 2 additional, new trials, Key Question 6: 3 trials (all new) in 5 publications, Key Question 7: Wet AMD VEGF inhibitors: VEGF inhibitors vs. placebo/no treatment: 4 trials (all carried forward) in 4 publications, Newer vs. older VEGF inhibitors: 3 trials (all new) in 2 publications, Dry AMD Vitamin and Mineral Supplements: 1 updated SR (of 19 trials) and 2 additional, new trials.

## Appendix A4 Included Studies

Age-Related Eye Disease Study 2 Research Group. Lutein + zeaxanthin and omega-3 fatty acids for age-related macular degeneration: the Age-Related Eye Disease Study 2 (AREDS2) randomized clinical trial. JAMA. 2013 May 15;309(19):2005–15. doi: 10.1001/jama.2013.4997. PMID: 23644932.23644932
Age-Related Eye Disease Research Group. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E, beta carotene, and zinc for age-related macular degeneration and vision loss: AREDS report no. 8. Arch Ophthalmol. 2001 Oct;119(10):1417–36. PMID: 11594942.11594942
Ariyasu RG, Lee PP, Linton KP, . Sensitivity, specificity, and predictive values of screening tests for eye conditions in a clinic-based population. Ophthalmology. 1996;103(11):1751–60. PMID: 8942866.8942866
Arora KS, Chang DS, Supakontanasan W, . Assessment of a rapid method to determine approximate visual acuity in large surveys and other such settings. Am J Ophthalmol. 2014 Jun;157(6):1315–21.e1. doi: 10.1016/j.ajo.2014.02.031. PMID: 24548874.24548874
Bartlett HE, F.A. E. Effect of lutein and antioxidant dietary supplementation on contrast sensitivity in age-related macular degeneration: a randomized controlled trial. Eur J Clin Nutr. 2007;61(9):1121–7. PMID: 17268417.17268417
Beatty S, Chakravarthy U, Nolan JM, . Secondary outcomes in a clinical trial of carotenoids with coantioxidants versus placebo in early age-related macular degeneration. Ophthalmology. 2013 Mar;120(3):600–6. doi: 10.1016/j.ophtha.2012.08.040. PMID: 23218821.23218821
Berrow EJ, Bartlett HE, Eperjesi F, . The effects of a lutein-based supplement on objective and subjective measures of retinal and visual function in eyes with age-related maculopathy - a randomised controlled trial. Br J Nutr. 2013 Jun;109(11):2008–14. doi: 10.1017/s0007114512004187. PMID: 23084077.23084077
Bressler NM, Chang TS, Varma R, . Driving ability reported by neovascular age-related macular degeneration patients after treatment with ranibizumab. Ophthalmology. 2013 Jan;120(1):160–8. doi: 10.1016/j.ophtha.2012.07.027. PMID: 23009891.23009891
Chang TS, Bressler NM, Fine JT, . Improved vision-related function after ranibizumab treatment of neovascular age-related macular degeneration: results of a randomized clinical trial. Arch Ophthalmol. 2007 Nov;125(11):1460–9. PMID: 17998507.17998507
Chew EY, Clemons T, SanGiovanni JP, . The Age-Related Eye Disease Study 2 (AREDS2): study design and baseline characteristics (AREDS2 report number 1). Ophthalmology. 2012 Nov;119(11):2282–9. doi: 10.1016/j.ophtha.2012.05.027. PMID: 22840421.22840421
Chew EY, Clemons TE, Agron E, . Effect of omega-3 fatty acids, lutein/zeaxanthin, or other nutrient supplementation on cognitive function: the AREDS2 Randomized Clinical Trial. JAMA. 2015 Aug 25;314(8):791–801. doi: 10.1001/jama.2015.9677. PMID: 26305649.26305649
Chew EY, Clemons TE, Agron E, . Long-term effects of vitamins C and E, beta-carotene, and zinc on age-related macular degeneration: AREDS report no. 35. Ophthalmology. 2013 Aug;120(8):1604–11.e4. doi: 10.1016/j.ophtha.2013.01.021. PMID: 23582353.23582353
Chew EY, Sperduto RD, Milton RC, . Risk of advanced age-related macular degeneration after cataract surgery in the Age-Related Eye Disease Study: AREDS report 25. Ophthalmology. 2009 Feb;116(2):297–303. doi: 10.1016/j.ophtha.2008.09.019. PMID: 19091420.19091420
Eekhof J, De Bock G, Schaapveld K, . Effects of screening for disorders among the elderly: an intervention study in general practice. Fam Pract. 2000;17(4):329–33. PMID: 10934182.10934182
Eekhof JA, De Bock GH, Schaapveld K, . Screening for hearing and visual loss among elderly with questionnaires and tests: which method is the most convincing for action? Scand J Prim Health Care. 2000;18(4):203–7. PMID: 11205087.11205087
Gillies MC, Hunyor AP, Arnold JJ, . Effect of ranibizumab and aflibercept on best-corrected visual acuity in treat-and-extend for neovascular age-related macular degeneration: a randomized clinical trial. JAMA Ophthalmol. 2019 Apr 01;137(4):372–9. doi: 10.1001/jamaophthalmol.2018.6776. PMID: 30676617.30676617
Gillies MC, Hunyor AP, Arnold JJ, . Macular Atrophy in Neovascular Age-Related Macular Degeneration: A Randomized Clinical Trial Comparing Ranibizumab and Aflibercept (RIVAL Study). Ophthalmology. 2020 Feb;127(2):198–210. doi: 10.1016/j.ophtha.2019.08.023. PMID: 31619357.31619357
Gragoudas ES, Adamis AP, Cunningham ET, . Pegaptanib for neovascular age-related macular degeneration. N Engl J Med. 2004;351(27):2805–16. PMID: 15625332.15625332
Heier JS, Brown DM, Chong V, . Intravitreal aflibercept (VEGF trap-eye) in wet age-related macular degeneration. Ophthalmology. 2012 Dec;119(12):2537–48. doi: 10.1016/j.ophtha.2012.09.006. PMID: 23084240.23084240
Hiller R, Krueger DE. Validity of a survey question as a measure of visual acuity impairment. Am J Public Health. 1983;73:93–6. PMID: 6848004.6848004
Ho AC, Saroj N, Baker K, . Impact of baseline characteristics on treatment response to intravitreal aflibercept injection for wet age-related macular degeneration. Ophthalmol Retina. 2018 07;2(7):676–83. doi: 10.1016/j.oret.2017.10.017. PMID: 31047376.31047376
Holz F, Wolfensberger T, Piguet B, . Oral zinc-therapy in age-related macular degeneration: a double blind study. Germ J Ophthalmol. 1993;2(Suppl):391.
Ivers RQ, Optom B, Macaskill P, . Sensitivity and specificity of tests to detect eye disease in an older population. Ophthalmology. 2001;108(5):968–75. PMID: 11320029.11320029
Jee J, Wang JJ, Rose K, . Incorporating vision and hearing tests into aged care assessment: methods and the pilot study. Ophthalmic Epidemiol. 2004 Dec;11(5):427–36. doi: 10.1080/09286580490888807. PMID: 15590588.15590588
Jessa Z, Evans BJW, Thomson DW. The development & evaluation of two vision screening tools for correctable visual loss in older people. Ophthalmic Physiol Opt. 2012 Jul;32(4):332–48. doi: 10.1111/j.1475-1313.2012.00919.x. PMID: 22670892.22670892
Johnson AR, Munoz A, Gottlieb JL, . High dose zinc increases hospital admissions due to genitourinary complications. J Urol. 2007 Feb;177(2):639–43. PMID: 17222649.17222649
Kaiser HJ, Flammer J, Stumpfig D, . Visaline in the treatment of age-related macular degeneration: a pilot study. Ophthalmologica. 1995;209(6):302–5. doi: 10.1159/000310646. PMID: 8751336.8751336
Ma L, Yan SF, Huang YM, . Effect of lutein and zeaxanthin on macular pigment and visual function in patients with early age-related macular degeneration. Ophthalmology. 2012 Nov;119(11):2290–7. doi: 10.1016/j.ophtha.2012.06.014. PMID: 22858124.22858124
McMurdo M, Baines P. The detection of visual disability in the elderly. Health Bull (Edinb). 1988;46(6):327–9. PMID: 3240947.3240947
Moore AA, Siu A, Partridge JM, . A randomized trial of office-based screening for common problems in older persons. Am J Med. 1997;102(4):371–8. PMID: 9217619.9217619
Mueller YK, Monod S, Locatelli I, . Performance of a brief geriatric evaluation compared to a comprehensive geriatric assessment for detection of geriatric syndromes in family medicine: a prospective diagnostic study. BMC Geriatr. 2018 03 13;18(1):72. doi: 10.1186/s12877-018-0761-z. PMID: 29534680.29534680
Murray IJ, Makridaki M, van der Veen RLP, . Lutein supplementation over a one-year period in early AMD might have a mild beneficial effect on visual acuity: the CLEAR study. Invest Ophthalmol Vis Sci. 2013 Mar;54(3):1781–8. doi: 10.1167/iovs.12-10715. PMID: 23385792.23385792
Newsome DA, Swartz M, Leone NC, . Oral zinc in macular degeneration. Arch Ophthalmol. 1988 Feb;106(2):192–8. doi: 10.1001/archopht.1988.01060130202026. PMID: 3277606.3277606
Newsome DA. A randomized, prospective, placebo-controlled clinical trial of a novel zinc-monocysteine compound in age-related macular degeneration. Curr Eye Res. 2008 Jul;33(7):591–8. doi: 10.1080/02713680802178437. PMID: 18600492.18600492
Piatti A, Croce A, Mazzacane D, . Effect of 2-year nutritional supplementation on progression of age-related macular degeneration. Eur J Ophthalmol. 2020 Mar 18;30(2):376–81. doi: 10.1177/1120672119836007. PMID: 30880442.30880442
Piermarocchi S, Saviano S, Parisi V, . Carotenoids in Age-related Maculopathy Italian Study (CARMIS): two-year results of a randomized study. Eur J Ophthalmol. 2012 Mar–Apr;22(2):216–25. doi: 10.5301/ejo.5000069. PMID: 22009916.22009916
Regillo CD, Brown DM, Abraham P, . Randomized, double-masked, sham-controlled trial of ranibizumab for neovascular age-related macular degeneration: PIER Study year 1. Am J Ophthalmol. 2008;145(2):239–48. PMID: 18222192.18222192
Richer S, Stiles W, Statkute L, . Double-masked, placebo-controlled, randomized trial of lutein and antioxidant supplementation in the intervention of atrophic age-related macular degeneration: the Veterans LAST study (Lutein Antioxidant Supplementation Trial). Optometry. 2004 Apr;75(4):216–30. doi: 10.1016/s1529-1839(04)70049-4. PMID: 15117055.15117055
Richer S. Multicenter ophthalmic and nutritional age-related macular degeneration study-part 2: antioxidant intervention and conclusions. J Am Optom Assoc. 1996 Jan;67(1):30–49. PMID: 8825017.8825017
Rosenfeld PJ, Brown DM, Heier JS, . Ranibizumab for neovascular age-related macular degeneration. N Engl J Med. 2006;355(14):1419–31. PMID: 17021318.17021318
Smeeth L, Fletcher AE, Hanciles S, . Screening older people for impaired vision in primary care: cluster randomised trial. BMJ. 2003 November 1, 2003;327(7422):1027–31. doi: 10.1136/bmj.327.7422.1027. PMID: 14593039.14593039
Stur M, Tittl M, Reitner A, . Oral zinc and the second eye in age-related macular degeneration. Invest Ophthalmol Vis Sci. 1996 Jun;37(7):1225–35. PMID: 8641826.8641826
Swanson MW, McGwin G, Jr., Elliott AF, . The nursing home minimum data set for vision and its association with visual acuity and contrast sensitivity. J Am Geriatr Soc. 2009 Mar;57(3):486–91. doi: 10.1111/j.1532-5415.2008.02144.x. PMID: 19187419.19187419
Tao Y, Jiang P, Wei Y, . alpha-lipoic acid treatment improves vision-related quality of life in patients with dry age-related macular degeneration. Tohoku J Exp Med. 2016 11;240(3):209–14. PMID: 27840374.27840374
Tay T, Rochtchina E, Mitchell P, . Eye care service utilization in older people seeking aged care. Clin Exp Ophthalmol. 2006 Mar;34(2):141–5. doi: 10.1111/j.1442-9071.2006.01139.x. PMID: 16626428.16626428
Taylor HR, Tikellis G, Robman LD, . Vitamin E supplementation and macular degeneration: randomised controlled trial. BMJ. 2002 Jul 6;325(7354):11. doi: 10.1136/bmj.325.7354.11. PMID: 12098721.12098721
Waldstein SM, Simader C, Staurenghi G, . Morphology and visual acuity in aflibercept and ranibizumab therapy for neovascular age-related macular degeneration in the VIEW trials. Ophthalmology. 2016 07;123(7):1521–9. doi: 10.1016/j.ophtha.2016.03.037. PMID: 27157149.27157149
Wang H, Li R, Wang M. Effects of zinc and antioxidant on visual function of patients with age-related macular degeneration. Zhongguo Linchuant Kangfu. 2004;8:1290–1.
Weigert G, Kaya S, Pemp B, . Effects of lutein supplementation on macular pigment optical density and visual acuity in patients with age-related macular degeneration. Invest Ophthalmol Vis Sci. 2011;52(11):8174–8. doi: 10.1167/iovs.11-7522. PMID: 21873668.21873668
Woods RL, Tregear SJ, Mitchell RA. Screening for ophthalmic disease in older subjects using visual acuity and contrast sensitivity. Ophthalmology. 1998;105(12):2318–26. doi: 10.1016/S0161-6420(98)91235-0. PMID: 9855166.9855166
Yaffe K, Clemons TE, McBee WL, . Impact of antioxidants, zinc, and copper on cognition in the elderly: a randomized, controlled trial. Neurology. 2004 Nov 9;63(9):1705–7. doi: 10.1212/01.wnl.0000142969.19465.8f. PMID: 15534261.15534261

### Systematic Review

Evans JR, Lawrenson JG. Antioxidant vitamin and mineral supplements for slowing the progression of age-related macular degeneration. Cochrane Database Syst Rev. 2017 Jul 30;7:Cd000253. doi: 10.1002/14651858.CD000253.pub4. PMID: 28756617.28756617

## Appendix A5 Excluded Studies

Abdelfattah NS, Al-Sheikh M, Pitetta S, . Macular atrophy in neovascular age-related macular degeneration with monthly versus treat-and-extend ranibizumab: findings from the TREX-AMD trial. Ophthalmology. 2017;124(2):215–23. doi: 10.1016/j.ophtha.2016.10.002. PMID: 27863845. Excluded for wrong comparator.27863845
Abraham P, Yue H, Wilson L. Randomized, double-masked, sham-controlled trial of ranibizumab for neovascular age-related macular degeneration: PIER study year 2. Am J Ophthalmol. 2010;150(3):315–24.e1. doi: 10.1016/j.ajo.2010.04.011. PMID: 20598667. Excluded for wrong intervention.20598667
Acharya UR, Mookiah MR, Koh JE, . Automated screening system for retinal health using bi-dimensional empirical mode decomposition and integrated index. Comput Biol Med. 2016;75:54–62. doi: 10.1016/j.compbiomed.2016.04.015. PMID: 27253617. Excluded for results not usable or not fully reported.27253617
Acharya UR, Mookiah MR, Koh JE, . Novel risk index for the identification of age-related macular degeneration using radon transform and DWT features. Comput Biol Med. 2016;73:131–40. doi: 10.1016/j.compbiomed.2016.04.009. PMID: 27107676. Excluded for wrong intervention.27107676
Age-Related Eye Disease Study Research Group. The age-related eye disease study system for classifying age-related macular degeneration from stereoscopic color fundus photographs: the age-related eye disease study report number 6. Am J Ophthalmol. 2001;132(5):668–81. doi: 10.1016/S0002-9394(01)01218-1. Excluded for ancillary publication not relevant to the current systematic review.11704028
Agostini H, Mulyukov Z, Tsilimbaris M, . Comparison of the efficacy of brolucizumab with natural disease progression in wet AMD using clinical data from the phase III HAWK and HARRIER trials and dodelled placebo data. Curr Eye Res. 2020:1–4. doi: 10.1080/02713683.2020.1731832. PMID: 32065533. Excluded for wrong study design for key question.32065533
Agron E, Mares J, Clemons TE, . Dietary nutrient intake and progression to late age-related macular degeneration in the Age-Related Eye Disease Studies 1 and 2. Ophthalmology. 2021;128(3):425–55. doi: 10.1016/j.ophtha.2020.08.018. PMID: 32858063. Excluded for ancillary publication not relevant to current systematic review.32858063
Ahmed D, Stattin M, Graf A, . Detection of treatment-naive choroidal neovascularization in age-related macular degeneration by swept source optical coherence tomography angiography. Retina. 2018;38(11):2143–9. doi: 10.1097/IAE.0000000000001832. PMID: 28902095. Excluded for wrong population.28902095
Akuffo KO, Beatty S, Peto T, . The impact of supplemental antioxidants on visual function in nonadvanced age-related macular degeneration: a head-to-head randomized clinical trial. Invest Ophthalmol Vis Sci. 2017;58(12):5347–60. doi: 10.1167/iovs.16-21192. PMID: 29053808. Excluded for wrong comparator.29053808
Akuffo KO, Nolan JM, Howard AN, . Sustained supplementation and monitored response with differing carotenoid formulations in early age-related macular degeneration. Eye. 2015;29(7):902–12. doi: 10.1038/eye.2015.64. PMID: 25976647. Excluded for wrong comparator.25976647
Alster Y, Bressler NM, Bressler SB, . Preferential Hyperacuity Perimeter (PreView PHP) for detecting choroidal neovascularization study. Ophthalmology. 2005;112(10):1758–65. doi: 10.1016/j.ophtha.2005.06.008. PMID: 16154198. Excluded for wrong study design for key question.16154198
Amin R, Saputra EB. Efficacy of oral glutathione addition in lutein supplementation on contrast sensitivity improvement in dry age-related macular degeneration: a randomized controlled trial. Asian J Pharm Clin Res. 2019;12(3):397–9. Excluded for wrong outcome.
Amlani A, Choi MY, Tarnopolsky M, . Anti-NT5c1A autoantibodies as biomarkers in inclusion body myositis. Front Immunol. 2019;10:745. doi: 10.3389/fimmu.2019.00745. PMID: 31024569. Excluded for wrong population.31024569
Aslam TM, Zaki HR, Mahmood S, . Use of a neural net to model the impact of optical coherence tomography abnormalities on vision in age-related macular degeneration. Am J Ophthalmol. 2018;185:94–100. doi: 10.1016/j.ajo.2017.10.015. PMID: 29101008. Excluded for wrong outcome.29101008
Ba J, Peng RS, Xu D, . Intravitreal anti-VEGF injections for treating wet age-related macular degeneration: a systematic review and meta-analysis. Drug Des Devel Ther. 2015;9:5397–405. doi: 10.2147/DDDT.S86269. PMID: 26451092. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.26451092
Bagchi A, Schwartz R, Hykin P, . Diagnostic algorithm utilising multimodal imaging including optical coherence tomography angiography for the detection of myopic choroidal neovascularisation. Eye. 2019;33(7):1111–8. doi: 10.1038/s41433-019-0378-2. PMID: 30809019. Excluded for wrong population.30809019
Barikian A, Mahfoud Z, Abdulaal M, . Induction with intravitreal bevacizumab every two weeks in the management of neovascular age-related macular degeneration. Am J Ophthalmol. 2015;159(1):131–7. doi: 10.1016/j.ajo.2014.10.005. PMID: 25308787. Excluded for wrong comparator.25308787
Bartlett H, Eperjesi F. A randomised controlled trial investigating the effect of nutritional supplementation on visual function in normal, and age-related macular disease affected eyes: design and methodology [ISRCTN78467674]. Nutr J. 2003;2:12. doi: 10.1186/1475-2891-2-12. PMID: 14594455. Excluded for study covered in an included systematic review.14594455
Beatty S, Nolan JM, Muldrew KA, . Visual outcome after antioxidant supplementation. Ophthalmology. 2013;120(3):645. doi: 10.1016/j.ophtha.2012.09.013. PMID: 23714607. Excluded for wrong publication type.23714607
Bell KJ, Hayen A, Glasziou P, . Early CRT monitoring using time-domain optical coherence tomography does not add to visual acuity for predicting visual loss in patients with central retinal vein occlusion treated with intravitreal ranibizumab: a secondary analysis of trial data. Retina. 2017;37(3):509–14. PMID: 27548351. Excluded for wrong intervention.27548351
Bhandari S, Nguyen V, Arnold J, . Treatment outcomes of ranibizumab versus aflibercept for neovascular age-related macular degeneration: data from the Fight Retinal Blindness! Registry. Ophthalmology. 2020;127(3):369–76. doi: 10.1016/j.ophtha.2019.10.006. PMID: 31757494. Excluded for wrong study design for key question.31757494
Bhisitkul RB, Desai SJ, Boyer DS, . Fellow eye comparisons for 7-year outcomes in ranibizumab-treated AMD subjects from ANCHOR, MARINA, and HORIZON (SEVEN-UP study). Ophthalmology. 2016;123(6):1269–77. doi: 10.1016/j.ophtha.2016.01.033. PMID: 26996339. Excluded for wrong comparator.26996339
Bonds DE, Harrington M, Worrall BB, . Effect of long-chain omega-3 fatty acids and lutein + zeaxanthin supplements on cardiovascular outcomes: results of the Age-Related Eye Disease Study 2 (AREDS2) randomized clinical trial. JAMA Intern Med. 2014;174(5):763–71. doi: 10.1001/jamainternmed.2014.328. PMID: 24638908. Excluded for ancillary publication not relevant to current systematic review.24638908
Boyer DS, Antoszyk AN, Awh CC, . Subgroup analysis of the MARINA study of ranibizumab in neovascular age-related macular degeneration. Ophthalmology. 2007;114(2):246–52. doi: 10.1016/j.ophtha.2006.10.045. PMID: 17270674. Excluded for results not usable or not fully reported.17270674
Brinks M, Zaback T, Park DW, . Community-based vision health screening with on-site definitive exams: design and outcomes. Cogent Med. 2018;5(1)doi: 10.1080/2331205X.2018.1560641. PMID: 31428660. Excluded for wrong population.31428660
Broadhead GK, Grigg JR, McCluskey P, . Saffron therapy for the treatment of mild/moderate age-related macular degeneration: a randomised clinical trial. Graefes Arch Clin Exp Ophthalmol. 2019;257(1):31–40. doi: 10.1007/s00417-018-4163-x. PMID: 30343354. Excluded for ancillary publication not relevant to current systematic review.30343354
Brown DM, Kaiser PK, Michels M, . Ranibizumab versus verteporfin for neovascular age-related macular degeneration. N Engl J Med. 2006;355(14):1432–44. Excluded for wrong comparator.17021319
Bruender MC, Benjamin N, Agostini HT, . Subjective evaluation of visual acuity is not reliable to detect disease activity in different exudative maculopathies. Graefes Arch Clin Exp Ophthalmol. 2018;256(9):1565–71. doi: 10.1007/s00417-018-4021-x. PMID: 29858676. Excluded for wrong population.29858676
Buckle M, Donachie PH, Johnston RL. Long-term outcomes of intravitreal ranibizumab for neovascular age-related macular degeneration in a well defined region of the UK. Br J Ophthalmol. 2016;100(2):240–5. doi: 10.1136/bjophthalmol-2014-306423. PMID: 26124462. Excluded for wrong study design for key question.26124462
Burlina PM, Joshi N, Pekala M, . Automated grading of age-related macular degeneration from color fundus images using deep convolutional neural networks. JAMA Ophthalmol. 2017;135(11):1170–6. doi: 10.1001/jamaophthalmol.2017.3782. PMID: 28973096. Excluded for wrong intervention.28973096
Camp AS, Shane TS, Kang J, . Evaluating self-refraction and ready-made spectacles for treatment of uncorrected refractive error. Ophthalmic Epidemiol. 2018;25(5–6):392–8. doi: 10.1080/09286586.2018.1500615. PMID: 30118609. Excluded for wrong intervention.30118609
Carrasco J, Pietsch GA, Nicolas MP, . Real-world effectiveness and real-world cost-effectiveness of intravitreal aflibercept and intravitreal ranibizumab in neovascular age-related macular degeneration: systematic review and meta-analysis of real-world studies. Adv Ther. 2020;37(1):300–15. doi: 10.1007/s12325-019-01147-6. PMID: 31728825. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.31728825
Castillo MM, Mowatt G, Elders A, . Optical coherence tomography for the monitoring of neovascular age-related macular degeneration: a systematic review. Ophthalmology. 2015;122(2):399–406. doi: 10.1016/j.ophtha.2014.07.055. PMID: 25444343. Excluded for wrong population.25444343
Chakravarthy U, Adamis AP, Cunningham ET, Jr., . Year 2 efficacy results of 2 randomized controlled clinical trials of pegaptanib for neovascular age-related macular degeneration. Ophthalmology. 2006;113(9):1508.e1–25. doi: 10.1016/j.ophtha.2006.02.064. PMID: 16828500. Excluded for wrong intervention.16828500
Chakravarthy U, Harding SP, Rogers CA, . A randomised controlled trial to assess the clinical effectiveness and cost-effectiveness of alternative treatments to Inhibit VEGF in Age-related choroidal Neovascularisation (IVAN). Health Technol Assess. 2015;19(78):1–298. doi: 10.3310/hta19780. PMID: 26445075. Excluded for wrong comparator.26445075
Chamard C, Lacombe S, Navarre S, . Is current age related macular degeneration self-monitoring a good tool for detecting exudative recurrence? J Fr Ophtalmol. 2019;42(10):1049–55. doi: 10.1016/j.jfo.2019.02.017. PMID: 31727329. Excluded for wrong study design for key question.31727329
Chandrasekaran N, Harlow S, Moroi S, . Visual impairment at baseline is associated with future poor physical functioning among middle-aged women: the Study of Women’s Health Across the Nation, Michigan Site. Maturitas. 2017;96:33–8. doi: 10.1016/j.maturitas.2016.11.009. PMID: 28041592. Excluded for wrong intervention.28041592
Chang AA, Broadhead GK, Hong T, . Intravitreal aflibercept for treatment-resistant neovascular age-related macular degeneration: 12-month safety and efficacy outcomes. Ophthalmic Res. 2015;55(2):84–90. doi: 10.1159/000440886. PMID: 26637166. Excluded for wrong population.26637166
Chen JS, Adelman RA. Hyperacuity exam screens for choroidal neovascularization in age-related macular degeneration on a mobile device. Ophthalmic Surg Lasers Imaging Retina. 2016;47(8):708–15. doi: 10.3928/23258160-20160808-03. PMID: 27548447. Excluded for wrong outcome.27548447
Cheung CMG, Yanagi Y, Akiba M, . Improved detection and diagnosis of polypoidal choroidal vasculopathy using a combination of optical coherence tomography and optical coherence tomography angiography. Retina. 2019;39(9):1655–63. doi: 10.1097/IAE.0000000000002228. PMID: 29927796. Excluded for wrong intervention.29927796
Chew EY, Clemons TE, Agron E, . Ten-year follow-up of age-related macular degeneration in the age-related eye disease study: AREDS report no. 36. JAMA Ophthalmol. 2014;132(3):272–7. doi: 10.1001/jamaophthalmol.2013.6636. PMID: 24385141. Excluded for ancillary publication not relevant to current systematic review.24385141
Chew EY, Clemons TE, Sangiovanni JP, . Secondary analyses of the effects of lutein/zeaxanthin on age-related macular degeneration progression: AREDS2 report No. 3. JAMA Ophthalmol. 2014;132(2):142–9. doi: 10.1001/jamaophthalmol.2013.7376. PMID: 24310343. Excluded for ancillary publication not relevant to current systematic review.24310343
Christakis PG, Agron E, Klein ML, . Incidence of macular atrophy after untreated neovascular age-related macular degeneration: age-related eye disease study report 40. Ophthalmology. 2020;127(6):784–92. doi: 10.1016/j.ophtha.2019.11.016. PMID: 31899035. Excluded for ancillary publication not relevant to current systematic review.31899035
Christen WG, Glynn RJ, Chew EY, . Folic acid, pyridoxine, and cyanocobalamin combination treatment and age-related macular degeneration in women: the Women’s Antioxidant and Folic Acid Cardiovascular Study. Arch Intern Med. 2009;169(4):335–41. doi: 10.1001/archinternmed.2008.574. PMID: 19237716. Excluded for wrong population.19237716
Christen WG, Glynn RJ, Chew EY, . Folic acid, vitamin B6, and vitamin B12 in combination and age-related cataract in a randomized trial of women. Ophthalmic Epidemiol. 2016;23(1):32–9. doi: 10.3109/09286586.2015.1130845. PMID: 26786311. Excluded for wrong outcome.26786311
Clarke EL, Evans JR, Smeeth L. Community screening for visual impairment in older people. Cochrane Database Syst Rev. 2018;2:CD001054. doi: 10.1002/14651858.CD001054.pub3. PMID: 29460275. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.29460275
Clemens CR, Wolf A, Alten F, . Response of vascular pigment epithelium detachment due to age-related macular degeneration to monthly treatment with ranibizumab: the prospective, multicentre RECOVER study. Acta Ophthalmol. 2017;95(7):683–9. doi: 10.1111/aos.13359. PMID: 28084038. Excluded for wrong population.28084038
Conlin PR, Asefzadeh B, Pasquale LR, . Accuracy of a technology-assisted eye exam in evaluation of referable diabetic retinopathy and concomitant ocular diseases. Br J Ophthalmol. 2015;99(12):1622–7. doi: 10.1136/bjophthalmol-2014-306536. PMID: 25995299. Excluded for wrong study design for key question.25995299
Csaky KG, Dugel PU, Pierce AJ, . Clinical evaluation of pazopanib eye drops versus ranibizumab intravitreal injections in subjects with neovascular age-related macular degeneration. Ophthalmology. 2015;122(3):579–88. doi: 10.1016/j.ophtha.2014.09.036. PMID: 25432081. Excluded for wrong intervention.25432081
Cui C, Lu H. Clinical observations on the use of new anti-VEGF drug, conbercept, in age-related macular degeneration therapy: a meta-analysis. Clin Interv Aging. 2018;13:51–62. doi: 10.2147/CIA.S151225. PMID: 29343949. Excluded for wrong intervention.29343949
Cui QN, Gray IN, Yu Y, . Repeated intravitreal injections of antivascular endothelial growth factors and risk of intraocular pressure medication use. Graefes Arch Clin Exp Ophthalmol. 2019;257(9):1931–9. doi: 10.1007/s00417-019-04362-7. PMID: 31152311. Excluded for wrong study design for key question.31152311
Cumberland PM, Chianca A, Rahi JS. Accuracy and utility of self-report of refractive error. JAMA Ophthalmol. 2016;134(7):794–801. PMID: 27197004. Excluded for wrong intervention.27197004
Cumming RG, Ivers R, Clemson L, . Improving vision to prevent falls in frail older people: a randomized trial. J Am Geriatr Soc. 2007;55(2):175–81. Excluded for wrong screener.17302652
Curcio CA, McGwin G, Jr., Sadda SR, . Functionally validated imaging endpoints in the Alabama study on early age-related macular degeneration 2 (ALSTAR2): design and methods. BMC Ophthalmol. 2020;20(1):196. doi: 10.1186/s12886-020-01467-0. PMID: 32429847. Excluded for wrong outcome.32429847
D’Amico DJ, Masonson HN, Patel M, . Pegaptanib sodium for neovascular age-related macular degeneration: two-year safety results of the two prospective, multicenter, controlled clinical trials. Ophthalmology. 2006;113(6):992–1001.e6. doi: 10.1016/j.ophtha.2006.02.027. PMID: 16647134. Excluded for wrong intervention.16647134
Dalvin LA, Starr MR, AbouChehade JE, . Association of intravitreal anti-vascular endothelial growth factor therapy with risk of stroke, myocardial infarction, and death in patients with exudative age-related macular degeneration. JAMA Ophthalmol. 2019;137(5):483–90. doi: 10.1001/jamaophthalmol.2018.6891. PMID: 30703203. Excluded for wrong study design for key question.30703203
Danyliv A, Glanville J, McCool R, . The clinical effectiveness of ranibizumab treat and extend regimen in nAMD: systematic review and network meta-analysis. Adv Ther. 2017;34(3):611–9. doi: 10.1007/s12325-017-0484-0. PMID: 28188433. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.28188433
Dapp U, Anders JA, von Renteln-Kruse W, . A randomized trial of effects of health risk appraisal combined with group sessions or home visits on preventive behaviors in older adults. J Gerontol A Biol Sci Med Sci. 2011;66(5):591–8. doi: 10.1093/gerona/glr021. PMID: 21350242. Excluded for wrong outcome.21350242
Duchin KS, Asefzadeh B, Poulaki V, . Teleretinal imaging for detection of referable macular degeneration. Optom Vis Sci. 2015;92(6):714–8. doi: 10.1097/opx.0000000000000598. PMID: 25955641. Excluded for wrong screener.25955641
Dugel PU, Jaffe GJ, Sallstig P, . Brolucizumab versus aflibercept in participants with neovascular age-related macular degeneration: a randomized trial. Ophthalmology. 2017;124(9):1296–304. doi: 10.1016/j.ophtha.2017.03.057. PMID: 28551167. Excluded for wrong comparator.28551167
Dugel PU, Koh A, Ogura Y, . HAWK and HARRIER: phase 3, multicenter, randomized, double-masked trials of brolucizumab for neovascular age-related macular degeneration. Ophthalmology. 2020;127(1):72–84. doi: 10.1016/j.ophtha.2019.04.017. PMID: 30986442. Excluded for wrong comparator.30986442
Dugel PU, Singh N, Francom S, . The systemic safety of ranibizumab in patients 85 years and older with neovascular age-related macular degeneration. Ophthalmol Retina. 2018;2(7):667–75. doi: 10.1016/j.oret.2018.01.010. PMID: 31047375. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.31047375
Eckstrom E, Parker EM, Lambert GH, . Implementing STEADI in academic primary care to address older adult fall risk. Innov Aging. 2017;1(2):igx028. doi: 10.1093/geroni/igx028. PMID: 29955671. Excluded for wrong outcome.29955671
Eldem BM, Muftuoglu G, Topbas S, . A randomized trial to compare the safety and efficacy of two ranibizumab dosing regimens in a Turkish cohort of patients with choroidal neovascularization secondary to AMD. Acta Ophthalmol. 2015;93(6):e458–64. doi: 10.1111/aos.12540. PMID: 25160859. Excluded for wrong comparator.25160859
Elshout JA, Bergsma DP, Sibbel J, . Improvement in activities of daily living after visual training in patients with homonymous visual field defects using goal attainment scaling. Restor Neurol Neurosci. 2018;36(1):1–12. PMID: 29439358. Excluded for wrong population.29439358
Enseleit F, Michels S, Sudano I, . SAVE-AMD: safety of VEGF inhibitors in age-related macular degeneration. Ophthalmologica. 2017;238(4):205–16. doi: 10.1159/000478665. PMID: 28866675. Excluded for wrong comparator.28866675
Erden B, Bolukbasi S, Ozkaya A, . Comparison of two different treatment regimens’ efficacy in neovascular age-related macular degeneration in Turkish population-based on real life data-Bosphorus RWE Study Group. Int J Ophthalmol. 2020;13(1):104–11. doi: 10.18240/ijo.2020.01.15. PMID: 31956577. Excluded for wrong study design for key question.31956577
Evans J. Antioxidant supplements to prevent or slow down the progression of AMD: a systematic review and meta-analysis. Eye (Lond). 2008;22(6):751–60. doi: 10.1038/eye.2008.100. PMID: 18425071. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.18425071
Evans JR. Ginkgo biloba extract for age-related macular degeneration. Cochrane Database Syst Rev. 2013 (1). Excluded for wrong intervention.
Evans JR, Henshaw KS. Antioxidant vitamin and mineral supplements for slowing the progression of age-related macular degeneration. Cochrane Database Syst Rev. 2008;Issue 1. Art. No.: CD000253. DOI: 10.1002/14651858.CD0000253.pub2. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.18253971
Evans JR, Igwe C, Jackson TL, . Radiotherapy for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2020;8:CD004004. doi: 10.1002/14651858.CD004004.pub4. PMID: 32844399. Excluded for wrong intervention.32844399
Evans JR, Lawrenson JG. Antioxidant vitamin and mineral supplements for slowing the progression of age-related macular degeneration. Cochrane Database Syst Rev. 2012;11. Art. No.: CD000254. DOI: 10.1002/14651858.CD000254.pub3:CD000254. doi: 10.1002/14651858.CD000254.pub3. PMID: 23152201. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.23152201
Evans JR, Lawrenson JG. Antioxidant vitamin and mineral supplements for preventing age-related macular degeneration. Cochrane Database Syst Rev. 2017;7:Cd000253. doi: 10.1002/14651858.CD000253.pub4. PMID: 28756617. Excluded for wrong outcome.28756617
Evans JR, Virgili G, Gordon I, . Interventions for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2016 (10). Excluded for not a study.
Evans RN, Reeves BC, Phillips D, . Long-term visual outcomes after release from protocol in patients who participated in the inhibition of VEGF in age-related choroidal neovascularisation (IVAN) trial. Ophthalmology. 2020;127(9):1191–200. doi: 10.1016/j.ophtha.2020.03.020. PMID: 32359843. Excluded for wrong comparator.32359843
Faes L, Bodmer NS, Bachmann LM, . Diagnostic accuracy of the Amsler grid and the preferential hyperacuity perimetry in the screening of patients with age-related macular degeneration: systematic review and meta-analysis. Eye. 2014;28(7):788–96. doi: 10.1038/eye.2014.104. PMID: 24788016. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.24788016
Faes L, Bodmer NS, Locher S, . Test performance of optical coherence tomography angiography in detecting retinal diseases: a systematic review and meta-analysis. Eye. 2019;33(8):1327–38. doi: 10.1038/s41433-019-0421-3. PMID: 30971815. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.30971815
Feeny AK, Tadarati M, Freund DE, . Automated segmentation of geographic atrophy of the retinal epithelium via random forests in AREDS color fundus images. Comput Biol Med. 2015;65:124–36. doi: 10.1016/j.compbiomed.2015.06.018. PMID: 26318113. Excluded for ancillary publication not relevant to current systematic review.26318113
Ferreira GA, Rezende MA, Meneghim R, . Barriers between community screening for visual problems and treatments in a tertiary center. Rev Saude Publica. 2018;52:85. doi: 10.11606/S1518-8787.2018052000589. PMID: 30517520. Excluded for wrong setting.30517520
Forte R, Panzella L, Cesarano I, . Epilutein for early-stage age-related macular degeneration: a randomized and prospective study. Ophthalmic Res. 2017;58(4):231–41. doi: 10.1159/000479930. PMID: 28957818. Excluded for wrong comparator.28957818
Fotis K, Siannis F, Chandra A. Optical coherence tomography angiography for monitoring the treatment of neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2019 (11). Excluded for not a study.
Framme C, Eter N, Hamacher T, . Aflibercept for patients with neovascular age-related macular degeneration in routine clinical practice in Germany: twelve-month outcomes of PERSEUS. Ophthalmol Retina. 2018;2(6):539–49. doi: 10.1016/j.oret.2017.09.017. PMID: 31047606. Excluded for wrong population.31047606
Frampton GK, Kalita N, Payne L, . Accuracy of fundus autofluorescence imaging for the diagnosis and monitoring of retinal conditions: a systematic review. Health Technol Assess. 2016;20(31):1–108. doi: 10.3310/hta20310. PMID: 27115052. Excluded for wrong outcome.27115052
Fredette MJ, Giguere A, Anderson DR, . Comparison of matrix with Humphrey Field Analyzer II with SITA. Optom Vis Sci. 2015;92(5):527–36. doi: 10.1097/OPX.0000000000000583. PMID: 25875683. Excluded for wrong study design for key question.25875683
Freund KB, Hoang QV, Saroj N, . Intraocular pressure in patients with neovascular age-related macular degeneration receiving intravitreal aflibercept or ranibizumab. Ophthalmology. 2015;122(9):1802–10. doi: 10.1016/j.ophtha.2015.04.018. PMID: 26025097. Excluded for wrong comparator.26025097
Garrett SK, McNeil JJ, Silagy C, . Methodology of the VECAT study: vitamin E intervention in cataract and age-related maculopathy. Ophthalmic Epidemiol. 1999;6(3):195–208. Excluded for study covered in an included systematic review.10487974
Ge Z, Li L, Lohfeld L, . Validity and feasibility of a self-administered home vision examination in Yueqing, China: a cross-sectional study. BMJ Open. 2020;10(4):e030956. doi: 10.1136/bmjopen-2019-030956. PMID: 32303511. Excluded for wrong setting.32303511
Gehlbach P, Li T, Hatef E. Statins for age-related macular degeneration. Cochrane Database Syst Rev. 2016 (8) PMID: 27490232. Excluded for wrong intervention.27490232
Gerding H. Long-term results of intravitreal anti-VEGF injections in wet AMD: a meta-analysis. Klin Monatsbl Augenheilkd. 2016;233(4):471–4. doi: 10.1055/s-0041-111835. PMID: 27116511. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.27116511
Gharbiya M, Giustolisi R, Marchiori J, . Comparison of short-term choroidal thickness and retinal morphological changes after intravitreal anti-VEGF therapy with ranibizumab or aflibercept in treatment-naive eyes. Curr Eye Res. 2018;43(3):391–6. doi: 10.1080/02713683.2017.1405045. PMID: 29166140. Excluded for wrong outcome.29166140
Gillies MC, Campain A, Barthelmes D, . Long-term outcomes of treatment of neovascular age-related macular degeneration: data from an observational study. Ophthalmology. 2015;122(9):1837–45. doi: 10.1016/j.ophtha.2015.05.010. PMID: 26096346. Excluded for wrong study design for key question.26096346
Gillies MC, Nguyen V, Daien V, . Twelve-month outcomes of ranibizumab vs. aflibercept for neovascular age-related macular degeneration: data from an observational study. Ophthalmology. 2016;123(12):2545–53. doi: 10.1016/j.ophtha.2016.08.016. PMID: 27707549. Excluded for wrong study design for key question.27707549
Gong J, Yu S, Gong Y, . The diagnostic accuracy of optical coherence tomography angiography for neovascular age-related macular degeneration: a comparison with fundus fluorescein angiography. J Ophthalmol. 2016;2016:7521478. doi: 10.1155/2016/7521478. PMID: 27110394. Excluded for wrong country.27110394
Gonzalez-Gonzalo C, Sanchez-Gutierrez V, Hernandez-Martinez P, . Evaluation of a deep learning system for the joint automated detection of diabetic retinopathy and age-related macular degeneration. Acta Ophthalmol. 2020;98(4):368–77. doi: 10.1111/aos.14306. PMID: 31773912. Excluded for wrong intervention.31773912
Gower EW, Silverman E, Cassard SD, . Barriers to attending an eye examination after vision screening referral within a vulnerable population. J Health Care Poor Underserved. 2013;24(3):1042–52. Excluded for wrong study design for key question.23974379
Grassmann F, Mengelkamp J, Brandl C, . A deep learning algorithm for prediction of age-related eye disease study severity scale for age-related macular degeneration from color fundus photography. Ophthalmology. 2018;125(9):1410–20. doi: 10.1016/j.ophtha.2018.02.037. PMID: 29653860. Excluded for wrong intervention.29653860
Gualino V, Tadayoni R, Cohen SY, . Optical coherence tomography, fluorescein angiography, and diagnosis of choroidal neovascularization in age-related macular degeneration. Retina. 2019;39(9):1664–71. doi: 10.1097/IAE.0000000000002220. PMID: 30045134. Excluded for wrong population.30045134
Gupta SC, Sinha SK, Dagar AB. Evaluation of the effectiveness of diagnostic & management decision by teleophthalmology using indigenous equipment in comparison with in-clinic assessment of patients. Indian J Med Res. 2013;138(4):531–5. PMID: 24434260. Excluded for wrong screener.24434260
Guymer RH, Baird PN, Varsamidis M, . Proof of concept, randomized, placebo-controlled study of the effect of simvastatin on the course of age-related macular degeneration. PLoS One. 2013;8(12):e83759. doi: 10.1371/journal.pone.0083759. PMID: 24391822. Excluded for wrong intervention.24391822
Haanes GG, Kirkevold M, Hofoss D, . Discrepancy between self-assessments and standardised tests of vision and hearing abilities in older people living at home: an ROC curve analysis. J Clin Nurs. 2015;24(23–24):3380–8. doi: 10.1111/jocn.12967. PMID: 26335133. Excluded for wrong outcome.26335133
Haanes GG, Kirkevold M, Hofoss D, . An intervention designed to improve sensory impairments in the elderly and indoor lighting in their homes: an exploratory randomized controlled trial. J Multidiscip Healthc. 2015;8:11–20. doi: 10.2147/jmdh.S71718. PMID: 25678795. Excluded for wrong setting.25678795
Hadziahmetovic M, Nicholas P, Jindal S, . Evaluation of a remote diagnosis imaging model vs dilated eye examination in referable macular degeneration. JAMA Ophthalmol. 2019;137(7):802–8. doi: 10.1001/jamaophthalmol.2019.1203. PMID: 31095245. Excluded for wrong screener.31095245
Hanhart J, Comaneshter DS, Vinker S. Mortality after a cerebrovascular event in age-related macular degeneration patients treated with bevacizumab ocular injections. Acta Ophthalmol. 2018;96(6):e732–e9. doi: 10.1111/aos.13731. PMID: 29660843. Excluded for wrong study design for key question.29660843
Harari D, Iliffe S, Kharicha K, . Promotion of health in older people: a randomised controlled trial of health risk appraisal in British general practice. Age Ageing. 2008;37(5):565–71. doi: 10.1093/ageing/afn150. PMID: 18755784. Excluded for wrong outcome.18755784
Hark LA, Adeghate J, Katz LJ, . Philadelphia telemedicine glaucoma detection and follow-up study: cataract classifications following eye screening. Telemed J E Health. 2020;26(8):992–1000. doi: 10.1089/tmj.2019.0170. PMID: 31721654. Excluded for wrong screener.31721654
Hark LA, Myers JS, Rahmatnejad K, . Philadelphia telemedicine glaucoma detection and follow-up study: analysis of unreadable fundus images. J Glaucoma. 2018;27(11):999–1008. doi: 10.1097/IJG.0000000000001082. PMID: 30180021. Excluded for wrong intervention.30180021
Heinemann M, Welker SG, Li JQ, . Impact of visual impairment on physical activity in early and late age-related macular degeneration. PLoS One. 2019;14(10):e0222045. doi: 10.1371/journal.pone.0222045. PMID: 31634374. Excluded for wrong study design for key question.31634374
Holz F, Wolfensberger T, Piguet B, . Oral zinc-therapy in age-related macular degeneration: a double-blind study (abstract). Germ J Ophthalmol. 1993;2:391. Excluded for wrong publication type.
Holz FG, Dugel PU, Weissgerber G, . Single-chain antibody fragment VEGF inhibitor RTH258 for neovascular age-related macular degeneration: a randomized controlled study. Ophthalmology. 2016;123(5):1080–9. doi: 10.1016/j.ophtha.2015.12.030. PMID: 26906165. Excluded for wrong comparator.26906165
Huang YM, Dou HL, Huang FF, . Effect of supplemental lutein and zeaxanthin on serum, macular pigmentation, and visual performance in patients with early age-related macular degeneration. Biomed Res Int. 2015;2015(564738) PMID: 25815324. Excluded for study covered in an included systematic review.25815324
Huang YM, Dou HL, Huang FF, . Changes following supplementation with lutein and zeaxanthin in retinal function in eyes with early age-related macular degeneration: a randomised, double-blind, placebo-controlled trial. Br J Ophthalmol. 2015;99(3):371–5. doi: 10.1136/bjophthalmol-2014-305503. PMID: 25228440. Excluded for wrong outcome.25228440
Huang YM, Yan SF, Ma L, . Serum and macular responses to multiple xanthophyll supplements in patients with early age-related macular degeneration. Nutrition. 2013;29(2):387–92. doi: 10.1016/j.nut.2012.06.009. PMID: 23312760. Excluded for study covered in an included systematic review.23312760
Jaffe GJ, Kaiser PK, Thompson D, . Differential response to anti-VEGF regimens in age-related macular degeneration patients with early persistent retinal fluid. Ophthalmology. 2016;123(9):1856–64. doi: 10.1016/j.ophtha.2016.05.016. PMID: 27369111. Excluded for wrong study design for key question.27369111
Javitt JC, Zhou Z, Willke RJ. Association between vision loss and higher medical care costs in Medicare beneficiaries costs are greater for those with progressive vision loss. Ophthalmology. 2007;114(2):238–45. doi: 10.1016/j.ophtha.2006.07.054. PMID: 17270673. Excluded for wrong study design for key question.17270673
Jelin E, Wisloff T, Jorstad OK, . Patient-reported outcome measures in the management of neovascular age-related macular degeneration: a 1-year prospective study. BMJ Open Ophthalmol. 2019;4(1):e000353. doi: 10.1136/bmjophth-2019-000353. PMID: 31673632. Excluded for wrong intervention.31673632
Jensen H, Tubaek G. Elderly people need an eye examination before entering nursing homes. Dan Med J. 2017;64(2) PMID: 28157061. Excluded for wrong setting.28157061
Jolly JK, Gray JM, Salvetti AP, . A randomized crossover study to assess the usability of two new vision tests in patients with low vision. Optom Vis Sci. 2019;96(6):443–52. doi: 10.1097/OPX.0000000000001380. PMID: 31058709. Excluded for wrong population.31058709
Kahn HA, Moorhead HB. Statistics on blindness in the model reporting area 1969-1970. 1973. Excluded for not a study.
Kaiser PK, Singer M, Tolentino M, . Long-term safety and visual outcome of intravitreal aflibercept in neovascular age-related macular degeneration: VIEW 1 Extension Study. Ophthalmol Retina. 2017;1(4):304–13. doi: 10.1016/j.oret.2017.01.004. PMID: 31047516. Excluded for wrong intervention.31047516
Katibeh M, Sabbaghi H, Kalantarion M, . Eye care utilization in a community-oriented mobile screening programme for improving eye health in Iran: a cluster randomized trial. Ophthalmic Epidemiol. 2020:1–12. doi: 10.1080/09286586.2020.1768552. PMID: 32449414. Excluded for wrong outcome.32449414
Kawaguchi A, Sharafeldin N, Sundaram A, . Tele-Ophthalmology for age-related macular degeneration and diabetic retinopathy screening: a systematic review and meta-analysis. Telemed J E Health. 2018;24(4):301–8. doi: 10.1089/tmj.2017.0100. PMID: 28783458. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.28783458
Keane PA, Heussen FM, Ouyang Y, . Assessment of differential pharmacodynamic effects using optical coherence tomography in neovascular age-related macular degeneration. Invest Ophthalmol Vis Sci. 2012;53(3):1152–61. doi: 10.1167/iovs.11-8130. PMID: 22281826. Excluded for wrong outcome.22281826
Keel S, Li Z, Scheetz J, . Development and validation of a deep-learning algorithm for the detection of neovascular age-related macular degeneration from colour fundus photographs. Clin Experiment Ophthalmol. 2019;47(8):1009–18. doi: 10.1111/ceo.13575. PMID: 31215760. Excluded for wrong intervention.31215760
Keenan TD, Agron E, Mares J, . Adherence to the Mediterranean diet and progression to late age-related macular degeneration in the Age-Related Eye Disease Studies 1 and 2. Ophthalmology. 2020;127(11):1515–28. doi: 10.1016/j.ophtha.2020.04.030. PMID: 32348832. Excluded for ancillary publication not relevant to current systematic review.32348832
Keenan TD, Agron E, Mares JA, . Adherence to a mediterranean diet and cognitive function in the age-related eye disease studies 1 & 2. Alzheimers Dement. 2020;16(6):831–42. doi: 10.1002/alz.12077. PMID: 32285590. Excluded for ancillary publication not relevant to current systematic review.32285590
Keenan TD, Dharssi S, Peng Y, . A deep learning approach for automated detection of geographic atrophy from color fundus photographs. Ophthalmology. 2019;126(11):1533–40. doi: 10.1016/j.ophtha.2019.06.005. PMID: 31358385. Excluded for wrong intervention.31358385
Khalid S, Akram MU, Hassan T, . Automated segmentation and quantification of drusen in fundus and optical coherence tomography images for detection of ARMD. J Digit Imaging. 2018;31(4):464–76. doi: 10.1007/s10278-017-0038-7. PMID: 29204763. Excluded for wrong intervention.29204763
Khalid S, Akram MU, Hassan T, . Fully automated robust system to detect retinal edema, central serous chorioretinopathy, and age related macular degeneration from optical coherence tomography images. Biomed Res Int. 2017;2017:7148245. doi: 10.1155/2017/7148245. PMID: 28424788. Excluded for wrong intervention.28424788
Khurana RN, Rahimy E, Joseph WA, . Extended (every 12 weeks or longer) dosing interval with intravitreal aflibercept and ranibizumab in neovascular age-related macular degeneration: post hoc analysis of VIEW trials. Am J Ophthalmol. 2019;200:161–8. doi: 10.1016/j.ajo.2019.01.005. PMID: 30664844. Excluded for wrong study design for key question.30664844
Kim BJ, Hunter A, Brucker AJ, . Orally administered alpha lipoic acid as a treatment for geographic atrophy: a randomized clinical trial. Ophthalmol Retina. 2020;4(9):889–98. doi: 10.1016/j.oret.2020.03.019. PMID: 32418846. Excluded for wrong population.32418846
Kim JH, Lee DW, Chang YS, . Twelve-month outcomes of treatment using ranibizumab or aflibercept for neovascular age-related macular degeneration: a comparative study. Graefes Arch Clin Exp Ophthalmol. 2016;254(11):2101–9. PMID: 27230919. Excluded for wrong study design for key question.27230919
Kim LN, Mehta H, Barthelmes D, . Metaanalysis of real-world outcomes of intravitreal ranibizumab for the treatment of neovascular age-related macular degeneration. Retina. 2016;36(8):1418–31. doi: 10.1097/IAE.0000000000001142. PMID: 27388744. Excluded for wrong study design for key question.27388744
Kim YJ, Kim KG. Automated segmentation methods of drusen to diagnose age-related macular degeneration screening in retinal images. Comput Math Methods Med. 2018 doi: 10.1155/2018/6084798. PMID: 29721037. Excluded for wrong intervention.29721037
Kodjikian L, Decullier E, Souied EH, . Predictors of one-year visual outcomes after anti-vascular endothelial growth factor treatment for neovascular age-related macular degeneration. Retina. 2018;38(8):1492–9. doi: 10.1097/IAE.0000000000001736. PMID: 28654629. Excluded for wrong study design for key question.28654629
Lai Y, Grattan J, Shi Y, . Functional and morphologic benefits in early detection of neovascular age-related macular degeneration using the preferential hyperacuity perimeter. Retina. 2011;31(8):1620–6. doi: 10.1097/IAE.0b013e31820d3ed1. PMID: 21610564. Excluded for study covered in an included systematic review.21610564
Lanzetta P, Cruess AF, Cohen SY, . Predictors of visual outcomes in patients with neovascular age-related macular degeneration treated with anti-vascular endothelial growth factor therapy: post hoc analysis of the VIEW studies. Acta Ophthalmol. 2018;96(8):e911–e8. doi: 10.1111/aos.13751. PMID: 29659183. Excluded for wrong study design for key question.29659183
Lawrenson JG, Evans JR. Omega 3 fatty acids for preventing or slowing the progression of age-related macular degeneration. Cochrane Database Syst Rev. 2015 (4) PMID: 25856365. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.25856365
Lee CS, Baughman DM, Lee AY. Deep learning is effective for the classification of OCT images of normal versus age-related macular degeneration. Ophthalmol Retina. 2017;1(4):322–7. doi: 10.1016/j.oret.2016.12.009. PMID: 30693348. Excluded for wrong intervention.30693348
Lee H, Kang KE, Chung H, . Automated segmentation of lesions including subretinal hyperreflective material in neovascular age-related macular degeneration. Am J Ophthalmol. 2018;191:64–75. doi: 10.1016/j.ajo.2018.04.007. PMID: 29655643. Excluded for wrong intervention.29655643
Levine ES, Custo Greig E, Mendonca LSM, . The long-term effects of anti-vascular endothelial growth factor therapy on the optical coherence tomography angiographic appearance of neovascularization in age-related macular degeneration. Int J Retina Vitreous. 2020;6:39. doi: 10.1186/s40942-020-00242-z. PMID: 32844038. Excluded for wrong study design for key question.32844038
Leys A, Zlateva G, Shah SN, . Quality of life in patients with age-related macular degeneration: results from the VISION study. Eye (Lond). 2008;22(6):792–8. doi: 10.1038/sj.eye.6702900. PMID: 17585313. Excluded for wrong intervention.17585313
Li B, Powell AM, Hooper PL, . Prospective evaluation of teleophthalmology in screening and recurrence monitoring of neovascular age-related macular degeneration: a randomized clinical trial. JAMA Ophthalmol. 2015;133(3):276–82. doi: 10.1001/jamaophthalmol.2014.5014. PMID: 25473945. Excluded for wrong screener.25473945
Li E, Donati S, Lindsley KB, . Treatment regimens for administration of anti-vascular endothelial growth factor agents for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2020;5:CD012208. doi: 10.1002/14651858.CD012208.pub2. PMID: 32374423. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.32374423
Li S, Liu N, Lin L, . Macular pigment and serum zeaxanthin levels with Goji berry supplement in early age-related macular degeneration. Int J Ophthalmol. 2018;11(6):970–5. doi: 10.18240/ijo.2018.06.12. PMID: 29977809. Excluded for wrong intervention.29977809
Lonn E, Bosch J, Yusuf S, . Effects of long-term vitamin E supplementation on cardiovascular events and cancer: a randomized controlled trial. JAMA. 2005;293:1338–47. Excluded for wrong population.15769967
Lord SR, Tiedemann A, Chapman K, . The effect of an individualized fall prevention program on fall risk and falls in older people: a randomized, controlled trial. J Am Geriatr Soc. 2005;53(8):1296–304. doi: 10.1111/j.1532-5415.2005.53425.x. PMID: 16078954. Excluded for wrong intervention.16078954
Lotfy A, Solaiman KAM, Abdelrahman A, . Efficacy and frequency of intravitreal aflibercept versus bevacizumab for macular edema secondary to central retinal vein occlusion. Retina. 2018;38(9):1795–800. doi: 10.1097/IAE.0000000000001782. PMID: 28767552. Excluded for wrong population.28767552
Lott LA, Schneck ME, Haegerstrom-Portnoy G, . Simple vision function tests that distinguish eyes with early to intermediate age-related macular degeneration. Ophthalmic Epidemiol. 2020:1–12. doi: 10.1080/09286586.2020.1793371. PMID: 32781860. Excluded for results not usable or not fully reported.32781860
Lu W, Tong Y, Yu Y, . Applications of artificial intelligence in ophthalmology: general overview. J Ophthalmol. 2018;2018doi: 10.1155/2018/5278196. Excluded for wrong intervention.
Ly A, Nivison-Smith L, Assaad N, . Multispectral pattern recognition reveals a diversity of clinical signs in intermediate age-related macular degeneration. Invest Ophthalmol Vis Sci. 2018;59(5):1790–9. doi: 10.1167/iovs.17-23076. PMID: 29610844. Excluded for wrong study design for key question.29610844
Ly A, Nivison-Smith L, Hennessy MP, . Collaborative care of non-urgent macular disease: a study of inter-optometric referrals. Ophthalmic Physiol Opt. 2016;36(6):632–42. doi: 10.1111/opo.12322. PMID: 27790767. Excluded for wrong population.27790767
Ma L, Dou HL, Huang YM, . Improvement of retinal function in early age-related macular degeneration after lutein and zeaxanthin supplementation: a randomized, double-masked, placebo-controlled trial. Am J Ophthalmol. 2012;154(4):625–34.e1. doi: 10.1016/j.ajo.2012.04.014. PMID: 22835510. Excluded for study covered in an included systematic review.22835510
Maa AY, Evans C, DeLaune WR, . A novel tele-eye protocol for ocular disease detection and access to eye care services. Telemed J E Health. 2014;20(4):318–23. doi: 10.1089/tmj.2013.0185. PMID: 24527668. Excluded for wrong screener.24527668
Maa AY, McCord S, Lu X, . The impact of OCT on diagnostic accuracy of the technology-based eye care services protocol: Part II of the Technology-Based Eye Care Services Compare Trial. Ophthalmology. 2020;127(4):544–9. doi: 10.1016/j.ophtha.2019.10.025. PMID: 31791664. Excluded for wrong screener.31791664
Maa AY, Medert CM, Lu X, . Diagnostic accuracy of technology-based eye care services: The Technology-Based Eye Care Services Compare Trial Part I. Ophthalmology. 2020;127(1):38–44. doi: 10.1016/j.ophtha.2019.07.026. PMID: 31522900. Excluded for wrong screener.31522900
Maa AY, Patel S, Chasan JE, . Retrospective evaluation of a teleretinal screening program in detecting multiple nondiabetic eye diseases. Telemed J E Health. 2017;23(1):41–8. doi: 10.1089/tmj.2016.0039. PMID: 27310867. Excluded for wrong screener.27310867
Maa AY, Wojciechowski B, Hunt KJ, . Early experience with Technology-Based Eye Care Services (TECS): a novel ophthalmologic telemedicine initiative. Ophthalmology. 2017;124(4):539–46. doi: 10.1016/j.ophtha.2016.11.037. PMID: 28081944. Excluded for wrong screener.28081944
Mantel I, Gianniou C, Dirani A. Conversion to aflibercept therapy versus continuing with ranibizumab therapy for neovascular age-related macular degeneration dependent on monthly ranibizumab treatment. Retina. 2016;36(1):53–8. doi: 10.1097/IAE.0000000000000664. PMID: 26166797. Excluded for wrong study design for key question.26166797
Maruyama-Inoue M, Kitajima Y, Mohamed S, . Sensitivity and specificity of high-resolution wide field fundus imaging for detecting neovascular age-related macular degeneration. PLoS One. 2020;15(8):e0238072. doi: 10.1371/journal.pone.0238072. PMID: 32822418. Excluded for wrong intervention.32822418
Mathew MC, Ervin AM, Tao J, . Antioxidant vitamin supplementation for preventing and slowing the progression of age-related cataract. Cochrane Database Syst Rev. 2012 (6):CD004567. doi: 10.1002/14651858.CD004567.pub2. PMID: 22696344. Excluded for wrong intervention.22696344
Matsuba S, Tabuchi H, Ohsugi H, . Accuracy of ultra-wide-field fundus ophthalmoscopy-assisted deep learning, a machine-learning technology, for detecting age-related macular degeneration. Int Ophthalmol. 2019;39(6):1269–75. doi: 10.1007/s10792-018-0940-0. PMID: 29744763. Excluded for wrong intervention.29744763
McCafferty S, Tetrault K, McColgin A, . Intraocular pressure measurement accuracy and repeatability of a modified goldmann prism: multicenter randomized clinical trial. Am J Ophthalmol. 2018;196:145–53. PMID: 30195894. Excluded for wrong population.30195894
McEwan RT, Davison N, Forster DP, . Screening elderly people in primary care: a randomized controlled trial. Br J Gen Pract. 1990;40(332):94–7. PMID: 2112022. Excluded for wrong setting.2112022
McKibbin M, Baker L, Baxter P, . The accuracy of home monitoring to detect disease activity during maintenance therapy for neovascular ARMD. Graefes Arch Clin Exp Ophthalmol. 2015;253(9):1479–83. doi: 10.1007/s00417-014-2839-4. PMID: 25367832. Excluded for wrong population.25367832
Michalska-Malecka K, Kaluzny J, Nowak M, . Evaluation of retinal function improvement in neovascular age-related macular degeneration after intravitreal aflibercept injections with the use of the assessment of retinal sensitivity: the use of the assessment of retinal sensitivity in anti-VEGF treatment - a STROBE-compliant observational study. Medicine. 2019;98(44):e17599. doi: 10.1097/MD.0000000000017599. PMID: 31689763. Excluded for wrong comparator.31689763
Midena E, Frizziero L, Torresin T, . Optical coherence tomography and color fundus photography in the screening of age-related macular degeneration: a comparative, population-based study. PLoS One. 2020;15(8):e0237352. doi: 10.1371/journal.pone.0237352. PMID: 32797085. Excluded for wrong intervention.32797085
Moja L, Lucenteforte E, Kwag KH, . Systemic safety of bevacizumab versus ranibizumab for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2014 (9):CD011230. doi: 10.1002/14651858.CD011230.pub2. PMID: 25220133. Excluded for wrong comparator.25220133
Molina-Torres MJ, Crespo MS, Frances AT, . Diagnosis accuracy of two vision screeners for visual health surveillance of workers who use video display terminals. J Occup Health. 2016;58(5):444–51. PMID: 27488039. Excluded for wrong population.27488039
Mookiah MR, Acharya UR, Fujita H, . Local configuration pattern features for age-related macular degeneration characterization and classification. Comput Biol Med. 2015;63:208–18. doi: 10.1016/j.compbiomed.2015.05.019. PMID: 26093788. Excluded for wrong intervention.26093788
Morales S, Engan K, Naranjo V, . Retinal disease screening through local binary patterns. IEEE J Biomed Health Inform. 2017;21(1):184–92. doi: 10.1109/JBHI.2015.2490798. PMID: 26469792. Excluded for wrong intervention.26469792
Moshfeghi DM, Hariprasad SM, Marx JL, . Effect of fluid status at week 12 on visual and anatomic outcomes at week 52 in the VIEW 1 and 2 trials. Ophthalmic Surg Lasers Imaging Retina. 2016;47(3):238–44. doi: 10.3928/23258160-20160229-06. PMID: 26985797. Excluded for wrong study design for key question.26985797
Moshfeghi DM, Thompson D, Saroj N. Changes in neovascular activity following fixed dosing with an anti-vascular endothelial growth factor agent over 52 weeks in the phase III VIEW 1 and VIEW 2 studies. Br J Ophthalmol. 2020;104(9):1223–7. doi: 10.1136/bjophthalmol-2019-315021. PMID: 31826853. Excluded for wrong comparator.31826853
Motohashi R, Noma H, Yasuda K, . Dynamics of inflammatory factors in aqueous humor during ranibizumab or aflibercept treatment for age-related macular degeneration. Ophthalmic Res. 2017;58(4):209–16. doi: 10.1159/000478705. PMID: 28796997. Excluded for wrong outcome.28796997
Newbury JW, Marley JE, Beilby JJ. A randomised controlled trial of the outcome of health assessment of people aged 75 years and over. Med J Aust. 2001;175(2):104–7. PMID: 11556409. Excluded for wrong intervention.11556409
Ng WY, Tan GS, Ong PG, . Incidence of myocardial infarction, stroke, and death in patients with age-related macular degeneration treated with intravitreal anti-vascular endothelial growth factor therapy. Am J Ophthalmol. 2015;159(3):557–64.e1. doi: 10.1016/j.ajo.2014.12.005. PMID: 25497143. Excluded for wrong study design for key question.25497143
Nittala MG, Velaga SB, Hariri A, . Retinal sensitivity using microperimetry in age-related macular degeneration in an Amish population. Ophthalmic Surg Lasers Imaging Retina. 2019;50(9):e236–e41. doi: 10.3928/23258160-20190905-15. PMID: 31589764. Excluded for wrong outcome.31589764
Nixon DR, Flinn NA. Evaluation of contrast sensitivity and other visual function outcomes in neovascular age-related macular degeneration patients after treatment switch to aflibercept from ranibizumab. Clin Ophthalmol. 2017;11:715–21. doi: 10.2147/OPTH.S131343. PMID: 28458510. Excluded for wrong comparator.28458510
Ogbuehi KC, Almaliki WH, AlQarni A, . Reliability and reproducibility of a handheld videorefractor. Optom Vis Sci. 2015;92(5):632–41. doi: 10.1097/OPX.0000000000000566. PMID: 25822015. Excluded for wrong study design for key question.25822015
Ogura Y, Terasaki H, Gomi F, . Efficacy and safety of intravitreal aflibercept injection in wet age-related macular degeneration: outcomes in the Japanese subgroup of the VIEW 2 study. Br J Ophthalmol. 2015;99(1):92–7. doi: 10.1136/bjophthalmol-2014-305076. PMID: 25107900. Excluded for wrong population.25107900
Ohji M, Lanzetta P, Korobelnik JF, . Efficacy and treatment burden of iIntravitreal aflibercept versus intravitreal ranibizumab treat-and-extend regimens at 2 years: network meta-analysis incorporating individual patient data meta-regression and matching-adjusted indirect comparison. Adv Ther. 2020;37(5):2184–98. doi: 10.1007/s12325-020-01298-x. PMID: 32222903. Excluded for wrong study design for key question.32222903
Okada M, Mitchell P, Finger RP, . Non-adherence or non-persistence to intravitreal injection therapy for neovascular age-related macular degeneration: a mixed-methods systematic review. Ophthalmology. 2021;128(2):234–7. doi: 10.1016/j.ophtha.2020.07.060. PMID: 32763265. Excluded for wrong outcome.32763265
Oliveira MA, Farinha C, Rodrigues TM, . Macular atrophy development in neovascular age-related macular degeneration during first year of treatment: incidence and risk factors. Eur J Ophthalmol. 2020:1120672120908718. doi: 10.1177/1120672120908718. PMID: 32103681. Excluded for wrong study design for key question.32103681
Olsen AS, la Cour M, Damato B, . Detection of visual field defects by opticians - with damato multifixation campimetry online. Acta Ophthalmol. 2019;97(6):577–82. doi: 10.1111/aos.14005. PMID: 30593721. Excluded for wrong study design for key question.30593721
Omenn GS, Goodman GE, Thornquist MD, . Effects of a combination of beta carotene and vitamin A on lung cancer and cardiovascular disease. N Engl J Med. 1996;334:1150–5. Excluded for wrong population.8602180
Oskarsdottir SE, Heijl A, Bengtsson B. Predicting undetected glaucoma according to age and IOP: a prediction model developed from a primarily European-derived population. Acta Ophthalmol. 2019;97(4):422–6. doi: 10.1111/aos.13941. PMID: 30324772. Excluded for wrong study design for key question.30324772
Otero C, Aldaba M, Pujol J. Clinical evaluation of an automated subjective refraction method implemented in a computer-controlled motorized phoropter. J Optom. 2019;12(2):74–83. doi: 10.1016/j.optom.2018.09.001. PMID: 30389250. Excluded for wrong study design for key question.30389250
Owsley C, McGwin G, Jr., Lee DJ, . Diabetes eye screening in urban settings serving minority populations: detection of diabetic retinopathy and other ocular findings using telemedicine. JAMA Ophthalmol. 2015;133(2):174–81. doi: 10.1001/jamaophthalmol.2014.4652. PMID: 25393129. Excluded for wrong population.25393129
Palkovits S, Seidel G, Pertl L, . Macular choroidal volume changes after intravitreal bevacizumab for exudative age-related macular degeneration. Retina. 2017;37(12):2262–8. doi: 10.1097/IAE.0000000000001480. PMID: 28129216. Excluded for wrong study design for key question.28129216
Parekh PK, Folk JC, Gupta P, . Fluorescein angiography does not alter the initial clinical management of choroidal neovascularization in age-related macular degeneration. Ophthalmol Retina. 2018;2(7):659–66. doi: 10.1016/j.oret.2018.01.002. PMID: 31047374. Excluded for wrong study design for key question.31047374
Parikh R, Avery RL, Saroj N, . Incidence of new choroidal neovascularization in fellow eyes of patients with age-related macular degeneration treated with intravitreal aflibercept or ranibizumab. JAMA Ophthalmol. 2019;137(8):914–20. doi: 10.1001/jamaophthalmol.2019.1947. PMID: 31294771. Excluded for wrong outcome.31294771
Parke DW, 2nd, Repka MX, Lum F. The US preventive services task force recommendation on vision screening in older adults: a narrow view. JAMA Ophthalmol. 2016;134(5):485–6. doi: 10.1001/jamaophthalmol.2016.0222. PMID: 26934146. Excluded for not a study.26934146
Pathipati AS, Wood EH, Lam CK, . Visual acuity measured with a smartphone app is more accurate than Snellen testing by emergency department providers. Graefes Arch Clin Exp Ophthalmol. 2016;254(6):1175–80. doi: 10.1007/s00417-016-3291-4. PMID: 26931323. Excluded for wrong intervention.26931323
Peng Y, Dharssi S, Chen Q, . DeepSeeNet: a deep learning model for automated classification of patient-based age-related macular degeneration severity from color fundus photographs. Ophthalmology. 2019;126(4):565–75. doi: 10.1016/j.ophtha.2018.11.015. PMID: 30471319. Excluded for wrong intervention.30471319
Peng Y, Keenan TD, Chen Q, . Predicting risk of late age-related macular degeneration using deep learning. NPJ Digit Med. 2020;3:111. doi: 10.1038/s41746-020-00317-z. PMID: 32904246. Excluded for wrong intervention.32904246
Pham B, Thomas SM, Lillie E, . Anti-vascular endothelial growth factor treatment for retinal conditions: a systematic review and meta-analysis. BMJ Open. 2019;9(5):e022031. doi: 10.1136/bmjopen-2018-022031. PMID: 31142516. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.31142516
Phan TV, Seoud L, Chakor H, . Automatic screening and grading of age-related macular degeneration from texture analysis of fundus images. J Ophthalmol. 2016;2016:5893601. doi: 10.1155/2016/5893601. PMID: 27190636. Excluded for wrong intervention.27190636
Pichi F, Elbarky AM, Elhamaky TR. Outcome of “treat and monitor” regimen of aflibercept and ranibizumab in macular edema secondary to non-ischemic branch retinal vein occlusion. Int Ophthalmol. 2019;39(1):145–53. doi: 10.1007/s10792-017-0798-6. PMID: 29274022. Excluded for wrong population.29274022
Pillay J, Freeman EE, Hodge W, . Screening for impaired visual acuity and vision-related functional limitations in adults 65 years and older in primary health care: systematic review. Edmonton, AB; Evidence Review Synthesis Centre. 2017. http://canadiantaskforce.ca/ctfphc-guidelines/overview/ Accessed May 8, 2020. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.
Pirbhai A, Sheidow T, Hooper P. Prospective evaluation of digital non-stereo color fundus photography as a screening tool in age-related macular degeneration. Am J Ophthalmol. 2005;139(3):455–61. doi: 10.1016/j.ajo.2004.09.077. PMID: 15767053. Excluded for wrong study design for key question.15767053
Pitrelli Vazquez N, Harding SP, Heimann H, . Radial shape discrimination testing for new-onset neovascular age-related macular degeneration in at-risk eyes. PLoS One. 2018;13(11):e0207342. doi: 10.1371/journal.pone.0207342. PMID: 30408127. Excluded for wrong study design for key question.30408127
Plyukhova AA, Budzinskaya MV, Starostin KM, . Comparative safety of bevacizumab, ranibizumab, and aflibercept for treatment of neovascular age-related macular degeneration (AMD): a systematic review and network meta-analysis of direct comparative studies. J Clin Med. 2020;18(9):1522. doi: 10.3390/jcm9051522. PMID: 32443612. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.32443612
Porwal P, Pachade S, Kokare M, . Retinal image analysis for disease screening through local tetra patterns. Comput Biol Med. 2018;102:200–10. doi: 10.1016/j.compbiomed.2018.09.028. PMID: 30308336. Excluded for wrong intervention.30308336
Prahs P, Radeck V, Mayer C, . OCT-based deep learning algorithm for the evaluation of treatment indication with anti-vascular endothelial growth factor medications. Graefes Arch Clin Exp Ophthalmol. 2018;256(1):91–8. doi: 10.1007/s00417-017-3839-y. PMID: 29127485. Excluded for wrong intervention.29127485
Querques L, Giuffre C, Corvi F, . Optical coherence tomography angiography of myopic choroidal neovascularisation. Br J Ophthalmol. 2017;101(5):609–15. doi: 10.1136/bjophthalmol-2016-309162. PMID: 27531357. Excluded for wrong study design for key question.27531357
Ra H, Song LD, Choi JA, . The cost-effectiveness of systematic screening for age-related macular degeneration in South Korea. PLoS One. 2018;13(10):e0206690. doi: 10.1371/journal.pone.0206690. PMID: 30379971. Excluded for wrong outcome.30379971
Reis GM, Grigg J, Chua B, . Incidence of intraocular pressure elevation following intravitreal ranibizumab (Lucentis) for age-related macular degeneration. J Curr Glaucoma Pract. 2017;11(1):3–7. doi: 10.5005/jp-journals-10008-1213. PMID: 28138211. Excluded for wrong study design for key question.28138211
Richard G, Mones J, Wolf S, . Scheduled versus pro re nata dosing in the VIEW trials. Ophthalmology. 2015;122(12):2497–503. doi: 10.1016/j.ophtha.2015.08.014. PMID: 26477840. Excluded for results not usable or not fully reported.26477840
Rodriguez-Vallejo M, Monsoriu JA, Furlan WD. Inter-display reproducibility of contrast sensitivity measurement with iPad. Optom Vis Sci. 2016;93(12):1532–6. PMID: 27560848. Excluded for wrong outcome.27560848
Rofagha S, Bhisitkul RB, Boyer DS, . Seven-year outcomes in ranibizumab-treated patients in ANCHOR, MARINA, and HORIZON: a multicenter cohort study (SEVEN-UP). Ophthalmology. 2013;120(11):2292–9. doi: 10.1016/j.ophtha.2013.03.046. PMID: 23642856. Excluded for study covered in an included systematic review.23642856
Rono H, Bastawrous A, Macleod D, . Smartphone-guided algorithms for use by community volunteers to screen and refer people with eye problems in Trans Nzoia County, Kenya: development and validation study. JMIR Mhealth Uhealth. 2020;8(6):e16345. doi: 10.2196/16345. PMID: 32558656. Excluded for wrong setting.32558656
Rowe FJ, Hepworth LR, Hanna KL, . Visual Impairment Screening Assessment (VISA) tool: pilot validation. BMJ Open. 2018;8(3):e020562. doi: 10.1136/bmjopen-2017-020562. PMID: 29511021. Excluded for wrong study design for key question.29511021
Sacu S, Michels S, Prager F, . Randomised clinical trial of intravitreal Avastin vs photodynamic therapy and intravitreal triamcinolone: long-term results. Eye (Lond). 2009;23(12):2223–7. doi: 10.1038/eye.2008.423. PMID: 19169239. Excluded for wrong comparator.19169239
Saha S, Nassisi M, Wang M, . Automated detection and classification of early AMD biomarkers using deep learning. Sci Rep. 2019;9(1):10990. doi: 10.1038/s41598-019-47390-3. PMID: 31358808. Excluded for wrong intervention.31358808
Sakamoto S, Takahashi H, Inoue Y, . Intravitreal aflibercept for exudative age-related macular degeneration with good visual acuity: 2-year results of a prospective study. Clin Ophthalmol. 2018;12:1137–47. doi: 10.2147/OPTH.S160961. PMID: 29970955. Excluded for wrong study design for key question.29970955
Salonen L, Kivela SL. Eye diseases and impaired vision as possible risk factors for recurrent falls in the aged: a systematic review. Curr Gerontol Geriatr Res. 2012;2012:271481. doi: 10.1155/2012/271481. PMID: 22927843. Excluded for wrong study design for key question.22927843
Santos AM, Paiva AC, Santos APM, . Semivariogram and semimadogram functions as descriptors for AMD diagnosis on SD-OCT topographic maps using support vector machine. Biomed Eng Online. 2018;17(1):160. doi: 10.1186/s12938-018-0592-3. PMID: 30352604. Excluded for wrong intervention.30352604
Sarwar S, Clearfield E, Soliman MK, . Aflibercept for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2016;2:CD011346. doi: 10.1002/14651858.CD011346.pub2. PMID: 26857947. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.26857947
Saxena N, George PP, Heng BH, . Cost-effectiveness of anti-oxidant vitamins plus zinc treatment to prevent the progression of intermediate age-related macular degeneration. A Singapore perspective. Indian J Ophthalmol. 2015;63(6):516–23. doi: 10.4103/0301-4738.158533. PMID: 26265643. Excluded for wrong study design for key question.26265643
Schauwvlieghe AM, Dijkman G, Hooymans JM, . Comparing the effectiveness of bevacizumab to ranibizumab in patients with exudative age-related macular degeneration. The BRAMD study. PLoS One. 2016;11(5):e0153052. doi: 10.1371/journal.pone.0153052. PMID: 27203434. Excluded for wrong comparator.27203434
Schmetterer L. Effects of lutein supplmentation on macular pigment optical density and visual acuity in patients with age-related macular degeneration. Eur J Ophthalmol. 2013;23(4):605. Excluded for wrong publication type.
Schmid MK, Faes L, Bachmann LM, . Accuracy of a self-monitoring test for identification and monitoring of age-related macular degeneration: a diagnostic case-control study. Open Ophthalmol J. 2018;12:19–28. doi: 10.2174/1874364101812010019. PMID: 29619125. Excluded for wrong study design for key question.29619125
Shariatzadeh M, Brandt MM, Cheng C, . Three-dimensional tubule formation assay as therapeutic screening model for ocular microvascular disorders. Eye. 2018;32(8):1380–6. doi: 10.1038/s41433-018-0089-0. PMID: 29743587. Excluded for wrong intervention.29743587
Shi Y, Motulsky EH, Goldhardt R, . Predictive value of the OCT double-layer sign for identifying subclinical neovascularization in age-related macular degeneration. Ophthalmol Retina. 2019;3(3):211–9. doi: 10.1016/j.oret.2018.10.012. PMID: 31014697. Excluded for wrong population.31014697
Shiragami C, Miyake M, Fujiwara A, . Effect of topical isopropyl unoprostone on macular atrophy progression in eyes with exudative age-related macular degeneration. Medicine (Baltimore). 2017;96(12):e6422. doi: 10.1097/md.0000000000006422. PMID: 28328847. Excluded for wrong intervention.28328847
Singerman LJ, Masonson H, Patel M, . Pegaptanib sodium for neovascular age-related macular degeneration: third-year safety results of the VEGF Inhibition Study in Ocular Neovascularisation (VISION) trial. Br J Ophthalmol. 2008;92(12):1606–11. doi: 10.1136/bjo.2007.132597. PMID: 18614570. Excluded for wrong intervention.18614570
Sloan FA, Picone G, Brown DS, . Longitudinal analysis of the relationship between regular eye examinations and changes in visual and functional status. J Am Geriatr Soc. 2005;53(11):1867–74. Excluded for wrong study design for key question.16274366
Smit C, Wiertz-Arts K, van de Garde EM. Intravitreal aflibercept versus intravitreal ranibizumab in patients with age-related macular degeneration: a comparative effectiveness study. J Comp Eff Res. 2018;7(6):561–7. doi: 10.2217/cer-2017-0099. PMID: 29855194. Excluded for wrong study design for key question.29855194
Sobolewska B, Golenko J, Poeschel S, . Influence of aflibercept on platelet activation profile. Exp Eye Res. 2018;175:166–72. doi: 10.1016/j.exer.2018.06.009. PMID: 29908884. Excluded for wrong outcome.29908884
Sogawa T, Tabuchi H, Nagasato D, . Accuracy of a deep convolutional neural network in the detection of myopic macular diseases using swept-source optical coherence tomography. PLoS One. 2020;15(4):e0227240. doi: 10.1371/journal.pone.0227240. PMID: 32298265. Excluded for wrong intervention.32298265
Soler V, Sourdet S, Balardy L, . Visual impairment screening at the geriatric frailty clinic for assessment of frailty and prevention of disability at the gerontopole. J Nutr Health Aging. 2016;20(8):870–7. PMID: 27709237. Excluded for wrong study design for key question.27709237
Solomon SD, Lindsley K, Vedula SS, . Anti-vascular endothelial growth factor for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2014;3:CD005139. doi: 10.1002/14651858.CD005139.pub4. PMID: 30834517. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.30834517
Soorya M, Issac A, Dutta MK. An automated and robust image processing algorithm for glaucoma diagnosis from fundus images using novel blood vessel tracking and bend point detection. Int J Med Inform. 2018;110:52–70. doi: 10.1016/j.ijmedinf.2017.11.015. PMID: 29331255. Excluded for not a study.29331255
Souied EH, Delcourt C, Querques G, . Oral docosahexaenoic acid in the prevention of exudative age-related macular degeneration: the Nutritional AMD Treatment 2 study. Ophthalmology. 2013;120(8):1619–31. doi: 10.1016/j.ophtha.2013.01.005. PMID: 23395546. Excluded for wrong intervention.23395546
Stem MS, Moinuddin O, Kline N, . Outcomes of anti-vascular endothelial growth factor treatment for choroidal neovascularization in fellow eyes of previously treated patients with neovascular age-related macular degeneration. JAMA Ophthalmol. 2018;136(7):820–3. doi: 10.1001/jamaophthalmol.2018.1534. PMID: 29800991. Excluded for wrong study design for key question.29800991
Stone DH, Shannon DJ. Screening for impaired visual acuity in middle age in general practice. Br Med J. 1978;2(6141):859–61. Excluded for wrong population.709095
Stoor K, Karvonen E, Liinamaa J, . Evaluating refraction and visual acuity with the Nidek autorefractometer AR-360A in a randomized population-based screening study. Acta Ophthalmol. 2018;96(4):384–9. doi: 10.1111/aos.13636. PMID: 29193822. Excluded for wrong outcome.29193822
Su D, Greenberg A, Simonson JL, . Efficacy of the amsler grid test in evaluating glaucomatous central visual field defects. Ophthalmology. 2016;123(4):737–43. doi: 10.1016/j.ophtha.2015.12.003. PMID: 26783097. Excluded for wrong study design for key question.26783097
Subzwari S, Desapriya E, Babul-Wellar S, . Vision screening of older drivers for preventing road traffic injuries and fatalities. Cochrane Database Syst Rev. 2009 (1):CD006252. doi: 10.1002/14651858.CD006252.pub2. PMID: 19160271. Excluded for not a study.19160271
Suda K, Murakami T, Gotoh N, . High-density lipoprotein mutant eye drops for the treatment of posterior eye diseases. J Controlled Release. 2017;266:301–9. doi: 10.1016/j.jconrel.2017.09.036. PMID: 28987881. Excluded for wrong intervention.28987881
Suram V, Addepalli UK, Krishnaiah S, . Accuracy of vision technicians in screening ocular pathology at rural vision centres of southern India. Clin Exp Optom. 2016;99(2):183–7. doi: 10.1111/cxo.12345. PMID: 27012692. Excluded for wrong comparator.27012692
Swamy B, Cumming RG, Ivers R, . Vision screening for frail older people: a randomised trial. Br J Ophthalmol. 2009;93(6):736–41. doi: 10.1136/bjo.2007.134650. PMID: 18614568. Excluded for wrong screener.18614568
Tamura H, Goto R, Akune Y, . The clinical effectiveness and cost-effectiveness of screening for age-related macular degeneration in Japan: a Markov Modeling Study. PLoS One. 2015;10(7):e0133628. doi: 10.1371/journal.pone.0133628. PMID: 26214804. Excluded for wrong intervention.26214804
Tan AC, Man R, Wong CW, . Randomized controlled trial evaluating a novel community eye care programme for elderly individuals with visual impairment. Clin Exp Ophthalmol. 2018;46(6):593–9. doi: 10.1111/ceo.13140. PMID: 29282844. Excluded for wrong setting.29282844
Teh RC, Lim WS. Utility of a patient-response screening question for visual impairment. J Am Geriatr Soc. 2006;54(2):370–2. PMID: 16460398. Excluded for poor quality.16460398
The Alpha-Tocopherol Beta Carotene Cancer Prevention Study Group. The effect of vitamin E and beta carotene on the incidence of lung cancer and other cancers in male smokers. N Engl J Med. 1994;330:1029–35. Excluded for wrong population.8127329
Tidbury LP, Czanner G, Newsham D. Fiat Lux: the effect of illuminance on acuity testing. Graefes Arch Clin Exp Ophthalmol. 2016;254(6):1091–7. doi: 10.1007/s00417-016-3329-7. PMID: 27106623. Excluded for wrong intervention.27106623
Ting DSW, Peng L, Varadarajan AV, . Deep learning in ophthalmology: the technical and clinical considerations. Prog Retin Eye Res. 2019;72:100759. doi: 10.1016/j.preteyeres.2019.04.003. PMID: 31048019. Excluded for not a study.31048019
Ting SL, Lim LT, Ooi CY, . Comparison of icare rebound tonometer and perkins applanation tonometer in community eye screening. Asia Pac J Ophthalmol (Phila). 2019;8(3):229–32. doi: 10.22608/APO.2018433. PMID: 31165604. Excluded for wrong study design for key question.31165604
Torres E, Morales PH, Bittar O, . Teleophthalmology support for primary care diagnosis and management. Med Hypothesis Discov Innov Ophthalmol. 2018;7(2):57–62. PMID: 30250853. Excluded for wrong study design for key question.30250853
Tran K, Ryce A. CADTH Rapid Response Reports. Laser Refractive Surgery For Vision Correction: A Review of Clinical Effectiveness and Cost-Effectiveness. Ottawa (ON): Canadian Agency for Drugs and Technologies in Health; 2018. Excluded for wrong intervention.
Treder M, Lauermann JL, Eter N. Automated detection of exudative age-related macular degeneration in spectral domain optical coherence tomography using deep learning. Graefes Arch Clin Exp Ophthalmol. 2018;256(2):259–65. doi: 10.1007/s00417-017-3850-3. PMID: 29159541. Excluded for wrong intervention.29159541
Tufail A, Patel PJ, Egan C, . Bevacizumab for neovascular age related macular degeneration (ABC Trial): multicentre randomised double masked study. BMJ. 2010;340:c2459. doi: 10.1136/bmj.c2459. PMID: 20538634. Excluded for wrong comparator.20538634
van Asten F, Chiu CY, Agron E, . No CFH or ARMS2 interaction with omega-3 fatty acids, low versus high zinc, or beta-carotene versus lutein and zeaxanthin on progression of age-related macular degeneration in the age-related eye disease study 2: age-related eye disease study 2 report no. 18. Ophthalmology. 2019;126(11):1541–8. doi: 10.1016/j.ophtha.2019.06.004. PMID: 31358387. Excluded for ancillary publication not relevant to current systematic review.31358387
van Nispen R, van der Aa H, Timmermans F, . Reducing avoidable visual impairment in elderly home healthcare patients by basic ophthalmologic screening. Acta Ophthalmol. 2019;97(4):401–8. doi: 10.1111/aos.13956. PMID: 30369070. Excluded for wrong setting.30369070
van Rossum E, Frederiks CM, Philipsen H, . Effects of preventive home visits to elderly people. BMJ. 1993;307(6895):27–32. doi: 10.1136/bmj.307.6895.27. PMID: 8343668. Excluded for wrong setting.8343668
Vancleef K, Serrano-Pedraza I, Sharp C, . ASTEROID: a new clinical stereotest on an autostereo 3D tablet. Transl Vis Sci Technol. 2019;8(1):25. doi: 10.1167/tvst.8.1.25. PMID: 30834173. Excluded for wrong intervention.30834173
Vaze A, Nguyen V, Daien V, . Ranibizumab and aflibercept for the treatment of pigment epithelial detachment in neovascular age-related macular degeneration: data from an observational study. Retina. 2018;38(10):1954–61. doi: 10.1097/IAE.0000000000001815. PMID: 28820848. Excluded for wrong outcome.28820848
Vedula SS, Krzystolik MG. Antiangiogenic therapy with anti-vascular endothelial growth factor modalities for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;2. Art. No.: CD005139. DOI: 10.1002/14651858.CD005139.pub2. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.
Vega R, Sanchez-Ante G, Falcon-Morales LE, . Retinal vessel extraction using lattice neural networks with dendritic processing. Comput Biol Med. 2015;58:20–30. doi: 10.1016/j.compbiomed.2014.12.016. PMID: 25589415. Excluded for wrong intervention.25589415
Venhuizen FG, van Ginneken B, van Asten F, . Automated staging of age-related macular degeneration using optical coherence tomography. Invest Ophthalmol Vis Sci. 2017;58(4):2318–28. doi: 10.1167/iovs.16-20541. PMID: 28437528. Excluded for wrong intervention.28437528
Vetter NJ, Jones DA, Victor CR. Effect of health visitors working with elderly patients in general practice: a randomised controlled trial. Br Med J (Clin Res Ed). 1984;288(6414):369–72. doi: 10.1136/bmj.288.6414.369. PMID: 6229314. Excluded for wrong setting.6229314
Vetter NJ, Lewis PA, Ford D. Can health visitors prevent fractures in elderly people? BMJ. 1992;304(6831):888–90. doi: 10.1136/bmj.304.6831.888. PMID: 1392755. Excluded for wrong intervention.1392755
Vidal PL, de Moura J, Novo J, . Intraretinal fluid identification via enhanced maps using optical coherence tomography images. Biomed Opt Express. 2018;9(10):4730–54. doi: 10.1364/BOE.9.004730. PMID: 30319899. Excluded for not a study.30319899
Virgili G, Bini A. Laser photocoagulation for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2007;Issue 3. Art. No.: CD0004763. DOI: 10.1002/14651858.CD004763.pub2doi: 10.1002/14651858.CD004763.pub2. PMID: 17636773. Excluded for wrong intervention.17636773
Vitale S, Agron E, Clemons TE, . Association of 2-year progression along the AREDS AMD scale and development of late age-related macular degeneration or loss of visual acuity: AREDS Report 41. JAMA Ophthalmol. 2020;138(6):610–7. doi: 10.1001/jamaophthalmol.2020.0824. PMID: 32271358. Excluded for ancillary publication not relevant to current systematic review.32271358
Wagner EH, LaCroix AZ, Grothaus L, . Preventing disability and falls in older adults: a population-based randomized trial. Am J Public Health. 1994;84(11):1800–6. doi: 10.2105/ajph.84.11.1800. PMID: 7977921. Excluded for wrong intervention.7977921
Wang F, Tielsch JM, Ford DE, . Evaluation of screening schemes for eye disease in a primary care setting. Ophthalmic Epidemiol. 1998;5(2):69–82. PMID: 9672907. Excluded for poor quality.9672907
Wang J, Hormel TT, Gao L, . Automated diagnosis and segmentation of choroidal neovascularization in OCT angiography using deep learning. Biomed Opt Express. 2020;11(2):927–44. doi: 10.1364/BOE.379977. PMID: 32133230. Excluded for wrong intervention.32133230
Wang Y, Zhang Y, Yao Z, . Machine learning based detection of age-related macular degeneration (AMD) and diabetic macular edema (DME) from optical coherence tomography (OCT) images. Biomed Opt Express. 2016;7(12):4928–40. doi: 10.1364/BOE.7.004928. PMID: 28018716. Excluded for wrong intervention.28018716
Ward E, Wickens RA, O’Connell A, . Monitoring for neovascular age-related macular degeneration (AMD) reactivation at home: the MONARCH study. Eye. 2021;35(2):592–600. doi: 10.1038/s41433-020-0910-4. PMID: 32367004. Excluded for wrong intervention.32367004
Waugh N, Loveman E, Colquitt J, . Treatments for dry age-related macular degeneration and Stargardt disease: a systematic review. Health Technol Assess. 2018;22(27):1–168. doi: 10.3310/hta22270. PMID: 29846169. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.29846169
Wei Y, Liao H, Ye J. Therapeutic effects of various therapeutic strategies on non-exudative age-related macular degeneration: a PRISMA-compliant network meta-analysis of randomized controlled trials. Medicine. 2018;97(21):e10422. doi: 10.1097/MD.0000000000010422. PMID: 29794727. Excluded for wrong population.29794727
Wijeyekoon S, Kharicha K, Iliffe S. Heuristics in primary care for recognition of unreported vision loss in older people: a technology development study. Prim Health Care Res Dev. 2015;16(5):429–35. doi: 10.1017/S1463423614000425. PMID: 25348032. Excluded for wrong intervention.25348032
Williams MA, McKay GJ, Chakravarthy U. Complement inhibitors for age-related macular degeneration. Cochrane Database Syst Rev. 2014;Issue 1. Art. No.: CD009300. DOi:. 10.1002/14651858.CD009300.pub2doi: 10.1002/14651858.CD009300.pub2. Excluded for wrong intervention.24431152
Williams PD, Chong D, Fuller T, . Noninfectious vitritis after intravitreal injection of anti-vegf agents: variations in rates and presentation by medication. Retina. 2016;36(5):909–13. doi: 10.1097/IAE.0000000000000801. PMID: 27115856. Excluded for wrong study design for key question.27115856
Wisse RPL, Muijzer MB, Cassano F, . Validation of an independent web-based tool for measuring visual acuity and refractive error (the manifest versus online Refractive Evaluation Trial): prospective open-label noninferiority clinical trial. J Med Internet Res. 2019;21(11):e14808. doi: 10.2196/14808. PMID: 31702560. Excluded for wrong study design for key question.31702560
Wormald R, Evans J, Smeeth L, . Photodynamic therapy for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2007;1. Art. No.: CD002030. DOI: 10.1002/14651858.CD002030.pub3doi: 10.1002/14651858.CD002030.pub3. PMID: 17636693. Excluded for wrong intervention.17636693
Xu L, Wang X, Wu M. Topical medication instillation techniques for glaucoma. Cochrane Database Syst Rev. 2017;2:CD010520. doi: 10.1002/14651858.CD010520.pub2. PMID: 28218404. Excluded for wrong outcome.28218404
Yashkin AP, Hahn P, Sloan FA. Introducing anti-vascular endothelial growth factor therapies for AMD did not raise risk of myocardial infarction, stroke, and death. Ophthalmology. 2016;123(10):2225–31. doi: 10.1016/j.ophtha.2016.06.053. PMID: 27523614. Excluded for wrong comparator.27523614
Ying GS, Maguire MG, Daniel E, . Association between antiplatelet or anticoagulant drugs and retinal or subretinal hemorrhage in the comparison of age-related macular degeneration treatments trials. Ophthalmology. 2016;123(2):352–60. doi: 10.1016/j.ophtha.2015.09.046. PMID: 26545320. Excluded for wrong comparator.26545320
Yoo TK, Choi JY, Seo JG, . The possibility of the combination of OCT and fundus images for improving the diagnostic accuracy of deep learning for age-related macular degeneration: a preliminary experiment. Med Biol Eng Comput. 2019;57(3):677–87. doi: 10.1007/s11517-018-1915-z. PMID: 30349958. Excluded for wrong intervention.30349958
Yuan J. Role of inflammatory factors in the effects of aflibercept or ranibizumab treatment for alleviating wet age-associated macular degeneration. Exp Ther Med. 2019;17(5):4249–58. doi: 10.3892/etm.2019.7427. PMID: 30988797. Excluded for wrong population.30988797
Zapata MA, Arcos G, Fonollosa A, . Telemedicine for a general screening of retinal disease using nonmydriatic fundus cameras in optometry centers: three-year results. Telemed J E Health. 2017;23(1):30–6. doi: 10.1089/tmj.2016.0020. PMID: 27228051. Excluded for wrong screener.27228051
Zarbin MA, Francom S, Grzeschik S, . Systemic safety in ranibizumab-treated patients with neovascular age-related macular degeneration: a patient-level pooled analysis. Ophthalmol Retina. 2018;2(11):1087–96. PMID: 31047547. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.31047547
Zeri F, Calcatelli P, Funaro E, . How accurate is an LCD screen version of the Pelli-Robson test? Int Ophthalmol. 2018;38(4):1473–84. doi: 10.1007/s10792-017-0609-0. PMID: 28639086. Excluded for wrong outcome.28639086
Zhang J, Liang Y, Xie J, . Conbercept for patients with age-related macular degeneration: a systematic review. BMC Ophthalmol. 2018;18(1):142. doi: 10.1186/s12886-018-0807-1. PMID: 29902977. Excluded for wrong intervention.29902977
Zhang XJ, Leung CKS, Li EY, . Diagnostic accuracy of rapid assessment of avoidable blindness: a population-based assessment. Am J Ophthalmol. 2020;213:235–43. doi: 10.1016/j.ajo.2019.12.009. PMID: 31846622. Excluded for wrong intervention.31846622
Zhang Y, Chioreso C, Schweizer ML, . Effects of aflibercept for neovascular age-related macular degeneration: a systematic review and meta-analysis of observational comparative studies. Invest Ophthalmol Vis Sci. 2017;58(13):5616–27. doi: 10.1167/iovs.17-22471. PMID: 29094167. Excluded for wrong study design for key question.29094167

## Appendix A6 US Preventive Services Task Force Quality Criteria

### Systematic Reviews

Criteria:

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

Definition of ratings based on above criteria:

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions.
Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies.
Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies.

### RCTs and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  ○ For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ For cohort studies: consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs

Definition of ratings based on above criteria:

Good: Meets all criteria: comparable groups are assembled initially and maintained throughout the study (followup greater than or equal to 80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
Poor: Studies are graded “poor” if any of the following fatal flaws exists: groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of ratings based on above criteria:

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (greater than 100) of broad-spectrum patients with and without disease.
Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
Poor: Has a fatal flaw, such as: uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients.

Internet Citation:Appendix VI. Criteria for Assessing Internal Validity of Individual Studies. U.S. Preventive Services Task Force. July 2017. https://www.uspreventiveservicestaskforce.org/uspstf/procedure-manual/procedure-manual-appendix-vi-criteria-assessing-internal-validity-individual-studies

## Appendix A7 Expert Reviewers of the Draft Report

❖ April Maa, MD, Emory University School of Medicine, Emory Eye Center; Atlanta VA Medical Center
❖ Nancy Weintraub, MD, David Geffen School of Medicine at University of California at Los Angeles
❖ Jennifer Evans, PhD, MSc, London School of Hygiene and Tropical Medicine
❖ Centers for Disease Control and Prevention representatives
❖ One undisclosed reviewer

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the report findings