# References

1 American Psychiatric Association, D. S. M. Task Force. Diagnostic and statistical manual of mental disorders : DSM-5. Arlington, VA: American Psychiatric Association; 2013.
2 Udo T, Grilo CM. Prevalence and correlates of DSM-5-Defined Eating Disorders in a nationally representative sample of U.S. adults. Biol Psychiatry. 2018 Sep 1;84(5):345–54. doi: 10.1016/j.biopsych.2018.03.014. PMID: 29859631.29859631
3 Hudson JI, Hiripi E, Pope HG, Jr., . The prevalence and correlates of eating disorders in the National Comorbidity Survey Replication. Biol Psychiatry. 2007 Feb 1;61(3):348–58. doi: 10.1016/j.biopsych.2006.03.040. PMID: 16815322.16815322
4 Kessler RC, Avenevoli S, Costello EJ, . Design and field procedures in the US National Comorbidity Survey Replication Adolescent Supplement (NCS-A). Int J Methods Psychiatr Res. 2009 Jun;18(2):69–83. doi: 10.1002/mpr.279. PMID: 19507169.19507169
5 Marques L, Alegria M, Becker AE, . Comparative prevalence, correlates of impairment, and service utilization for eating disorders across US ethnic groups: implications for reducing ethnic disparities in health care access for eating disorders. Int J Eat Disord. 2011 Jul;44(5):412–20. doi: 10.1002/eat.20787. PMID: 20665700.20665700
6 Connolly MD, Zervos MJ, Barone CJ, 2nd, . The Mental Health of Transgender Youth: Advances in Understanding. J Adolesc Health. 2016 Nov;59(5):489–95. doi: 10.1016/j.jadohealth.2016.06.012. PMID: 27544457.27544457
7 Diemer EW, Grant JD, Munn-Chernoff MA, . Gender identity, sexual orientation, and eating-related pathology in a national sample of college students. J Adolesc Health. 2015;57(2):144–9. doi: 10.1016/j.jadohealth.2015.03.003.25937471
8 Forney KJ, Buchman-Schmitt JM, Keel PK, . The medical complications associated with purging. Int J Eat Disord. 2016 Mar;49(3):249–59. doi: 10.1002/eat.22504. PMID: 26876429.26876429
9 Kessler RC, Berglund PA, Chiu WT, . The prevalence and correlates of binge eating disorder in the World Health Organization World Mental Health Surveys. Biol Psychiatry. 2013 May 1;73(9):904–14. doi: 10.1016/j.biopsych.2012.11.020. PMID: 23290497.23290497
10 Faje AT, Fazeli PK, Miller KK, . Fracture risk and areal bone mineral density in adolescent females with anorexia nervosa. Int J Eat Disord. 2014;47(5):458–66. doi: 10.1002/eat.22248. PMID: 2014-24189-001.24430890
11 Miller KK, Grinspoon SK, Ciampa J, . Medical findings in outpatients with anorexia nervosa. Arch Intern Med. 2005;165(5):561–6. doi: 10.1001/archinte.165.5.561.15767533
12 Chesney E, Goodwin GM, Fazel S. Risks of all-cause and suicide mortality in mental disorders: a meta-review. World Psychiatry. 2014;13(2):153–60. doi: 10.1002/wps.20128. PMID: 24890068.24890068
13 Arcelus J, Mitchell AJ, Wales J, . Mortality rates in patients with anorexia nervosa and other eating disorders. A meta-analysis of 36 studies. Arch Gen Psychiatry. 2011 Jul;68(7):724–31. doi: 10.1001/archgenpsychiatry.2011.74. PMID: 21727255.21727255
14 Udo T, Grilo CM. Psychiatric and medical correlates of DSM-5 eating disorders in a nationally representative sample of adults in the United States. Int J Eat Disord. 2019 Jan;52(1):42–50. doi: 10.1002/eat.23004. PMID: 30756422.30756422
15 Zakzanis KK, Campbell Z, Polsinelli A. Quantitative evidence for distinct cognitive impairment in anorexia nervosa and bulimia nervosa. J Neuropsychol. 2010 Mar;4(Pt 1):89–106. doi: 10.1348/174866409x459674. PMID: 19619407.19619407
16 Grau A, Magallón-Neri E, Faus G, . Cognitive impairment in eating disorder patients of short and long-term duration: a case-control study. Neuropsychiatr Dis Treat. 2019;15:1329–41. doi: 10.2147/NDT.S199927. PMID: 31190837.31190837
17 Treasure J, Duarte TA, Schmidt U. Eating disorders. Lancet. 2020 Mar 14;395(10227):899–911. doi: 10.1016/s0140-6736(20)30059-3. PMID: 32171414.32171414
18 Schaumberg K, Welch E, Breithaupt L, . The science behind the academy for eating disorders’ nine truths about eating disorders. Eur Eat Disord Rev. 2017 Nov;25(6):432–50. doi: 10.1002/erv.2553. PMID: 28967161.28967161
19 Kaye WH, Bulik CM, Plotnicov K, . The genetics of anorexia nervosa collaborative study: methods and sample description. Int J Eat Disord. 2008;41(4):289–300. doi: 10.1002/eat.20509. PMID: 2008-05314-001.18236451
20 Bakalar JL, Shank LM, Vannucci A, . Recent advances in developmental and risk factor research on eating disorders. Curr Psychiatry Rep. 2015 Jun;17(6):42. doi: 10.1007/s11920-015-0585-x. PMID: 25894358.25894358
21 Watson HJ, Yilmaz Z, Thornton LM, . Genome-wide association study identifies eight risk loci and implicates metabo-psychiatric origins for anorexia nervosa. Nat Genet. 2019;51(8):1207–14. doi: 10.1038/s41588-019-0439-2. PMID: 31308545.31308545
22 Mitchell KS, Mazzeo SE, Schlesinger MR, . Comorbidity of partial and subthreshold ptsd among men and women with eating disorders in the national comorbidity survey-replication study. Int J Eat Disord. 2012 Apr;45(3):307–15. doi: 10.1002/eat.20965. PMID: 22009722.22009722
23 Hazzard VM, Loth KA, Hooper L, . Food insecurity and eating disorders: a review of emerging evidence. Curr Psychiatry Rep. 2020 Oct 30;22(12):74. doi: 10.1007/s11920-020-01200-0. PMID: 33125614.33125614
24 Jones BA, Haycraft E, Murjan S, . Body dissatisfaction and disordered eating in trans people: a systematic review of the literature. Int Rev Psychiatry. 2016;28(1):81–94. doi: 10.3109/09540261.2015.1089217. PMID: 26618239.26618239
25 Calzo JP, Blashill AJ, Brown TA, . Eating disorders and disordered weight and shape control behaviors in sexual minority populations. Curr Psychiatry Rep. 2017;19(8):49-. doi: 10.1007/s11920-017-0801-y. PMID: 28660475.28660475
26 Sundgot-Borgen J, Torstveit MK. Prevalence of eating disorders in elite athletes is higher than in the general population. Clin J Sport Med. 2004 Jan;14(1):25–32. doi: 10.1097/00042752-200401000-00005. PMID: 14712163.14712163
27 Eddy KT, Dorer DJ, Franko DL, . Diagnostic crossover in anorexia nervosa and bulimia nervosa: implications for DSM-V. Am J Psychiatry. 2008 Feb;165(2):245–50. doi: 10.1176/appi.ajp.2007.07060951. PMID: 18198267.18198267
28 Ali K, Farrer L, Fassnacht DB, . Perceived barriers and facilitators towards help-seeking for eating disorders: a systematic review. Int J Eat Disord. 2017 Jan;50(1):9–21. doi: 10.1002/eat.22598. PMID: 27526643.27526643
29 Cotton M-A, Ball C, Robinson P. Four simple questions can help screen for eating disorders. J Gen Intern Med. 2003;18(1):53–6. doi: 10.1046/j.1525-1497.2003.20374.x. PMID: 2003-04278-007.12534764
30 Maguen S, Hebenstreit C, Li Y, . Screen for disordered eating: improving the accuracy of eating disorder screening in primary care. Gen Hosp Psychiatry. 2018 Jan–Feb;50:20–5. doi: 10.1016/j.genhosppsych.2017.09.004. PMID: 28987918.28987918
31 Morgan JF, Reid F, Lacey JH. The SCOFF questionnaire: assessment of a new screening tool for eating disorders. BMJ. 1999 Dec 4;319(7223):1467–8. doi: 10.1136/bmj.319.7223.1467. PMID: 10582927.10582927
32 National Institute for Health Care Excellence. Eating disorders: recognition and treatment: NICE; 2017.
33 Academy for Eating Disorders’ Medical Care Standards Committee. Eating disorders: a guide to medical care: AED; 2016.
34 Yager J, Devlin MJ, Halmi KA, . Guideline watch (August 2012): practice guideline for the treatment of patients with eating disorders. Focus (Madison). 2014;12(4):416–31.
35 American Psychiatric Association. Treating eating disorders: a quick reference guide. American Psychiatric Association practice guidelines for the treatment of psychiatric disorders: compendium 2006. Arlington, VA: American Psychiatric Association; 2006.
36 Yager J, Andersen A, Devlin M, . Practice guideline for the treatment of patients with eating disorders: American Psychiatric Association; 2002.
37 Berkman ND, Brownley KA, Peat CM, . Management and outcomes of binge-eating disorder. 2015.
38 Berkman ND, Bulik CM, Brownley KA, . Management of eating disorders. Evid Rep Technol Assess (Full Rep). 2006 Apr(135):1–166. PMID: 17628126.17628126
39 Lock J, La Via MC. Practice parameter for the assessment and treatment of children and adolescents with eating disorders. J Am Acad Child Adolesc Psychiatry. 2015;54(5):412–25.25901778
40 Rosen DS. Clinical report—identification and management of eating disorders in children and adolescents. Pediatrics. 2010.
41 ACOG Committee Opinion No. 740: gynecologic care for adolescents and young women with eating disorders. Obstet Gynecol. 2018 Jun;131(6):e205–e13. doi: 10.1097/aog.0000000000002652. PMID: 29794682.29794682
42 Hornberger LL, Lane MA. Identification and management of eating disorders in children and adolescents. Pediatrics. 2020:e2020040279. doi: 10.1542/peds.2020-040279.33386343
43 United Nations Development Programme. Human development index. New York City, NY: United Nations Development Programme; 2016. http://hdr.undp.org/en/composite/HDI. Accessed August 20, 2018.
44 Veritas Health Innovation. Covidence systematic review software. Melbourne, Australia: Level 10; n.d. www.covidence.org. Accessed December 17, 2019.
45 Sterne JAC, Savovic J, Page MJ, . RoB 2: a revised tool for assessing risk of bias in randomised trials. BMJ. 2019 Aug 28;366:l4898. doi: 10.1136/bmj.l4898. PMID: 31462531.31462531
46 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529–36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
47 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force procedure manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed December 17, 2019.
48 West SL, Gartlehner G, Mansfield AJ, . Comparative effectiveness review methods: clinical heterogeneity. Report No.: 10-EHC070-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2010.
49 StataCorp. Stata statistical software: release 16.0. College Station, TX: StataCorp LP; 2019.
50 Hill LS, Reid F, Morgan JF, . SCOFF, the development of an eating disorder screening questionnaire. Int J Eat Disord. 2010 May;43(4):344–51. doi: 10.1002/eat.20679. PMID: 19343793.19343793
51 Wan Wahida WMZ, Lai PSM, Abdul Hadi H. Validity and reliability of the english version of the sick, control, one stone, fat, food (SCOFF) in Malaysia. Clin Nutr ESPEN. 2017 Apr;18:55–8. doi: 10.1016/j.clnesp.2017.02.001. PMID: 29132739.29132739
52 Graham AK, Trockel M, Weisman H, . A screening tool for detecting eating disorder risk and diagnostic symptoms among college-age women. J Am Coll Health. 2019 May–Jun;67(4):357–66. doi: 10.1080/07448481.2018.1483936. PMID: 29979922.29979922
53 Siervo M, Boschi V, Papa A, . Application of the SCOFF, Eating Attitude Test 26 (EAT 26) and Eating Inventory (TFEQ) Questionnaires in young women seeking diet-therapy. Eat Weight Disord. 2005 Jun;10(2):76–82. doi: 10.1007/bf03327528. PMID: 16114220.16114220
54 Garcia FD, Grigioni S, Chelali S, . Validation of the French version of SCOFF questionnaire for screening of eating disorders among adults. World J Biol Psychiatry. 2010 Oct;11(7):888–93. doi: 10.3109/15622975.2010.483251. PMID: 20509759.20509759
55 Luck AJ, Morgan JF, Reid F, . The SCOFF questionnaire and clinical interview for eating disorders in general practice: comparative study. BMJ. 2002 Oct 5;325(7367):755–6. doi: 10.1136/bmj.325.7367.755. PMID: 12364305.12364305
56 Rosenvinge JH, Perry JA, Bjørgum L, . A new instrument measuring disturbed eating patterns in community populations: development and initial validation of a five-item scale (EDS-5). Eur Eat Disord Rev. 2001;9(2):123–32. doi: 10.1002/erv.371. PMID: 2001-17053-004.
57 Liu CY, Tseng MC, Chen KY, . Sex difference in using the SCOFF questionnaire to identify eating disorder patients at a psychiatric outpatient clinic. Compr Psychiatry. 2015 Feb;57:160–6. doi: 10.1016/j.comppsych.2014.11.014. PMID: 25542817.25542817
58 Parker SC, Lyons J, Bonner J. Eating disorders in graduate students: exploring the SCOFF questionnaire as a simple screening tool. J Am Coll Health. 2005 Sep–Oct;54(2):103–7. doi: 10.3200/jach.54.2.103-107. PMID: 16255322.16255322
59 Chamay-Weber C, Combescure C, Lanza L, . Screening obese adolescents for binge eating disorder in primary care: the Adolescent Binge Eating Scale. J Pediatr. 2017 Jun;185:68–72.e1. doi: 10.1016/j.jpeds.2017.02.038. PMID: 28285753.28285753
60 Striegel-Moore RH, Perrin N, DeBar L, . Screening for binge eating disorders using the patient health questionnaire in a community sample. Int J Eat Disord. 2010 May;43(4):337–43. doi: 10.1002/eat.20694. PMID: 19424976.19424976
61 Ricca V, Mannucci E, Moretti S, . Screening for binge eating disorder in obese outpatients. Compr Psychiatry. 2000 Mar–Apr;41(2):111–5. doi: 10.1016/s0010-440x(00)90143-3. PMID: 10741889.10741889
62 Dorflinger LM, Ruser CB, Masheb RM. A brief screening measure for binge eating in primary care. Eat Behav. 2017 Aug;26:163–6. doi: 10.1016/j.eatbeh.2017.03.009. PMID: 28402901.28402901
63 Muro-Sans P, Amador-Campos JA, Morgan JF. The SCOFF-c: psychometric properties of the Catalan version in a Spanish adolescent sample. J Psychosom Res. 2008 Jan;64(1):81–6. doi: 10.1016/j.jpsychores.2007.06.011. PMID: 18158003.18158003
64 Mond JM, Myers TC, Crosby RD, . Screening for eating disorders in primary care: EDE-Q versus SCOFF. Behav Res Ther. 2008 May;46(5):612–22. doi: 10.1016/j.brat.2008.02.003. PMID: 18359005.18359005
65 Lähteenmäki S, Aalto-Setälä T, Suokas JT, . Validation of the Finnish version of the SCOFF questionnaire among young adults aged 20 to 35 years. BMC Psychiatry. 2009 Feb 8;9:5. doi: 10.1186/1471-244x-9-5. PMID: 19200401.19200401
66 Guerdjikova AI, Mori N, Blom TJ, . Lisdexamfetamine dimesylate in binge eating disorder: a placebo controlled trial. Hum Psychopharmacol. 2016 Sep;31(5):382–91. doi: 10.1002/hup.2547. PMID: 27650406.27650406
67 McElroy SL, Mitchell JE, Wilfley D, . Lisdexamfetamine dimesylate effects on binge eating behaviour and obsessive-compulsive and impulsive features in adults with binge eating disorder. Eur Eat Disord Rev. 2016 May;24(3):223–31. doi: 10.1002/erv.2418. PMID: 26621156.26621156
68 McElroy SL, Hudson J, Ferreira-Cornwell MC, . Lisdexamfetamine dimesylate for adults with moderate to severe binge eating disorder: results of two pivotal phase 3 randomized controlled trials. Neuropsychopharmacology. 2016 Apr;41(5):1251–60. doi: 10.1038/npp.2015.275. PMID: 26346638.26346638
69 White MA, Grilo CM. Bupropion for overweight women with binge-eating disorder: a randomized, double-blind, placebo-controlled trial. J Clin Psychiatry. 2013 Apr;74(4):400–6. doi: 10.4088/JCP.12m08071. PMID: 23656848.23656848
70 McElroy SL, Hudson JI, Mitchell JE, . Efficacy and safety of lisdexamfetamine for treatment of adults with moderate to severe binge-eating disorder: a randomized clinical trial. JAMA Psychiatry. 2015 Mar;72(3):235–46. doi: 10.1001/jamapsychiatry.2014.2162. PMID: 25587645.25587645
71 Arnold LM, McElroy SL, Hudson JI, . A placebo-controlled, randomized trial of fluoxetine in the treatment of binge-eating disorder. J Clin Psychiatry. 2002 Nov;63(11):1028–33. doi: 10.4088/jcp.v63n1113. PMID: 12444817.12444817
72 Guerdjikova AI, McElroy SL, Winstanley EL, . Duloxetine in the treatment of binge eating disorder with depressive disorders: a placebo-controlled trial. Int J Eat Disord. 2012 Mar;45(2):281–9. doi: 10.1002/eat.20946. PMID: 21744377.21744377
73 McElroy SL, Casuto LS, Nelson EB, . Placebo-controlled trial of sertraline in the treatment of binge eating disorder. Am J Psychiatry. 2000 Jun;157(6):1004–6. doi: 10.1176/appi.ajp.157.6.1004. PMID: 10831483.10831483
74 Walsh BT, Hadigan CM, Devlin MJ, . Long-term outcome of antidepressant treatment for bulimia nervosa. Am J Psychiatry. 1991 Sep;148(9):1206–12. doi: 10.1176/ajp.148.9.1206. PMID: 1882999.1882999
75 Pearlstein T, Spurell E, Hohlstein LA, . A double-blind, placebo-controlled trial of fluvoxamine in binge eating disorder: a high placebo response. Arch Womens Ment Health. 2003 Apr;6(2):147–51. doi: 10.1007/s00737-003-0172-8. PMID: 12720065.12720065
76 Fluoxetine Bulimia Nervosa Collaborative Study Group. Fluoxetine in the treatment of bulimia nervosa. A multicenter, placebo-controlled, double-blind trial. Arch Gen Psychiatry. 1992 Feb;49(2):139–47. PMID: 1550466.1550466
77 McElroy SL, Hudson JI, Capece JA, . Topiramate for the treatment of binge eating disorder associated with obesity: a placebo-controlled study. Biol Psychiatry. 2007 May 1;61(9):1039–48. doi: 10.1016/j.biopsych.2006.08.008. PMID: 17258690.17258690
78 Laederach-Hofmann K, Graf C, Horber F, . Imipramine and diet counseling with psychological support in the treatment of obese binge eaters: a randomized, placebo-controlled double-blind study. Int J Eat Disord. 1999 Nov;26(3):231–44. doi: 10.1002/(sici)1098-108x(199911)26:3<231::aid-eat1>3.0.co;2-6. PMID: 10441239.10441239
79 Guerdjikova AI, McElroy SL, Kotwal R, . High-dose escitalopram in the treatment of binge-eating disorder with obesity: a placebo-controlled monotherapy trial. Hum Psychopharmacol. 2008 Jan;23(1):1–11. doi: 10.1002/hup.899. PMID: 18058852.18058852
80 Sheehan DV, Gasior M, McElroy SL, . Effects of lisdexamfetamine dimesylate on functional impairment measured on the sheehan disability scale in adults with moderate-to-severe binge eating disorder: results from two randomized, placebo-controlled trials. Innov Clin Neurosci. 2018;15(5–6):22–9. PMID: CN-01617953.30013816
81 McElroy SL, Arnold LM, Shapira NA, . Topiramate in the treatment of binge eating disorder associated with obesity: a randomized, placebo-controlled trial. Am J Psychiatry. 2003;160(2):255–61. doi: 10.1176/appi.ajp.160.2.255. PMID: CN-00413019.12562571
82 Kaneva R, Rissanen A, Sarna S. Fluoxetine in the treatment of anxiety, depressive symptoms, and eating-related symptoms in bulimia nervosa. Nordic Journal of Psychiatry. 1995;49(4):237–42. doi: 10.3109/08039489509011912. PMID: 1996-20791-001.
83 Grilo CM, Masheb RM, Wilson GT. Efficacy of cognitive behavioral therapy and fluoxetine for the treatment of binge eating disorder: a randomized double-blind placebo-controlled comparison. Biol Psychiatry. 2005 Feb 1;57(3):301–9. doi: 10.1016/j.biopsych.2004.11.002. PMID: 15691532.15691532
84 Mitchell JE, Fletcher L, Hanson K, . The relative efficacy of fluoxetine and manual-based self-help in the treatment of outpatients with bulimia nervosa. J Clin Psychopharmacol. 2001 Jun;21(3):298–304. doi: 10.1097/00004714-200106000-00008. PMID: 11386493.11386493
85 Deal LS, Wirth RJ, Gasior M, . Validation of the Yale-Brown Obsessive Compulsive Scale modified for binge eating. Int J Eat Disord. 2015 Nov;48(7):994–1004. doi: 10.1002/eat.22407. PMID: 26032442.26032442
86 Wade S, Byrne S, Allen K. Enhanced cognitive behavioral therapy for eating disorders adapted for a group setting. Int J Eat Disord. 2017 Aug;50(8):863–72. doi: 10.1002/eat.22723. PMID: 28489288.28489288
87 Wagner B, Nagl M, Dölemeyer R, . Randomized controlled trial of an internet-based cognitive-behavioral treatment program for binge-eating disorder. Behav Ther. 2016 Jul;47(4):500–14. doi: 10.1016/j.beth.2016.01.006. PMID: 27423166.27423166
88 Sánchez-Ortiz VC, Munro C, Stahl D, . A randomized controlled trial of internet-based cognitive-behavioural therapy for bulimia nervosa or related disorders in a student population. Psychol Med. 2011 Feb;41(2):407–17. doi: 10.1017/s0033291710000711. PMID: 20406523.20406523
89 Kelly AC, Carter JC. Self-compassion training for binge eating disorder: a pilot randomized controlled trial. Psychol Psychother. 2015 Sep;88(3):285–303. doi: 10.1111/papt.12044. PMID: 25330466.25330466
90 Grilo CM, White MA, Gueorguieva R, . Self-help for binge eating disorder in primary care: a randomized controlled trial with ethnically and racially diverse obese patients. Behav Res Ther. 2013 Dec;51(12):855–61. doi: 10.1016/j.brat.2013.10.002. PMID: 24189569.24189569
91 Ljotsson B, Lundin C, Mitsell K, . Remote treatment of bulimia nervosa and binge eating disorder: a randomized trial of Internet-assisted cognitive behavioural therapy. Behav Res Ther. 2007 Apr;45(4):649–61. doi: 10.1016/j.brat.2006.06.010. PMID: 16899213.16899213
92 Fairburn CG, Cooper Z, Doll HA, . Transdiagnostic cognitive-behavioral therapy for patients with eating disorders: a two-site trial with 60-week follow-up. Am J Psychiatry. 2009 Mar;166(3):311–9. doi: 10.1176/appi.ajp.2008.08040608. PMID: 19074978.19074978
93 Carter JC, Kenny TE, Singleton C, . Dialectical behavior therapy self-help for binge-eating disorder: a randomized controlled study. Int J Eat Disord. 2020 Mar;53(3):451–60. doi: 10.1002/eat.23208. PMID: 31821592.31821592
94 Hill DM, Craighead LW, Safer DL. Appetite-focused dialectical behavior therapy for the treatment of binge eating with purging: a preliminary trial. Int J Eat Disord. 2011 Apr;44(3):249–61. doi: 10.1002/eat.20812. PMID: 20196109.20196109
95 Grilo CM, Masheb RM, White MA, . Treatment of binge eating disorder in racially and ethnically diverse obese patients in primary care: randomized placebo-controlled clinical trial of self-help and medication. Behav Res Ther. 2014;58:1–9. doi: 10.1016/j.brat.2014.04.002. PMID: 2014-27567-002.24857821
96 Alfonsson S, Parling T, Ghaderi A. Group behavioral activation for patients with severe obesity and binge eating disorder: a randomized controlled trial. Behav Modif. 2015;39(2):270–94. doi: 10.1177/0145445514553093. PMID: 2015-07848-002.25268019
97 Carter JC, Olmsted MP, Kaplan AS, . Self-help for bulimia nervosa: a randomized controlled trial. Am J Psychiatry. 2003;160(5):973–8. doi: 10.1176/appi.ajp.160.5.973. PMID: 2003-03852-025.12727703
98 Green MA, Kroska A, Herrick A, . A preliminary trial of an online dissonance-based eating disorder intervention. Eat Behav. 2018;31:88–98. doi: 10.1016/j.eatbeh.2018.08.007. PMID: 2018-56763-016.30199771
99 Schag K, Rennhak SK, Leehr EJ, . IMPULS: impulsivity-focused group intervention to reduce binge eating episodes in patients with binge eating disorder - a randomised controlled trial. Psychother Psychosom. 2019;88(3):141–53. doi: 10.1159/000499696. PMID: 31108488.31108488
100 Schmidt U, Andiappan M, Grover M, . Randomised controlled trial of CD-ROM-based cognitive-behavioural self-care for bulimia nervosa. Br J Psychiatry. 2008 Dec;193(6):493–500. doi: 10.1192/bjp.bp.107.046607. PMID: 19043154.19043154
101 Wilfley DE, Agras WS, Telch CF, . Group cognitive-behavioral therapy and group interpersonal psychotherapy for the nonpurging bulimic individual: a controlled comparison. J Consult Clin Psychol. 1993 Apr;61(2):296–305. doi: 10.1037//0022-006x.61.2.296. PMID: 8473584.8473584
102 Schlup B, Munsch S, Meyer AH, . The efficacy of a short version of a cognitive-behavioral treatment followed by booster sessions for binge eating disorder. Behav Res Ther. 2009 Jul;47(7):628–35. doi: 10.1016/j.brat.2009.04.003. PMID: 19446793.19446793
103 Telch CF, Agras WS, Rossiter EM, . Group cognitive-behavioral treatment for the nonpurging bulimic: an initial evaluation. J Consult Clin Psychol. 1990 Oct;58(5):629–35. doi: 10.1037//0022-006x.58.5.629. PMID: 2254511.2254511
104 Masson PC, von Ranson KM, Wallace LM, . A randomized wait-list controlled pilot study of dialectical behaviour therapy guided self-help for binge eating disorder. Behav Res Ther. 2013 Nov;51(11):723–8. doi: 10.1016/j.brat.2013.08.001. PMID: 24029304.24029304
105 Cachelin FM, Gil-Rivas V, Palmer B, . Randomized controlled trial of a culturally-adapted program for Latinas with binge eating. Psychol Serv. 2019;16(3):504–12. doi: 10.1037/ser0000182. PMID: 2018-14470-001.29620392
106 Laessle RG, Waadt S, Pirke KM. A structured behaviorally oriented group treatment for bulimia nervosa. Psychother Psychosom. 1987;48(1–4):141–5. doi: 10.1159/000288044. PMID: 3505706.3505706
107 DeBar LL, Wilson GT, Yarborough BJ, . Cognitive behavioral treatment for recurrent binge eating in adolescent girls: A pilot trial. Cogn Behav Pract. 2013;20(2):147–61. doi: 10.1016/j.cbpra.2012.04.001. PMID: 2012-15354-001.23645978
108 Palmer RL, Birchall H, McGrain L, . Self-help for bulimic disorders: a randomised controlled trial comparing minimal guidance with face-to-face or telephone guidance. Br J Psychiatry. 2002 Sep;181:230–5. doi: 10.1192/bjp.181.3.230. PMID: 12204928.12204928
109 Kessler RC, Berglund P, Demler O, . Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005 Jun;62(6):593–602. doi: 10.1001/archpsyc.62.6.593. PMID: 15939837.15939837