# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Iris Mabry-Hernandez, MD, MPH, AHRQ Medical Officer; current and former member of the U.S. Preventive Services Task Force; expert reviewers: Bryn Austin, ScD, Harvard Medical School; Denise Wilfley, PhD, Washington University School of Medicine; Devan Kansagara, MD, Oregon Health and Science University; Susan Kornstein, MD, Virginia Commonwealth University; federal partners from the Centers for Disease Control and Prevention; Christiane Voisin, MSLS, research librarian; Sharon Barrell, MA, editor; Loraine Monroe, publications specialist; Carol Woodell, EPC Program Manager; Caroline Rains, MPH, research assistant; Kayla Giger, research assistant; Ina Wallace, PhD, senior research analyst.