# Chapter 4 Discussion

## Summary of Evidence

Table 5 provides a summary of the main findings in this evidence review organized by KQ along with a description of consistency, precision, quality, limitations, strength of evidence, and applicability.

## Evidence for Benefit and Harms of Screening

We did not find direct evidence on the benefits and harms of screening. Potential harms include false-positive screening results that lead to unnecessary referrals (and associated time and economic burden), treatment, or labeling. Based on our pooled analyses of the SCOFF for detecting any eating disorder among adults 10 studies (4,348 participants), the expected rate of false-positives tests would be 20 percent (Table 2). Other harms of screening are likely to be minimal because screening is noninvasive.

## Diagnostic Test Accuracy

Screening tools are available for clinical practice that may reasonably identify adults with eating disorders. Of 18 included studies reporting on the accuracy of screening questionnaires, most reported on the SCOFF (k=10) and assessed the accuracy to identify adults with any eating disorder. Most others were assessed by only one study each, limiting our ability to make stronger conclusions about the accuracy of screening tests.

Some studies of screening test accuracy were limited by unclear applicability to populations presenting for routine primary care. For example, the one study assessing the accuracy of a screening questionnaire among adolescents enrolled participants from a pediatric obesity clinic, which is likely to have a higher prevalence of binge eating. Overall, the estimates of SCOFF screening test accuracy were derived from populations with a current prevalence of eating disorders of approximately 4 to 46 percent based on the reference standard.

## Benefits of Interventions for Screen-Detected or Recently Diagnosed Eating Disorders

Forty RCTs evaluated benefits of interventions to improve eating disorder symptoms, most limited to adult women with BED and BN. Included interventions were heterogenous. Both lisdexamfetamine and topiramate were effective in reducing eating disorder severity for populations with BED measured by the YBOCS-BE but were also associated with various adverse effects. Studies reported outcomes over a relatively short duration (8 to 12 weeks). Few studies of SSRIs reported an eligible health outcome specific to eating disorder symptoms, however, results of 5 studies enrolling populations with BED found consistent improvement in depression symptoms associated with various SSRIs based on mean score changes. Although studies did not enroll participants based on depression status, rates of lifetime depression among participants with BED ranged from 37 to 77 percent in four studies that reported on mental health comorbidity. Population cohort studies in the United States indicate high rates of mental health comorbidity among populations with BED. In the 2001–2003 National Comorbidity Replication cohort study (n=9,282), 32 percent of U.S. adults with BED reported a history of major depression and 65 percent reported a history of any anxiety disorder.^109^ Results for other medications were mixed; studies included heterogeneous populations and measured different outcomes. Twenty-three trials assessed a psychological intervention. Guided self-help and unguided self-help BED improved eating disorder symptom severity and depressive symptoms; results for guided self-help were generally more precise and larger in magnitude than pooled estimates for unguided self-help. Group therapy for BED (7 trials; 253 participants) was also more effective for improving depression than inactive control. Only three trials of individual therapy met our inclusion criteria. These trials differed in type of therapy and measured various outcomes, limiting our ability to make stronger conclusions about the benefit of individual therapy compared with inactive control for populations meeting our inclusion criteria (i.e., not previously treated, no obvious signs or symptoms of eating disorders). No studies of psychological interventions reported on potential harms of interventions, including whether some participants experienced increased anxiety or distress as a result of the intervention; however, harms associated with these interventions are likely to be minimal. Despite benefits of these interventions, generalizability to populations detected by routine screening in primary care is limited.

## Limitations

The limitations of the included studies are discussed above in Results and Summary of Evidence. Here we focus on limitations of this review. We excluded studies limited to persons with signs and symptoms of eating disorders, including populations who are underweight (defined by BMI or other criteria). We also excluded head-to-head comparisons of different interventions because the scope was designed to provide evidence on benefits of treatments compared with no treatment rather than assess the comparative effectiveness of interventions. For these reasons, no included studies focused on populations with AN met our eligibility criteria. Second, for studies related to benefits of screening and interventions for screen-detected populations, we limited the review to study designs that included a control group and those that reported on health outcomes. Intermediate outcomes, including mean changes in the frequency of binge-eating episodes over relatively short durations may not indicate that people identified by routine screening have better long-term health outcomes than those who are identified and referred for treatment in the context of routine primary care. Finally, we excluded studies assessing primary prevention strategies to reduce eating disorders (e.g., among groups considered “at risk” but who do not meet threshold or subthreshold eating disorder condition definitions), many of which are targeted to school or university settings. Our aim was to limit the review to interventions for individuals with eating disorders (or subthreshold conditions) that are appropriate to deliver in primary care settings or refer to from primary care.

## Future Research Needs

Trials directly assessing the benefit of screening compared with no screening that focus on health outcomes and enroll asymptomatic or unselected populations from general primary care are needed, as are studies on potential harms of screening such as labeling, harms from false-positive results, burden, and inconvenience. Such studies could also address the acceptability of screening and provide insight on the prevalence of various eating disorders among primary care populations, in addition to clarifying whether routine screening (followed by appropriate referral and treatment) leads to improved health outcomes compared with identification and treatment in the context of usual care. Included trials of eating disorder treatment enrolled treatment-seeking populations, primarily via advertisements. Trials of treatment focused on both adolescent and adult populations that are applicable to U.S. populations would inform future recommendations on the benefit of screening, for example, populations recruited from primary care using brief screening questionnaires. Most included studies of treatment enrolled participants via advertisements and focused on specific eating disorders (primarily BN and BED); the applicability of results to populations that are not seeking care for eating disorder symptoms or who may have a new onset or less severe eating disorder is uncertain.

Accuracy studies enrolling asymptomatic or unselected populations from primary care settings that use consistent definitions of and reference standards to define eating disorder conditions would improve certainty about the accuracy of primary care–relevant screening tests. There is a need for studies assessing screening accuracy among adolescents, given that adolescence is a known time of risk for eating disorder onset. Few included studies enrolled adolescents, and the extent to which screening tools developed for adults are appropriate for adolescents is not clear. Similarly, studies of screening test accuracy that enroll a more diverse population with respect to race, ethnicity, gender, and sexual identity would help assess whether findings are broadly representative of the U.S. population.

The evidence from the current report highlights several important research needs. First, studies directly focusing on health outcomes among screen-detected populations in a general primary care population are needed to better understand the potential benefits and harms of screening. Such studies could also address the potential feasibility and acceptability of screening and provide a better sense of the prevalence of eating disorders in primary care. Some evidence indicates that prognosis is improved when individuals receive diagnosis and treatment early, so future primary care screening studies could confirm whether routine screening in the context of primary care improves outcomes among those who are not seeking treatment and have no obvious signs or symptoms of eating disorders.

## Conclusion

No studies directly assessed the benefits and harms of screening. Screening questionnaires available for use in primary care have adequate accuracy for detecting eating disorders among adults; the most commonly studied screening questionnaire is the SCOFF. The accuracy of screening questionnaires for detecting eating disorders among adolescents is unclear. No treatment studies were found that enrolled participants who were screen detected in primary care. Guided self-help interventions are effective for reducing eating disorder symptom severity and depressive symptoms among referred populations. Lisdexamfetamine and topiramate are effective in reducing eating disorder symptom severity in populations with BED but are also associated with adverse effects.