# Chapter 3 Results

## Literature Search

This review identified 15,037 unique records and assessed 1,451 full-text articles for eligibility (Figure 2). The review excluded 1,392 studies for various reasons, detailed in Appendix C, and included 57 unique studies (described in 59 publications). Of the included studies, 17 studies (described in 18 publications) evaluated the accuracy of one or more screening questionnaires for eating disorders (KQ 2). Forty RCTs (described in 41 publications) addressed the benefits (KQ 4) of interventions compared with no treatment for adults and adolescents with screen-detected eating disorders, and nine studies (described in 8 publications) assessed harms of interventions (KQ 5). No studies evaluating the direct benefits or harms of screening (KQs 1 and 3) were found. Details of quality assessments of included studies and studies excluded because of poor quality are in Appendix D Tables 1–4.

Figure 2 Summary of Evidence Search and Selection

Figure 2 is a flow diagram that documents the search and selection of articles. There were 16,700 unique records identified by searching PubMed (n=8,927), Cochrane Library (n=2,320), and PsycINFO (n=5,453). In addition, 263 records were identified from public comment (n=1), ClinicalTrials.gov (n=262), and handsearching (n=0). In total, 15,037 titles and abstracts were screened for potential inclusion. Of these, 1,451 were deemed appropriate for full-text review to determine eligibility. After full-text review, 1,392 were excluded: 4 for wrong language/non-English; 18 for wrong condition; 231 for wrong population; 215 for wrong screening test; 261 for wrong or no comparator; 279 for wrong or no outcome; 76 for wrong intervention; 30 for wrong setting; 174 for wrong study design; 14 for having intermediate outcomes only; 7 for wrong country; 13 for not being original research; 21 for being abstracts only; and 48 for poor quality. Fifty-seven studies, described in 59 articles, met inclusion criteria. Zero studies were included for Key Question 1. Seventeen studies, described in 18 articles, were included for Key Question 2. Zero studies were included for Key Question 3. Thirty-nine studies, described in 41 articles, were included for Key Question 4. Nine studies, described in 8 articles were included for Key Question 5.

## Results by Key Question

### KQ 1 Does Screening for Eating Disorders in Adolescents and Adults Improve Health Outcomes, Including for Specific Subgroups of Interest?

We identified no eligible studies for this KQ.

### KQ 2 What Is the Accuracy of Primary Care–Relevant Screening Tests for Eating Disorders in Adolescents and Adults, Including for Specific Subgroups of Interest?

#### Summary

Seventeen studies (reported in 18 articles) evaluated the accuracy of screening tests for detecting eating disorders. Most enrolled only females^30,^ ^50–56^ or were predominantly female (>60% girls or women);^29,^ ^57–61^ two enrolled a population with a majority of males, one study set in the Veterans Health Administration (89% male),^62^ and one in a primary and secondary school setting (51% male).^63^ Included studies assessed a range of screening questionnaires that varied in length from a single question^62^ to as many as 16 questions. Screening questionnaires varied in terms of whether they screened for any eating disorder (e.g., transdiagnostic) or if they screened for specific eating disorder diagnoses (e.g., BED only). Thirteen studies evaluated transdiagnostic questionnaires,^29,^ ^30,^ ^51–53,^ ^55–58,^ ^63–65^ and most (k=11 assessed the SCOFF). Four evaluated questionnaires designed to detect eating disorders characterized by binge eating only (e.g., BN or BED).^59–62^ Ten studies (4,348 participants) assessed the accuracy of the SCOFF in adult women or women and men.^29,^ ^30,^ ^51,^ ^53–55,^ ^57,^ ^58,^ ^64,^ ^65^ With a cut point of at least 2, the pooled sensitivity of the SCOFF was 84 percent (95% CI, 74% to 91%), and the pooled specificity was 80 percent (95% CI, 65% to 89%) (10 studies; 3,684 participants). Using a cut point of 3 or greater for the SCOFF, the pooled sensitivity was 69 percent (95% CI, 56% to 80%), and pooled specificity was 90 percent (95% CI, 69% to 98%) (7 studies; 3,424 participants). A single study evaluated the SCOFF in a sample of adolescent girls and boys and found a sensitivity of 73 percent and a specificity of 78 percent.^63^ The only other transdiagnostic screener evaluated by more than one study was the EDS-PC; in two studies, sensitivity of the EDS-PC ranged from 97 to 100 percent, and specificity ranged from 40 to 71 percent using a cut point of at least 2. All other studies of screening test accuracy were evaluated by only one study each.

#### Detailed Evidence

Ten good-^29,^ ^30,^ ^50–52,^ ^54,^ ^55,^ ^57–59,^ ^62,^ ^63^ and 7 fair-quality^53,^ ^56,^ ^58,^ ^60,^ ^61,^ ^64,^ ^65^ studies (reported in 18 articles) assessed the accuracy of 10 screening questionnaires for identifying any eating disorder or specific eating disorders (Table 1).

Table 1 Characteristics of Included Studies for KQ 2

Author, Year; Quality | Screener | Reference Standard: ED Diagnoses Assessed | Type of Study | Recruitment Setting and Country | N | Population | Prevalence of ED (%)^*^ | Age, Mean (SD) | Sex (% F) | % Non-White | Mean BMI (SD)
Lui, 2015^57^; Good | SCOFF | SCID (DSM-IV): AN, BN, BED, EDNOS | Cohort | Outpatient psychiatric clinics; Taiwan | 1,541 | Adults (18-45 y) recruited at their first outpatient psychiatric visit | Any ED: 16 | 31 (7.9) | 61 | NR^†^ | 22.2 (5.4)
Graham, 2019^52^; Good | SWED | EDE (DSM-5): AN, BN, BED | Cohort | University campuses; United States | 549 | College-age women (18-25 y) responding to recruitment ads and flyers for an ED prevention trial | Any ED: 19^‡,¶^ | 21 (1.97) | 100 | 44^¶^ | 24.5 (5.02)
Maugen, 2018^30^; Good | EDS-PC, SCOFF, SDE | EDE-Q (DSM-5^§^): AN, BN, BED | Cross-sectional | VHA medical center; United States | 402 | Female veterans (18-70 y) responding to mailed questionnaires | Any ED: 16^¶^ | 49 (NR)^¶^ | 100 | 52^‖^ | NR
Chamay-Weber, 2017^59^; Good | ADO-BED | SCID (DSM-IV): BED | Cross-sectional | Outpatient pediatric obesity center; Switzerland | 94 | Adolescents (12-18 y) recruited at their outpatient pediatric visit | BED, sub: 28; BED, full: 22; BED, overall: 50 | Median 14 (Range 11-18) | 60 | NR | NR
Dorflinger, 2017^62^; Good | VA-BES | QEWP-R: BED | Cohort | VHA medical center; United States | 116 | Veterans recruited at primary care–based weight management group | BED: 8 | 62 (8.73) | 11 | 26 | 37.9 (7.35)
Luck, 2002;^55^ Hill, 2010^50^; Good | SCOFF | Clinical interview (DSM-IV): AN, BN, EDNOS | Cross-sectional | Primary care practices; United Kingdom | 341 | Women (18-50 y) attending primary care practices | Any ED: 4^¶^ | NR | 100 | NR | NR
Siervo, 2005^53^; Fair | SCOFF | “Clinical diagnosis” (DSM-IV): BN, BED | Cross-sectional | Outpatient diet clinics; Italy | 162 | Women (16-35 y) recruited at an outpatient dietetic clinic | Any ED: 46^¶^ | 24^¶^ | 100 | NR | 29.6^¶^
Parker, 2005^58^; Good | SCOFF | EDE-Q (DSM-IV): AN, BN, EDNOS | Cross-sectional | University Health Center; United States | 297 | Adults (20-51 y) recruited at their campus health visit | Any ED: 20 | <23 y: 10; 23-26 y: 66; >26 y: 23 | 72 | 33 | (Range: 16-44)
Ricca, 2000^61^; Fair | BES | SCID (DSM-IV): BN, BED | Cross-sectional | Outpatient clinic for metabolic diseases; Italy | 344 | Patients recruited at an outpatient clinic for metabolic diseases including obesity | BED: 8 | 43.5 (13.6) | 83 | NR | 35.8 (6.1)
Rosenvinge, 2001^56^; Fair | EDS-5 | SCID (DSM-III-R): Any ED | Cohort | University campuses; Norway | 51 | College-age women (20-42 y) recruited at their teaching and nursing colleges | CED: 20^¶^ | 25.2 (5.33) | 100 | NR | NR
Wan Wahida, 2017^51^; Good | SCOFF | EAT-26 | Cross-sectional | University; Malaysia | 292 | Undergraduate students (18-22 y) who understood English | Any ED: 11 | 20 (0.5) | 65 | Malay: 44; Chinese: 42; Indian: 14 | NR
Mond, 2008^64^; Fair | SCOFF | EDE | Cohort | Primary care practices; United States | 147 | Adult women (18-40 y) recruited at their primary care visit | Any ED: 17 | 28 (6.50) | 100 | 12 | 28.10 (7.20)
Cotton, 2003^29^; Good | SCOFF, ESP | QEDD | Cohort | University campuses and primary care; United Kingdom | 225 | Students (18-65 y) recruited from posters and lecture announcements and adults (18-65 y) recruited at a primary care visit | Any ED: 12 | 29 | 77 | NR | 22
Garcia, 2010^54^; Good | SCOFF | MINI (DSM-IV-TR): Any ED, AN, BN | Cross-sectional | University clinic; France | 400 | Female undergraduate students (18-35 y) | Any ED: 9 | 21 (2.5) | 100 | 14^‖^ | 21.98 (3.5)
Muro-Sans, 2008^63^; Good | SCOFF | EDI-2 | Cross-sectional | Primary and secondary schools; Spain | 954 | Adolescents (10-17 y) recruited from schools | Any ED: 8^¶^ | 14 (1.31) | 49 | NR | NR
Lähteenmäki, 2009^65^; Fair | SCOFF | SCID (DSM-IV): AN, BN, EDNOS | Cohort | Households; Finland | 541 | Young adults recruited via mail | Current AN, BN, EDNOS: 1^¶^; Lifetime AN, BN, EDNOS: 4^¶^ | NR | NR | NR | NR
Striegel-Moore, 2010^60^; Fair | PHQ-ED | EDE (DSM-IV): BN, BED | Cross-sectional | Health maintenance organization; United States | 348 | Adults (18-35 y) selected from the EHR of a HMO via letter | BN or BED: 8^§,¶,^ | 28 (5.38) | 82 | 13 | NR

* “Full” refers to meeting the full diagnostic criteria for a given eating disorder; “sub” refers to a subthreshold condition definition.

† Conducted in Taiwan and required to understand Mandarin.

‡ Also conducted analysis including subthreshold BN, BED, and purging disorder (in addition to threshold AN, BN, and BED).

§ BED defined as an average of one or more objective binge episodes per week without compensatory or purging behaviors.

‖ Enrolled all screen-positive participants and a random sample of those who screened negative.

¶ Computed by data abstractors.

Abbreviations: ADO-BED=Adolescent Binge-Eating Disorder Questionnaire; AN=anorexia nervosa; BED=binge eating disorder; BES=Binge Eating Scale; BMI=body mass index (kg/m^2^); BN=bulimia nervosa; CED=clinical eating disorder; DSM=Statistical Manual of Mental Disorders; EAT-26=Eating Attitudes Test; ED=eating disorder; EDE=Eating Disorder Examination; EDE-Q=Eating Disorder Examination Questionnaire; EDNOS=Eating disorder not otherwise specified; EDS-5=Eating Disturbance Scale-5; EDS-PC=Eating Disorder Screen for Primary Care; EHR=electronic health record; ESP=Eating Disorder Screen for Primary Care; HMO=health maintenance organization; KQ=key question; MINI=Mini International Neuropsychiatric Interview; NR=not reported; PHQ-ED=Eating disorder module of the Patient Health Questionnaire; QEDD=Questionnaire for Eating Disorder Diagnoses; QEWP-R=Questionnaire of Eating and Weight Patterns-Revised; SCID=Structured Clinical Interview for DSM Disorders; SCOFF=not an acronym; SD=standard deviation; SDE=Screen for Disordered Eating; SWED=Stanford-Washington University Eating Disorder screen; VA-BES=Veterans Affairs Binge Eating Screener; VHA=Veterans Health Administration.

Eleven studies (reported in 12 articles) evaluated the SCOFF; most assessed accuracy among adults,^29,^ ^30,^ ^50,^ ^51,^ ^53–55,^ ^57,^ ^58,^ ^63–65^ and one study evaluated an adapted version for use in a pediatric population.^63^ The accuracy of eight other screening questionnaires was evaluated by one study each.^29,^ ^30,^ ^52,^ ^56,^ ^59–62^ Screening questionnaires varied in terms of the range of eating disorders they detected. Most were evaluated to detect any eating disorder (e.g., transdiagnostic),^29,^ ^30,^ ^50–58,^ ^63–65^ and four were designed to detect a disorder in which binge eating is the hallmark (e.g., BN, BED).^59–62^

The screening questionnaires were compared with two categories of reference standards, either a diagnostic clinical interview or a longer self-reported diagnostic questionnaire. Nine studies used a semi-structured interview as the reference standard based on Diagnostic and Statistical Manual (fourth edition) (DSM-IV) or Diagnostic and Statistical Manual fifth edition) (DSM-5) diagnostic criteria, either diagnostic clinical interview^50,^ ^53–57,^ ^59,^ ^61,^ ^65^ or the Eating Disorder Examination (EDE).^52,^ ^64^ Seven studies used the following diagnostic questionnaires to diagnose eating disorders: Questionnaire on Weight and Eating Patterns-Revised (QEWP-R),^62^ Eating Attitudes Test-26,^51^ Questionnaire for Eating Disorder Diagnoses (QEDD),^29^ EDE-Questionnaire (EDE-Q),^30,^ ^58^ EDE-14,^60^ and Eating Disorders Inventory-2.^63^

Most studies (k=6) were set in the United States.^30,^ ^52,^ ^58,^ ^60,^ ^62,^ ^64^ The remainder were in the United Kingdom,^29,^ ^55^ Italy,^53,^ ^61^ Taiwan,^57^ Malaysia,^51^ and other European countries.^54,^ ^56,^ ^59,^ ^63,^ ^65^ Studies enrolled participants from community settings or outpatient clinical settings. Community recruitment of adults most often occurred in a university setting,^29,^ ^51,^ ^52,^ ^54,^ ^56,^ ^58^ while one study recruited young adults identified via a population database through the mail,^65^ and another recruited students from primary and secondary schools.^63^ Outpatient primary care clinics were the most common clinical setting from which patients were recruited (k=5).^29,^ ^30,^ ^55,^ ^62,^ ^64^ Of these, two recruited patients from a Veterans Affairs (VA) primary care clinic,^30,^ ^62^and one enrolled from primary care and a university campus.^29^ Four studies recruited from specialty or referral settings, including one from an outpatient psychiatry clinic^57^ and three from diet or obesity clinics.^53,^ ^59,^ ^61^

Most studies reported on the prevalence of any eating disorder, which ranged from 2 to 46 percent; four studies examined BN or BED only, where prevalence ranged from 8 to 22 percent.^59–62^ The three studies reporting an eating disorder prevalence of greater than 20 percent were conducted in a pediatric obesity clinic,^59^ an outpatient diet clinic,^53^ and a university health center.^58^

Most study populations were either entirely female^30,^ ^50–56^ or predominantly female, enrolling over 60 percent girls or women.^29,^ ^57–61^ Males outnumbered females in two studies: one study set in the Veterans Health Administration (89% male)^62^ and one in a primary and secondary school setting (51% male).^63^ One study did not report the sex of participants.^65^

Sample sizes analyzed varied from 51 to 1,541 participants, with a median of 341. Across the 15 studies that reported on the age of enrolled participants (mean, median, or range), age ranged from 11 to 62 years. Two studies focused on study populations under 18 years of age, recruiting from pediatric or school settings.^59,^ ^63^ Three studies enrolled an older sample of participants, mean ages ranging from 44 to 62 years; two of these studies were set in the Veterans Health Administration,^30,^ ^62^ and one recruited participants from an outpatient specialty clinic for metabolic diseases.^61^ The remaining 10 studies included participants in which the mean age, median age, or age range primary fell between 20 and 30 years.^29,^ ^50–58,^ ^60,^ ^64^ Among the nine studies reporting BMI (mg/kg^2^), four studies reported a mean BMI of less than 25 (underweight or normal),^29,^ ^52,^ ^54,^ ^57^ two studies reported mean BMI ranging from 25 to 30 (overweight),^53,^ ^64^ two studies reported BMI over 30 (obese),^61,^ ^62^ and one study reported BMI range of 16 to 44.^58^

Of the 17 studies, eight^30,^ ^51,^ ^52,^ ^54,^ ^58,^ ^60,^ ^62,^ ^64^ reported on race or ethnicity; the percentage of participants who were non-White ranged from 12 to 100. For the six studies set in the United States, non-White participants ranged from 12 to 52 percent.^30,^ ^52,^ ^58,^ ^60,^ ^62,^ ^64^ Only two studies reported mental health comorbidity: mood disorder (44%) and dysthymia (29%) were the most common psychiatric disorders reported, respectively.^57,^ ^61^

We rated 10 studies as good quality^29,^ ^30,^ ^50–52,^ ^54,^ ^55,^ ^57–59,^ ^62,^ ^63^ and the remainder as fair quality (Appendix D Table 1). In the studies rated as fair quality, common limitations included risk of bias in patient selection (e.g., accuracy metrics based on a subset of participants who underwent screening) and the flow and timing domain.

Screening test accuracy results are organized by screener below. Detailed results by screening questionnaire are also shown in Table 2.

Table 2 Summary of Accuracy for Included Screening Tests (KQ 2)

Screener (Cut Point) | ED Diagnosis | N Studies (Participants) | Sensitivity (%) (95% CI) | Specificity (%) (95% CI) | PLR (95% CI) | NLR (95% CI)
SCOFF (≥3) | Any | 7 (2,749) | Pooled: 69 (56 to 80) | Pooled: 90 (69 to 98) | Pooled: 7.3 (2.2 to 24.0) | Pooled: 0.34 (0.25 to 0.46)
SCOFF (≥2) | Any | 10 (3,684) | Pooled: 84 (74 to 90) | Pooled: 80 (65 to 89) | Pooled: 4.1 (2.3 to 7.3) | Pooled: 0.2 (0.12 to 0.33)
SWED (>59)^52^ | Any | 1 (549) | 80 (NR) | 82 (NR) | NR | NR
EDS-PC (≥2)^29,^ ^30^ | Any | 2 (627) | 97 (88 to 100); 100 (90 to 100) | 40 (35–46); 71 (64 to 77) | NR | NR
SDE (≥2)^30^ | Any | 1 (402) | 91 (80 to 96) | 58 (80 to 96) | NR | NR
EDS-5 (≥16)^56^ | Any | 1 (51) | 90 (NR) | 88 (NR) | NR | NR
PHQ-ED (NA)^60^ | BN, BED | 1 (348) | 100 (NR) | 30 (NR)^*^
ADO-BED (NA)^59^ | BED | 1 (94 adolescents) | 100 (NR) | 27 (NR) | NR | NR
VA-BES (≥ 1)^62^ | BED | 1 (162) | 89 (NR) | 65 (NR) | NR | NR
BES (≥ 17)^61^ | BED | 1 (344) | 85 (NR) | 75 (NR) | NR | NR

* Value calculated based on individual cell frequencies differs from reported specificity value reported in study (91.7% vs. 27.7%, respectively).

Abbreviations: ADO-BED=Adolescent Binge-Eating Disorder Questionnaire; BED=binge-eating disorder; BES=Binge Eating Scale; BN=bulimia nervosa; CI=confidence interval; ED=eating disorder; EDS-5=Eating Disturbance Scale-5; EDS-PC=Eating Disorder Screen for Primary Care; KQ=key question; NA=not available; NLR=negative likelihood ratio; PHQ-ED=Eating disorder module of the Patient Health Questionnaire; PLR=positive likelihood ratio; SCOFF=not an acronym; SDE=Screen for Disordered Eating; SWED=Stanford-Washington University Eating Disorder screen; VA-BES=Veterans Affairs Binge Eating Screener; vs.=versus.

##### Studies Evaluating the SCOFF

Ten studies assessed the accuracy of the SCOFF screening questionnaire among adults (Table 1). Of these, two enrolled populations from primary care settings,^55,^ ^64^ four enrolled from university-based settings,^29,^ ^51,^ ^54,^ ^58^ one recruited veterans,^30^ and two recruited from specialty settings including an outpatient diet clinic and an outpatient psychiatric clinic.^53,^ ^57^ One study used a nationally representative sample of households in Finland.^65^ The SCOFF is a 5-question self-report screening questionnaire assessing the following hallmark criteria for eating disorders: self-induced vomiting, recent weight loss, binge eating, and intrusive thoughts about food or body weight or shape. Scores on the SCOFF range from 0 to 5 with each positive response assigned one point. Using the original cut point of at least 2 in studies enrolling adult men and women or women only, the pooled sensitivity based on 10 studies (4,348 participants) was 84 percent (95% CI, 74% to 90%), and the pooled specificity was 80 percent (95% CI, 65% to 89%) (Appendix F Figure 1). Seven studies (3,424 participants) also assessed the accuracy using a cut point of 3.^51,^ ^53–55,^ ^57,^ ^64^ The pooled sensitivity was lower at 69 percent (95% CI, 56% to 80%), but the specificity improved to 90 percent (95% CI, 69% to 98%) (Appendix F Figure 2).

A single study assessed the accuracy of the SCOFF among a sample of 954 female and male adolescents (mean age=13.6, standard deviation=1.31) enrolled from primary and secondary schools.^63^ The optimal cut point was at least 2, which yielded a sensitivity of 73 percent (95% CI, 63% to 83%) and a specificity of 78 percent (95% CI, 75% to 80%).

Specific populations. Two included studies also evaluated the SCOFF among various populations of adults including sex, age, and BMI; one recruited a sample of 1,541 women and men from an outpatient psychiatric clinic,^57^ and another recruited 147 women from a primary care setting.^64^ The one study reporting on sex differences found that because it used a cut point of at least 2 the SCOFF demonstrated greater sensitivity in women (95% vs. 86%), but greater specificity in men (74% vs. 66%).^57,^ ^64^ With respect to age, younger age (less than 30 years) was associated with better SCOFF performance in women, but the opposite pattern was found among men.^57^ Across both studies, the SCOFF performed better at a lower BMI (<27.5 kg/m^2^) for both women and men (Table 2).^57,^ ^64^

##### Studies Evaluating Other Eating Disorder Screeners

Eight other screening questionnaires were assessed across eight included studies;^29,^ ^30,^ ^52,^ ^56,^ ^59–62^ of these, one (EDS-PC) was assessed in two studies, and all others were evaluated by one study each (Table 1). The screening questionnaires varied in terms of whether they were designed to screen for any eating disorder (i.e., transdiagnostic) or binge eating only. Results are organized by diagnostic category below and in Table 2, highlighting results for commonly used cut points or cut points considered optimal. Many studies reported on the accuracy of screening tests at various cut points, and some reported on the accuracy of different eating disorder reference standard definitions.

Four separate transdiagnostic screening tests were evaluated across four included studies among adults enrolled from various settings including primary care,^29^ colleges or universities,^52,^ ^56^ and the VA.^30^ Two studies evaluated the EDS-PC: one recruited females and males from primary care (77% female)^29^ and the other recruited all female veterans.^30^ The EDS-PC is a 5-item self-report measure developed specifically for use in the primary care setting.^29^ Scores range from 0 to 5, and a cut point of at least 2 is considered a positive screen. Across both studies (627 participants), sensitivity ranged from 97 to 100 percent, and specificity ranged from 40 to 71 percent.^29,^ ^30^

The three remaining transdiagnostic screening tests were assessed in single studies that recruited adult females only.^30,^ ^52,^ ^56^ The Stanford-Washington University Eating Disorder Screen (SWED)^52^ and the Eating Disturbance Scale (EDS)^56^ were both evaluated in college or university populations. The SWED is an 11-item self-report measure derived from existing questionnaires assessing eating disorder behaviors (e.g., dietary restriction, self-induced vomiting) and weight concerns. Among 549 college-aged women, the SWED demonstrated a sensitivity of 80 percent and a specificity of 82 percent in detecting any eating disorder with a cut point of at least 59 on the Weight Concerns Scale (WCS).^52^ The EDS is a 5-item self-report questionnaire that assesses eating-disordered thoughts and behaviors (e.g., feeling guilty after eating, engaging in strict diets). Each item is scored on a Likert-type scale from 1 to 7, with seven being the most pathological response. Using a cut point of at least 16, the EDS had a sensitivity of 90 percent and a specificity of 88 percent among a smaller sample of 51 women enrolled in teaching or nursing colleges.^56^

The Screen for Disordered Eating (SDE) is a 5-item self-report questionnaire derived from existing measures with face valid items that map onto eating disorder diagnoses including AN, BN, and BED.^30^ The SDE was evaluated in a single study of 402 female veterans and demonstrated a sensitivity of 91 percent (95% CI, 80% to 96%) and a specificity of 58 percent (52% to 63%) using a cut point of at least 2.^30^

##### Studies Evaluating Binge-Eating Disorder Screeners

Four studies screened for eating disorders in which binge eating is the hallmark (e.g., BN, BED).^59–62^ Three screening questionnaires were evaluated in adult populations: the Binge Eating Scale (BES),^61^ the VA Binge Eating Screener (VA-BES),^62^ and the Eating Disorder Module of the Patient Health Questionnaire (PHQ-ED).^60^ The BES is a 16-item self-report questionnaire assessing thoughts and feelings associated with binge-eating episodes. Scores range from 0 to 46 with higher scores indicating a more pathological response. In a sample of 334 adults with obesity recruited from an outpatient metabolic clinic, a cut point score of at least 17 on the BES yielded a sensitivity of 85 percent and a specificity of 75 percent.^61^ The VA-BES is a single item derived from a more general assessment used in the VA’s weight management program—the VA MOVE! program.^62^ The binge-eating item (referred to as the VA-BES in this included study) asks participants how often they eat large amounts of food while feeling out of control (i.e., a binge-eating episode) with Likert-type responses ranging from “never” to “five or more times per week.” In a sample of 116 veterans recruited from the MOVE! program (12% female), a cut point of at least 2 on the VA-BES yielded a sensitivity of 89 percent and a specificity of 83 percent.^62^ The PHQ-ED is a 6-item self-report questionnaire that assesses engagement in binge-eating episodes or inappropriate compensatory behaviors (e.g., self-induced vomiting, abuse of laxatives).^60^ Two additional items assessing frequency and duration are required if either binge-eating episodes or inappropriate compensatory behaviors are endorsed. In a sample of 348 adults (82% female) recruited from a health maintenance organization, a positive screen on the PHQ-ED demonstrated a sensitivity of 100 percent and a specificity of 28 percent.^60^

One study assessed a screening for binge eating in adolescents recruited from a pediatric obesity clinic (94 participants, age range 11 to 18 years) using the Adolescent Binge-Eating Disorder Questionnaire (ADO-BED).^59^ The ADO-BED is a 10-item self-report questionnaire that assesses several diagnostic criteria for BED. The first two questions are interrelated and assess the presence of binge-eating episodes (“Do you sometimes have a strong craving to eat although you are not really hungry or have recently eaten?” and “In this situation, do you sometimes find yourself starting to eat and then being unable to stop?”). A positive response to both questions yielded a sensitivity of 100 percent, but a specificity of only 27 percent for detecting binge eating.^59^

### KQ 3 What Are the Harms of Screening for Eating Disorders in Adolescents and Adults, Including for Specific Subgroups of Interest?

We identified no eligible studies for this KQ.

### KQ 4 How Effective Are Interventions for Improving Health Outcomes in Screen-Detected or Previously Untreated Adolescents and Adults With Eating Disorders, Including for Specific Subgroups of Interest?

#### Summary

Forty included RCTs assessed heterogenous interventions, none enrolled populations who were screen-detected. One was limited to adolescents; all others enrolled adults. Most enrolled a majority of women and limited to populations with BED or BN only. Eighteen assessed the benefit of pharmacotherapy. Four trials of lisdexamfetamine for BED (900 participants) measured change in eating disorder symptom severity using the Yale–Brown Obsessive Compulsive Scale modified for binge eating (YBOCS-BE) and found larger reductions in change from baseline scores associated with lisdexamfetamine than placebo (pooled mean difference, −5.75 [95% CI, −8.32 to −3.17]). Two trials compared topiramate with placebo for BED (465 participants) and both found significantly larger reductions in YBOCS-BE scores from baseline among those receiving topiramate than placebo, from −6.40 (p<0.001) to −2.55 (p=0.004). Five trials assessed various selective serotonin reuptake inhibitors (SSRIs) among persons with BED; two reported on change in eating disorder symptoms and results were imprecise. SSRIs were associated with a larger reduction in depression symptom scores than placebo over 6-16 weeks (pooled standardized mean difference [SMD], −0.6 [95% CI, −0.90 to −0.33]) (5 studies; 208 participants). Three trials assessed fluoxetine for populations with BN; two found benefit favoring fluoxetine for eating disorder symptom severity and depression.

Twenty-four trials assessed a psychological intervention. Guided self-help improved eating disorder symptom severity more than control (pooled SMD for difference in change from baseline score, −0.96 [95% CI, −1.26 to −0.67]) (5 studies; 391 participants); pooled estimates for unguided self-help (6 studies, 368 participants) also favored the intervention, but the difference between groups was not statistically significant (SMD, −0.18 [95% CI, −0.38 to 0.03]). Similarly, self-help interventions also reduced depression symptoms more than control, including both guided self-help (pooled SMD, −0.73 [95% CI, −1.04 to −0.43]; 4 studies, 324 participants) and unguided self-help (pooled SMD, −0.37 [95% CI, −0.68 to −0.05]; 3 studies, 156 participants). Few trials of self-help measured other outcomes. Group therapy (7 studies, 253 participants) was associated with larger reductions in depression scores from baseline than inactive control (pooled SMD, −0.48 [95% CI, −0.69 to −0.27]). Few studies of group therapy measured other outcomes. Four studies assessed different forms of individual therapy and measured heterogeneous outcomes. Common limitations included risk of bias due to missing outcome data, and few trials assessed outcomes over a duration longer than 16 weeks (most reported outcomes over 6 to 12 weeks).

#### Detailed Evidence

We identified 40 RCTs comparing an intervention for eating disorders with a control: 18 (19 publications) evaluated pharmacotherapy,^66–82^ and 24 evaluated therapy; two RCTs included both pharmacotherapy and therapy interventions.^83,^ ^84^

##### Pharmacotherapy

Eighteen included trials evaluated the benefit of pharmacotherapy versus placebo among populations with an eating disorder (Table 3); most (k=14) enrolled populations with BED defined by DSM-IV or DSM-5 criteria. Four trials enrolled populations with BN defined by DSM-III criteria,^74,^ ^76,^ ^81,^ ^84^ and two of these were limited to populations with BN and recurrent binge-eating behavior.^81,^ ^84^ No included studies enrolled populations who were screen detected in primary care (or via routine screening in other healthcare settings). Most trials described recruiting participants via media or newspaper advertisements or a combination of both referrals and trial advertisements;^74,^ ^75,^ ^77,^ ^84^ three trials mentioned that advertisements were for studies addressing binge eating and obesity.^77,^ ^79,^ ^81^ Two trials mentioned recruiting participants from referrals or from specialty clinical settings only,^82,^ ^83^ and one trial invited potentially eligible participants identified by chart reviews of patients previously seen at a university-based outpatient clinic for “weight problems.”^78^ Most studies were set in the United States (k=13); three trials (described in 2 publications) enrolled participants from both the United States and other country settings (Canada^76^ or various European countries,^68^) and one trial each was set in Switzerland^78^ and Finland.^82^

Table 3 Characteristics of Randomized, Placebo Controlled Trials of Pharmacotherapy for Eating Disorders (KQ 4)

Author, Year; Quality Rating | Medication Dose | Duration (Weeks) | Recruitment | Population | Country Setting | N | Mean Age, y (SD) | % Female | % Non-White | Mean BMI (SD) | % With Comorbid Psych. Disorder
Arnold, 2002^71^; Fair | Fluoxetine 20-80 mg/day | 6 | Advertisements for a binge-eating trial | Adults (18-60 y) with BED (DSM-IV), ≥3 binge-eating episodes/week for ≥6 m, >85% ideal body weight | United States | 60 | 41 | 93 | 12 | 38.2 | Current MDD: 25; Lifetime MDD: 65
Fluoxetine Bulimia Nervosa Collaborative Study Group, 1992^76^; Fair | Fluoxetine 20-60 mg/day | 8 | Advertisements and referrals | Adult women (≥18 y) with BN (DSM-III-R), ≥3 binge-eating episodes/week for ≥6 m, no other BN treatment initiated in previous month | United States, Canada | 387 | 27 | 100 | 3 | 22.6 | NR
Grilo, 2005^83^; Fair | Fluoxetine 60 mg/day, and fluoxetine 60 mg/day + CBT | 16 | Referrals to a university outpatient treatment center | Adults (18-60 y) with BED (DSM-IV) classified as overweight/obese (100-200% ideal weight for height)^*^ | United States | 108 | 44 (8.6) | 78 | 11 | 36.3 (7.9) | Lifetime MDD: 50%.; Lifetime anxiety d/o: 37%
Guerdjikova, 2012^72^; Fair | Duloxetine 60-90 mg/day^†^ (mean: 77 mg/day) | 12 | Newspaper advertisements for a study on medications for binge eating and depression | Adults (18-65 y) with BED and current depressive disorder (DSM-IV-TR) for ≥4 weeks | United States | 40 | 40 (12.0) | 88 | 17 | 40.6 (7.4) | MDD, recurrent: 63; MDD, single episode: 23; Dysthymic disorder: 13; Lifetime anxiety disorder: 30; Lifetime substance use disorder: 13
Guerdjikova, 2008^79^; Fair | Escitalopram 10-30 mg/day (mean: 27 mg/day) | 12 | Advertisements for trial of binge eating and obesity | Adults (18-60 y) with BED (DSM-IV) and BMI ≥30 | United States | 44 | 39 | 96 | 25 | 40.2 | Current MDD: 23; Lifetime disorder:; MDD: 77; Alcohol use: 11; Anxiety: 23
Guerdjikova, 2016^66^; Fair | Lisdexam-fetamine 20-70 mg/day (mean: 60 mg/day) | 12 | Newspaper advertisements for a study on binge eating | Adults (18-55 y) with BED (DSM-IV) and ≥3 binge-eating episodes/week for ≥2 weeks before enrollment | United States | 50 | 38 (8.9) | 92 | 22 | 39.8 (9.3) | Lifetime disorder:; Depressive: 32; Anxiety: 4; Substance: 2; Probable childhood ADHD: 6
Kaneva, 1995^82^; Fair | Fluoxetine 60 mg/day | 8 | Referrals to an outpatient university psychiatry clinic | Adults and adolescent females (>15 y) with BN (DSM-III-R) and BMI ≥ 16 | Finland | 50 | 25 (range: 16-55) | 100 | NR | NR | NR
Laederach-Hofmann, 1998^78^; Fair | Imipramine 75 mg/day (+ co-intervention)^ǂ^ | 8 | Chart reviews of patients seen at a university outpatient clinic for “weight problems” | Adults (20-60 y) with BED (DSM-IV) and BMI >27.5, seen for weight problems within the previous 2 y | Switzerland | 31 | 38 | 87 | NR | 39.5 | NR
McElroy, 2000^73^; Fair | Sertraline 50-200 mg/day | 6 | NR | Adults (18-60 y) with BED (DSM-IV), ≤3 binge-eating episodes/week for ≥6 m, and 85% of ideal body weight | United States | 34 | 42 (NR) | 94 | NR | 36.1 | Lifetime MDD: 53; Current MDD: 18
McElroy, 2003^81^; Fair | Topiramate 25-600 mg/day; median: 212 mg/day (range: 50-600) | 14 | Radio advertisement for a study of binge eating associated with obesity | Adults (18-60 y) with BED (DSM-IV-TR), BMI ≥30, and marked distress related to binge-eating (YBOCS-BE score ≥15) | United States | 61 | 41 | 87 | NR | 43 | Lifetime disorder:; Depressive: 54; Bipolar: 10
McElroy, 2007^77^; Fair | Topiramate 25-400 mg/day (mean: 300 mg/day) | 16 | Radio and newspaper advertisements for study of medication for binge eating and obesity, and clinical referrals | Adults (18-65 y) with BED (DSM-IV), ≥3 binge days/week 2 weeks before randomization, and BMI ≥30 and ≤ 50 | United States | 404 | 44 | 84 | 22 | 38.5 | NR
McElroy, 2015;^70^ McElroy, 2016^67^; Fair | Lisdexam-fetamine 30, 50, or 70 mg/day | 11 | Clinical research centers, university-affiliated clinics, and psychiatric practices (methods of recruitment NR) | Adults (18-55 y) with BED (DSM-IV-TR), BMI ≥25 and ≤45, and ≥3 binge-eating days/week during a 2-4 week screening period | United States | 260 | 39 (10.2) | 82 | 22 | 34.9 (5.3) | NA^§^
McElroy, 2016a;^68^ Sheehan, 2018^80^; Fair | Lisdexam-fetamine 30-70 mg/day (mean: 57 mg/day) | 12 | Investigators’ databases, local/central advertisements | Adults (18-55 y) with BED (DSM-IV-TR) and ≥3 binge-eating days/week over prior 2 weeks, CGI-S score ≥4, and BMI ≥18 and ≤45 | United States, Sweden, Spain, Germany | 379 | 38 | 87 | 22 | 33.4 | NA^ǁ^
McElroy, 2016b;^68^ Sheehan, 2018^80^; Fair | Lisdexam-fetamine 30-70 mg/day (mean: 58 mg/day) | 12 | Investigators’ databases, local/central advertisements | Adults (18-55 y) with BED (DSM-IV-TR) and ≥3 binge-eating days/week for 2 consecutive weeks before baseline, CGI-S score ≥4, and BMI ≥18 and ≤45 | United States, Germany | 366 | 38 | 85 | 27 | 33.5 | NA^ǁ^
Mitchell, 2001^84^; Fair | Fluoxetine^¶^ 60 mg/day | 16 | Referrals to an outpatient university ED program, local newspaper advertisements | Adult women (≥18 y) with BN (DSM-III-R) and binge eating coupled with self-induced vomiting ≥3 times weekly over previous 6m, within 85% of ideal body weight, not currently receiving other ED treatment | United States | 91 | 27 (7.1) | 100 | 3 | NR | NR
Pearlstein, 2003^75^; Fair | Fluvoxamine up to 300 mg/day (mean 239 mg/day) | 12 | Media advertisement and referral from health professionals | Adults (age range NR) with BED (DSM-IV) | United States | 20 | 41 | 85 | 10 | 41.2 | NR
Walsh, 1991^74^; Fair | Desipramine 200-300 mg/day | 8 | Advertisements in local media and referrals | Adult women (18-45 y) with BN (DSM-III-R) between 85-120% of ideal weight^*^ | United States | 78 | 25 (NR) | 100 | NR | 22.2 | Currently depressed: 52
White, 2013^69^; Good | Bupropion 300 mg/day | 8 | NR | Adult women (18-65 y) with BED (DSM-IV-TR) and BMI 25-50 | United States | 61 | 44 (12.5) | 100 | 16 | 35.8 (6.8) | Lifetime disorder:; Mood: 53; Anxiety: 38; Substance: 25

* Based on the 1959 Metropolitan Life Insurance Company Tables.

† Medication started at 30 mg/day for the first 7 days. At the beginning of the second week, medication was increased, as tolerated, to 60 mg/day and this dose was kept constant for 2 weeks. In the absence of remission of binge eating or depressive symptoms and intolerable side effects, the dose could be further increased as follows: 90 mg/day at the beginning of the fourth treatment week and 120 mg/day at the beginning of the sixth treatment week.

ǂ Both treatment and placebo groups received 30 min of individual diet counseling by a dietician on a biweekly basis in addition to behavioral-oriented psychological support. Individual evaluation of problems (weight, relations in the family, professional concern, personal difficulties) took place after each diet counseling session (for approximately 15–35 min). Participants were also invited to a behavioral-oriented group therapy that took place monthly guided by an assistant dietitian and supervised by a physician.

§ Participants with the following conditions were excluded: current BN, AN, ADHD, or another psychiatric disorder; a lifetime history of bipolar disorder or psychosis or other conditions that may confound efficacy and safety assessments; a total Montgomery-Åsberg Depression Rating Scale score of at least 18 at screening or baseline visits.

ǁ Exclusion criteria included current AN or BN, comorbid current psychiatric disorders either controlled with prohibited medications or uncontrolled and associated with significant symptoms or any condition/symptom that may confound clinical assessment; psychotherapy or weight loss support (including peer support) for BED ≤3 months before screening; use of psychostimulants for fasting or dieting for BED ≤6 months before screening; Montgomery–Åsberg Depression Rating Scale total score ≥18 at screening; being considered a suicide risk by the investigator, having previously made a suicide attempt, or currently demonstrating active suicidal ideation; lifetime histories of psychosis, mania, hypomania, dementia, or ADHD.

¶ Fluoxetine + self-help, self-help manual + placebo.

Abbreviations: ADHD=attention-deficit hyperactivity disorder; AN=anorexia nervosa; BED=binge-eating disorder; BMI=body mass index (kg/m^2^); BN=bulimia nervosa; CBT= cognitive behavioral therapy; CGI-S= Clinical Global Impressions scale-Severity; DSM=Diagnostic and Statistical Manual of Mental Disorders; ED=eating disorder; MDD=major depressive disorder; n=sample size randomized; NA=not applicable; NR=not reported: Psych.=psychiatric; SD=standard deviation; YBOCS-BE=Yale–Brown Obsessive Compulsive Scale modified for binge eating.

All studies enrolled adults, and only one included both adolescents and adults (15 years or older) with BN.^82^ Mean ages of enrolled populations ranged from 25 to 44 years. Five trials were limited to women only,^69,^ ^74,^ ^76,^ ^82,^ ^84^ and all others enrolled a majority of women (78% to 96%). Across 14 studies describing race or ethnicity, all enrolled a minority of non-White participants ranging from 3 to 27 percent. One study of duloxetine was limited to adults with BED and current depressive disorder.^72^ Seventeen trials reported on mean BMI (kg/m^2^), and most enrolled a population with a mean BMI greater than 33; four studies (all focused on populations with BN) enrolled populations with a lower mean BMI (range 25 to 27).^74,^ ^76,^ ^81,^ ^84^ Eleven studies described the proportion of participants with various psychiatric comorbidity using heterogenous definitions (Table 3). The most commonly reported comorbid condition was depression (k=8), with rates of lifetime depressive disorder or any mood disorder ranging from 32 to 77 percent, and rates of current depression ranging from 23 to 52 percent.^66,^ ^69,^ ^71–74,^ ^79,^ ^81^ Ten studies focused on BED limited to populations who were overweight or obese (using various criteria);^69,^ ^70,^ ^77–79,^ ^81,^ ^83^ the mean BMI in these studies ranged from 34.9 to 44.

Studies assessed various pharmacotherapy. Three medications were evaluated by two or more trials: fluoxetine (k=4),^71,^ ^76,^ ^82–84^ lisdexamfetamine (k=4),^66,^ ^68,^ ^70^ and topiramate (k=2).^77,^ ^81^ Medications evaluated by one study include fluvoxetine,^75^ sertraline,^73^ escitalopram,^79^ duloxetine,^72^ bupropion,^69^ desipramine,^74^ and imipramine.^78^ The dose of medications evaluated is shown in Table 2. All trials compared the active medication with placebo. One trial of imipramine included a co-intervention of dietary counseling and psychological support delivered to both groups.^78^

All included trials were parallel RCTs. Sample sizes ranged from 20 to 404 participants, and most evaluated outcomes over a duration of 6 to 12 weeks; three assessed outcomes over a slightly longer duration (16 weeks).^77,^ ^83,^ ^84^ Detailed results of studies are summarized in Appendix E Table 2. Two were rated good quality and the remainder were rated fair. Common limitations included risk of bias due to missing outcome data.

#### Binge-Eating Disorder

##### Lisdexamfetamine

Four trials (described in 3 publications) compared lisdexamfetamine with placebo among adults with BED.^66,^ ^68,^ ^70^ One (n=260) randomized participants to three separate doses of medication (30, 50, or 70 mg/day), and three randomized participants to flexible dosing of lisdexamfetamine (20 to 70 mg/day, mean 57 to 60 mg/day). All measured BED symptom severity using the YBOCS-BE; for doses ranging from 50 to 60 mg/day, pooled mean difference in change from baseline score over 11 to 12 weeks (4 studies, 900 participants) was −5.75 (95% CI, −8.32 to −3.17) (Figure 3). This difference falls within the range considered a minimum clinically important change on the YBOCS-BE (−4 to −17).^85^ Other eligible outcomes were reported by only one or two studies each (Appendix E Table 2). One trial found significantly higher reduction in mean BES scores associated with lisdexamfetamine (difference between groups, −5.4; p=0.002 for 50 mg/day),^70^ but no significant difference on measures of depression, anxiety or QOL using the 12-Item Short Form Survey (SF-12). Two trials (reported in 1 publication) found no significant differences between groups in functional impairment measured by the Sheehan Disability Scale.^68^

Figure 3 LDX and Topiramate

Abbreviations: BED=binge-eating disorder; CI=confidence interval; ED=eating disorder; HAM-A=Hamilton Anxiety Rating Scale; HAM-D=Hamilton Depression Rating Scale-Depression; KQ=key question; MADRS=Montgomery-Åsberg Depression Rating Scale; N=number; YBOCS-BE=Yale–Brown Obsessive Compulsive Scale modified for binge eating.

Figure 3 displays a forest plot reporting the mean differences comparing lisdexamfetamine or topiramate to control on the outcomes of eating disorder symptom severity, depression, and anxiety (KQ 4). Lisdexamfetamine was associated with a reduction in eating disorder symptom severity measured by the YCBOCS-BE (pooled standardized mean difference, −5.75[95% CI, −8.32 to −3.17]; I2 = 82.75; 4 trials). Two trials of topiramate yielded mean differences ranging between −2.55 (95% CI, −4.29 to −0.81) and −6.4 (95% CI, −8.14 to −4.66) in eating disorder symptom severity measured by the YCBOCS-BE. One trial of topiramate yielded a mean difference of −0.55 (95% CI, −1.57 to 0.46) on the HAM-D. One trial of topiramate yielded a mean difference of −0.50 (95% CI, −1.79 to 0.79) on the MADRS. One trial of topiramate yielded a mean difference of −0.60 (95% CI, −1.52 to 0.32) on the HAM-A.

##### Topiramate

Two trials of topiramate (465 participants) measured reduction in eating disorder symptom severity using the YBOCS-BE over 14 to 15 weeks (mean or median dose of 212 to 300 mg/day),^77,^ ^81^ and both found significant improvement favoring topiramate (Figure 3). The difference between groups in mean change from baseline score was within the range considered a minimum clinically important change (−4 to −17) in one trial (−6.40)^77^ but not the other (−2.55).^81^ Neither found a significant difference between groups on depression scores (measured by the Montgomery-Åsberg Depression Rating Scale [MADRS]^77^ and Hamilton Depression Rating Scale [HAM-D]^81^) and one found no significant differences between groups for anxiety measured by Hamilton Anxiety Rating Scale (HAM-A) scores.^70^

##### Selective Serotonin Reuptake Inhibitor

Five trials assessed an SSRI for improving BED: two assessed fluoxetine,^71,^ ^83^ and one study each assessed fluvoxetine,^75^ sertraline,^73^ and escitalopram.^79^ None selected participants based on presence of comorbid depression. Four reported on the proportion with lifetime major depressive disorder with prevalence rates ranging from 37 to 77 percent.^71,^ ^73,^ ^79,^ ^83^ Three trials also reported on the prevalence of current major depressive disorder with rates ranging from 18 to 25 percent.^71,^ ^73,^ ^79^ Two measured eating disorder symptom severity and both found reduction in symptom scores favoring SSRIs (Figure 4), although results were imprecise; other trials of SSRIs reported on intermediate outcomes associated with binge eating only. The trial of fluoxetine^83^ found no significant difference between groups on EDE-Q scores (SMD −0.29; 95% CI, −0.83 to 0.24) and the trial of escitalopram^79^ found significant benefit for YBOCS-BE score reduction (SMD −0.69; 95% CI, −1.30 to −0.08) that did not fall within the range considered a minimum clinically important change (−4 to −17).^85^ All five reported on change in depression symptoms over 6-16 weeks (Figure 4); SSRIs were associated with a larger reduction in depression symptom scores than placebo over 6-16 weeks (pooled SMD, −0.6 [95% CI, −0.90 to −0.33]) (5 studies; 208 participants).

Figure 4 SSRI versus Placebo

Abbreviations: BDI=Beck Depression Inventory; CI=confidence interval; ED=eating disorder; EDE-Q=Eating Disorder Examination Questionnaire; HAM-A=Hamilton Anxiety Rating Scale; HAM-D=Hamilton Depression Rating Scale-Depression; KQ=key question; N=number; SSRI=selective serotonin reuptake inhibitor; YBOCS-BE=Yale–Brown Obsessive Compulsive Scale modified for binge eating.

Figure 4 displays a forest plot reporting the standardized mean differences comparing SSRIs to placebo on the outcomes of eating disorder symptom severity, depression, and anxiety (KQ 4). One trial of escitalopram yielded a standardized mean difference of −0.69 (95% CI, −1.30 to −0.08) on the YBOCS-BE. One trial of fluoxetine yielded a standardized mean difference of −0.29 (95% CI, −0.83 to 0.24) on the EDE-Q. SSRIs were associated with a reduction in depression symptom severity measured by the HAM-D or BDI (pooled standardized mean difference, −0.61 [95% CI, −0.90 to −0.33]; I2=5.92; 5 trials). One trial of fluvoxamine yielded a standardized mean difference of −0.59 (95% CI, −1.59 to 0.41) on the HAM-A.

##### Other Medications

One trial each evaluated duloxetine (n=40),^72^ bupropion (n=61),^69^ and imipramine (n=31) for populations with BED (Appendix E Table 2).^78^ No significant difference was found between groups for any health outcome, including measures of eating disorder symptom severity associated with bupropion (EDE-Q) and duloxetine (YBOCS-BE), and measures of depression associated with imipramine (HAM-D and Self-Rating Depression Scale) and bupropion (BDI).

#### Bulimia Nervosa

Four trials enrolled populations with BN,^74,^ ^76,^ ^82,^ ^84^ including two that limited to populations with BN and recurrent binge-eating behavior.^81,^ ^84^ Three assessed fluoxetine and one assessed desipramine.^74^ One trial of fluoxetine also included an arm comparing fluoxetine plus a self-help intervention with placebo (in addition to fluoxetine alone).^84^

The three trials of fluoxetine assessed a dose of 60 mg/day (Appendix E Table 2); two reported outcomes at 8 weeks^76,^ ^82^ and one at 16 weeks.^84^ All reported on a measure of eating disorder symptom severity. two found benefit associated with fluoxetine over 8 weeks on the Eating Attitudes Test (EAT); differences between groups were significant in one trial (difference in mean change from baseline: −4.5; p=0.001),^76^ but not the second.^82^ One found no significant difference between groups over 16 weeks on the Eating Disorder Inventory (EDI) but only reported a p-value (p>0.05),^84^ All three measured depression using the HAM-D. Only one found a significant difference favoring fluoxetine (difference in mean change from baseline: −2; p<0.001 at 8 weeks). In the other two trials, one found a similar reduction in HAM-D scores favoring fluoxetine that was not statistically significant (−2.10; p=0.12),^82^ and the other reported that changes were not significant but did not provide numerical results for mean score changes.^84^ The one trial assessing a combined intervention (fluoxetine plus self-help vs. placebo) found no significant differences between groups on EDI and HAM-D score changes from baseline.^84^ In the trial assessing desipramine, there was no significant difference between groups on measures of BN symptom severity (EAT), depression (HAM-D, BDI), or anxiety (State-Trait Anxiety Inventory Scores) (Appendix E Table 2).^74^

#### Psychological Interventions

Twenty-four trials assessed the benefit of a psychological intervention for eating disorders compared with an inactive control (Table 4).^83,^ ^84,^ ^86–107^ Most trials enrolled populations with binge eating, either BED defined as those with BN and recurrent binge-eating behavior; one trial enrolled those with BN without mention of binge eating,^106^ and three enrolled women with any eating disorder based on DSM-5.^86,^ ^92,^ ^98^ No included studies enrolled populations who were screen detected in primary care. Most trials recruited participants via media or newspaper advertisements or a combination of both referrals and trial advertisements. Nine trials were set in the United States; others were set in a range of country settings, including the United Kingdom (k=3),^88,^ ^92,^ ^100^ Canada (k=4),^89,^ ^93,^ ^97,^ ^104^ Sweden, (k=2)^91,^ ^96^ Germany (k=3),^87,^ ^99,^ ^106^ and one each in Switzerland,^91^ and Australia.^86^

Table 4 Characteristics of Randomized, Placebo Controlled Trials of Psychological Interventions for Eating Disorders (KQ 4)

Author, Year; Quality | Intervention Type; No. of Sessions | Duration (Weeks) | Control | Country | Population | N | Mean Age, Years (SD) | Sex (% Female) | Race/Ethnicity (% Non-White) | Mean BMI (kg/m^2^)(SD)
Alfonsson, 2015^96^; Fair | Group psychotherapy (Behavioral Activation); 10 weekly 90-minute group sessions | 10 | Wait-list | Sweden | Adults with BED (DSM-5) and obesity (BMI >30) presenting to an initial assessment at an outpatient obesity clinic | 96 | 44 (10.74) | 94 | NR | 41.17 (5.32)
Cachelin, 2019^105^; Fair | Culturally adapted CBT-based guided self-help; 8 25-min guided sessions | 12 | Wait-list | United States | Adult Latinas (18-55 y) who met criteria for BED and had a BMI ≥18 mg/kg, responding to trial advertisement | 40 | 27 | 100 | 100 (Latinas) | 29.4
Carter, 2003^97^; Fair | Unguided CBT-based self-help (Overcoming Binge Eating manual) | 8 | Wait-list and unguided^*^ non-specific self-help control | Canada | Women (≥17 y) with BN (DSM-IV, but inclusive of those with one binge-eating episode and compensatory behaviors per week vs. 2) and BMI ≥18, recruited from a wait-list of patients referred for outpatient ED treatment | 85 | 27 (8) | 100 | 17 | 23 (5)
Carter, 2020^93^; Fair | DBT self-help, guided and unguided (The DBT Solution for Emotional Eating manual); 6 30-min sessions in guided group | 12 | Self-esteem^†^ unguided self-help | Canada | Adults (19-65 y) with BED (DSM-5) and BMI of ≥18.5, recruited from the community or health centers via advertisements | 71 | 41 (11.46) | 93 | 8 | 37.3 (9.4)
DeBar, 2013^107^; Fair | Individual CBT (adolescent specific); 8 in-person sessions, option of supplemental sessions to address mood and interpersonal relationships | 24 | Wait-list | United States | Female adolescents (12-18 y) enrolled in an HMO with BN or BED (DSM-IV) and at least one binge-eating episode over the previous 3 months | 25 | 15 (1.9) | 100 | 29 | 26.6 (5.7)
Fairburn, 2009^92^; Fair | Two forms of individual CBT: focused form targeting ED pathology only or broad form also addressing other problems common with ED; Both groups:1 90-min session, then 20 50-min sessions | 20 | Wait-list | United Kingdom | Adults (18-65 y) with any ED (DSM-IV) requiring treatment (judged by referring provider and ED specialist) and BMI >17.5 | 154 | 26 (7.0) | 96 | 10 | Lowest adult BMI: 18.7 (2.9); Highest adult BMI: 26.4 (4.8)
Green, 2018^98^; Fair | Unguided online dissonance-based intervention (online version of the Body Project); 8 online modules and activities | NR | Wait-list | United States | Adults and adolescents (14-52 y) any ED (DSM-5) or subclinical disorder,^ǂ^ recruited via online advertisements and local flyers | 82 | 26 (6.09) | 100 | 10 | NR
Grilo, 2005^83^; Fair | Individual CBT (+ placebo), or CBT + fluoxetine 60 mg/day; 16 1-hr individual weekly sessions | 16 | Placebo | United States | Adults (18-60 y) with BED (DSM-IV) and overweight/obese (between 100-200% ideal weight for height based on the 1959 Metropolitan Life Insurance Company Tables) | 108 | 44 (8.6) | 78 | 11 | 36.3 (7.9)
Grilo, 2013^90^; Good | Self-help CBT via a structured manual, initiated by PCP; One introductory session with PCP based on trial script^ǁ^ | 16 | Usual primary care | United States | Adults with BED (DSM-IV-TR)^§^ and obesity (BMI ≥30) recruited from primary care settings (via advertisements or referral) | 48 | 46 (11.0) | 79 | 54 | 37.62 (4.79)
Grilo, 2014^95^; Fair | Self-help CBT (+ placebo)^¶^ (Overcoming Binge Eating manual); PCP training and to assist with assigning the program | 12 | Placebo^#^ | United States | Adults (18-65 y) with BED (DSM-5 except for duration of 6 vs.3 months) and obesity (BMI ≥30), recruited from advertisements and referrals in primary care | 53 | 44 | 72 | 55 | 37.9
Hill, 2011^94^; Fair | Individual DBT-appetite focused (DBT-AF); 12 weekly individual sessions | 12 | Wait-list | United States | Adult women (≥ 18 y) with BN (DSM-IV) or subthreshold^**^ BN (at least 1 binge eating and 1 vomit episode per week over the previous 12 weeks); excluded those with BED or AN and those in concurrent therapy for BN | 32 | 22 | 100 | 6 | 22.6 (NR)
Kelly, 2014^89^; Fair | Two forms of self-help: compassion-focused therapy, and behaviorally based self-help; Both groups; 1 in-lab self-help session | 3 | Wait-list | Canada | Adults (>18 y) with BED (DSM-5) not currently receiving therapy, recruited via advertisements | 41 | 45 (15) | 83 | 24 | 33 (1.05)
Laessle, 1987^106^; Fair | Behaviorally oriented group treatment; Twice weekly for 8 weeks, then once weekly 8 weeks | 16 | Wait-list | Germany | Adult women with bulimia (DSM-III) seeking treatment at an outpatient psychiatry clinic | 17 | 23 | 100 | NR | 21.3
Ljotsson, 2007^91^; Fair | Internet-assisted CBT-self-help (Overcoming Binge Eating); E-mail contact from coach (1-2 per week), online private discussion forum | 12 | Wait-list | Sweden | Adults (≥ 18 y) with full or subthreshold BN or BED (criteria NR),^††^BMI ≥18 not receiving current treatment, responding to study advertisements and online trial application form | 73 | 34 | 94 | NR | 28.7
Masson, 2013^104^; Fair | DBT guided self-help; 1 in-person session, 6 biweekly support phone calls | 13 | Wait-list | Canada | Adults (≥ 18 y) with BED (DSM-IV, also including those with binge-eating frequency once weekly for 6 months vs. twice weekly), responding to trial advertisements | 60 | 43 (10.5) | 88 | 8 | 37.97 (NR)
Mitchell, 2001^84^; Fair | Unguided self-help; provision of manual (manual with elements of CBT, behavioral strategies, and meal planning) | 16 | Placebo | United States | Adult women (≥18 y) with BN (DSM-III-R) and binge eating coupled with self-induced vomiting 3 times weekly over previous 6 months, within 85% of ideal body weight, not currently receiving treatment | 91 | 27 (7.1) | 100 | 3 | NR
Sánchez-Ortiz, 2011^88^; Good | Internet-based CBT (Overcoming Bulimia Online); 8 self-guided sessions, 1-2 support emails per week | 12 | Wait-list | United Kingdom | Students (college age) with BN or EDNOS^ǂǂ^ (DSM-IV, but no min number of binge or purge episodes) and BMI >18.5 kg/m^2^, recruited from higher education institutions | 76 | 24 (5.9) | 99 | NR | 22.0 (2.8)
Schag, 2019^99^; Fair | Impulsivity-focused group intervention; 8 weekly 90-min group sessions | 8 | Wait-list | Germany | Adults with BED (DSM-5) recruited by email, flyers, press releases, and from an outpatient psychiatry department of a university hospital | 80 | 40 | 84 | NR | 36.9
Schlup, 2009^102^; Fair | Group CBT; 8 weekly 90-min sessions | 8 | Wait-list | Switzerland | Adults (ages 18-70 y) with BED (DSM-IV-TR), responding to study advertisements | 36 | 44 (10.3) | 100 | NR | 33.4 (7.6)
Schmidt, 2008^100^; Fair | CD-ROM-based unguided CBT; 8 modules | 12 | Wait-list | United Kingdom | Adults^§§^ with BN and EDNOS (DSM-IV), referred by general practitioners to an ED outpatient center | 97 | 27 (7.6) | 97 | 27 | 23.6 (5.2)
Telch, 1990^103^; Fair | Group CBT; 10 weekly 90 min sessions | 10 | Wait-list | United States | Adult women (18-65 y) with compulsive binge eating but no purging (DSM-II-R BN criteria except for purging criterion), responding to trial advertisements | 44 | 43 (8.4) | 100 | 9 | 32.6 (5.1)
Wade, 2017^86^; Fair | Group CBT; 18 2h group sessions, one 1-hr individual session | 8 | Wait-list | Australia | Adult^ǁǁ^ women (18-36 y) with any ED (DSM-5), referred by a clinician or responding to trial advertisements | 40 | 24 (5) | 100 | 5 | 22.12 (0.54)
Wagner, 2016^87^; Good | Web-based CBT; 11 assignments, individual feedback from therapists | 16 | Wait-list | Germany | Adults (18-65 y) with BED (DSM-IV) and no current AN or BN, responding to trial advertisements | 139 | 35 (9.9) | 96 | NR | 32.4 (7.4)
Wilfley, 1993^101^; Fair | Two forms of group therapy: Group-CBT and group interpersonal therapy; 15 90-min sessions | 16 | Wait-list | United States | Adult women (18-65 y) with BN and binge eating (DSM-III BN criteria, and those meeting all BN criteria except for purging), responding to trial advertisements | 56 | 44 (8.3) | 100 | 14 | 32.8 (5.2)

* Provision of Self-Assertion for Women manual of similar length/difficulty as intervention but does not address BN.

† Control group received a self-help book on cognitive behavioral techniques for improving self-esteem that does not address binge eating.

ǂ Definition used for subclinical eating disorder included endorsement of high levels of body dissatisfaction and one or more of the following behaviors at subclinical levels for weight-control purposes on the Questionnaire for Eating Disorder Diagnoses: binging, laxative use, diuretic use, 24-h fasting, appetite control pill use, strict dieting, or maladaptive exercise (exercising despite injury or exercise which interfered with other important activities).

§ Full or subthreshold criteria; subthreshold criteria defined as binge eating greater than once weekly in frequency and with a duration of at least 6 months (42% randomized).

ǁ PCP introduced study and did informed consent; gave patients manual and indicated treatment would be 4 months and they would receive monthly assessments during treatment period.

¶ In addition to groups randomized to self-help + placebo and placebo only, this study included two additional arms involving a medication that is no longer FDA approved (Sibutramine) and therefore not eligible. The sample size and characteristics here refer to only those randomized to self-help + placebo and placebo.

# In addition to groups randomized to self-help + placebo and placebo only, this study included two additional arms involving a medication that is no longer FDA approved (Sibutramine) and therefore not eligible. The sample size and characteristics here refer to only those randomized to self-help + placebo and placebo. Overall, 35 percent had a subclinical diagnosis; of those with a full clinical diagnosis (65%), specific diagnoses included AN (n=1), BN (n=29), BED (n=13), and OSFED (n=10).

** All but six met full DSM-IV criteria for BN.

†† DSM (or other condition definition) used were not reported. Subthreshold BN was defined as at least twice-monthly episodes of binge eating and compensatory behaviors during the last 3 months. Subthreshold BED required at least 2 days with objective bulimic episodes per month during the past 6 months, with binge-eating episodes rated as “markedly stressful.” Overall, 48 percent had BN and 52 percent had BED.

ǂǂ Of those randomized, 51 percent met criteria for BN and 49 percent met criteria for EDNOS.

§§ Of those randomized, 62 percent had BN and 38 percent had EDNOS.

ǁǁ Eight (20%) had AN, 23 (58%) had BN, two (5%) had BED, and seven (18%) had OSFED.

Abbreviations: AN=anorexia nervosa; BED=binge eating disorder; BMI=body mass index (kg/m^2^); BN=bulimia nervosa; CBT=cognitive behavioral therapy; DBT=dialectical behavioral therapy; DBT-AF=dialectical behavioral therapy-appetite focused; DSM=Diagnostic and Statistical Manual of Mental Disorders; ED=eating disorder; EDNOS=Eating disorder not otherwise specified; FDA=Food and Drug Administration; HMO=health maintenance organization; KQ=key question; N=number of participants; No.=number; NR=not reported; OSFED=Other Specified Feeding and Eating Disorder; PCP=primary care physician; SD=standard deviation.

One study was limited to adolescents (12 to 18 years; mean age of 15),^107^ and all others enrolled adults; one study enrolled both adults and adolescents (as young as 14 years).^98^ Among studies enrolling adults, mean ages of enrolled populations ranged from 22 to 46 years. Included studies either limited enrollment to women or girls only (k=11) or enrolled a majority of women (72% to 99%). In 17 studies describing race or ethnicity of enrolled populations, one limited to Latinas only,^105^ two enrolled a population that was 54 to 55 percent non-White (from the United States),^90,^ ^95^ and the others enrolled a population with a majority of White participants. Four studies limited to populations who were overweight or obese only (using various criteria).^83,^ ^90,^ ^95,^ ^96^ Most trials reported on mean BMI (kg/m^2^) (Table 5), and the majority enrolled populations with a BMI in the overweight or obese range; seven enrolled populations with a BMI less than 25.^86,^ ^88,^ ^92,^ ^94,^ ^97,^ ^100,^ ^106^

Table 5 Summary of Evidence for Screening in Eating Disorders in Adolescents and Adults

Key Question and Topic | No. of Studies;; No. of Participants (n) | Summary of Findings | Consistency and Precision | Study Quality | Limitations (Including Reporting Bias) | Overall Strength of Evidence | Applicability
KQ 1. Benefits of screening | 0 (0) | No eligible studies | NA | NA | NA | Insufficient | NA
KQ 2. Accuracy of screening tests for detecting eating disorders | SCOFF (≥2); 10 (3,684) | Pooled:; Sn: 84 (74 to 90); Sp: 80 (65 to 89) | Consistent and precise for Sn; Inconsistent and imprecise for Sp^*^ | 7 Good; 3 Fair | Potential bias related to participant selection. Reference standards varied across studies | Moderate for adequate accuracy | Studies enrolled adults and either limited to women or enrolled a majority of women. Several studies enrolled from specialty clinics or college campuses
| SCOFF (≥3); 7 (2,749) | Pooled:; Sn: 69 (56 to 80); Sp: 90 (69 to 98) | Inconsistent and imprecise for both Sn and Sp^†^ | 4 Good; 3 Fair | Potential bias related to participant selection. Reference standards varied across studies | Low for adequate accuracy | All studies enrolled adults and either limited to women or enrolled a majority of women. Several studies enrolled from specialty clinics or college campuses
| EDS-PC (≥ 2); 2 (627) | Sn:; 97 (88-100); 100 (90-100); Sp:; 40 (35 to 46); 71 (64-77) | Consistent and precise for Sn; inconsistent and imprecise for Sp | 2 Good | Studies used different reference standards and enrolled diverse populations | Insufficient | One study recruited females and males from primary care and college campuses in the U.K. (77% females), and the other recruited female U.S. veterans.
KQ 3: Harms of screening | 0 (0) | No eligible studies | NA | NA | NA | Insufficient | NA
KQ 4. Benefits pharmacotherapy for screen-detected or previously untreated ED | LDX (BED); 4 (900) | Pooled mean difference for reduction in YBOCS-BE scores larger in LDX group vs. placebo: −5.75 (−9.32 to −3.17); Other outcomes assessed by one trial each (depression, anxiety, QOL, and function) | YBOCS-BE: consistent, precise; Other health outcomes: unknown consistency and imprecise | 4 Fair | Outcomes assessed over relatively short duration (11-12 weeks) | Moderate for benefit in ED symptom severity; insufficient for other health outcomes | Studies enrolled adults with BED and obesity recruited via study advertisements.
| Topiramate (BED); 2 (465) | Larger reduction in YBOCS-BE in topiramate groups vs. placebo; difference between groups in score change −6.40 (p<0.001) and −2.55 (p=004).; Other outcomes assessed by one trial each (depression, anxiety). | YBOCS-BE; consistent, imprecise^ǂ^; Other outcomes: unknown consistency, imprecise | 2 Fair | Outcomes assessed over a relatively short duration (14-16 weeks) | Low for benefit in ED symptom severity; insufficient for other outcomes | Studies enrolled adults with BED and obesity recruited via study advertisements.
| SSRIs (BED) 5 (208) | Two reported on ED symptom severity (SMD): fluoxetine (EDE-Q): −0.69 (−1.30 to −0.08), and escitalopram (YBOCS-BE): −0.29 (−0.83 to −0.24).; Larger reduction in depression symptoms among SSRI groups vs. placebo (5 trials): pooled SMD −0.61 (−0.90 to −0.33) | ED symptom severity: unknown consistency,^§^ imprecise; Depression: consistent, imprecise | 5 Fair | Studies assessed different SSRIs and reported outcomes over 6-16 weeks. Study eligibility criteria varied in terms of body weight and duration/frequency of binge-eating episodes. | Insufficient for ED symptom severity; Low for benefit in depression symptom severity | Studies enrolled adults with BED, most recruited via advertisements. Two limited to populations that were obese, and one limited to those with concurrent depression.
| Fluoxetine (BN); 3 (528) | Two^ǁ^ found larger reduction in EAT scores among fluoxetine group vs. placebo, difference was statistically significant in one trial. Two found larger reductions in HAM-D scores among fluoxetine vs. placebo, difference was statistically significant in one trial. | ED symptom severity: consistent; imprecise; Depression symptom severity: consistent; imprecise | 3 Fair | Studies reported outcomes at different durations (8 and 16 weeks). | Low for benefit (ED and depression symptom severity) | All enrolled populations with BN recruited via advertisements; one limited to those with BN and recurrent binge-eating.
KQ 4. Benefits therapy interventions for screen-detected or previously untreated ED | Guided self-help; 7 (431) | Guided self-help reduced ED symptom severity more than control (k=5; 391): pooled SMD −0.96 (−1.26 to −0.67); Guided self-help reduced depression symptoms more than control (k=4, 324): pooled SMD, −0.73 (−1.04 to −0.43) | ED symptom severity: consistent, precise; Depression symptom severity: consistent, precise | 7 Fair | Frequency and mode of delivering guidance varied (e.g., emails, individual sessions); studies assessed ED and depression symptoms using different measures over a relatively short duration (8-16 weeks). | Moderate for benefit (ED and depression symptom severity) | All enrolled adults with BED recruited primarily via advertisements; several limited to populations that were obese
| Unguided self-help; 7 (421) | Pooled results (k=6; 368) favored self-help for reduction in ED symptom severity but difference was not statistically significant: SMD, −0.18 (−0.38 to 0.03); Unguided self-help reduced depression symptoms more than control (k=3,156 participants): SMD 0.37 (−0.68 to −0.05) | ED symptom severity: consistent, imprecise; Depression symptom severity: consistent, imprecise | 7 Fair | Studies assessed ED and depression symptoms using various measures over a relatively short duration (8-16 weeks). Content and underlying theory of some interventions varied. | Low for benefit (ED and depression symptom severity) | All enrolled adults with BED recruited primarily via advertisements; several limited to populations that were obese
| Group interventions; 7 (253) | Group therapy reduced depression symptoms more than control (k=7; 253): pooled SMD, −0.48 (−0.69 to −0.27). Three measured ED symptom severity using the EDE-Q; one found a statistically significant benefit vs. control (SMD −1.01) and two found no significant differences between groups (SMD −0.10 and −0.30) | ED symptom severity: inconsistent, imprecise; Depression symptom severity: consistent, precise | 7 Fair | Type of group therapy differed across studies (e.g., CBT-based, interpersonal therapy). Outcomes were measured over a relatively short duration (8-16 weeks). Number, length, and frequency of sessions varied. | Moderate for benefit in depression symptom severity; insufficient for ED symptom severity | All enrolled adults with BED recruited primarily via advertisements; several limited to populations that were obese
| Individual interventions; 4 (319) | One trial assessing two forms of individual CBT found no significant differences between groups on EDE-Q scores); one trial of AF-DBT found significant improvement in EDE-Q scores (SMD, −1.18; −1.94 to −0.43).; One trial of CBT found improvement on BDI scores (SMD −0.60, −1.14 to −0.06) and a trial of DBT-AF found significant improvement on BDI-II scores (SMD, −0.92, −1.65 to −0.19). One trial limited to adolescents found no significant improvement in depression (BDI scores) or psychosocial function (SCARED scores). | Unknown consistency; imprecise | Fair | Trials addressed different types of individual therapy (e.g., CBT, DBT) and reported on different outcomes over a relatively short duration (6 to 16 weeks) | Insufficient | All enrolled adults with BED (or BED and BN) referred or recruited via trial advertisements.
KQ 4. Harms of pharmacotherapy for screen-detected or previously untreated ED | 9 (2,006) | LDX (k=4) is associated with higher rates of dry mouth, headache, and insomnia vs. placebo. Topiramate (k=2) is associated with significant higher rates of paresthesia, taste, and difficulty with concentration/confusion vs. placebo. Trials of other medications were assessed by only one study each and results were imprecise. | LDX: consistent; imprecise; Topiramate; consistent, imprecise; Other medications: unknown consistency; imprecise | Fair | Some trials did not prespecify adverse events or describe how they were ascertained; trials assessed adverse events over a relatively short duration. | Topiramate and LDX: Moderate for increased rates of various adverse effects; Other medications: insufficient | All studies enrolled adults with BED and obesity, recruited via referrals or study advertisements. Most studies of LDX limited to populations without ADHD, substance abuse or other psychiatric comorbidity
KQ 4. Harms of therapy interventions for screen-detected or previously untreated ED | 0 (0) | No eligible studies | NA | NA | NA | Insufficient | NA

* Based on Appendix F Figure 1, the 95 percent prediction region indicates the results are mostly consistent for sensitivity and somewhat inconsistent for specificity; based on the 95 percent confidence region, estimates are precise for sensitivity and somewhat imprecise for specificity.

† Based on Appendix F Figure 2, the 95 percent prediction region indicates results are inconsistent; based on the 95 percent confidence region, estimates are imprecise.

ǂ Difference between groups in mean YBOCS-BE met threshold considered to be an MCIC in only one of two studies.

§ Although results were in same direction of effect (favoring SSRI), only two studies assessed change in ED symptom reduction. Each assessed a different medication using different measures of ED symptom burden (YBOCS-BE vs. EDE-Q) and reported outcomes at slightly different durations (12 vs. 16 weeks), limiting ability to assess consistency for this outcome.

ǁ One additional trial (n=42) assessed Fluoxetine 60mg/day for BN and reported no significant difference between groups for ED symptom severity (EDI) and depression (HAM-D), p>0.05

Abbreviations: ADHD=attention deficit hyperactivity disorder; AF-DBT=appetite focused-dialectical behavior therapy; BDI=Beck Depression Inventory; BED= binge eating disorder; BN=bulimia nervosa; CBT=cognitive behavioral therapy; DBT=dialectical behavior therapy; DBT-AF=dialectical behavior therapy, appetite focused; EAT=Eating Attitudes Test; ED=eating disorders; EDE-Q=Eating Disorder Examination Questionnaire; EDI=Eating Disorder Inventory; EDS-PC=Eating Disorder Screen for Primary Care; k=number of studies; HAM-D=Hamilton Depression Rating Scale-Depression; KQ=key question; LDX=lisdexamfetamine; MCID=minimal clinically important change; n=number of participants; NA=not applicable; No.=number; QOL=quality of life; SCARED= Screen for Child Anxiety Related-Emotional Disorders; SMD=standardized mean difference; Sn=sensitivity; Sp=specificity; SSRI=selective serotonin reuptake inhibitor; U.K.=United Kingdom; US=United States; YBOCS-BE=Yale–Brown Obsessive Compulsive Scale modified for binge eating; vs.=versus.

All included trials were parallel RCTs. Sample sizes ranged from 17 to 154 participants and most evaluated outcomes over a duration of 8 to 16 weeks. Studies focused on a variety of psychological interventions (Table 4). Most evaluated a form of self-help (k=14) based on CBT, DBT, or other strategies designed to help participants cope with eating disorder symptoms.^84,^ ^88–91,^ ^93,^ ^95,^ ^97,^ ^98,^ ^100,^ ^104,^ ^105,^ ^108^ Seven trials evaluated a type of group therapy for eating disorders,^86,^ ^96,^ ^99,^ ^101–103,^ ^106^ and four evaluated a form of individual CBT.^83,^ ^92,^ ^94,^ ^107^ Appendix E Table 1 provides additional detail related to the intervention components and intensity. Results are summarized below by intervention type.

#### Self-Help Interventions

Of the 13 trials evaluating a self-help intervention, seven assessed a form of “guided” self-help,^87,^ ^88,^ ^91,^ ^93,^ ^100,^ ^104,^ ^105^ and seven assessed an “unguided” self-help intervention.^84,^ ^89,^ ^90,^ ^93,^ ^95,^ ^97,^ ^98^ One trial compared both guided and unguided self-help interventions with a control.^93^ Guided interventions included ongoing support and guidance; for example, three studies included six to eight brief (25- to 30-minute) individually guided sessions or phone calls for support:^93,^ ^104,^ ^105^ two provided regular email contact with coaches, (1 to 2 per week)^88,^ ^91^ and one provided individual feedback from therapists on 11 completed assignments.^87^ Unguided interventions involved providing the intervention materials with instructions (e.g., providing a written manual or access to online modules with activities). Most (k=9) self-help interventions were based on CBT, two were based on DBT,^93,^ ^104^ one trial each assessed other types of self-help, including an online form of The Body Project intervention,^98^ and one trial assessed two forms of self-help (compassion-focused therapy and behaviorally based self-help).^89^

Most trials of self-help reported on changes in eating disorder severity and depression using various outcome measures. Figure 5 shows results for self-help interventions organized by intervention type (guided or unguided) and outcome. For reduction in eating disorder symptom severity (measured by the EDE or EDE-Q), guided self-help was associated with a larger reduction in eating disorder severity scores than control over 12-24 weeks [pooled SMD, −0.96 [95% CI, −1.26 to −0.67] [5 studies, 391 participants]). Results from studies assessing unguided self-help (6 studies, 368 participants) were consistent in favoring self-help, but pooled results were not statistically significant (SMD, −0.18 [95% CI, −0.38 to 0.03]) (Figure 5). For measures of depression, pooled results demonstrated larger reductions in mean scores than controls for both guided self-help (SMD, −0.73 [95% CI, −1.04 to −0.43]; 4 studies; 324 participants) and unguided self-help (SMD, −0.37 [95% CI, −0.68 to −0.05]; 3 studies; 156 participants).

Figure 5 Results of Randomized, Controlled Trials of Self-Help Interventions for Eating Disorders (KQ 4)

Abbreviations: BDI=Beck Depression Inventory; BDI-II=Beck Depression Inventory-II; CBT=cognitive behavioral therapy; CI=confidence interval; DBT=dialectical behavioral therapy; ED=eating disorder; EDE=Eating Disorder Examination; EDE-Q=Eating Disorder Examination Questionnaire; HADS-Dep=Hospital Anxiety and Depression Score—Depression score; KQ=key question; MADRS=Montgomery-Åsberg Depression Rating Scale.

Figure 5 displays a forest plot reporting the standardized mean differences comparing self-help interventions to control on the outcomes of eating disorder symptom severity and depression (KQ 4). Guided self-help was associated with a reduction in the EDE-Q and EDE (pooled standardized mean difference, −0.96 [95% CI, −1.26 to −0.67]; I2 = 46.37; 5 trials). Six trials of unguided self-help yielded a pooled standardized mean difference of −0.18 (95% CI, −0.38 to 0.03; I2 = 0.00). Guided self-help was associated with a reduction in depression symptoms measured by the BDI-II, BDI, MADRS, or HADS-D (pooled standardized mean difference, −0.73 [95% CI, −1.04 to −0.43]; I2=41.88; 4 trials). Unguided self-help was associated with a reduction in depression symptoms measured by BDI (pooled standardized mean difference, −0.37 [95% CI, −0.68 to −0.05]; I2 = 0.00; 3 trials).

Few trials of self-help measured other outcomes. One trial of DBT guided self-help (n=60) measured the Eating Disorder Quality of Life Scale (EDQLS) over 13 weeks and found significantly higher improvement in EDQLS scores from baseline among the self-help group than controls (18.37 vs. 0.14; difference in change from baseline: 18.23; p<0.05).^104^ A second trial of DBT self-help (assessing both guided and unguided interventions) measured general health-related QOL using the Short Form 6D (SF6D) and found no significant differences between either form of self-help and controls.^93^ Finally, one trial of guided CBT-self-help measured QOL using the World Health Organization Quality of Life scale at 12 weeks and only reported on subdomain scores; results were mixed, with significant improvement on some domains but not others.^88^ Two studies reported on anxiety (one guided and one unguided) using different outcome measures and time points; one (n=56) found a statistically significant benefit in favor of guided CBT at 12 weeks on the HADS-Anxiety scale (SMD, −0.91 [95% CI, −1.38 to −0.44])^88^ and one trial (n=76) of unguided CBT found no significant differences between groups at 8 weeks on the BAI (SMD, −0.50 [95% CI, −1.03 to −0.03].^97^

#### Group and Individual Interventions

Outcomes from trials assessing group or individual psychological interventions are shown in Figure 6. Seven trials assessed a group-based psychological intervention, including four CBT-based group interventions,^86,^ ^101–103^ and one trial each of group-based behavioral activation,^96^ behaviorally oriented therapy,^106^ impulsivity-focused therapy^99^ and interpersonal therapy.^101^ One trial compared two forms of therapy (CBT based and interpersonal therapy based) with a control group.^101^ Most enrolled women with BED or BN and recurrent binge eating; one enrolled women with any eating disorder based on DSM-5.^86^ Most offered 8 to 10 weekly group sessions (90 minutes each); one trial offered sessions twice weekly for 8 weeks, then 8 weekly sessions (total of 16).^106^ Most studies of group interventions reported on depression using various measures (Figure 6); group therapy was more effective than control for reducing depression symptoms over 8 to 16 weeks (pooled SMD, −0.48 [95% CI, −0.69 to −0.27]) (7 studies; 253 participants). Few studies of group therapy measured other outcomes. Three measured eating disorder symptom severity using the EDE-Q; one study of group-based CBT found a statistically significant benefit compared with controls (SMD, −1.01 [95% CI, −1.71 to −0.31]),^86^ and two trials found no significant differences between groups (Figure 6).^96,^ ^99^ Two trials of group therapy assessed changes in anxiety scores over 8 to 10 weeks, and neither found a significant difference between groups (Figure 6).^96,^ ^99^

Figure 6 Results of Randomized, Controlled Trials of Group and Individual Therapy for Eating Disorders (KQ 4)

Abbreviations: BAI=Beck Anxiety Inventory; BDI=Beck Depression Inventory; BDI-II=Beck Depression Inventory-II; CBT=cognitive behavioral therapy; CBT-Ef=focused form of enhanced cognitive behavioral therapy; CBT-Eb=broad form of enhanced cognitive behavioral therapy; CI=confidence interval; DBT=dialectical behavioral therapy; DBT-AF=appetite focused dialectical behavioral therapy; ED=eating disorder; EDE=Eating Disorder Examination; EDE-Q=Eating Disorder Examination Questionnaire; HADS-Anx=Hospital Anxiety and Depression Score—Anxiety score; HADS-Dep= Hospital Anxiety and Depression Score—Depression score; IPT=interpersonal therapy; KQ=key question; MADRS=Montgomery-Åsberg Depression Rating Scale.

Figure 6 displays a forest plot reporting the standardized mean differences comparing group and individual therapy to control on the outcomes of eating disorder symptom severity, depression, and anxiety (KQ 4). Three trials of group therapy yielded standardized mean differences ranging between −1.01 (95% CI, −1.71 to −0.31) and −0.1 (95% CI, −0.50 to 0.30) in the EDE-Q. Group therapy was associated with a reduction in depression symptoms measured by the BDI, BDI-II, and HADS-Dep (pooled standardized mean difference, −0.48 [95% CI, −0.69 to −0.27]; I2=0.00; 7 trials). Two trials of group therapy yielded standardized mean differences ranging between −0.34 (95% CI, −0.99 to 0.32) and −0.03 (95% CI, −0.43 to 0.38) in anxiety symptoms measured by the BAI and HADS-Anx. Three trials of individual therapy yielded standardized mean differences ranging between −0.19 (95% CI, −0.59 to 0.20) and −0.15 (95% CI, −0.53 to 0.24) on the EDE-Q. Two trials of individual therapy yielded standardized mean differences ranging between −0.92 (95% CI, −1.65 to −0.19) and −0.6 (95% CI, −1.14 to −0.06) in depression symptoms measured by the BDI and BDI-II.

Four trials assessed an individual psychological intervention. One trial of CBT (8 sessions) was limited to adolescents and found no significant difference between CBT and control groups at 12 or 24 weeks on measures of depression (BDI) and psychosocial functioning (Youth Social Adjustment Scale).^107^ Of the three trials enrolling adults, two focused on individual CBT (16 to 21 sessions),^83,^ ^92^ and one evaluated appetite-focused DBT (AF-DBT) delivered over 12 weekly sessions.^94^ One trial evaluated two forms of individual CBT (n=154): one focused on eating disorder pathology only, and a second “broad form” also addressed other problems common with eating disorders^92^ and found no significant differences between groups in the change from baseline EDE-Q scores (Figure 6). The second trial of individual CBT (n=108) found a significant improvement in depression scores (measured by the BDI) among the intervention group compared with controls (SMD, −0.60 [95% CI, −1.14 to −0.06]).^83^ Finally, the trial of AF-DBT (n=32) found improvement in EDE-Q scores (SMD, −1.18 [95% CI, −1.94 to −0.43]) and depression measured by the BDI-II (SMD, −0.92 [95% CI, −1.65 to −0.19]) over 6 weeks (Figure 6).^94^

### KQ 5 What Are the Harms of Interventions for Eating Disorders, Including for Specific Subgroups of Interest?

No included studies of psychological interventions reported on harms. Nine trials of pharmacotherapy reported various harms associated with four medications, including lisdexamfetamine (k=4),^66,^ ^68,^ ^70^ topiramate (k=2),^77,^ ^81^ fluoxetine (k=2),^71,^ ^76^ and escitalopram (k=1).^79^ Characteristics are described in KQ 4 and Table 3, and outcomes are shown in Appendix E Table 3.

In one trial of lisdexamfetamine (n=259) over 11 weeks,^70^ one participant died during the study, and postmortem toxicology analysis found that methamphetamine/amphetamine levels were consistent with a methamphetamine overdose (death was not attributed to the study drug). Across all three arms of lisdexamfetamine and placebo, rates of specific adverse effects were low (Appendix E Table 3); combined incidence of any treatment-emergent adverse events was higher (85%) for the treatment group than the placebo group (59%).^70^ Similarly, a second trial (n=50) of lisdexamfetamine reported few rates of specific adverse events over 12 weeks;^66^ those that were significantly higher in the treatment arm versus control included insomnia, jitteriness, and dry mouth. Finally, in one study reporting on two separate trials of lisdexamfetamine (626 total participants), more than 50 percent in each treatment group reported treatment-emergent adverse events; more treatment-emergent adverse events were related to lisdexamfetamine than with placebo, those reported by more than 10 percent treated with lisdexamfetamine included dry mouth, headache, and insomnia (vs. no treatment-emergent adverse events reported by more than 10% of the placebo groups).^68^

Two trials of topiramate reported rates of specific adverse events over 14-16 weeks, and both found significantly higher rates of paresthesia and taste perversion^77,^ ^81^ among groups receiving topiramate versus placebo; one also found significantly higher rates of difficulty concentrating^77^ and another found significantly higher rates of confusion.^81^

In three trials of SSRIs, one assessing fluoxetine found rates of several adverse effects significantly higher in the treatment arm than in the placebo arm (Appendix E Table 3), such as insomnia, nausea, and tremor; however, authors noted that there was no significant difference between groups in the proportion that discontinued because of adverse effects. The second trial of fluoxetine reported no significant differences between groups for any adverse effects over 6 weeks.^71^ The trial of escitalopram (n=44) reported adverse effects experienced by 5 percent or more of enrolled participants (Appendix E Table 3) and reported that no differences between groups were statistically significant.^79^