# Chapter 2 Methods

## Key Questions and Analytic Framework

The scope and key questions (KQs) were developed by the Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers. The analytic framework and KQs that guided the review are shown in Figure 1. Five KQs were developed for this review:

1. Does screening for eating disorders in adolescents and adults improve health outcomes, including for specific subgroups of interest?
2. What is the accuracy of primary care–relevant screening tools for eating disorders in adolescents and adults, including for specific subgroups of interest?
3. What are the harms of screening for eating disorders in adolescents and adults, including for specific subgroups of interest?
4. How effective are interventions for improving health outcomes in screen-detected or previously untreated adolescents and adults with eating disorders, including for specific subgroups of interest?
5. What are the harms of interventions for eating disorders, including for specific subgroups of interest?

Figure 1 Analytic Framework

Figure 1 depicts the key questions within the context of the eligible populations, screenings/interventions, comparisons, outcomes, and settings. On the left, the population of interest is adults and adolescents without recognized signs or symptoms of eating disorders. Moving from left to right, the figure illustrates the overarching question: Does screening for eating disorders in adults and adolescents improve health outcomes (KQ 1)? The figure depicts the pathway from screening to reduction in the morbidity and mortality of eating disorders to illustrate the question: What is the accuracy of primary care-relevant screening tools for eating disorders in adolescents and adults (KQ 2). Screening may result in harms (KQ 3). After early detection of eating disorders, the figure illustrates the following questions: How effective are interventions for improving health outcomes for screen-detected or previously untreated adults and adolescents with eating disorders and do interventions improve health outcomes compared with no interventions, usual care, or different treatment targets (KQ 4)? Treatment may result in harms (KQ 5).

## Data Sources and Searches

We searched PubMed/MEDLINE, the Cochrane Library, and PsycINFO for English-language articles published through June 23, 2020. Medical Subject Headings were used as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, tests, interventions, outcomes, and study designs. Complete search terms and limits are detailed in Appendix B1. This search was updated during the peer review process by applying the same search strategies, limited from the date of the original searches through December 18, 2020. Targeted searches for unpublished literature were conducted by searching ClinicalTrials.gov. To supplement electronic searches, reference lists of pertinent articles were reviewed. Studies suggested by peer reviewers or public comment respondents were reviewed and, if appropriate, were incorporated into the final review. Since December 18, 2020, ongoing surveillance was conducted through article alerts and targeted searches of journals to identify major studies published in the interim that might affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on January 1, 2022 and no additional studies meeting eligibility criteria were identified. All literature search results were managed using EndNote™ version 9.2 (Thomson Reuters, New York, NY).

## Study Selection

Inclusion and exclusion criteria for populations, interventions, comparators, outcomes, settings, and study designs were developed with input from the USPSTF (Appendix B2). For all KQs, English-language studies of adolescents and adults age 10 years or older conducted in settings generalizable to primary care, including school-based health centers and other community settings, and in countries categorized as “very high” on the United Nations Human Development Index were included.^43^ Studies limited to populations undergoing evaluation for bariatric surgery or who were identified based on physical signs or symptoms associated with eating disorders were also excluded, including studies limited to populations who are underweight. These include treatment studies (KQ 4) limited to populations with AN who are underweight. Measurement of weight and BMI are part of routine primary care, and assessment of eating disorders would be part of the diagnostic evaluation for those identified as being underweight. The scope of this review is focused on populations with eating disorders who are unlikely to be detected based on physical signs or symptoms in the context of routine care.

For KQs 1 and 3 (direct evidence of benefits and harms of screening), controlled clinical trials enrolling adults with asymptomatic or undetected eating disorders comparing screening with no screening were eligible. Cohort studies with a concurrent control group for KQ 3 (harms of screening) were also eligible. For KQ 2 (accuracy of eating disorder screening tests), cohort or cross-sectional studies of asymptomatic or unselected adolescents or adults comparing one or more screening tests with an acceptable reference standard. Eligible reference standards included a structured or semi-structured diagnostic interview with a mental health clinician or diagnostic questionnaire (e.g., Eating Disorder Examination-Questionnaire). For KQs 1 through 3, eligible screening tests included those used, or feasible for use in primary care settings (e.g., the SCOFF or the EDS-PC. Studies evaluating tests not feasible for routine screening in primary care settings (e.g., longer, time-intensive questionnaires such as the 26-item Eating Attitudes Test) or investigating serologic screening (e.g., using biomarkers) were excluded.

For KQs on benefits (KQ 4) and harms (KQ 5) of treatment, controlled clinical trials of adolescents and adults with screen-detected eating disorders (from primary care or other healthcare settings) were included. Studies enrolling populations from specialty settings who were referred or found the study through advertisements and were diagnosed with an eating disorder but had not been previously treated for eating disorders were also included. As noted above, studies limited to populations identified based on physical signs or symptoms of eating disorders were excluded. Cohort studies with a concurrent control group for KQ 5 (harms of treatment) were also eligible. Eligible studies evaluated psychological interventions (e.g., cognitive behavioral therapy or other forms of therapy) delivered in a group, individual or family-based sessions, including variations of self-help interventions, or pharmacotherapy with Food and Drug Administration–approved medications. Interventions that combine psychological interventions with pharmacotherapy, or those that include other components such as education or nutritional counseling (in addition to therapy or pharmacotherapy) were also eligible. Eligible studies had to compare treatment with an inactive control group (i.e., no treatment, wait-list, minimal intervention [e.g., brief education about eating disorders], or placebo in controlled pharmacotherapy studies). Head-to-head comparisons of two active treatments were excluded. Public awareness campaigns without specific interventions linked to screening, complementary and alternative therapies, those considered to be adjunctive therapy (e.g., acupuncture, herbal supplements, massage, light therapy), and interventions designed for primary prevention of eating disorders only were ineligible.

Eligible outcomes for KQs on the benefit of screening or treatment (KQs 1 and 4) include measures of health outcomes such as eating disorder remission or symptom reduction based on validated questionnaires (e.g., Eating Disorders Examination-Questionnaire) or diagnostic interviews, health-related quality of life (QOL) or function, depression, and others. Intermediate outcomes were excluded, such as mean change in BMI and frequency of specific behaviors (e.g., change in frequency of binge-eating episodes). For KQ 2 (accuracy of eating disorder screening tests), we included studies reporting on test accuracy, including sensitivity and specificity. Eligible outcomes of KQ 3 (harms of screening) include increased anxiety and labeling and stigma associated with screening, and for KQ 5 (harms of treatment), we included any harms attributed to interventions, such as adverse effects associated with medications.

Two investigators independently reviewed titles and abstracts; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. The full texts were then independently reviewed by two investigators to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus. Covidence systematic review software (Covidence, Melbourne, Australia) was used to assign and track literature review decisions.^44^

## Quality Assessment and Data Abstraction

Two reviewers independently assessed each study’s methodological quality. Disagreements in study quality ratings were resolved through discussion or with an independent assessment from a third senior investigator. For randomized, controlled trials (RCTs), the most recent versions of the Cochrane Risk of Bias Tool (RoB 2.0) available for parallel and crossover trials was used.^45^ It assessed the following risk-of-bias domains: bias arising from selection or randomization, bias due to missing outcome data, bias due to departures from intended interventions, bias from measurement of outcomes, and bias from selective reporting of results. For studies of diagnostic test accuracy, the QUADAS-2 instrument was used.^46^ Our risk-of-bias assessments using these instruments were translated into an overall study quality rating of good, fair, or poor using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B3). Only studies rated as having good or fair quality were included.

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. A second team member reviewed all data extractions for completeness and accuracy.

## Data Synthesis and Analysis

Findings for each KQ were summarized in tabular and narrative format. The overall strength of the evidence for each KQ was assessed as high, moderate, low, or insufficient based on the overall quality of the studies, consistency of results between studies, precision of findings, risk of reporting bias, and limitations of the body of evidence, using methods developed for the USPSTF (and the EPC program).^47^ Additionally, the applicability of the findings to U.S. primary care populations and settings was assessed. Discrepancies were resolved through consensus discussion.

To determine whether meta-analyses were appropriate, the clinical heterogeneity and methodological heterogeneity of the studies were assessed following established guidance.^48^ The populations, tests, treatments, comparators, outcomes, and study designs were assessed qualitatively, looking for similarities and differences. For KQ 2 pooled sensitivities and specificities for screening tests were calculated using a hierarchical summary receiver operating characteristic curve analysis when at least four similar studies were available. For KQ 4, we ran random-effects restricted maximum likelihood models on continuous measures of eating disorder and depression symptom severity (analyzing standardized mean difference or unstandardized mean difference in change between groups) when at least three similar studies were available. For psychological interventions, we pooled studies separately for guided self-help, unguided self-help, and group interventions. When studies reported more than one continuous outcome for eating disorder symptom severity, we preferentially selected the outcome most commonly reported by similar studies. Comprehensive Meta-Analysis version 3.4 (Biostat Inc) and Stata version 16 were used to conduct all quantitative analyses.^49^

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF website for public comment from June 25, 2020, to July 28, 2020. In response to comments, the following changes were made: (1) added two specific populations based on a rationale for how these factors may affect outcomes of screening and treatment: “sexual orientation” (in addition to “gender identity”) and “recruitment setting”; (2) clarified which specific populations are of interest in this review by removing the “part b” from each KQ and adding “including for specific populations of interest” at the end of each KQ (3); clarified that interventions designed for primary prevention only are not eligible (KQs 4 and 5); and (4) clarified that eligible interventions could have multiple components. The final version of the research plan was posted on the USPSTF website on September 24, 2020. A draft report was reviewed by four content experts, one representative of Federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments received. In response to these comments, we provided additional information regarding the rationale for screening, clarified the scope of the review and limitations of included studies, and expanded the future research needs section. The draft report was posted for public comment from October 19, 2020 to November 16, 2020. Minor revisions were made based on comments received to clarify the rationale for population eligibility criteria and eligibility criteria for studies of treatment. All references suggested by expert or public reviewers were evaluated for inclusion/exclusion.

## USPSTF and AHRQ Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions and to resolve issues around scope for the final evidence synthesis.

AHRQ staff provided oversight for the project, coordinated systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.