# Chapter 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to inform a recommendation on screening adolescents and adults for eating disorders in primary care settings to prevent adverse health outcomes. The USPSTF has not previously made a recommendation on this topic.

## Condition Definition

Eating disorders refer to a group of psychiatric conditions marked by a disturbance in eating or eating-related behaviors that impairs physical or psychosocial functioning. Current diagnostic criteria are based on the fifth version of the Diagnostic and Statistical Manual of Mental Disorders (DSM-5),^1^ which divides eating disorders into mutually exclusive diagnoses based on observed symptoms (summarized in Appendix A Table 1). This review focuses on common eating disorders that have the potential to be asymptomatic or undetected in the context of routine primary care, including the following: anorexia nervosa (AN), avoidant/restrictive food intake disorder (ARFID), bulimia nervosa (BN), binge-eating disorder (BED), and other specified eating or feeding disorder (OSFED). DSM-5, released in 2013, included several changes to previous eating disorder diagnostic criteria. Most notably, BED was categorized as a separate diagnosis instead of being included as an eating disorder not otherwise specified (EDNOS), and the frequency and duration criteria for BN and BED were lowered compared with criteria in the previous version of the DSM. Additionally, amenorrhea was removed from the diagnostic criteria for AN.

As with the previous version of the DSM, current eating disorder diagnoses remain mutually exclusive (individuals are not given more than one diagnosis at a time);^1^ however, there are similarities between diagnostic criteria, and many individuals experience diagnostic crossover during their lifetime. Individuals may also experience varying levels of eating disorder symptom burden with threshold diagnoses indicating that all diagnostic criteria have been met and subthreshold diagnoses indicating that some but not all criteria are met. Based on strict DSM-5 criteria, these individuals may be diagnosed with OSFED, which includes those with symptoms that cause significant distress or impair psychosocial functioning but do not meet the full criteria for a specific eating disorder. However, in the published research literature, these individuals are often categorized as having a “subthreshold” diagnosis for a specific eating disorder rather than OSFED. Definitions for subthreshold eating disorder diagnoses vary across research studies or clinical settings; however, common definitions include endorsement of key behaviors (e.g., binge-eating episodes) that fall short of the required frequency and duration thresholds. This review includes populations diagnosed with full or subthreshold eating disorder diagnoses to be inclusive of populations likely to be detected by routine screening in primary care.

## Prevalence

Details of study cohorts and results of nationally representative surveys of eating disorders’ prevalence in the United States are summarized in Appendix A Table 2.

### Age

Among adults (age 18 years or older), the most recent estimates come from the National Epidemiologic Survey on Alcohol and Related Conditions (NESARC-III) (n=36,309) fielded between 2012 and 2013 using DSM-5 criteria. Lifetime prevalence for AN, BN, and BED in women were 1.42 percent, 0.46 percent, and 1.25 percent, respectively.^2^ Estimates were lower among men (AN, 0.12%; BN, 0.08%; BED, 0.42%). Other prevalence estimates for adults come from smaller surveys conducted between 2001 and 2003 that categorized eating disorders using DSM-IV criteria: the National Comorbidity Replication Survey (NCS-R) (n=2,980) and the Collaborative Epidemiologic Psychological Surveys (CEPS) (n=12,337). Compared with these older surveys, the estimated prevalence of AN among women was higher in the NESARC-III (1.42% vs. 0.90% in the NCS-R) but lower for BN and BED (BN 0.08% vs. 1.50% in the NCS-R; BED 0.42% vs. 3.50% in the NCS-R). The lower prevalences of BN and BED were unexpected given the lower number of binge episodes required for diagnosis by DSM-5 compared with DSM-IV, although NESARC was a larger cohort compared with the other studies.^2^

Across age categories, younger adults are at higher risk of having a lifetime-prevalent eating disorder than older populations. In a national sample, the odds of lifetime risk of AN, BN, and BED for individuals ages 18 to 29 years compared with those older than 60 years was 2.0 (95% confidence interval [CI], 0.7 to 5.3), 16.8 (95% CI, 3.0 to 95.6), and 4.9 (95% CI, 2.1 to 11.5), respectively.^3^ Similar correlations of younger age and higher risk of BN and BED were observed in an international study of 14 countries. The odds of BN for participants ages 18 to 29 years compared with those age 60 years was 21.4 (95% CI, 11.5 to 39.6) and for BED 14.6 (95% CI, 9.1 to 23.6).

Among adolescents (12 to 17 years), the NCS-A (adolescent supplement to the NCS-R) (n=10,123) estimated prevalence of eating disorders based on surveys conducted in 2001 and 2004 using DSM-IV criteria.^4^ Lifetime prevalences of AN, BN, and BED were 0.3 percent, 1.3 percent, and 2.3 percent, respectively, for females and 0.3 percent, 0.5 percent, and 1.3 percent for males.

### Race/Ethnicity, Sexual Identity, and Gender Identity

Prevalence estimates of eating disorders also varied by race/ethnicity, sexual identity, and gender identity. Data from large, national samples indicated that White individuals are approximately twice as likely to receive a lifetime diagnosis of AN compared with Black individuals and 5 times as likely compared with Hispanic individuals.^2,^ ^5^ However, contrary to previous conceptualizations of eating disorders, there is a demonstrated burden of eating disorders among racial and ethnic minorities. Data from the NESARC indicate that the odds of lifetime diagnosis of BN and BED among Black and Hispanic individuals were not significantly different from White counterparts, and the CEPS study found BN was more prevalent among Latinos, Asians, and African Americans than non-Latino Whites.^5^ Evidence also suggests that transgender adolescents and young adults have higher rates of eating disorders than same-age peers.^6^ In fact, a 2015 survey of U.S. university students (N=289,024, mean age 20 years) found that transgender students had higher rates of self-reported eating disorder diagnoses than cisgender heterosexual women (15.82% vs. 1.85%) and higher rates of past-month vomiting or laxative use (15.01% vs. 3.71%).^7^

## Burden and Natural History

Eating disorders are associated with significant short-term and long-term adverse health outcomes, including physical, psychological, and social problems.

### Physical Complications

Eating disorders can lead to physical complications affecting all organs and systems. Specific complications vary by diagnosis and frequency of certain behaviors. For example, purging behaviors (e.g., self-induced vomiting, laxative abuse, and diuretic abuse) are associated with morbidity affecting the teeth, esophagus, gastrointestinal system, kidneys, skin, cardiovascular system, and musculoskeletal system.^8^ BN is particularly associated with consequences related to purging, including cardiovascular issues (e.g., arrhythmias, cardiac failure), electrolyte disturbances, pancreatitis, gastric erosions or perforations, dental erosion, and renal injury.^8^ BED, if untreated, can contribute to obesity (30% to 45%) and related metabolic disorders.^9^ AN is associated with physical complications directly attributed to weight loss and malnutrition, such as low bone density and increased fracture prevalence.^10^ The degree of weight loss and chronicity of illness increase the risk of complications.^11^

### Mortality

Evidence also suggests that individuals with eating disorders have higher mortality rates than the general population, particularly those with AN.^12^ One meta-analysis (36 studies) estimated weighted annual mortality for AN, BN, and BED as 5.10 deaths (95% CI, 3.99 to 6.14) per 1,000 person-years, 1.74 deaths (95% CI, 1.09 to 2.44) per 1,000 person-years, and 3.31 deaths (95% CI, 1.48 to 5.75) per 1,000 person-years, respectively. The overall pooled standardized mortality rates (ratio of the crude mortality rate to the expected mortality rate) for AN, BN, and BED were 5.86, 1.93, and 1.92, respectively.^13^

### Psychological and Social Complications

Eating disorders are commonly comorbid with other psychiatric conditions including mood, anxiety, and substance abuse disorders.^14^ Across eating disorder diagnoses, depression is the most common comorbidity followed by alcohol use disorder.^14^ Eating disorders have also been associated with disturbances in cognitive and emotional functioning;^15^ however, there is debate about whether deficits are etiologic (and lead to eating disorders) or whether deficits occur because of consequences of the disorder. In one case-control study (N=148), cognitive impairment was more frequent in patients with long-term eating disorders (>10 years) compared with healthy controls, but those with short-term eating disorders (<2 years) had similar performance as controls on neuropsychological testing.^16^ In terms of social function, results from one nationally representative sample using the National Institute on Alcohol Abuse and Alcoholism’s Alcohol Use Disorder and Associated Disabilities Interview Schedule-5 to measure function found high rates of any social impairment in persons across all eating disorders, with significantly higher impairment among those with BN (61.4%) and BED (53.7%) than those with AN (30.7%).^2^ Similarly, participants with BN (49.5%) and BED (52.5%) reported greater interference with daily activities than participants with AN (23.5%). Other evidence suggests disparities in social functioning across ethnic groups. In one nationally representative survey assessing functional impairment using the World Health Organization’s Disability Assessment Schedule instrument, African Americans with AN, BN, or BED reported significantly greater levels of impairment with respect to days out of role due to mental disorder, cognition, mobility, and role functioning compared with the non-Latino White reference group, with similar findings for men and women.^5^

## Etiology and Risk

Much about the natural history and pathogenesis of eating disorders is not well understood. Underlying causes of eating disorders have been categorized into predisposing (background vulnerabilities), precipitating (environmental context at onset), and perpetuating factors (secondary aspects of the illness that cause it to be valued and maintained).^17,^ ^18^

Predisposing risk factors for eating disorders can be biological, psychological, or socioenvironmental. Twin studies and gene studies suggest genetic heritability may contribute to the risk of developing AN or BN.^19–21^ Identified psychological and socioenvironmental factors include childhood adversity or trauma,^20,^ ^22^ personality traits such as rigidity and attention to detail, perfectionism, and a high ability to delay reward.^17^ Recent evidence suggests an association between food insecurity and higher rates of eating disorder pathology.^23^ Additionally, both psychological and societal pressures may serve to maintain an eating disorder including idealization of a thin physique, social isolation, and overcontrol of weight and shape.^17^

Research also suggests that some groups are at disproportionate risk for eating disorders. As summarized in the prevalence section, women have a higher rate of lifetime eating disorders than men, and younger adults (18-29 years) have a higher rate of prevalent eating disorders compared with those older than 50 years.^3^ Risk of eating disorder diagnosis also varies by race/ethnicity: White populations have higher rates of prevalent AN and BN, while BED is more prevalent among racial minorities.^2^ Similarly, sexual and gender minorities have demonstrated a higher risk for eating disorders than their heterosexual and cisgendered peers.^24,^ ^25^ Athletes are another group at higher risk of having an eating disorder. In a study of elite athletes compared with age-matched controls, 13.5 percent of elite athletes met diagnostic criteria for threshold or subthreshold eating disorders compared with controls from the general population (4.6%, p<0.001).^26^ In terms of natural history, morbidity and mortality associated with untreated eating disorders are summarized above. For those diagnosed with one eating disorder, evidence suggests that diagnostic crossover is relatively common over time.^1^ For example, in one cohort study of women diagnosed with AN or BN (n=216) 34 percent with an initial diagnosis of AN later developed BN, and 14 percent of those originally diagnosed with BN developed AN over 7 years of followup.^27^

## Rationale for Screening and Screening Strategies

Routine screening for eating disorders in populations without signs or symptoms could detect eating disorders early or identify disorders not otherwise known, lead to earlier treatment, and reduce future morbidity and mortality. Assessment of weight, height, and body mass index (BMI) is considered the standard of care in primary care settings, and changes in growth or weight may lead to detection of some eating disorders. Those without obvious physical symptoms may go unrecognized, or symptoms may be attributed to other conditions. In addition, individuals experiencing eating disorder symptoms may not seek care for various reasons. A 2017 systematic review on perceived barriers of help-seeking for eating disorders (k=13 studies) found the following to be the most commonly reported barriers: stigma and shame, denial of and failure to perceive the severity of illness, practical barriers (e.g., cost of treatment), low motivation to change, negative attitudes toward seeking help, lack of encouragement from others to seek help, and lack of knowledge about help resources.^28^ Screening questionnaires are available that could be used in primary care settings, including those designed to detect a range of eating disorders, such as the Eating Disorder Screen for Primary Care (EDS-PC),^29^ Screen for Disordered Eating,^30^ and the SCOFF, which some experts recommend not considering an acronym since signaling questions are based on specific terminology from each signaling questions (e.g., “Have you recently lost more than O ne stone in a 3 month period?”).^31^ Some screening questionnaires that could be used in primary care are designed to detect eating disorders in which binge eating is the hallmark (e.g., BN, BED).

## Interventions/Treatment for Eating Disorders

Broadly speaking, the recommended treatments for eating disorders involve an interdisciplinary approach encompassing psychological/behavioral, medical, and nutritional interventions.^32–36^ Given the complicated nature of eating disorder symptomatology, screen-detected or newly diagnosed patients are typically referred to specialists for a diagnostic evaluation and specific treatment recommendations based on symptomatology and symptom severity.

Psychological components of treatment include a range of psychotherapies, including family-based therapy (the Maudsley Method), cognitive behavioral therapy, dialectical behavioral therapy, acceptance and commitment therapy, and interpersonal psychotherapy.^37,^ ^38^ Many of these were initially developed for other psychiatric conditions but have since been adapted for use in patients with eating disorders. Specific approaches to psychological interventions may vary based on eating disorder diagnosis and severity. Medical management centers around monitoring physical and medical complications of the eating disorder (e.g., cardiac instability, musculoskeletal injury, endocrine function) and providing appropriate medical intervention.^37,^ ^38^

In terms of pharmacotherapy, there is only one Food and Drug Administration–approved pharmacological monotherapy for the treatment of an eating disorder (lisdexamfetamine for BED). However, other psychotropic medications have been evaluated and are sometimes prescribed to patients to address eating disorder symptoms as well as comorbid psychiatric conditions (e.g., depression, anxiety) but are not always indicated.^37,^ ^38^ Nutritional management is focused on providing nutritional rehabilitation to patients who are malnourished and/or helping patients establish a regular pattern of eating that encourages variety and flexibility.^37,^ ^38^ Although the interdisciplinary components of treatment are typical for eating disorder management, guidance may vary by age, with children/adolescents typically requiring a greater involvement of parents/guardians in the treatment process and adults being able to engage in treatment more independently.^39,^ ^40^

The treatment components above can be administered throughout different levels of care depending on the severity of the eating disorder symptoms. Levels of care can include inpatient medical hospitalization, inpatient psychiatric hospitalization, residential care, partial hospitalization (or day treatment), intensive outpatient therapy, and outpatient therapy. Determination of the appropriate level of care is typically overseen by an eating disorder specialist(s) in conjunction with primary care providers who can provide input on the overall medical status/stability of the patient. Several established guidelines provide guidance on the level of care, and each takes into account medical stability (including weight status), severity and/or frequency of risky eating disorder behaviors (e.g., self-induced vomiting, laxative/diuretic misuse), and overall psychiatric stability (e.g., risk for suicide, chronicity of the disorder).^34–36^ Availability of specialty services and/or geographic limitations are acknowledged as crucial in making level-of-care determinations.

## Recommendations of Other Organizations and Current Clinical Practice

Appendix A Table 3 summarizes recommendations from other organizations relevant to screening for eating disorders in clinical settings. Many guidelines mention screening in the context of monitoring for potential signs and symptoms of eating disorders. For example, the American Congress of Obstetricians and Gynecologists’ recommendations highlight gynecologic concerns/symptoms associated with eating disorders and recommend providers be comfortable recognizing and screening “at-risk” patients.^41^The American Academy of Pediatrics recommends screening for eating disorders by monitoring and assessing risk factors and symptoms at annual and sports physicals, including monitoring for changes in height, weight and BMI longitudinally.^42^ Similarly, guidelines from specialty groups promote awareness of eating disorder symptoms and screening of certain groups who may be at risk (e.g., adolescent and young female athletes). Screening rates for eating disorders in primary care are not clear; we found no recent estimates in the literature related to current clinical practice.