# Appendix F Pooled Analyses of Screening Test Accuracy (KQ 2)

Appendix F Figure 1 Summary Receiver Operating Characteristics Curve for Screening Test Accuracy of SCOFF (cut-point ≥ 2) in Adults

Figure Notes: The 95% confidence region provides a visual estimate of the amount of variation around the pooled estimate that is due to sampling variation (i.e., chance). It is the region within which we expect the true pooled summary point to lie. It can be used to assess precision of the pooled estimate. The smaller the region, the more precise the estimate. In this figure, precision of the estimates for specificity is higher compared with the precision of the estimates for sensitivity. The 95% prediction region provides a visual estimate of the between-study variability that cannot be attributed to chance. It is the region within which we expect any future individual study estimate to lie. It can be used to assess the consistency of study findings. The larger the prediction region is within the SROC space and relative to the size of the confidence region, the more inconsistency (i.e., heterogeneity) is present.

Abbreviations: HSROC=hierarchical summary receiver operating characteristic; SROC=summary receiver operating characteristic.

Appendix F Figure 1 is a Receiver Operating Characteristics curve diagram depicting the pooled sensitivity and the pooled specificity of ten studies using a cut point of at least 2.

Appendix F Figure 2 Summary Receiver Operating Characteristics Curve for Screening Test Accuracy of SCOFF (cut-point ≥ 3) in Adults

Figure Notes: The 95% confidence region provides a visual estimate of the amount of variation around the pooled estimate that is due to sampling variation (i.e., chance). It is the region within which we expect the true pooled summary point to lie. It can be used to assess precision of the pooled estimate. The smaller the region, the more precise the estimate. In this figure, precision of the estimates for specificity is higher compared with the precision of the estimates for sensitivity. The 95% prediction region provides a visual estimate of the between-study variability that cannot be attributed to chance. It is the region within which we expect any future individual study estimate to lie. It can be used to assess the consistency of study findings. The larger the prediction region is within the SROC space and relative to the size of the confidence region, the more inconsistency (i.e., heterogeneity) is present.

Abbreviations: HSROC=hierarchical summary receiver operating characteristic SROC=summary receiver operating characteristic.

Appendix F Figure 2 is a Receiver Operating Characteristics curve diagram depicting the pooled sensitivity and the pooled specificity of seven studies using a cut point of at least 3.

## Appendix Reference

1 American Psychiatric Association, D. S. M. Task Force. Diagnostic and statistical manual of mental disorders : DSM-5. Arlington, VA: American Psychiatric Association; 2013.
2 Hudson JI, Hiripi E, Pope HG, Jr., . The prevalence and correlates of eating disorders in the National Comorbidity Survey Replication. Biol Psychiatry. 2007 Feb 1;61(3):348–58. doi: 10.1016/j.biopsych.2006.03.040. PMID: 16815322.16815322
3 Kessler RC, Berglund P, Chiu WT, . The US National Comorbidity Survey Replication (NCS-R): design and field procedures. Int J Methods Psychiatr Res. 2004;13(2):69–92. doi: 10.1002/mpr.167. PMID: 15297905.15297905
4 Kessler RC, Ustun TB. The World Mental Health (WMH) Survey Initiative Version of the World Health Organization (WHO) Composite International Diagnostic Interview (CIDI). Int J Methods Psychiatr Res. 2004;13(2):93–121. doi: 10.1002/mpr.168. PMID: 15297906.15297906
5 Swanson SA, Crow SJ, Le Grange D, . Prevalence and correlates of eating disorders in adolescents. Results from the national comorbidity survey replication adolescent supplement. Arch Gen Psychiatry. 2011 Jul;68(7):714–23. doi: 10.1001/archgenpsychiatry.2011.22. PMID: 21383252.21383252
6 Kessler RC, Avenevoli S, Costello EJ, . Design and field procedures in the US National Comorbidity Survey Replication Adolescent Supplement (NCS-A). Int J Methods Psychiatr Res. 2009 Jun;18(2):69–83. doi: 10.1002/mpr.279. PMID: 19507169.19507169
7 Duncan AE, Ziobrowski HN, Nicol G. The Prevalence of Past 12-Month and Lifetime DSM-IV Eating Disorders by BMI Category in US Men and Women. Eur Eat Disord Rev. 2017 May;25(3):165–71. doi: 10.1002/erv.2503. PMID: 28127825.28127825
8 Udo T, Grilo CM. Prevalence and correlates of DSM-5-Defined Eating Disorders in a nationally representative sample of U.S. adults. Biol Psychiatry. 2018 Sep 1;84(5):345–54. doi: 10.1016/j.biopsych.2018.03.014. PMID: 29859631.29859631
9 Grant BF, Kaplan K, Shepard J, . Source and accuracy statement for wave 1 of the 2001–2002 National Epidemiologic Survey on Alcohol and Related Conditions. 2003.
10 Hornberger LL, Lane MA. Identification and management of eating disorders in children and adolescents. Pediatrics. 2020:e2020040279. doi: 10.1542/peds.2020-040279.33386343
11 ACOG Committee Opinion No. 740: gynecologic care for adolescents and young women with eating disorders. Obstet Gynecol. 2018 Jun;131(6):e205–e13. doi: 10.1097/aog.0000000000002652. PMID: 29794682.29794682
12 Yager J, Andersen A, Devlin M, . Practice guideline for the treatment of patients with eating disorders: American Psychiatric Association; 2002.
13 National Institute for Health Care Excellence. Eating disorders: recognition and treatment: NICE; 2017.
14 Academy for Eating Disorders’ Medical Care Standards Committee. Eating disorders: a guide to medical care: AED; 2016.
15 Golden NH, Katzman DK, Sawyer SM, . Position paper of the society for adolescent health and medicine: medical management of restrictive eating disorders in adolescents and young adults references. J Adolesc Health. 2015;56(1):121–5.25530605
16 Lock J, La Via MC. Practice parameter for the assessment and treatment of children and adolescents with eating disorders. J Am Acad Child Adolesc Psychiatry. 2015;54(5):412–25.25901778
17 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force procedure manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed December 17, 2019.
18 Agras WS, Schneider JA, Arnow B, . Cognitive-behavioral and response-prevention treatments for bulimia nervosa. J Consult Clin Psychol. 1989 Apr;57(2):215–21. doi: 10.1037//0022-006x.57.2.215. PMID: 2708607.2708607
19 Alfonsson S, Parling T, Ghaderi A. Group behavioral activation for patients with severe obesity and binge eating disorder: a randomized controlled trial. Behav Modif. 2015;39(2):270–94. doi: 10.1177/0145445514553093. PMID: 2015-07848-002.25268019
20 Alger SA, Schwalberg MD, Bigaouette JM, . Effect of a tricyclic antidepressant and opiate antagonist on binge-eating behavior in normoweight bulimic and obese, binge-eating subjects. Am J Clin Nutr. 1991 Apr;53(4):865–71. doi: 10.1093/ajcn/53.4.865. PMID: 2008865.2008865
21 Arnold LM, McElroy SL, Hudson JI, . A placebo-controlled, randomized trial of fluoxetine in the treatment of binge-eating disorder. J Clin Psychiatry. 2002 Nov;63(11):1028–33. doi: 10.4088/jcp.v63n1113. PMID: 12444817.12444817
22 Bachar E, Latzer Y, Kreitler S, . Empirical comparison of two psychological therapies. Self psychology and cognitive orientation in the treatment of anorexia and bulimia. J Psychother Pract Res. 1999 Spring;8(2):115–28. PMID: 10079459.10079459
23 Barlow J, Blouin J, Blouin A, . Treatment of bulimia with desipramine: a double-blind crossover study. Can J Psychiatry. 1988 Mar;33(2):129–33. doi: 10.1177/070674378803300211. PMID: 3284630.3284630
24 Cachelin FM, Gil-Rivas V, Palmer B, . Randomized controlled trial of a culturally-adapted program for Latinas with binge eating. Psychol Serv. 2019;16(3):504–12. doi: 10.1037/ser0000182. PMID: 2018-14470-001.29620392
25 Carrard I, Crépin C, Rouget P, . Randomised controlled trial of a guided self-help treatment on the internet for binge eating disorder. Behav Res Ther. 2011;49(8):482–91. doi: 10.1016/j.brat.2011.05.004. PMID: 2011-11595-001.21641580
26 Carter JC, Fairburn CG. Cognitive-behavioral self-help for binge eating disorder: a controlled effectiveness study. J Consult Clin Psychol. 1998 Aug;66(4):616–23. doi: 10.1037//0022-006x.66.4.616. PMID: 9735577.9735577
27 Carter JC, Olmsted MP, Kaplan AS, . Self-help for bulimia nervosa: a randomized controlled trial. Am J Psychiatry. 2003;160(5):973–8. doi: 10.1176/appi.ajp.160.5.973. PMID: 2003-03852-025.12727703
28 Carter JC, Kenny TE, Singleton C, . Dialectical behavior therapy self-help for binge-eating disorder: a randomized controlled study. Int J Eat Disord. 2020 Mar;53(3):451–60. doi: 10.1002/eat.23208. PMID: 31821592.31821592
29 DeBar LL, Striegel-Moore RH, Wilson GT, . Guided self-help treatment for recurrent binge eating: replication and extension. Psychiatr Serv. 2011 Apr;62(4):367–73. doi: 10.1176/ps.62.4.pss6204_0367. PMID: 21459987.21459987
30 DeBar LL, Wilson GT, Yarborough BJ, . Cognitive behavioral treatment for recurrent binge eating in adolescent girls: A pilot trial. Cogn Behav Pract. 2013;20(2):147–61. doi: 10.1016/j.cbpra.2012.04.001. PMID: 2012-15354-001.23645978
31 Duarte C, Pinto-Gouveia J, Stubbs RJ. Compassionate Attention and Regulation of Eating Behaviour: A pilot study of a brief low-intensity intervention for binge eating. Clin Psychol Psychother. 2017 Nov;24(6):O1437–o47. doi: 10.1002/cpp.2094. PMID: 28612453.28612453
32 Fairburn CG, Cooper Z, Doll HA, . Transdiagnostic cognitive-behavioral therapy for patients with eating disorders: a two-site trial with 60-week follow-up. Am J Psychiatry. 2009 Mar;166(3):311–9. doi: 10.1176/appi.ajp.2008.08040608. PMID: 19074978.19074978
33 Fitzsimmons-Craft EE, Taylor CB, Graham AK, . Effectiveness of a Digital Cognitive Behavior Therapy-Guided Self-Help Intervention for Eating Disorders in College Women: a Cluster Randomized Clinical Trial. JAMA network open. 2020;3(8):e2015633-. doi: 10.1001/jamanetworkopen.2020.15633. PMID: CN-02177518.32865576
34 Golay A, Laurent-Jaccard A, Habicht F, . Effect of Orlistat in Obese Patients with Binge Eating Disorder. Obes Res. 2005;13(10):1701–8. doi: 10.1038/oby.2005.208. PMID: 2005-15566-005.16286517
35 Goldstein DJ, Wilson MG, Thompson VL, . Long-term fluoxetine treatment of bulimia nervosa. Fluoxetine Bulimia Nervosa Research Group. Br J Psychiatry. 1995 May;166(5):660–6. doi: 10.1192/bjp.166.5.660. PMID: 7620754.7620754
36 Grant JE, Valle S, Cavic E, . A double-blind, placebo-controlled study of vortioxetine in the treatment of binge-eating disorder. Int J Eat Disord. 2019 Jul;52(7):786–94. doi: 10.1002/eat.23078. PMID: 30938842.30938842
37 Green MA, Willis M, Fernandez-Kong K, . Dissonance-based eating disorder program reduces cardiac risk: A preliminary trial. Health Psychol. 2017 Apr;36(4):346–55. doi: 10.1037/hea0000438. PMID: 27808527.27808527
38 Green MA, Willis M, Fernandez-Kong K, . A Controlled Randomized Preliminary Trial of a Modified Dissonance-Based Eating Disorder Intervention Program. J Clin Psychol. 2017 Dec;73(12):1612–28. doi: 10.1002/jclp.22468. PMID: 28249107.28249107
39 Green MA, Kroska A, Herrick A, . A preliminary trial of an online dissonance-based eating disorder intervention. Eat Behav. 2018;31:88–98. doi: 10.1016/j.eatbeh.2018.08.007. PMID: 2018-56763-016.30199771
40 Grilo CM, Masheb RM, Wilson GT. Efficacy of cognitive behavioral therapy and fluoxetine for the treatment of binge eating disorder: a randomized double-blind placebo-controlled comparison. Biol Psychiatry. 2005 Feb 1;57(3):301–9. doi: 10.1016/j.biopsych.2004.11.002. PMID: 15691532.15691532
41 Grilo CM, White MA, Gueorguieva R, . Self-help for binge eating disorder in primary care: a randomized controlled trial with ethnically and racially diverse obese patients. Behav Res Ther. 2013 Dec;51(12):855–61. doi: 10.1016/j.brat.2013.10.002. PMID: 24189569.24189569
42 Grilo CM, Masheb RM, White MA, . Treatment of binge eating disorder in racially and ethnically diverse obese patients in primary care: randomized placebo-controlled clinical trial of self-help and medication. Behav Res Ther. 2014;58:1–9. doi: 10.1016/j.brat.2014.04.002. PMID: 2014-27567-002.24857821
43 Guerdjikova AI, McElroy SL, Kotwal R, . High-dose escitalopram in the treatment of binge-eating disorder with obesity: a placebo-controlled monotherapy trial. Hum Psychopharmacol. 2008 Jan;23(1):1–11. doi: 10.1002/hup.899. PMID: 18058852.18058852
44 Guerdjikova AI, McElroy SL, Welge JA, . Lamotrigine in the treatment of binge-eating disorder with obesity: a randomized, placebo-controlled monotherapy trial. Int Clin Psychopharmacol. 2009 May;24(3):150–8. doi: 10.1097/YIC.0b013e328329c7b5. PMID: 19357528.19357528
45 Guerdjikova AI, McElroy SL, Winstanley EL, . Duloxetine in the treatment of binge eating disorder with depressive disorders: a placebo-controlled trial. Int J Eat Disord. 2012 Mar;45(2):281–9. doi: 10.1002/eat.20946. PMID: 21744377.21744377
46 Guerdjikova AI, Mori N, Blom TJ, . Lisdexamfetamine dimesylate in binge eating disorder: a placebo controlled trial. Hum Psychopharmacol. 2016 Sep;31(5):382–91. doi: 10.1002/hup.2547. PMID: 27650406.27650406
47 Hedges DW, Reimherr FW, Hoopes SP, . Treatment of bulimia nervosa with topiramate in a randomized, double-blind, placebo-controlled trial, part 2: improvement in psychiatric measures. J Clin Psychiatry. 2003 Dec;64(12):1449–54. doi: 10.4088/jcp.v64n1208. PMID: 14728106.14728106
48 Hill DM, Craighead LW, Safer DL. Appetite-focused dialectical behavior therapy for the treatment of binge eating with purging: a preliminary trial. Int J Eat Disord. 2011 Apr;44(3):249–61. doi: 10.1002/eat.20812. PMID: 20196109.20196109
49 Hoopes SP, Reimherr FW, Hedges DW, . Treatment of bulimia nervosa with topiramate in a randomized, double-blind, placebo-controlled trial, part 1: improvement in binge and purge measures. J Clin Psychiatry. 2003 Nov;64(11):1335–41. doi: 10.4088/jcp.v64n1109. PMID: 14658948.14658948
50 Horne RL, Ferguson JM, Pope HG, Jr., . Treatment of bulimia with bupropion: a multicenter controlled trial. J Clin Psychiatry. 1988 Jul;49(7):262–6. PMID: 3134343.3134343
51 Hudson JI, McElroy SL, Raymond NC, . Fluvoxamine in the treatment of binge-eating disorder: a multicenter placebo-controlled, double-blind trial. Am J Psychiatry. 1998 Dec;155(12):1756–62. doi: 10.1176/ajp.155.12.1756. PMID: 9842788.9842788
52 Hughes PL, Wells LA, Cunningham CJ, . Treating bulimia with desipramine. A double-blind, placebo-controlled study. Arch Gen Psychiatry. 1986 Feb;43(2):182–6. doi: 10.1001/archpsyc.1986.01800020092012. PMID: 3511878.3511878
53 Jacobi C, Völker U, Trockel MT, . Effects of an Internet-based intervention for subthreshold eating disorders: a randomized controlled trial. Behav Res Ther. 2012 Feb;50(2):93–9. doi: 10.1016/j.brat.2011.09.013. PMID: 22137366.22137366
54 Kaneva R, Rissanen A, Sarna S. Fluoxetine in the treatment of anxiety, depressive symptoms, and eating-related symptoms in bulimia nervosa. Nordic Journal of Psychiatry. 1995;49(4):237–42. doi: 10.3109/08039489509011912. PMID: 1996-20791-001.
55 Kelly AC, Carter JC. Self-compassion training for binge eating disorder: a pilot randomized controlled trial. Psychol Psychother. 2015 Sep;88(3):285–303. doi: 10.1111/papt.12044. PMID: 25330466.25330466
56 Laederach-Hofmann K, Graf C, Horber F, . Imipramine and diet counseling with psychological support in the treatment of obese binge eaters: a randomized, placebo-controlled double-blind study. Int J Eat Disord. 1999 Nov;26(3):231–44. doi: 10.1002/(sici)1098-108x(199911)26:3<231::aid-eat1>3.0.co;2-6. PMID: 10441239.10441239
57 Laessle RG, Waadt S, Pirke KM. A structured behaviorally oriented group treatment for bulimia nervosa. Psychother Psychosom. 1987;48(1–4):141–5. doi: 10.1159/000288044. PMID: 3505706.3505706
58 Ljotsson B, Lundin C, Mitsell K, . Remote treatment of bulimia nervosa and binge eating disorder: a randomized trial of Internet-assisted cognitive behavioural therapy. Behav Res Ther. 2007 Apr;45(4):649–61. doi: 10.1016/j.brat.2006.06.010. PMID: 16899213.16899213
59 Linardon J. Rates of abstinence following psychological or behavioral treatments for binge-eating disorder: Meta-analysis. Int J Eat Disord. 2018 Aug;51(8):785–97. doi: 10.1002/eat.22897. PMID: 30058074.30058074
60 Masson PC, von Ranson KM, Wallace LM, . A randomized wait-list controlled pilot study of dialectical behaviour therapy guided self-help for binge eating disorder. Behav Res Ther. 2013 Nov;51(11):723–8. doi: 10.1016/j.brat.2013.08.001. PMID: 24029304.24029304
61 McCann UD, Agras WS. Successful treatment of nonpurging bulimia nervosa with desipramine: A double-blind, placebo-controlled study. The American Journal of Psychiatry. 1990;147(11):1509–13. doi: 10.1176/ajp.147.11.1509. PMID: 1991-07992-001.2221164
62 McElroy SL, Casuto LS, Nelson EB, . Placebo-controlled trial of sertraline in the treatment of binge eating disorder. Am J Psychiatry. 2000 Jun;157(6):1004–6. doi: 10.1176/appi.ajp.157.6.1004. PMID: 10831483.10831483
63 McElroy SL, Hudson JI, Malhotra S, . Citalopram in the treatment of binge-eating disorder: a placebo-controlled trial. J Clin Psychiatry. 2003 Jul;64(7):807–13. doi: 10.4088/jcp.v64n0711. PMID: 12934982.12934982
64 McElroy SL, Arnold LM, Shapira NA, . Topiramate in the treatment of binge eating disorder associated with obesity: a randomized, placebo-controlled trial. Am J Psychiatry. 2003;160(2):255–61. doi: 10.1176/appi.ajp.160.2.255. PMID: CN-00413019.12562571
65 McElroy SL, Kotwal R, Guerdjikova AI, . Zonisamide in the treatment of binge eating disorder with obesity: a randomized controlled trial. J Clin Psychiatry. 2006 Dec;67(12):1897–906. doi: 10.4088/jcp.v67n1209. PMID: 17194267.17194267
66 McElroy SL, Guerdjikova A, Kotwal R, . Atomoxetine in the treatment of binge-eating disorder: a randomized placebo-controlled trial. J Clin Psychiatry. 2007 Mar;68(3):390–8. doi: 10.4088/jcp.v68n0306. PMID: 17388708.17388708
67 McElroy SL, Hudson JI, Capece JA, . Topiramate for the treatment of binge eating disorder associated with obesity: a placebo-controlled study. Biol Psychiatry. 2007 May 1;61(9):1039–48. doi: 10.1016/j.biopsych.2006.08.008. PMID: 17258690.17258690
68 McElroy SL, Guerdjikova AI, Winstanley EL, . Acamprosate in the treatment of binge eating disorder: a placebo-controlled trial. Int J Eat Disord. 2011 Jan;44(1):81–90. doi: 10.1002/eat.20876. PMID: 21080416.21080416
69 McElroy SL, Hudson JI, Mitchell JE, . Efficacy and safety of lisdexamfetamine for treatment of adults with moderate to severe binge-eating disorder: a randomized clinical trial. JAMA Psychiatry. 2015 Mar;72(3):235–46. doi: 10.1001/jamapsychiatry.2014.2162. PMID: 25587645.25587645
70 McElroy SL, Mitchell JE, Wilfley D, . Lisdexamfetamine dimesylate effects on binge eating behaviour and obsessive-compulsive and impulsive features in adults with binge eating disorder. Eur Eat Disord Rev. 2016 May;24(3):223–31. doi: 10.1002/erv.2418. PMID: 26621156.26621156
71 McElroy SL, Hudson J, Ferreira-Cornwell MC, . Lisdexamfetamine dimesylate for adults with moderate to severe binge eating disorder: results of two pivotal phase 3 randomized controlled trials. Neuropsychopharmacology. 2016 Apr;41(5):1251–60. doi: 10.1038/npp.2015.275. PMID: 26346638.26346638
72 Sheehan DV, Gasior M, McElroy SL, . Effects of lisdexamfetamine dimesylate on functional impairment measured on the sheehan disability scale in adults with moderate-to-severe binge eating disorder: results from two randomized, placebo-controlled trials. Innov Clin Neurosci. 2018;15(5–6):22–9. PMID: CN-01617953.30013816
73 McElroy SL, Hudson JI, Grilo CM, . Efficacy and Safety of Dasotraline in Adults With Binge-Eating Disorder: A Randomized, Placebo-Controlled, Flexible-Dose Clinical Trial. J Clin Psychiatry. 2020 Sep 8;81(5)doi: 10.4088/JCP.19m13068. PMID: 32926604.32926604
74 Mitchell JE, Pyle RL, Eckert ED, . A comparison study of antidepressants and structured intensive group psychotherapy in the treatment of bulimia nervosa. Arch Gen Psychiatry. 1990 Feb;47(2):149–57. doi: 10.1001/archpsyc.1990.01810140049008. PMID: 2405806.2405806
75 Keel PK, Mitchell JE, Davis TL, . Long-term impact of treatment in women diagnosed with bulimia nervosa. Int J Eat Disord. 2002 Mar;31(2):151–8. doi: 10.1002/eat.10017. PMID: 11920976.11920976
76 Mitchell JE, Fletcher L, Hanson K, . The relative efficacy of fluoxetine and manual-based self-help in the treatment of outpatients with bulimia nervosa. J Clin Psychopharmacol. 2001 Jun;21(3):298–304. doi: 10.1097/00004714-200106000-00008. PMID: 11386493.11386493
77 Fluoxetine Bulimia Nervosa Collaborative Study Group. Fluoxetine in the treatment of bulimia nervosa. A multicenter, placebo-controlled, double-blind trial. Arch Gen Psychiatry. 1992 Feb;49(2):139–47. PMID: 1550466.1550466
78 Pearlstein T, Spurell E, Hohlstein LA, . A double-blind, placebo-controlled trial of fluvoxamine in binge eating disorder: a high placebo response. Arch Womens Ment Health. 2003 Apr;6(2):147–51. doi: 10.1007/s00737-003-0172-8. PMID: 12720065.12720065
79 Peterson CB, Mitchell JE, Engbloom S, . Group cognitive-behavioral treatment of binge eating disorder: a comparison of therapist-led versus self-help formats. Int J Eat Disord. 1998 Sep;24(2):125–36. doi: 10.1002/(sici)1098-108x(199809)24:2<125::aid-eat2>3.0.co;2-g. PMID: 9697011.9697011
80 Peterson CB, Mitchell JE, Crow SJ, . The efficacy of self-help group treatment and therapist-led group treatment for binge eating disorder. Am J Psychiatry. 2009 Dec;166(12):1347–54. doi: 10.1176/appi.ajp.2009.09030345. PMID: 19884223.19884223
81 Pope HG, Jr., Keck PE, Jr., McElroy SL, . A placebo-controlled study of trazodone in bulimia nervosa. J Clin Psychopharmacol. 1989 Aug;9(4):254–9. PMID: 2671058.2671058
82 Robinson P, Serfaty M. Getting better byte by byte: a pilot randomised controlled trial of email therapy for bulimia nervosa and binge eating disorder. Eur Eat Disord Rev. 2008 Mar;16(2):84–93. doi: 10.1002/erv.818. PMID: 17879223.17879223
83 Sánchez-Ortiz VC, Munro C, Stahl D, . A randomized controlled trial of internet-based cognitive-behavioural therapy for bulimia nervosa or related disorders in a student population. Psychol Med. 2011 Feb;41(2):407–17. doi: 10.1017/s0033291710000711. PMID: 20406523.20406523
84 Schag K, Rennhak SK, Leehr EJ, . IMPULS: impulsivity-focused group intervention to reduce binge eating episodes in patients with binge eating disorder - a randomised controlled trial. Psychother Psychosom. 2019;88(3):141–53. doi: 10.1159/000499696. PMID: 31108488.31108488
85 Schlup B, Munsch S, Meyer AH, . The efficacy of a short version of a cognitive-behavioral treatment followed by booster sessions for binge eating disorder. Behav Res Ther. 2009 Jul;47(7):628–35. doi: 10.1016/j.brat.2009.04.003. PMID: 19446793.19446793
86 Schmidt U, Andiappan M, Grover M, . Randomised controlled trial of CD-ROM-based cognitive-behavioural self-care for bulimia nervosa. Br J Psychiatry. 2008 Dec;193(6):493–500. doi: 10.1192/bjp.bp.107.046607. PMID: 19043154.19043154
87 Stice E, Yokum S, Rohde P, . Randomized trial of a dissonance-based transdiagnostic group treatment for eating disorders: An evaluation of target engagement. J Consult Clin Psychol. 2019 Sep;87(9):772–86. doi: 10.1037/ccp0000430. PMID: 31403814.31403814
88 Sundblad C, Landén M, Eriksson T, . Effects of the androgen antagonist flutamide and the serotonin reuptake inhibitor citalopram in bulimia nervosa: a placebo-controlled pilot study. J Clin Psychopharmacol. 2005 Feb;25(1):85–8. doi: 10.1097/01.jcp.0000150222.31007.a9. PMID: 15643104.15643104
89 Telch CF, Agras WS, Rossiter EM, . Group cognitive-behavioral treatment for the nonpurging bulimic: an initial evaluation. J Consult Clin Psychol. 1990 Oct;58(5):629–35. doi: 10.1037//0022-006x.58.5.629. PMID: 2254511.2254511
90 Telch CF, Agras WS, Linehan MM. Dialectical behavior therapy for binge eating disorder. J Consult Clin Psychol. 2001 Dec;69(6):1061–5. doi: 10.1037//0022-006x.69.6.1061. PMID: 11777110.11777110
91 Traviss GD, Heywood-Everett S, Hill AJ. Guided self-help for disordered eating: A randomised control trial. Behav Res Ther. 2011 Jan;49(1):25–31. doi: 10.1016/j.brat.2010.10.007. PMID: 21092933.21092933
92 Wade S, Byrne S, Allen K. Enhanced cognitive behavioral therapy for eating disorders adapted for a group setting. Int J Eat Disord. 2017 Aug;50(8):863–72. doi: 10.1002/eat.22723. PMID: 28489288.28489288
93 Wagner B, Nagl M, Dölemeyer R, . Randomized controlled trial of an internet-based cognitive-behavioral treatment program for binge-eating disorder. Behav Ther. 2016 Jul;47(4):500–14. doi: 10.1016/j.beth.2016.01.006. PMID: 27423166.27423166
94 Walsh BT, Stewart JW, Roose SP, . A double-blind trial of phenelzine in bulimia. J Psychiatr Res. 1985;19(2–3):485–9. doi: 10.1016/0022-3956(85)90058-5. PMID: 3900362.3900362
95 Walsh BT, Gladis M, Roose SP, . A controlled trial of phenelzine in bulimia. Psychopharmacol Bull. 1987;23(1):49–51. PMID: 3299445.3299445
96 Walsh BT, Hadigan CM, Devlin MJ, . Long-term outcome of antidepressant treatment for bulimia nervosa. Am J Psychiatry. 1991 Sep;148(9):1206–12. doi: 10.1176/ajp.148.9.1206. PMID: 1882999.1882999
97 Walsh BT, Fairburn CG, Mickley D, . Treatment of bulimia nervosa in a primary care setting. Am J Psychiatry. 2004 Mar;161(3):556–61. doi: 10.1176/appi.ajp.161.3.556. PMID: 14992983.14992983
98 White MA, Grilo CM. Bupropion for overweight women with binge-eating disorder: a randomized, double-blind, placebo-controlled trial. J Clin Psychiatry. 2013 Apr;74(4):400–6. doi: 10.4088/JCP.12m08071. PMID: 23656848.23656848
99 Wilfley DE, Agras WS, Telch CF, . Group cognitive-behavioral therapy and group interpersonal psychotherapy for the nonpurging bulimic individual: a controlled comparison. J Consult Clin Psychol. 1993 Apr;61(2):296–305. doi: 10.1037//0022-006x.61.2.296. PMID: 8473584.8473584
100 Milano W, Petrella C, Sabatino C, . Treatment of bulimia nervosa with sertraline: a randomized controlled trial. Adv Ther. 2004 Jul–Aug;21(4):232–7. doi: 10.1007/bf02850155. PMID: 15605617.15605617
101 Milano W, Siano C, Putrella C, . Treatment of bulimia nervosa with fluvoxamine: a randomized controlled trial. Adv Ther. 2005 May–Jun;22(3):278–83. doi: 10.1007/bf02849936. PMID: 16236688.16236688
102 Corwin RL, Boan J, Peters KF, . Baclofen reduces binge eating in a double-blind, placebo-controlled, crossover study. Behav Pharmacol. 2012 Sep;23(5–6):616–25. doi: 10.1097/FBP.0b013e328357bd62. PMID: 22854310.22854310
103 Safer DL, Adler S, Dalai SS, . A randomized, placebo-controlled crossover trial of phentermine-topiramate er in patients with binge-eating disorder and bulimia nervosa. Int J Eat Disord. 2019doi: 10.1002/eat.23192. PMID: 2019-69468-001.
104 Mitchell JE, Christenson G, Jennings J, . A placebo-controlled, double-blind crossover study of naltrexone hydrochloride in outpatients with normal weight bulimia. J Clin Psychopharmacol. 1989 Apr;9(2):94–7. doi: 10.1097/00004714-198904000-00004. PMID: 2656781.2656781
105 Anstine D, Grinenko D. Rapid screening for disordered eating in college-aged females in the primary care setting. J Adolesc Health. 2000 May;26(5):338–42. doi: 10.1016/s1054-139x(99)00120-2. PMID: 10775826.10775826
106 Chamay-Weber C, Combescure C, Lanza L, . Screening obese adolescents for binge eating disorder in primary care: the Adolescent Binge Eating Scale. J Pediatr. 2017 Jun;185:68–72.e1. doi: 10.1016/j.jpeds.2017.02.038. PMID: 28285753.28285753
107 Cotton M-A, Ball C, Robinson P. Four simple questions can help screen for eating disorders. J Gen Intern Med. 2003;18(1):53–6. doi: 10.1046/j.1525-1497.2003.20374.x. PMID: 2003-04278-007.12534764
108 Dorflinger LM, Ruser CB, Masheb RM. A brief screening measure for binge eating in primary care. Eat Behav. 2017 Aug;26:163–6. doi: 10.1016/j.eatbeh.2017.03.009. PMID: 28402901.28402901
109 Duarte C, Pinto-Gouveia J, Ferreira C. Expanding binge eating assessment: Validity and screening value of the Binge Eating Scale in women from the general population. Eat Behav. 2015 Aug;18:41–7. doi: 10.1016/j.eatbeh.2015.03.007. PMID: 25880043.25880043
110 Franklin EV, Simpson V, Berthet-Miron M, . A Pilot Study Evaluating a Binge-Eating Screener in Children: Development of the Children’s Brief Binge-Eating Questionnaire in a Pediatric Obesity Clinic. Clin Pediatr (Phila). 2019 Sep;58(10):1063–71. doi: 10.1177/0009922819863664. PMID: 31331196.31331196
111 Freund KM, Boss RD, Handleman EK, . Secret patterns: validation of a screening tool to detect bulimia. J Womens Health Gend Based Med. 1999 Dec;8(10):1281–4. doi: 10.1089/jwh.1.1999.8.1281. PMID: 10643836.10643836
112 Garcia FD, Grigioni S, Chelali S, . Validation of the French version of SCOFF questionnaire for screening of eating disorders among adults. World J Biol Psychiatry. 2010 Oct;11(7):888–93. doi: 10.3109/15622975.2010.483251. PMID: 20509759.20509759
113 Graham AK, Trockel M, Weisman H, . A screening tool for detecting eating disorder risk and diagnostic symptoms among college-age women. J Am Coll Health. 2019 May–Jun;67(4):357–66. doi: 10.1080/07448481.2018.1483936. PMID: 29979922.29979922
114 Hill LS, Reid F, Morgan JF, . SCOFF, the development of an eating disorder screening questionnaire. Int J Eat Disord. 2010 May;43(4):344–51. doi: 10.1002/eat.20679. PMID: 19343793.19343793
115 Luck AJ, Morgan JF, Reid F, . The SCOFF questionnaire and clinical interview for eating disorders in general practice: comparative study. BMJ. 2002 Oct 5;325(7367):755–6. doi: 10.1136/bmj.325.7367.755. PMID: 12364305.12364305
116 Lähteenmäki S, Aalto-Setälä T, Suokas JT, . Validation of the Finnish version of the SCOFF questionnaire among young adults aged 20 to 35 years. BMC Psychiatry. 2009 Feb 8;9:5. doi: 10.1186/1471-244x-9-5. PMID: 19200401.19200401
117 Liu CY, Tseng MC, Chen KY, . Sex difference in using the SCOFF questionnaire to identify eating disorder patients at a psychiatric outpatient clinic. Compr Psychiatry. 2015 Feb;57:160–6. doi: 10.1016/j.comppsych.2014.11.014. PMID: 25542817.25542817
118 Maguen S, Hebenstreit C, Li Y, . Screen for disordered eating: improving the accuracy of eating disorder screening in primary care. Gen Hosp Psychiatry. 2018 Jan–Feb;50:20–5. doi: 10.1016/j.genhosppsych.2017.09.004. PMID: 28987918.28987918
119 Mond JM, Myers TC, Crosby RD, . Screening for eating disorders in primary care: EDE-Q versus SCOFF. Behav Res Ther. 2008 May;46(5):612–22. doi: 10.1016/j.brat.2008.02.003. PMID: 18359005.18359005
120 Muro-Sans P, Amador-Campos JA, Morgan JF. The SCOFF-c: psychometric properties of the Catalan version in a Spanish adolescent sample. J Psychosom Res. 2008 Jan;64(1):81–6. doi: 10.1016/j.jpsychores.2007.06.011. PMID: 18158003.18158003
121 Parker SC, Lyons J, Bonner J. Eating disorders in graduate students: exploring the SCOFF questionnaire as a simple screening tool. J Am Coll Health. 2005 Sep–Oct;54(2):103–7. doi: 10.3200/jach.54.2.103-107. PMID: 16255322.16255322
122 Ricca V, Mannucci E, Moretti S, . Screening for binge eating disorder in obese outpatients. Compr Psychiatry. 2000 Mar–Apr;41(2):111–5. doi: 10.1016/s0010-440x(00)90143-3. PMID: 10741889.10741889
123 Rosenvinge JH, Perry JA, Bjørgum L, . A new instrument measuring disturbed eating patterns in community populations: development and initial validation of a five-item scale (EDS-5). Eur Eat Disord Rev. 2001;9(2):123–32. doi: 10.1002/erv.371. PMID: 2001-17053-004.
124 Siervo M, Boschi V, Papa A, . Application of the SCOFF, Eating Attitude Test 26 (EAT 26) and Eating Inventory (TFEQ) Questionnaires in young women seeking diet-therapy. Eat Weight Disord. 2005 Jun;10(2):76–82. doi: 10.1007/bf03327528. PMID: 16114220.16114220
125 Solmi F, Hatch SL, Hotopf M, . Validation of the SCOFF questionnaire for eating disorders in a multiethnic general population sample. Int J Eat Disord. 2015 Apr;48(3):312–6. doi: 10.1002/eat.22373. PMID: 25504212.25504212
126 Striegel-Moore RH, Perrin N, DeBar L, . Screening for binge eating disorders using the patient health questionnaire in a community sample. Int J Eat Disord. 2010 May;43(4):337–43. doi: 10.1002/eat.20694. PMID: 19424976.19424976
127 Wan Wahida WMZ, Lai PSM, Abdul Hadi H. Validity and reliability of the english version of the sick, control, one stone, fat, food (SCOFF) in Malaysia. Clin Nutr ESPEN. 2017 Apr;18:55–8. doi: 10.1016/j.clnesp.2017.02.001. PMID: 29132739.29132739