# Appendix E Additional Evidence Tables

Appendix E Table 1 Detailed Evidence Table of Psychological Intervention Characteristics (KQ 4)

Appendix E Table 2 Results of Randomized, Placebo-Controlled Trials of Pharmacotherapy for Eating Disorders (KQ 4)

Appendix E Table 3 Harms