# Appendix D Assessments of Study Quality

Appendix D Table 1 Quality Assessment of Parallel Randomized, Controlled Trials (KQ 4)

First Author, Year; Trial Name | Randomization Process; Domain | Deviations From Intended Interventions; Domain | Missing Outcome Data; Domain | Outcome Measurement; Domain | Selection of Reported Result; Domain | Overall ROB | Comments
Agras, 1989^18^ | Some concerns | Low | High | Low | Some concerns | High | No analyses to correct for possible bias related to attrition. Greater number of dropouts in active treatment group vs. waitlist. No description of allocation sequence concealment.
Alfonsson, 2015^19^ | Some concerns | Some concerns | Some concerns | Some concerns | Low | Some concerns | Differential missing data between treatment and outcome groups. Lack of information about allocation concealment. Some differences in baseline measures.
Alger, 1991^20^ | Some concerns | Low | High | Low | Some concerns | High | Differential early termination across treatment groups. Baseline characteristics only presented for study completes (n=55), rather than entire initial sample (n=69).
Arnold, 2002^21^ | Low | Low | High | Low | Low | Some concerns | High amount of missing data in both groups; however, different reasons for each group. Potential for missingness to be dependent on true value of outcome.
Bachar, 1999^22^ | Some concerns | High | High | Low | Some concerns | High | Randomization process not described. No table of baseline characteristics or description in text by groups randomized. For both AN/BN (randomized separately), overall attrition was 25%. Missingness may depend on true outcome and affect results. Those who withdrew were excluded, no additional analyses to assess missing data.
Barlow, 1988^23^ | High | Low | High | Some concerns | Some concerns | High | No information about randomization process or balance at baseline. Approximately 50% population had data missing with different reasons for dropping out.
Cachelin, 2019^24^ | High | Some concerns | Some concerns | Low | Low | Some concerns | No reporting of randomization methods and suboptimal analyses to adjust for missing outcome data.
Carrard, 2011^25^ | Low | Low | High | Some concerns | Some concerns | High | Overall, there were few baseline differences, except for EDI-2 body dissatisfaction. Risk of bias due to missing data. Assessors not blinded to treatment allocation. Participants and carers aware of assigned intervention as expected. Baseline assessors were not blind to treatment allocation.
Carter, 1998^26^ | Low | Low | High | Low | Some concerns | High | Lack of further description of those who dropped out by group or baseline characteristics; dropout was higher among intervention group, although measured differently. Unclear if there was a prespecified analysis plan.
Carter, 2003^27^ | Low | Low | Low | Low | Some concerns | Some concerns | No information on whether there was a prespecified analysis plan.
Carter, 2019^28^ | Some concerns | Some concerns | Some concerns | Low | Low | Some concerns | No information on the randomization process. Treatment status not blinded. Groups randomized to control rated treatment “less suitable” than those in active arm. Attrition ranged from 35-37% for posttreatment and 3-month followup. Noncompleters differed on some baseline scores compared with completers.
DeBar, 2011^29^ | Some concerns | Some concerns | High | Low | Some concerns | High | No information on concealment. Baseline difference by race-ethnicity. Participants were not prohibited from using treatment resources offered by the HMO throughout the study, and usual care involved advising participants at trial assignment of treatment options within the HMO. Approximately 13% had missing data. Unclear if there was a prespecified data analysis plan.
DeBar, 2013^30^ | Some concerns | Low | Some concerns | Low | Some concerns | Some concerns | No information on randomization and concealment. High amount of missing data (15%) on top of an already small sample not addressed in analyses. Unclear if there was a prespecified data analysis plan.
Duarte, 2017^31^ | Some concerns | High | High | High | Some concerns | High | No information on randomization and concealment. Dropout was high between those who were randomized and those who actually completed posttreatment assessment. No information on whether assessors of other scales had knowledge of intervention groups.
Fairburn, 2009^32^ | Low | Low | Low | Low | Some concerns | Some concerns | Lack of information about patient blinding, but carers were aware of assignments. Limited information on missing data. No information provided on analysis plan.
Fitzsimmons-Craft, 2020^33^ | Some concerns | Low | Some concerns | Low | Some concerns | Some concerns | High loss to follow-up, and different by group assignment. Those that didn’t see a benefit may have been more likely to drop out from intervention group in particular. May expect differences in drop out for those in the control based on access to other resources.
Golay, 2005^34^ | Low | High | High | Low | Low | High | Authors do not report on specific adverse effects or whether participants suspected they were receiving the active medication. Methods note ITT analysis, but authors excluded 18% of randomized participants who discontinued the trial prematurely and did not provide data at the final outcome assessment (24 weeks).
Goldstein, 1995^35^ | Low | Low | High | Low | Some concerns | High | High overall attrition of 43%, and significant differential attrition (8% fluoxetine vs. 26% placebo) suggests a high risk of attrition bias.
Grant, 2019^36^ | Low | Low | High | Some concerns | Some concerns | High | Risk off bias due to lack of blinding. Unclear if a prespecified plan; only 45% of overall sample had efficacy data at baseline and week 12.
Green, 2016^37^ | Some concerns | Low | High | Low | Low | High | Lack of information about the randomization process. Large amount of missing data with suboptimal handling with mean imputation.
Green, 2017^38^ | Some concerns | Low | High | Some concerns | Low | High | Lack of information about the randomization process. No reporting of the extent of missing data and suboptimal handling of missing data that was present with mean imputation. Lack of blinding of outcome assessment.
Green, 2018^39^ | Some concerns | Some concerns | Some concerns | Low | Some concerns | Some concerns | No information on randomization or allocation concealment. No table or description of whether randomized groups were similar at baseline or whether sample analyzed differed in these factors (authors note that a higher proportion randomized to control group chose not to enroll in the trial vs. intervention group). Missing data were addressed by single imputation, and additional analyses were conducted using multiple imputation. Authors noted a difference in results—findings from multiple imputations led to no statistically significant interactions between groups.
Grilo, 2005^40^ | Low | Low | Low | Some concerns | Some concerns | Some concerns | Potential risk of bias due to lack of blinding, selection of reported results.
Grilo, 2013^41^ | Low | Low | Low | Low | Low | Low
Grilo, 2014^42^ | Some concerns | Low | Some concerns | Low | Low | Some concerns | Randomization not described. Most baseline characteristics are similar (age, ethnicity, comorbidity); however, participants in the placebo group had a lower rate of college education (5%) than the treatment group (14%). Overall attrition was 15%, slightly higher in placebo group than treatment arm. Analyses addressed missing data using LOCF.
Guerdjikova, 2008^43^ | Low | Low | Some concerns | Low | Some concerns | Some concerns | Most enrolled participants had at least one baseline assessment (43/44 randomized); however, 21% withdrew early, including 25% in the treatment and 17% in placebo groups. Analyses included time trends for treatment response, as well as LOCF. No other analyses were conducted to assess bias.
Guerdjikova, 2009^44^ | Low | Low | High | Low | Low | High | Of those randomized (n=51), most (n=49 had at least one postrandomization outcome measure; however, overall attrition was 35% and was higher in the lamotrigine group vs. placebo (44% vs. 29%). ITT analysis relied on LOCF; no other analyses performed to assess bias. Those who did not complete the study may have differed in terms of ED severity.
Guerdjikova, 2012^45^ | Low | Low | Some concerns | Low | Some concerns | Some concerns | High overall attrition (33%), and unclear how successfully statistical methods accounted for missing data (longitudinal analysis, LOCF modified ITT). Still, low differential attrition of only 5%, and reasons for discontinuation were mostly or entirely unrelated to the true value of the study’s outcomes.
Guerdjikova, 2016^46^ | Low | Low | Some concerns | Low | Low | Low
Hedges, 2003^47^ | Low | Low | High | Low | Some concerns | High | High overall attrition (41%), and although attrition was not significantly different between groups (12%, with 35% topiramate vs. 47% placebo), there were significantly more placebo patients than topiramate patients who dropped out because of “patient choice” (p=0.028). Unclear if this was related to severity of BN, but if so, unlikely that the study’s ITT analysis accounted for resulting attrition bias.
Hill, 2011^48^ | Low | Low | Some concerns | Low | Some concerns | Some concerns | Authors conducted ITT analysis that included all participants randomized; missing data were imputed based on an estimate of mean values from the sample. This may not address bias if those with missing data had worse outcomes; however, attrition was relatively low (13%) and not differential. Not clear if results were analyzed based on prespecified plan that was finalized before unblinded data were available.
Hoopes, 2003^49^ | Low | Low | High | Low | Some concerns | High | High overall attrition of 42%. Only ITT analyses were used to account for potential attrition bias. Relatively low differential attrition overall (10%), but a significantly greater N of patients discontinued placebo than topiramate because of “patient choice” (7 vs. 1, respectively). Unclear if allocation concealment was used.
Horne, 1988^50^; KQ4 | High | Some concerns | High | Low | Some concerns | High | Baseline differences based on baseline frequency of binge eating; results focused on completers, but reanalysis of data showed a greater impact of intervention. Measures were self-reported. ITT was not used. High attrition. No evidence that there was bias based on missing data. No information on why participants dropped out. Unclear if there was a prespecified analysis plan.
Hudson, 1998^51^ | Low | Low | High | Low | Some concerns | High | Potential bias from overall attrition (21%) and significant differential attrition with more fluvoxamine patients than placebo patients dropping out for adverse medical events (12% vs. 0%, respectively, p=0.03) or any reason (31% vs. 12%, respectively, p=0.04). Unclear that the study’s modified ITT and random regression analyses were successful at managing potential attrition bias.
Hughes, 1986^52^ | Low | Some concerns | High | Some concerns | Low | High | Unclear information about missing data. Deviations from the intended intervention.
Jacobi, 2012^53^ | Some concerns | High | High | Low | Some concerns | High | Average adherence across all intervention components was 66.2% and varied substantially by component. Study focused on completer’s analysis only. Lack of reporting about allocation concealment or whether there was a prespecified analysis plan.
Kanerva, 1995^54^ | Some concerns | High | Some concerns | Low | Some concerns | Some concerns | No information on randomization and allocation sequence. Few baseline characteristics reported. Placebo group had higher total EDI score (80.5 vs. 69.4) than fluoxetine group at baseline. No analyses to address missing data; however, overall attrition was relatively low (8%) and did not differ between groups.
Kelly, 2014^55^ | Low | Low | Low | Low | Some concerns | Some concerns | Unclear whether assessors are blinded. Unclear if there was a prespecified analysis plan.
Laederach-Hofmann, 1999^56^ | Some concerns | Some concerns | Low | Low | Some concerns | Some concerns | Participants randomized to placebo vs. imipramine were slightly older (mean age 36 vs. 41 years) and had a significantly higher BMI and body weight (authors attributed this to two participants in the placebo group with a very high BMI/weight). Data appear to be available for nearly all participants, except for two who discontinued treatment (6.8%, one from each group).
Laessle, 1987^57^ | Low | Low | Low | Some concerns | Some concerns | Some concerns | Limited information about analyses or dropout rates. Small sample so high likelihood of missingness being dependent on true value of outcome. Limited selection of reported results.
Ljotsson, 2007^58^ | Low | Low | Low | Some concerns | Some concerns | Some concerns | All eligible outcomes were self-reported or self-conveyed to an assessor, and all patients knew what their assigned condition was.
Linardon, 2020^59^ | Some concerns | Some concerns | High | Low | High | High | High dropout rates, differences in follow-up by group and baseline characteristics, and changes to the analysis make this high. Also of note, have those with subthreshold but not OSFED. Also have 44% of the total sample with prior ED treatment and 16% with current ED treatment, not sure if these overlap or not, but close to the 50% with prior treatment. May be excluded for several reasons
Masson, 2013^60^ | Low | Low | Some concerns | Low | Low | Some concerns | No information on concealment. High attrition, but reasons provided. No information on whether there was a prespecified analysis plan.
McCann, 1990^61^ | Some concerns | High | High | Low | Some concerns | High | No ITT analysis. Overall attrition was 23% and was higher among the intervention vs. control group (33% vs. 13%). Completers analysis only. No analyses to address missing data.
McElroy, 2000^62^ | Low | Low | Some concerns | Low | Some concerns | Some concerns | Potential bias from overall attrition (24%).
McElroy, 2003^63^ | Some concerns | Low | High | Low | Some concerns | High | The small sample size makes the study especially susceptible to attrition bias, even from a moderate amount of attrition (18% overall). Possible that the placebo group’s 10% higher rate of withdrawal due to worsening depression may have affected the statistical significance of outcomes, especially given that the placebo group had a significantly worse baseline CGI-S score than the citalopram group. Also unclear why completers analysis results were only reported for binge response, but not any other outcome.
McElroy, 2003^64^ | Low | Low | Some concerns | Low | Low | Some concerns | Despite overall attrition of 43%, authors reported adverse events among all those randomized.
McElroy, 2006^65^ | Low | Low | High | Low | Some concerns | High | High overall attrition (50%) and differential attrition (20%) with more zonisamide patients withdrawing than placebo patients (60% vs. 40%, respectively). Authors acknowledged their analyses may not have accounted for data missing not at random, which means BED severity or other outcomes measured may have contributed to problematic attrition bias.
McElroy, 2007^66^ | Some concerns | Low | High | Low | Low | High | No description of randomization. Of those randomized, all but one had at least one postrandomization outcome measure and were included in analyses; however, 37% withdrew early (30% in treatment group and 45% in placebo group). No other analyses to assess bias or assumption that those who withdrew had worse outcomes.
McElroy, 2007^67^ | Low | Low | Low | Low | Low | Some concerns | Overall, 30% of participants randomized did not complete the study (no differential attrition). Authors described a “repeated measures” random regression model to account for missing data, which implies imputation of missing data values as well as a two-way analysis that implies LOCF. However, assumptions made in models about missing data values are not clear and do not provide clear evidence that results were not biased by missing data.
McElroy, 2011^68^ | Low | Low | High | Low | Some concerns | High | High overall (40%) and differential (34%) attrition with significantly more placebo than acamprosate patients dropping out (55% vs. 21%, respectively). As a result, the study’s analyses relied heavily on assumptions about missing data underlying the study’s random regression and LOCF ITT analyses. More placebo patients than acamprosate patients withdrew due to lack of efficacy (4/11 vs. 0/5) or were lost to followup for unknown reasons (5/11 vs. 1/5). Likely that the placebo group’s higher attrition was related to the severity of BED and that the study’s analyses did not account for the resulting bias.
McElroy, 2015^69^; McElroy, 2016^70^ | Some concerns | Low | Low | Low | Some concerns | Some concerns | No assessment of whether baseline characteristics differed. While it does mention those who dropped out for adverse events, details of this are not included in this study but rather in the protocol paper.
McElroy, 2016^71^; Sheehan, 2017^72^ | Some concerns | Low | Low | Low | Some concerns | Some concerns | No statistical assessments of differences at baseline. Unclear if there was prespecified statistical analysis or not.
McElroy, 2020^73^ | Low | Low | Some concerns | Low | Low | Some concerns | Lack of sensitivity analyses for secondary outcomes of interest
Mitchell, 1990^74^; Keel, 2002^75^ | High | High | High | Some concerns | Some concerns | High | Randomization process altered periodically based on attrition. No information on baseline differences. High attrition and analyses focused on completers, no ITT or analyses to address missing data. No information on reasons for missingness. Unclear if there was a prespecified analysis plan.
Mitchell, 2001^76^ | Some concerns | Low | Some concerns | Some concerns | Some concerns | Some concerns | No information about allocation concealment or whether patient, provider, or outcome assessor blinding of treatment assignment was used, but patients were probably blinded to their assigned drug treatments. Unclear if assessors of clinician-measured outcomes were blinded to treatment assignment. Relatively low risk of bias from overall attrition (9%), despite lack of detail about differential attrition or reasons for dropout. Appears that only a completers analysis was used to analyze EDI scores, HAM-D-21 scores, laxative abuse, diuretic abuse, and fasting days.
Fluoxetine Bulimia Nervosa Collaborative Study Group, 1992^77^ | Some concerns | Low | Low | Low | Some concerns | Some concerns | Lack of information about the randomization process. Unclear whether outcome assessors were blinded.
Pearlstein, 2003^78^ | Some concerns | Some concerns | Some concerns | Low | Some concerns | Some concerns | No ITT analysis: of 25 who met criteria, authors noted that 20 completed the protocol. Unclear if this means they did not complete the study (after randomization) or the intake assessment.
Peterson, 1998^79^ | High | Low | High | Low | Some concerns | High | No information on randomization or allocation concealment. Participants were assigned to groups, and then four groups were randomized to treatment. Groups differed in terms of baseline frequency of objective and subjective binge-eating episodes. High risk of bias due to attrition; 16% of active treatment groups and 18% of the wait-list group did not complete the protocol. Analysis conducted using last observation but no other analyses to address bias.
Peterson, 2011^80^ | Low | Some concerns | High | Low | Some concerns | High | High risk of attrition bias affecting the self-help group (40% overall, 21% differential vs. waitlist), the therapist-assisted group (32% overall, 13% differential vs. waitlist), and to a lesser extent, the therapist-led group (12% overall, 7% differential vs. waitlist). Reasons for dropout not provided, which makes it impossible to determine if attrition was related to BED severity or other outcomes of interest. However, there was a notable pattern in attrition rates among the active groups.
Pope, 1989^81^ | Some concerns | High | High | Low | Some concerns | High | Randomization process not described. No ITT analysis: those who did not complete 4 weeks of treatment were excluded from analysis (10% of those randomized). An additional five participants (12%) withdrew early for various reasons—some related to factors associated with outcomes being measured (no improvement in ED symptoms, hospitalization for mental health comorbidity). Authors used LOCF in analyses for subjects who withdrew after week 4, which may not address bias.
Robinson, 2008^82^ | High | Low | High | Some concerns | Some concerns | High | High overall attrition (37%). Differential attrition for any reason not statistically significant between groups (21% for therapy vs. wait-list comparison and 12% for therapy vs. self-directed writing), but no data available on specific reasons for attrition that might have indicated missingness based on ED severity. Similar results from ITT and completers analyses do not rule out the possibility that attrition bias had a major impact on the findings. Lack of allocation concealment because the co-investigator who randomized participants may have also been an outcome assessor aware of treatment assignments.
Sanchez-Ortiz, 2010^83^ | Low | Low | Low | Low | Low | Low
Schag, 2019^84^ | Low | Low | Low | Low | Low | Some concerns | Overall, 16-22% did not complete study or had missing data across both time points. ITT analysis using imputed values for missing data was similar to per-protocol analyses. No differential attrition.
Schlup, 2009^85^ | Some concerns | Low | Low | Low | Some concerns | Some concerns | No information on concealment. No information on baseline differences. Assessors were not blinded. Unclear if there was a prespecified analysis plan.
Schmidt, 2008^86^ | Some concerns | Low | Some concerns | Low | Low | Some concerns | Minor differences in baseline characteristics. Overall, approximately 17% of sample did not have 3-month assessment, but no differential attrition. Authors conducted analyses that assess whether persons with missing data were associated with baseline variables. No imputation of missing data.
Stice, 2019^87^ | High | Low | Some concerns | Some concerns | Some concerns | High | Authors reported using random numbers table to randomize participants; however, the sample (n=12, or 12%) was not randomized, but rather assigned to the wait-list because it was not possible to implement groups due to a holiday. Some minor differences between groups in proportion that were Hispanic and proportion that met criteria for full or subthreshold AN (not statistically significant). Rates of missing data were 9%-27% at posttest; authors described using imputation for MRI-related outcomes. Proportion with missing data for self-reported eligible health outcomes and how this was addressed are not clear.
Sundbald, 2015^88^ | High | Low | High | Low | Some concerns | High | No information on randomization process, concealment, or baseline values between groups. High attrition (21%), but reasons for dropouts provided. No information on whether there was a prespecified analysis plan.
Telch, 1990^89^ | Some concerns | Some concerns | Some concerns | Low | Some concerns | Some concerns | Lack of information on randomization or concealment process. Baseline measures appear to be similar but no real information. Carers and participants aware, as expected. Measures were self-reported. ITT was not used. Differential attrition between groups but provided reasons. Unclear if there was a prespecified analysis plan.
Telch, 2001^90^ | Some concerns | High | High | High | Some concerns | High | High overall attrition (23%) in this relatively small sample of 44; only those who completed study were analyzed. No detail given about reasons for attrition, Lack of information about allocation concealment.
Traviss, 2011^91^ | Some concerns | Low | High | Low | Low | High | No information on randomization and allocation sequence. Approximately 30% who completed baseline assessment were lost to followup. Analyses primarily based on last observation carried forward. Participants with worse outcomes or continued disordered eating may have been less likely to continue in the trial.
Wade, 2017^92^ | Some concerns | Low | Low | Some concerns | Low | Some concerns | Missing information about randomization process and outcome measurement.
Wagner, 2016^93^ | Low | Low | Low | Low | Low | Low
Walsh, 1985^94^ | Low | High | High | Low | Some concerns | High | Deviations from intended interventions. High amount of missing outcome data.
Walsh, 1987^95^ | Low | High | High | Low | Some concerns | High | Limited information on randomization and allocation process. High attrition. Deviations from the intended intervention.
Walsh, 1991^96^ | Low | Low | Some concerns | Low | Some concerns | Some concerns | Potential bias from overall attrition (19%), but relatively low differential attrition (7%). Reasons for attrition were generally similar. Only a single patient (1/38, or 2.6%) withdrew from the placebo group because of lack of efficacy. LOCF ITT used to manage potential attrition bias.
Walsh, 2004^97^ | Some concerns | Low | High | Low | Some concerns | High | Lack of information on randomization or concealment process. High attrition used LOCF for missing data. Unclear if there was a prespecified analysis plan.
White, 2013^98^ | Low | Low | Low | Low | Low | Low
Wilfley, 1993^99^ | Some concerns | Low | Some concerns | Low | Some concerns | Some concerns | No information on randomization and allocation process. Assessors were not blinded. Unclear if there was a prespecified analysis plan.

Abbreviations: AN=anorexia nervosa; BED=binge-eating disorder; BMI=body mass index; BN=bulimia nervosa; CGI-S=Clinical Global Impression-Severity; ED=eating disorder; EDI=Eating Disorder Inventory; HAM-D-21=Hamilton Depression Rating Scale-21 Item; HMO=health maintenance organization; ITT=intent-to-treat; KQ=key question; LOCF=last observation carried forward; MRI=magnetic resonance imaging; NA=not available; ROB=risk of bias; vs.=versus.

Appendix D Table 2 Quality Assessment of Parallel Randomized, Controlled Trials (KQ 5)

First Author, Year; Trial Name | Randomization Process; Domain | Deviations From Intended Interventions; Domain | Missing Outcome Data; Domain | Outcome Measurement; Domain | Selection of Reported Result; Domain | Overall ROB | Comments
Arnold, 2002^21^ | Low | Low | Some concerns | Low | Low | Some concerns | High amount of missing data in both groups, but different reasons for each group. High likelihood of missingness being dependent on true value of outcome.
Goldstein, 1995^35^ | Low | Low | High | Low | Some concerns | High | High overall attrition of 43%, and significant differential attrition (8% fluoxetine vs. 26% placebo) for lack of efficacy suggests a high risk of attrition bias.
Grant, 2019^36^ | Low | Low | Low | Some concerns | Some concerns | Some concerns | Some self-report and assuming assessors were blind but unclear; unclear if a prespecified plan.
Guerdjikova, 2008^43^ | Low | Low | Low | Low | Some concerns | Some concerns | Most enrolled participants had at least one baseline assessment (43/44 randomized); however, 21% withdrew early, including 25% in the treatment and 17% in placebo groups. Analyses included time trends for treatment response, as well as LOCF. No other analyses were conducted to assess bias.
Guerdjikova, 2009^44^ | Low | Low | High | Low | Low | High | Of those randomized (n=51), most (n=49) had at least one post randomization outcome measure; however, overall attrition was 35% and was higher in the lamotrigine group vs. placebo (44% vs. 29%). ITT analysis relied on LOCF; no other analyses performed to assess bias. Those who did not complete the study may have differed in terms of ED severity.
Guerdjikova, 2012^45^ | Low | Low | Some concerns | Low | Some concerns | Some concerns | High overall attrition (33%), and unclear how successfully statistical methods accounted for missing data (longitudinal analysis, LOCF modified ITT). Still, low differential attrition of only 5%, and reasons for discontinuation were mostly or entirely unrelated to the true value of the study’s outcomes.
Guerdjikova, 2016^46^ | Low | Low | Some concerns | Low | Low | Low
Hedges, 2003^47^ | Low | Low | High | Low | Some concerns | High | Substantial overall attrition (41%), and although differential attrition was significantly different between groups (12%, with 35% topiramate vs. 47% placebo), there were significantly more placebo patients than topiramate patients who dropped out because of “patient choice” (p=0.028). Unclear if this was related to severity of BN, but if so, unlikely that the study’s ITT analysis accounted for resulting attrition bias.
Hoopes, 2003^49^ | Low | Low | High | Low | Some concerns | High | High overall attrition of 42%. Only ITT analyses were used to account for potential attrition bias. Relatively low differential attrition overall (10%), but a significantly greater N of patients discontinued placebo than topiramate because of “patient choice” (7 vs. 1, respectively). Also unclear if allocation concealment was used.
Horne, 1988^50^ | Some concerns | Some concerns | High | Some concerns | Some concerns | High | Differences based on baseline frequency of binge eating; focused on completers but reanalysis of data showed a greater impact of intervention. Measures were self-reported. ITT was not used. High attrition. No evidence that there was bias based on missing data. No information on why participants dropped out. Unclear if there was a prespecified analysis plan.
Hudson, 1998^51^ | Low | Low | High | Low | Some concerns | High | Potential bias from overall attrition (21%) and significant differential attrition with more fluvoxamine patients than placebo patients dropping out for adverse medical events (12% vs. 0%, respectively, p=0.03) or any reason (31% vs. 12%, respectively, p=0.04). Unclear that the study’s modified ITT and random regression analyses were successful at managing potential attrition bias.
McElroy, 2003^64^ | Low | Low | Some concerns | Low | Low | Some concerns | Despite overall attrition of 43%, authors reported adverse events among all those randomized.
McElroy, 2006^65^ | Low | Low | High | Low | Some concerns | High | High overall attrition (50%) and differential attrition (20%) with more zonisamide patients withdrawing than placebo patients (60% vs. 40%, respectively). Authors acknowledged their analyses may not have accounted for data missing not at random, which means BED severity or other outcomes measured may have contributed to problematic attrition bias.
McElroy, 2007^67^ | Low | Low | Low | Low | Low | Some concerns | Overall, 30% of participants randomized did not complete the study (no differential attrition). Authors described a “repeated measures” random regression model to account for missing data, which implies imputation of missing data values as well as a two-way analysis that implies LOCF. However, assumptions made in models about missing data values are not clear and do not provide clear evidence that results were not biased by missing data.
McElroy, 2011^68^ | Low | Low | High | Low | Some concerns | High | Substantial overall (40%) and differential (34%) attrition with significantly more placebo than acamprosate patients dropping out (55% vs. 21%, respectively). As a result, the study’s analyses relied heavily on assumptions about missing data underlying the study’s random regression and LOCF ITT analyses. More placebo patients than acamprosate patients withdrew because of lack of efficacy (4/11 vs. 0/5) or were lost to followup for unknown reasons (5/11 vs. 1/5). Likely that the placebo group’s higher attrition was related to the severity of BED and that the study’s analyses did not account for the resulting bias.
McElroy, 2015^69^; McElroy, 2016^70^ | Some concerns | Low | Low | Low | Some concerns | Some concerns | No statistical assessment of baseline characteristics. While it does mention those who dropped out for adverse events, details of this are not included in this study, but rather the protocol paper.
McElroy, 2016^71^; Sheehan, 2017^72^ | Some concerns | Low | Low | Low | Some concerns | Some concerns | No statistical assessments of differences at baseline. Unclear if there was prespecified statistical analysis or not.
Milano, 2004^100^ | Some concerns | High | High | High | Some concerns | High | No information on randomization or allocation process. No information on baseline characteristics or if there were differences. No information on if ITT was used. No information on whether participants and carers were aware. No information on missing data. No information on how outcomes were measured. No information on whether assessors were blind. Unclear if there was a prespecified analysis plan
Milano, 2005^101^ | High | Low | Low | Some concerns | Some concerns | High | Small sample size (n=12). Lack of numerical results of baseline demographic information. Participants and carers aware of assigned intervention as expected. No description in methods related to whether certain adverse effects were prespecified or how they were assessed.
Fluoxetine Bulimia Nervosa Collaborative Study Group, 1992^77^ | Some concerns | Low | Low | Low | Some concerns | Some concerns | Lack of information about the randomization process. Unclear whether outcome assessors were blinded.
Pearlstein, 2003^78^ | Some concerns | Some concerns | Some concerns | Low | Some concerns | Some concerns | No ITT analysis: of 25 who met criteria, authors noted that 20 completed the protocol. Unclear if this means they did not complete the study (after randomization) or the intake assessment.
Pope, 1989^81^ | Some concerns | High | Low | Low | Some concerns | High | Randomization process not described. No ITT analysis: those who did not complete 4 weeks of treatment were excluded from analysis (10% of those randomized). An additional five participants (12%) withdrew early for various reasons—some related to factors associated with outcomes being measured (no improvement in ED symptoms, hospitalization for mental health comorbidity). Authors used LOCF in analyses for subjects who withdrew after week 4, which may not address bias.
Walsh, 1991^96^ | Low | Low | Some concerns | Low | Some concerns | Some concerns | Potential bias from overall attrition (19%), but relatively low differential attrition (7%). Reasons for attrition were generally similar. Only a single patient (1/38, or 2.6%) withdrew from the placebo group because of lack of efficacy. LOCF ITT used to manage potential attrition bias.

Abbreviations: BED=binge-eating disorder; BN=bulimia nervosa; ED=eating disorder; ITT=intent-to-treat; KQ=key question; LOCF=last observation carried forward; N=number; NA=not available; ROB=risk of bias; vs.=versus.

Appendix D Table 3 Quality Assessment of Crossover Randomized, Controlled Trials (KQ 4)

First Author, Year; Trial Name; Outcome of Interest | Randomization Process; Domain | Deviations From Intended Interventions; Domain | Missing Outcome Data; Domain | Outcome Measurement; Domain | Selection of Reported Result; Domain | Overall ROB | Comments
Corwin, 2012^102^ | Some concerns | High | High | Low | Low | High | Study drug is associated with known drowsiness, fatigue, itching, and other adverse effects. There was sufficient time for carry-over effects to have disappeared in terms of blood levels of the active medication, but changes in disordered eating behavior may not have disappeared or returned to baseline.
Safer, 2019^103^ | Some concerns | High | Some concerns | Low | Low | High | Lack of information on randomization and allocation concealment.
Mitchell, 1988^104^ | Some concerns | High | High | Low | Some concerns | High | No information on whether analysis plan was prespecified. Small sample size and all withdrawals were from the placebo group. No information on randomization or concealment. No information on whether there were baseline differences.

Abbreviation: ROB=risk of bias.

Appendix D Table 4 Quality Assessment of Screening Test Accuracy Studies (KQ 2)

First Author, Year; Index Test | Bias due to patient selection? | Bias due to index test? | Bias due to the reference standard? | Bias due to flow and timing? | Quality Rating | Rationale
Anstine, 2000^105^ | Low | High | Low | High | Poor | Study assessed accuracy of five questions vs. EAT-26, but analysis grouped participants into high- vs. low-risk groups based on reference standard score and used correlation of index test responses to EAT-26 results to determine threshold for positive response. Only four of five questions were correlated, and accuracy results are only provided for these four questions separately (not for the four or five index questions as a bundle).
Chamay-Weber, 2017^106^; ADO-BES | Low | Low | Low | Unclear | Good
Cotton, 2003^107^; SCOFF, ESP | Low | Low | Low | Low | Good
Dorflinger, 2017^108^; VA-BES | Low | Low | Low | Low | Good
Duarte, 2015^109^ | Unclear | Low | Low | High | Poor | The only ones who received the reference standards were those in a small subsample recruited from the general sample, and details about the timing were unclear.
Franklin, 2019^110^ | Low | Low | Unclear | High | Poor | Only participants who had elevated screening results at intake on one or more questionnaires (depression, anxiety, eating, or sleeping) or needed social work assistance were given the reference test.
Freund, 1999^111^ | Low | Unclear | Unclear | High | Poor | Only a subset of those who completed the screening test consented to participate in the diagnostic interview. The timing between the screening test and reference standard is not clear (methods indicate it may have been as long as 2 years before the reference standard interview).
Garcia, 2010^112^; SCOFF-F | Low | Low | Low | Low | Good
Graham, 2019^113^; SWED | Low | Low | Low | Low | Good
Hill, 2010^114^; Luck, 2002^115^; SCOFF | Low | Low | Low | Low | Good
Lähteenmäki, 2009^116^; SCOFF | Unclear | Low | Low | Unclear | Fair | Study was based on a large population cohort study. Of those completing screening questionnaires, a subset of participants was selected to participate in the accuracy study (see patient selection domain). Of those who completed the screening questionnaire and were invited to participate, only 55% agreed. However, authors noted that mean SCOFF scores were similar among participants and nonparticipants.
Lui, 2015^117^; SCOFF | Unclear | Low | Low | Low | Good
Maugen, 2018^118^; EDS-PC | Low | Low | Low | Unclear | Fair | No description of missing data or proportion of participants who did not respond to mailed surveys.
Maugen, 2018^118^; SCOFF, SDE | Low | Low | Low | Unclear | Fair | No description of missing data or proportion of participants who did not respond to mailed surveys.
Mond, 2008^119^; SCOFF | Low | Low | Unclear | Unclear | Fair | Unclear whether results of index and reference standard interpreted independently. Potential selection bias due to flow/timing: of those completing index test, 33% did not participate in diagnostic interview. Authors stated that participants and nonparticipants did not differ significantly on study variables but did not provide this data or whether participants and nonparticipants differed in terms of index test scores.
Muro-Sans, 2008^120^; SCOFF-c | Low | Low | Low | Low | Good
Parker, 2005^121^; SCOFF | Low | Low | Low | Low | Good
Ricca, 2000^122^; BES | Low | Low | Unclear | Low | Fair | Unclear if diagnostic interviews were done before patients completed the BES and whether clinicians were blind to BES results. Limited information across multiple domains makes a good quality rating difficult.
Rosenvinge, 2001^123^; EDS-5 | Unclear | Low | Low | Low | Fair | Possible selection bias because two groups of 46 students each from a larger sample of 835 students (N=92/835, or 11%) were invited to participate based on having EDS-5 scores in the “upper” or “lower” range. This is different than a random or consecutive selection process. Unclear if any inappropriate exclusions took place.
Siervo, 2005^124^; SCOFF | Unclear | Low | Unclear | Low | Fair | Some potential for selection bias because nine patients (4.8% of 189 total who underwent “initial screening”) with AN, restrictive EDNOS, and bulimia were excluded because of small numbers in each diagnostic category, even though all included EDs were lumped together to evaluate SCOFF test accuracy. Some risk of bias because unclear if the reference standard—an unstructured DSM-IV clinical interview—led to any misclassification of EDs. Unclear if diagnostic interviews were done before patients completed the SCOFF and whether clinicians were blind to SCOFF results.
Solmi, 2015^125^; SCOFF | Unclear | Low | Low | High | Poor | Selection of index test sample was nonrandom, attrition was high, and details about the timing were unclear.
Striegel-Moore, 2010^126^ | Low | Low | Low | Unclear | Fair
Wan Wahida^127^; SCOFF | Low | Low | Low | Low | Good

Abbreviations: ADO-BES=Adolescent Binge Eating Scale; AN=anorexia nervosa; BES=Binge Eating Scale; DSM-IV= Statistical Manual of Mental Disorders, Version 4; EAT-26=Eating Attitudes Test-26; ED=eating disorder; EDNOS= Eating Disorder Not Otherwise Specified; EDS-5=Eating Disturbance Scale-5; EDS-PC=Eating Disturbance Scale for Primary Care; ESP=Eating disorder Scale for Primary Care; KQ=key question; SDE=Screen for Disordered Eating; SWED=Stanford-Washington University Eating Disorder screen; VA-BES=Veterans Administration Binge Eating Scale; vs.=versus.