# Appendix C Excluded Studies

- X1: Non-English
- X2: Ineligible condition
- X3: Ineligible population
- X4: Ineligible screening
- X5: Ineligible intervention
- X6: Ineligible comparison
- X7: Ineligible outcome
- X8: Ineligible clinical setting
- X9: Ineligible study design
- X10: Intermediate outcome only
- X11: Ineligible country
- X12: Not original research
- X13: Abstract only
- X14: Poor quality rating

1 Eating disorders and diet management in contact sports; EAT-26 Questionnaire does not seem appropriate to evaluate eating disorders in sports. Nutr Hosp. 2015;32(4):1708–14. doi: 10.3305/nh.2015.32.4.9214. PMID: CN-01475544. Exclusion Code: X7.26545540
2 ‘Predicting meaningful outcomes to medication and self-help treatments for binge-eating disorder in primary care: The significance of early rapid response’: Correction to Grilo et al (2015). J Consult Clin Psychol. 2015;83(4):747-. doi: 10.1037/ccp0000043. PMID: 2015-33108-001. Exclusion Code: X7.26214545
3 Treating binge eating disorder and obesity with eye movement desensitisation reprocessing. Obesity facts. 2018;Conference: 25th European Congress on Obesity, ECO 2018. Austria. 11(Supplement 1):282. doi: 10.1159/000489691. PMID: CN-01628820. Exclusion Code: X13.
4 Placebo response and cessation in binge eating disorder: a pooled analysis of two randomized parallel-group clinical trials. Eur Eat Disord Rev. 2018doi: 10.1002/erv.2655. PMID: CN-01923110. Exclusion Code: X9.
5 Aardoom JJ, Dingemans AE, Fokkema M, . Moderators of change in an Internet-based intervention for eating disorders with different levels of therapist support: What works for whom? Behav Res Ther. 2017 Feb;89:66–74. doi: 10.1016/j.brat.2016.11.012. PMID: 27907817. Exclusion Code: X7.27907817
6 Aardoom JJ, Dingemans AE, Spinhoven P, . An Internet-based intervention for eating disorders consisting of automated computer-tailored feedback with or without supplemented frequent or infrequent support from a coach: study protocol for a randomized controlled trial. Trials. 2013;14:340. doi: 10.1186/1745-6215-14-340. PMID: CN-01120877. Exclusion Code: X7.24135131
7 Aardoom JJ, Dingemans AE, Spinhoven P, . Web-based fully automated self-help with different levels of therapist support for individuals with eating disorder symptoms: a randomized controlled trial. J Med Internet Res. 2016 Jun 17;18(6):e159. doi: 10.2196/jmir.5709. PMID: 27317358. Exclusion Code: X3.27317358
8 Aardoom JJ, Dingemans AE, van Ginkel JR, . Cost-utility of an internet-based intervention with or without therapist support in comparison with a waiting list for individuals with eating disorder symptoms: a randomized controlled trial. Int J Eat Disord. 2016 Dec;49(12):1068–76. doi: 10.1002/eat.22587. PMID: 27441418. Exclusion Code: X7.27441418
9 Abbott DW, Mitchell JE. Antidepressants vs psychotherapy in the treatment of bulimia nervosa. Psychopharmacol Bull. 1993;29(1):115–9. PMID: 1994-06460-001. Exclusion Code: X9.8378504
10 Abraham SF, von Lojewski A, Anderson G, . Feelings: what questions best discriminate women with and without eating disorders? Eat Weight Disord. 2009 Mar;14(1):e6–10. doi: 10.1007/bf03354621. PMID: 19367134. Exclusion Code: X3.19367134
11 Abrahamsson N, Ahlund L, Ahrin E, . Video-based CBT-E improves eating patterns in obese patients with eating disorder: A single case multiple baseline study. J Behav Ther Exp Psychiatry. 2018 Dec;61:104–12. doi: 10.1016/j.jbtep.2018.06.010. PMID: 29990679. Exclusion Code: X7.29990679
12 Adair CE, Marcoux GC, Bischoff TF, . Responsiveness of the Eating Disorders Quality of Life Scale (EDQLS) in a longitudinal multi-site sample. Health Qual Life Outcomes. 2010 Aug 11;8:83. doi: 10.1186/1477-7525-8-83. PMID: 20701776. Exclusion Code: X9.20701776
13 Affenito SG, Backstrand JR, Welch GW, . Subclinical and clinical eating disorders in IDDM negatively affect metabolic control. Diabetes Care. 1997 Feb;20(2):182–4. doi: 10.2337/diacare.20.2.182. PMID: 9118770. Exclusion Code: X3.9118770
14 Agras WS, Rossiter EM, Arnow B, . Pharmacologic and cognitive-behavioral treatment for bulimia nervosa: a controlled comparison. Am J Psychiatry. 1992 Jan;149(1):82–7. doi: 10.1176/ajp.149.1.82. PMID: 1728190. Exclusion Code: X7.1728190
15 Agras WS, Schneider JA, Arnow B, . Cognitive-behavioral and response-prevention treatments for bulimia nervosa. J Consult Clin Psychol. 1989 Apr;57(2):215–21. doi: 10.1037//0022-006x.57.2.215. PMID: 2708607. Exclusion Code: X14.2708607
16 Agüera Z, Brewin N, Chen J, . Eating symptomatology and general psychopathology in patients with anorexia nervosa from China, UK and Spain: A cross-cultural study examining the role of social attitudes. PLoS One. 2017;12(3):e0173781. doi: 10.1371/journal.pone.0173781. PMID: 28301566. Exclusion Code: X7.28301566
17 Ahmadi S, Moloodi R, Zarbaksh MR, . Psychometric properties of the Eating Attitude Test-26 for female Iranian students. Eat Weight Disord. 2014 Jun;19(2):183–9. doi: 10.1007/s40519-014-0106-7. PMID: 24563207. Exclusion Code: X4.24563207
18 Al-Adawi S, Dorvlo AS, Burke DT, . A survey of anorexia nervosa using the Arabic version of the EAT-26 and “gold standard” interviews among Omani adolescents. Eat Weight Disord. 2002 Dec;7(4):304–11. doi: 10.1007/bf03324977. PMID: 12588059. Exclusion Code: X4.12588059
19 Alberts HJ, Thewissen R, Raes L. Dealing with problematic eating behaviour. The effects of a mindfulness-based intervention on eating behaviour, food cravings, dichotomous thinking and body image concern. Appetite. 2012 Jun;58(3):847–51. doi: 10.1016/j.appet.2012.01.009. PMID: 22265753. Exclusion Code: X10.22265753
20 Alger SA, Schwalberg MD, Bigaouette JM, . Effect of a tricyclic antidepressant and opiate antagonist on binge-eating behavior in normoweight bulimic and obese, binge-eating subjects. Am J Clin Nutr. 1991 Apr;53(4):865–71. doi: 10.1093/ajcn/53.4.865. PMID: 2008865. Exclusion Code: X14.2008865
21 Allen KL, Byrne SM, Forbes D, . Risk factors for full- and partial-syndrome early adolescent eating disorders: a population-based pregnancy cohort study. J Am Acad Child Adolesc Psychiatry. 2009 Aug;48(8):800–9. doi: 10.1097/CHI.0b013e3181a8136d. PMID: 19564799. Exclusion Code: X7.19564799
22 Allen KL, Byrne SM, Lampard A, . Confirmatory factor analysis of the Eating Disorder Examination-Questionnaire (EDE-Q). Eat Behav. 2011;12(2):143–51. doi: 10.1016/j.eatbeh.2011.01.005. PMID: 2011-03143-001. Exclusion Code: X4.21385645
23 Allen KL, Byrne SM, McLean NJ. The dual-pathway and cognitive-behavioural models of binge eating: prospective evaluation and comparison. Eur Child Adolesc Psychiatry. 2012 Jan;21(1):51–62. doi: 10.1007/s00787-011-0231-z. PMID: 22120762. Exclusion Code: X9.22120762
24 Allen KL, Byrne SM, Oddy WH, . Early onset binge eating and purging eating disorders: course and outcome in a population-based study of adolescents. J Abnorm Child Psychol. 2013 Oct;41(7):1083–96. doi: 10.1007/s10802-013-9747-7. PMID: 23605960. Exclusion Code: X7.23605960
25 Allen KL, Byrne SM, Oddy WH, . DSM-IV-TR and DSM-5 eating disorders in adolescents: prevalence, stability, and psychosocial correlates in a population-based sample of male and female adolescents. J Abnorm Psychol. 2013 Aug;122(3):720–32. doi: 10.1037/a0034004. PMID: 24016012. Exclusion Code: X4.24016012
26 Allen KL, Fursland A, Watson H, . Eating disorder diagnoses in general practice settings: comparison with structured clinical interview and self-report questionnaires. J Ment Health. 2011 Jun;20(3):270–80. doi: 10.3109/09638237.2011.562259. PMID: 21574792. Exclusion Code: X4.21574792
27 Allen KL, McLean NJ, Byrne SM. Evaluation of a new measure of mood intolerance, the Tolerance of Mood States Scale (TOMS): psychometric properties and associations with eating disorder symptoms. Eat Behav. 2012 Dec;13(4):326–34. doi: 10.1016/j.eatbeh.2012.05.005. PMID: 23121783. Exclusion Code: X4.23121783
28 Allison KC, Crow SJ, Reeves RR, . Binge eating disorder and night eating syndrome in adults with type 2 diabetes. Obesity (Silver Spring). 2007 May;15(5):1287–93. doi: 10.1038/oby.2007.150. PMID: 17495205. Exclusion Code: X7.17495205
29 Allison KC, Lundgren JD, Stunkard AJ, . Validation of screening questions and symptom coherence of night eating in the Swedish Twin Registry. Compr Psychiatry. 2014 Apr;55(3):579–87. doi: 10.1016/j.comppsych.2013.01.006. PMID: 24457035. Exclusion Code: X4.24457035
30 al-Subaie A, al-Shammari S, Bamgboye E, . Validity of the Arabic version of the Eating Attitude Test. Int J Eat Disord. 1996 Nov;20(3):321–4. doi: 10.1002/(sici)1098-108x(199611)20:3<321::aid-eat12>3.0.co;2-2. PMID: 8912045. Exclusion Code: X4.8912045
31 al-Subaie AS, Bamgboye E, al-Shammari S, . Validity of the Arabic version of the eating disorders inventory (EDI). Br J Psychiatry. 1996 May;168(5):636–40. doi: 10.1192/bjp.168.5.636. PMID: 8733805. Exclusion Code: X4.8733805
32 Altman DR, Tanofsky-Kraff M, Shank LM, . Assessment of loss-of-control eating in healthy youth by interview and questionnaire. Int J Eat Disord. 2020 May;53(5):510–9. doi: 10.1002/eat.23262. PMID: 32202658. Exclusion Code: X4.32202658
33 Alvarenga Mdos S, Scagliusi FB, Philippi ST. Development and validity of the Disordered Eating Attitude Scale (DEAS). Percept Mot Skills. 2010 Apr;110(2):379–95. doi: 10.2466/pms.110.2.379-395. PMID: 20499550. Exclusion Code: X7.20499550
34 Alvarenga MS, Pereira RF, Scagliusi FB, . Psychometric evaluation of the Disordered Eating Attitude Scale (DEAS). English version. Appetite. 2010 Oct;55(2):374–6. doi: 10.1016/j.appet.2010.07.003. PMID: 20624435. Exclusion Code: X7.20624435
35 Alvarenga MS, Scagliusi FB, Philippi ST. Changing attitudes, beliefs and feelings towards food in bulimic patients. Arch Latinoam Nutr. 2008 Sep;58(3):274–9. PMID: 19137990. Exclusion Code: X9.19137990
36 Alvarez-Rayón G, Mancilla-Díaz JM, Vázquez-Arévalo R, . Validity of the Eating Attitudes Test: a study of Mexican eating disorders patients. Eat Weight Disord. 2004 Dec;9(4):243–8. doi: 10.1007/bf03325077. PMID: 15844395. Exclusion Code: X8.15844395
37 Ambrosi-Randić N, Pokrajac-Bulian A. Psychometric properties of the eating attitudes test and children’s eating attitudes test in Croatia. Eat Weight Disord. 2005 Dec;10(4):e76–82. doi: 10.1007/bf03327495. PMID: 16682865. Exclusion Code: X7.16682865
38 Ambwani S, Berenson KR, Simms L, . Seeing things differently: an experimental investigation of social cognition and interpersonal behavior in anorexia nervosa. Int J Eat Disord. 2016;49(5):499–506. doi: 10.1002/eat.22498. PMID: 2015-58809-001. Exclusion Code: X5.26712303
39 Amdur MJ, Tucker GJ, Detre T, . Anorexia nervosa: an interactional study. J Nerv Ment Dis. 1969 May;148(5):559–66. doi: 10.1097/00005053-196905000-00009. PMID: 5768205. Exclusion Code: X8.5768205
40 Amianto F, Spalatro A, Ottone L, . Naturalistic follow-up of subjects affected with anorexia nervosa 8 years after multimodal treatment: Personality and psychopathology changes and predictors of outcome. Eur Psychiatry. 2017 Sep;45:198–206. doi: 10.1016/j.eurpsy.2017.07.012. PMID: 28957787. Exclusion Code: X3.28957787
41 Ammann J, Egolf A, Hartmann C, . Cross-national comparison of the Food Disgust Picture Scale between Switzerland and China using confirmatory factor analysis. Food Qual Prefer. 2020;79doi: 10.1016/j.foodqual.2019.103756. PMID: 2019-65843-001. Exclusion Code: X4.
42 Ammann J, Hartmann C, Siegrist M. Development and validation of the Food Disgust Picture Scale. Appetite. 2018 Jun 1;125:367–79. doi: 10.1016/j.appet.2018.02.020. PMID: 29496601. Exclusion Code: X2.29496601
43 Anastasiadou D, Folkvord F, Brugnera A, . An mHealth intervention for the treatment of patients with an eating disorder: A multicenter randomized controlled trial. Int J Eat Disord. 2020 May 8doi: 10.1002/eat.23286. PMID: 32383503. Exclusion Code: X7.32383503
44 And A, Sylvester MD, Turan B, . The Turkish Palatable Eating Motives Scale (T-PEMS): utility in predicting binge-eating eating and obesity risk in university students. Eat Weight Disord. 2018 Aug;23(4):527–31. doi: 10.1007/s40519-017-0383-z. PMID: 28390007. Exclusion Code: X9.28390007
45 Anderson CB, Joyce PR, Carter FA, . The effect of cognitive-behavioral therapy for bulimia nervosa on temperament and character as measured by the temperament and character inventory. Compr Psychiatry. 2002 May–Jun;43(3):182–8. doi: 10.1053/comp.2002.32359. PMID: 11994835. Exclusion Code: X7.11994835
46 Andony LJ, Tay E, Allen KL, . Therapist adherence in the strong without anorexia nervosa (SWAN) study: A randomized controlled trial of three treatments for adults with anorexia nervosa. Int J Eat Disord. 2015 Dec;48(8):1170–5. doi: 10.1002/eat.22455. PMID: 26769445. Exclusion Code: X7.26769445
47 Andreas S, Rabung S, Mestel R, . Does a more specified version of the HoNOS (Health of the Nation Outcome Scales) increase psychometric properties of the inventory? Psychopathology. 2011;44(4):261–71. doi: 10.1159/000322690. PMID: 2012-08252-007. Exclusion Code: X4.21546787
48 Andreeva VA, Tavolacci MP, Galan P, . Sociodemographic correlates of eating disorder subtypes among men and women in France, with a focus on age. J Epidemiol Community Health. 2019 Jan;73(1):56–64. doi: 10.1136/jech-2018-210745. PMID: 30301763. Exclusion Code: X7.30301763
49 Andrewes DG, O’Connor P, Mulder C, . Computerised psychoeducation for patients with eating disorders. Aust N Z J Psychiatry. 1996 Aug;30(4):492–7. doi: 10.3109/00048679609065022. PMID: 8887699. Exclusion Code: X5.8887699
50 Andries A, Frystyk J, Flyvbjerg A, . Dronabinol in severe, enduring anorexia nervosa: a randomized controlled trial. Int J Eat Disord. 2014 Jan;47(1):18–23. doi: 10.1002/eat.22173. PMID: 24105610. Exclusion Code: X3.24105610
51 Andries A, Frystyk J, Flyvbjerg A, . Changes in IGF-I, urinary free cortisol and adipokines during dronabinol therapy in anorexia nervosa: Results from a randomised, controlled trial. Growth Horm IGF Res. 2015 Oct;25(5):247–52. doi: 10.1016/j.ghir.2015.07.006. PMID: 26248813. Exclusion Code: X3.26248813
52 Anstine D, Grinenko D. Rapid screening for disordered eating in college-aged females in the primary care setting. J Adolesc Health. 2000 May;26(5):338–42. doi: 10.1016/s1054-139x(99)00120-2. PMID: 10775826. Exclusion Code: X14.10775826
53 Aoun A, Azzam J, Jabbour FE, . Validation of the Arabic version of the SCOFF questionnaire for the screening of eating disorders. East Mediterr Health J. 2015 Aug 27;21(5):326–31. doi: 10.26719/2015.21.5.326. PMID: 26343121. Exclusion Code: X11.26343121
54 Appolinario JC, Bacaltchuk J, Sichieri R, . A randomized, double-blind, placebo-controlled study of sibutramine in the treatment of binge-eating disorder. Arch Gen Psychiatry. 2003 Nov;60(11):1109–16. doi: 10.1001/archpsyc.60.11.1109. PMID: 14609886. Exclusion Code: X11.14609886
55 Archer LA, Rosenbaum PL, Streiner DL. The children’s eating behavior inventory: reliability and validity results. J Pediatr Psychol. 1991 Oct;16(5):629–42. doi: 10.1093/jpepsy/16.5.629. PMID: 1744810. Exclusion Code: X3.1744810
56 Aruguete MS, Yates A, Edman JL. Further validation of the self-loathing subscale as a screening tool for eating disorders. Eat Disord. 2007 Jan–Feb;15(1):55–62. doi: 10.1080/10640260601044493. PMID: 17162641. Exclusion Code: X4.17162641
57 Askew AJ, Peterson CB, Crow SJ, . Not all body image constructs are created equal: Predicting eating disorder outcomes from preoccupation, dissatisfaction, and overvaluation. Int J Eat Disord. 2020 Jun;53(6):954–63. doi: 10.1002/eat.23277. PMID: 32304257. Exclusion Code: X9.32304257
58 Atkinson MJ, Wade TD. Mindfulness-based prevention for eating disorders: a school-based cluster randomized controlled study. Int J Eat Disord. 2015 Nov;48(7):1024–37. doi: 10.1002/eat.22416. PMID: 26052831. Exclusion Code: X5.26052831
59 Atkinson MJ, Wade TD. Does mindfulness have potential in eating disorders prevention? A preliminary controlled trial with young adult women. Early Interv Psychiatry. 2016 Jun;10(3):234–45. doi: 10.1111/eip.12160. PMID: 24894735. Exclusion Code: X3.24894735
60 Attia E, Kaplan AS, Walsh BT, . Olanzapine versus placebo for out-patients with anorexia nervosa. Psychol Med. 2011 Oct;41(10):2177–82. doi: 10.1017/s0033291711000390. PMID: 21426603. Exclusion Code: X3.21426603
61 Attia E, Steinglass JE, Walsh BT, . Olanzapine Versus Placebo in Adult Outpatients With Anorexia Nervosa: A Randomized Clinical Trial. Am J Psychiatry. 2019 Jun 1;176(6):449–56. doi: 10.1176/appi.ajp.2018.18101125. PMID: 30654643. Exclusion Code: X3.30654643
62 Augestad LB, Flanders WD. Assessment of two self-reporting questionnaires for eating disorders in women. Eat Weight Disord. 2003 Mar;8(1):12–9. doi: 10.1007/bf03324984. PMID: 12762620. Exclusion Code: X4.12762620
63 Babusa B, Urbán R, Czeglédi E, . Psychometric properties and construct validity of the Muscle Appearance Satisfaction Scale among Hungarian men. Body Image. 2012 Jan;9(1):155–62. doi: 10.1016/j.bodyim.2011.08.005. PMID: 21962394. Exclusion Code: X2.21962394
64 Bachar E, Latzer Y, Kreitler S, . Empirical comparison of two psychological therapies. Self psychology and cognitive orientation in the treatment of anorexia and bulimia. J Psychother Pract Res. 1999 Spring;8(2):115–28. PMID: 10079459. Exclusion Code: X14.10079459
65 Bailer U, de Zwaan M, Leisch F, . Guided self-help versus cognitive-behavioral group therapy in the treatment of bulimia nervosa. Int J Eat Disord. 2004 May;35(4):522–37. doi: 10.1002/eat.20003. PMID: 15101068. Exclusion Code: X7.15101068
66 Banasiak SJ, Paxton SJ, Hay P. Guided self-help for bulimia nervosa in primary care: A randomized controlled trial. Psychol Med. 2005;35(9):1283–94. doi: 10.1017/S0033291705004769. PMID: 2007-00390-005. Exclusion Code: X7.16168151
67 Banasiak SJ, Wertheim EH, Koerner J, . Test–retest reliability and internal consistency of a variety of measures of dietary restraint and body concerns in a sample of adolescent girls. Int J Eat Disord. 2001;29(1):85–9. doi: 10.1002/1098-108X(200101)29:1<85::AID-EAT14>3.0.CO;2-G. PMID: 2001-16082-014. Exclusion Code: X7.11135339
68 Baños RM, Cebolla A, Etchemendy E, . Validation of the Dutch Eating Behavior Questionnaire for Children (DEBQ-C) for use with Spanish children. Nutr Hosp. 2011 Jul–Aug;26(4):890–8. doi: 10.1590/s0212-16112011000400032. PMID: 22470039. Exclusion Code: X7.22470039
69 Bardone-Cone AM, Boyd CA. Psychometric properties of eating disorder instruments in Black and White young women: internal consistency, temporal stability, and validity. Psychol Assess. 2007 Sep;19(3):356–62. doi: 10.1037/1040-3590.19.3.356. PMID: 17845127. Exclusion Code: X9.17845127
70 Barlow J, Blouin J, Blouin A, . Treatment of bulimia with desipramine: a double-blind crossover study. Can J Psychiatry. 1988 Mar;33(2):129–33. doi: 10.1177/070674378803300211. PMID: 3284630. Exclusion Code: X14.3284630
71 Barnes J, Prescott T, Muncer S. Confirmatory factor analysis for the Eating Disorder Examination Questionnaire: Evidence supporting a three-factor model. Eat Behav. 2012 Dec;13(4):379–81. doi: 10.1016/j.eatbeh.2012.05.001. PMID: 23121792. Exclusion Code: X7.23121792
72 Barnes RD, Ivezaj V, Martino S, . Examining motivational interviewing plus nutrition psychoeducation for weight loss in primary care. J Psychosom Res. 2018;104:101–7. doi: 10.1016/j.jpsychores.2017.11.013. PMID: 2017-58619-016. Exclusion Code: X7.29275778
73 Barnes RD, Sawaoka T, White MA, . Factor structure and clinical correlates of the Food Thought Suppression Inventory within treatment seeking obese women with binge eating disorder. Eat Behav. 2013 Jan;14(1):35–9. doi: 10.1016/j.eatbeh.2012.10.008. PMID: 23265399. Exclusion Code: X4.23265399
74 Barrada JR, van Strien T, Cebolla A. Internal Structure and Measurement Invariance of the Dutch Eating Behavior Questionnaire (DEBQ) in a (Nearly) Representative Dutch Community Sample. Eur Eat Disord Rev. 2016 Nov;24(6):503–9. doi: 10.1002/erv.2448. PMID: 27075404. Exclusion Code: X7.27075404
75 Bartholdy S, McClelland J, Kekic M, . Clinical outcomes and neural correlates of 20 sessions of repetitive transcranial magnetic stimulation in severe and enduring anorexia nervosa (the TIARA study): study protocol for a randomised controlled feasibility trial. Trials. 2015;16:548. doi: 10.1186/s13063-015-1069-3. PMID: CN-01179783. Exclusion Code: X7.26634828
76 Bartlett BA, Iverson KM, Mitchell KS. Intimate partner violence and disordered eating among male and female veterans. Psychiatry Res. 2018 Feb;260:98–104. doi: 10.1016/j.psychres.2017.11.056. PMID: 29179017. Exclusion Code: X9.29179017
77 Basarkod G, Sahdra B, Ciarrochi J. Body Image-Acceptance and Action Questionnaire-5: an abbreviation using genetic algorithms. Behav Ther. 2018 May;49(3):388–402. doi: 10.1016/j.beth.2017.09.006. PMID: 29704968. Exclusion Code: X4.29704968
78 Baucom DH, Kirby JS, Fischer MS, . Findings from a couple-based open trial for adult anorexia nervosa. J Fam Psychol. 2017 Aug;31(5):584–91. doi: 10.1037/fam0000273. PMID: 28318287. Exclusion Code: X5.28318287
79 Bauer C, Fischer A, Keller U. Effect of sibutramine and of cognitive-behavioural weight loss therapy in obesity and subclinical binge eating disorder. Diabetes Obes Metab. 2006 May;8(3):289–95. doi: 10.1111/j.1463-1326.2005.00504.x. PMID: 16634988. Exclusion Code: X10.16634988
80 Bauer S, Bilić S, Reetz C, . Efficacy and cost-effectiveness of Internet-based selective eating disorder prevention: study protocol for a randomized controlled trial within the ProHEAD Consortium. Trials. 2019 Jan 30;20(1):91. doi: 10.1186/s13063-018-3161-y. PMID: 30700318. Exclusion Code: X7.30700318
81 Bautista JR, Pavlakis A, Rajagopal A. Bayesian analysis of randomized controlled trials. Int J Eat Disord. 2018 Jul;51(7):637–46. doi: 10.1002/eat.22928. PMID: 30051507. Exclusion Code: X7.30051507
82 Beales DL, Dolton R. Eating disordered patients: personality, alexithymia, and implications for primary care. Br J Gen Pract. 2000 Jan;50(450):21–6. PMID: 10695062. Exclusion Code: X7.10695062
83 Becker AE, Franko DL, Nussbaum K, . Secondary prevention for eating disorders: the impact of education, screening, and referral in a college-based screening program. Int J Eat Disord. 2004 Sep;36(2):157–62. doi: 10.1002/eat.20023. PMID: 15282685. Exclusion Code: X7.15282685
84 Becker AE, Franko DL, Speck A, . Ethnicity and differential access to care for eating disorder symptoms. Int J Eat Disord. 2003 Mar;33(2):205–12. doi: 10.1002/eat.10129. PMID: 12616587. Exclusion Code: X9.12616587
85 Becker AE, Thomas JJ, Bainivualiku A, . Validity and reliability of a Fijian translation and adaptation of the Eating Disorder Examination Questionnaire. Int J Eat Disord. 2010 Mar;43(2):171–8. doi: 10.1002/eat.20675. PMID: 19308995. Exclusion Code: X7.19308995
86 Becker AE, Thomas JJ, Franko DL, . Interpretation and use of weight information in the evaluation of eating disorders: counselor response to weight information in a National Eating Disorders Educational and Screening Program. Int J Eat Disord. 2005 Jan;37(1):38–43. doi: 10.1002/eat.20063. PMID: 15690464. Exclusion Code: X4.15690464
87 Becker KR, Keshishian AC, Liebman RE, . Impact of expanded diagnostic criteria for avoidant/restrictive food intake disorder on clinical comparisons with anorexia nervosa. Int J Eat Disord. 2019 Mar;52(3):230–8. doi: 10.1002/eat.22988. PMID: 30578644. Exclusion Code: X7.30578644
88 Beglin SJ, Fairburn CG. Evaluation of a new instrument for the detection of eating disorders in community samples. Psychiatry Res. 1992 Dec;44(3):191–201. doi: 10.1016/0165-1781(92)90023-v. PMID: 1289917. Exclusion Code: X4.1289917
89 Bektas M, Bektas I, Selekoğlu Y, . Psychometric properties of the Turkish version of the Emotional Eating Scale for children and adolescents. Eat Behav. 2016 Aug;22:217–21. doi: 10.1016/j.eatbeh.2016.06.021. PMID: 27322519. Exclusion Code: X4.27322519
90 Belafsky PC, Mouadeb DA, Rees CJ, . Validity and reliability of the Eating Assessment Tool (EAT-10). Ann Otol Rhinol Laryngol. 2008 Dec;117(12):919–24. doi: 10.1177/000348940811701210. PMID: 19140539. Exclusion Code: X4.19140539
91 Bellace DL, Tesser R, Berthod S, . The Yale-Brown-Cornell eating disorders scale self-report questionnaire: a new, efficient tool for clinicians and researchers. Int J Eat Disord. 2012 Nov;45(7):856–60. doi: 10.1002/eat.22023. PMID: 22532411. Exclusion Code: X8.22532411
92 Bello LS-D, Berard E, Klein R, . Fast screening of eating disorders among patients with bipolar disorder: Validation of the French version of BEDS questionnaire. European Review of Applied Psychology / Revue Européenne de Psychologie Appliquée. 2017;67(2):61–5. doi: 10.1016/j.erap.2016.12.005. PMID: 2017-47862-002. Exclusion Code: X7.
93 Belon KE, McLaughlin EA, Smith JE, . Testing the measurement invariance of the Eating Disorder Inventory in nonclinical samples of Hispanic and Caucasian women. Int J Eat Disord. 2015 Apr;48(3):262–70. doi: 10.1002/eat.22286. PMID: 24740890. Exclusion Code: X9.24740890
94 Belon KE, Smith JE, Bryan AD, . Measurement invariance of the Eating Attitudes Test-26 in Caucasian and Hispanic women. Eat Behav. 2011 Dec;12(4):317–20. doi: 10.1016/j.eatbeh.2011.07.007. PMID: 22051367. Exclusion Code: X7.22051367
95 Ben-Tovim DI, Whitehead J, Crisp AH. A controlled study of the perception of body width in anorexia nervosa. J Psychosom Res. 1979;23(4):267–72. doi: 10.1016/0022-3999(79)90029-1. PMID: 1981-05535-001. Exclusion Code: X3.529199
96 Berg KC, Stiles-Shields EC, Swanson SA, . Diagnostic concordance of the interview and questionnaire versions of the eating disorder examination. Int J Eat Disord. 2012 Nov;45(7):850–5. doi: 10.1002/eat.20948. PMID: 21826696. Exclusion Code: X4.21826696
97 Berg KC, Swanson SA, Stiles-Shields EC, . Response patterns on interview and questionnaire versions of the Eating Disorder Examination and their impact on latent structure analyses. Compr Psychiatry. 2013 Jul;54(5):506–16. doi: 10.1016/j.comppsych.2012.12.006. PMID: 23375185. Exclusion Code: X4.23375185
98 Bergh C, Brodin U, Lindberg G, . Randomized controlled trial of a treatment for anorexia and bulimia nervosa. Proc Natl Acad Sci U S A. 2002 Jul 9;99(14):9486–91. doi: 10.1073/pnas.142284799. PMID: 12082182. Exclusion Code: X5.12082182
99 Bergh C, Callmar M, Danemar S, . Effective treatment of eating disorders: Results at multiple sites. Behav Neurosci. 2013 Dec;127(6):878–89. doi: 10.1037/a0034921. PMID: 24341712. Exclusion Code: X9.24341712
100 Bergin J, Wade TD. Psychometric properties of the eating disorder belief questionnaire. Int J Eat Disord. 2014 Sep;47(6):640–6. doi: 10.1002/eat.22267. PMID: 24573779. Exclusion Code: X3.24573779
101 Bertoli S, Spadafranca A, Bes-Rastrollo M, . Adherence to the Mediterranean diet is inversely related to binge eating disorder in patients seeking a weight loss program. Clin Nutr. 2015 Feb;34(1):107–14. doi: 10.1016/j.clnu.2014.02.001. PMID: 24559856. Exclusion Code: X9.24559856
102 Beumont PJ, Kopec-Schrader EM, Talbot P, . Measuring the specific psychopathology of eating disorder patients. Aust N Z J Psychiatry. 1993 Sep;27(3):506–11. doi: 10.3109/00048679309075810. PMID: 8250797. Exclusion Code: X7.8250797
103 Beumont PJ, Russell JD, Touyz SW, . Intensive nutritional counselling in bulimia nervosa: a role for supplementation with fluoxetine? Aust N Z J Psychiatry. 1997 Aug;31(4):514–24. doi: 10.3109/00048679709065073. PMID: 9272261. Exclusion Code: X3.9272261
104 Beumont PJV, Russell JD, Touyz SW, . Intensive nutritional counseling in bulimia nervosa: A role for supplementation with fluoxetine? Aust N Z J Psychiatry. 1997;31(4):514–24. doi: 10.3109/00048679709065073. PMID: 1997-35811-011. Exclusion Code: X7.9272261
105 Bhatnagar KA, Wisniewski L, Solomon M, . Effectiveness and feasibility of a cognitive-behavioral group intervention for body image disturbance in women with eating disorders. J Clin Psychol. 2013 Jan;69(1):1–13. doi: 10.1002/jclp.21909. PMID: 22903360. Exclusion Code: X3.22903360
106 Bhugra D, Mastrogianni A, Maharajh H, . Prevalence of bulimic behaviours and eating attitudes in schoolgirls from Trinidad and Barbados. Transcult Psychiatry. 2003 Sep;40(3):409–28. doi: 10.1177/13634615030403005. PMID: 14649852. Exclusion Code: X7.14649852
107 Biederman J, Herzog DB, Rivinus TM, . Amitriptyline in the treatment of anorexia nervosa: a double-blind, placebo-controlled study. J Clin Psychopharmacol. 1985 Feb;5(1):10–6. PMID: 3973067. Exclusion Code: X8.3973067
108 Binford RB, Le Grange D, Jellar CC. Eating Disorders Examination versus Eating Disorders Examination-Questionnaire in adolescents with full and partial-syndrome bulimia nervosa and anorexia nervosa. Int J Eat Disord. 2005 Jan;37(1):44–9. doi: 10.1002/eat.20062. PMID: 15690465. Exclusion Code: X9.15690465
109 Birgegård A, Clinton D, Norring C. Diagnostic issues of binge eating in eating disorders. Eur Eat Disord Rev. 2013 May;21(3):175–83. doi: 10.1002/erv.2227. PMID: 23440765. Exclusion Code: X7.23440765
110 Birgegård A, Norring C, Clinton D. Binge eating in interview versus self-report: different diagnoses show different divergences. Eur Eat Disord Rev. 2014 May;22(3):170–5. doi: 10.1002/erv.2289. PMID: 24729193. Exclusion Code: X5.24729193
111 Bishop-Gilyard CT, Berkowitz RI, Wadden TA, . Weight reduction in obese adolescents with and without binge eating. Obesity (Silver Spring). 2011 May;19(5):982–7. doi: 10.1038/oby.2010.249. PMID: 20948512. Exclusion Code: X7.20948512
112 Bissada H, Tasca GA, Barber AM, . Olanzapine in the treatment of low body weight and obsessive thinking in women with anorexia nervosa: A randomized, double-blind, placebo-controlled trial. The American Journal of Psychiatry. 2008;165(10):1281–8. doi: 10.1176/appi.ajp.2008.07121900. PMID: 2008-14551-015. Exclusion Code: X7.18558642
113 Björck C, Björk T, Clinton D, . Self-image and treatment drop-out in eating disorders. Psychol Psychother. 2008 Mar;81(Pt 1):95–104. doi: 10.1348/147608307x224547. PMID: 17631699. Exclusion Code: X7.17631699
114 Black CM, Wilson GT. Assessment of eating disorders: interview versus questionnaire. Int J Eat Disord. 1996 Jul;20(1):43–50. doi: 10.1002/(sici)1098-108x(199607)20:1<43::aid-eat5>3.0.co;2-4. PMID: 8807351. Exclusion Code: X4.8807351
115 Black DR, Larkin LJS, Coster DC, . Physiologic Screening Test for Eating Disorders/Disordered Eating Among Female Collegiate Athletes. Journal of Athletic Training. 2003;38(4):286–97. PMID: 2004-10230-001. Exclusion Code: X4.14737209
116 Bloch M, Ish-Shalom S, Greenman Y, . Dehydroepiandrosterone treatment effects on weight, bone density, bone metabolism and mood in women suffering from anorexia nervosa-a pilot study. Psychiatry Res. 2012 Dec 30;200(2–3):544–9. doi: 10.1016/j.psychres.2012.07.012. PMID: 22858403. Exclusion Code: X3.22858403
117 Blom TJ, Guerdjikova AI, McElroy SL. Placebo response and cessation in binge eating disorder: A pooled analysis of two randomized parallel-group clinical trials. Eur Eat Disord Rev. 2019 Jul;27(4):421–8. doi: 10.1002/erv.2655. PMID: 30370658. Exclusion Code: X9.30370658
118 Blom TJ, Guerdjikova AI, Mori N, . Placebo cessation in binge eating disorder: Effect on anthropometric, cardiovascular, and metabolic variables. Eur Eat Disord Rev. 2015;23(1):86–8. doi: 10.1002/erv.2333. PMID: 2015-01402-011. Exclusion Code: X3.25385538
119 Blomquist KK, Grilo CM. Predictive significance of changes in dietary restraint in obese patients with binge eating disorder during treatment. Int J Eat Disord. 2011 Sep;44(6):515–23. doi: 10.1002/eat.20849. PMID: 20957705. Exclusion Code: X7.20957705
120 Blomquist KK, Roberto CA, Barnes RD, . Development and validation of the eating loss of control scale. Psychol Assess. 2014 Mar;26(1):77–89. doi: 10.1037/a0034729. PMID: 24219700. Exclusion Code: X9.24219700
121 Blouin AG, Blouin JH, Iversen H, . Light therapy in bulimia nervosa: a double-blind, placebo-controlled study. Psychiatry Res. 1996 Feb 28;60(1):1–9. doi: 10.1016/0165-1781(95)02532-4. PMID: 8852863. Exclusion Code: X5.8852863
122 Blouin AG, Blouin JH, Perez EL, . Treatment of bulimia with fenfluramine and desipramine. J Clin Psychopharmacol. 1988 Aug;8(4):261–9. PMID: 3062043. Exclusion Code: X7.3062043
123 Blouin J, Blouin A, Perez E, . Bulimia: independence of antibulimic and antidepressant properties of desipramine. Can J Psychiatry. 1989 Feb;34(1):24–9. doi: 10.1177/070674378903400107. PMID: 2647270. Exclusion Code: X10.2647270
124 Bodell LP, Keel PK. Current treatment for anorexia nervosa: Efficacy, safety, and adherence. Psychol Res Behav Manag. 2010;3 PMID: 2014-26288-001. Exclusion Code: X12.
125 Boerhout C, Swart M, Van Busschbach JT, . Effect of Aggression Regulation on Eating Disorder Pathology: RCT of a Brief Body and Movement Oriented Intervention. Eur Eat Disord Rev. 2016 Mar;24(2):114–21. doi: 10.1002/erv.2429. PMID: 26679955. Exclusion Code: X7.26679955
126 Boerhout C, Swart M, Voskamp M, . Aggression Regulation in Day Treatment of Eating Disorders: Two-Centre RCT of a Brief Body and Movement-Oriented Intervention. Eur Eat Disord Rev. 2017 Jan;25(1):52–9. doi: 10.1002/erv.2491. PMID: 27862660. Exclusion Code: X7.27862660
127 Boggiano MM, Wenger LE, Mrug S, . The Kids-Palatable Eating Motives Scale: relation to BMI and binge eating traits. Eat Behav. 2015 Apr;17:69–73. doi: 10.1016/j.eatbeh.2014.12.014. PMID: 25613823. Exclusion Code: X7.25613823
128 Boggiss AL, Consedine NS, Jefferies C, . Protocol for a feasibility study: a brief self-compassion intervention for adolescents with type 1 diabetes and disordered eating. BMJ Open. 2020 Feb 9;10(2):e034452. doi: 10.1136/bmjopen-2019-034452. PMID: 32041861. Exclusion Code: X7.32041861
129 Bohrer BK, Forbush KT, Hunt TK. Are common measures of dietary restraint and disinhibited eating reliable and valid in obese persons? Appetite. 2015 Apr;87:344–51. doi: 10.1016/j.appet.2014.12.226. PMID: 25582416. Exclusion Code: X7.25582416
130 Bond MJ, McDowell AJ, Wilkinson JY. The measurement of dietary restraint, disinhibition and hunger: an examination of the factor structure of the Three Factor Eating Questionnaire (TFEQ). Int J Obes Relat Metab Disord. 2001 Jun;25(6):900–6. doi: 10.1038/sj.ijo.0801611. PMID: 11439306. Exclusion Code: X4.11439306
131 Bonomi AE, Anderson ML, Nemeth J, . History of dating violence and the association with late adolescent health. BMC Public Health. 2013 Sep 10;13:821. doi: 10.1186/1471-2458-13-821. PMID: 24015863. Exclusion Code: X7.24015863
132 Borges MB, Morgan CM, Claudino AM, . Validation of the Portuguese version of the Questionnaire on Eating and Weight Patterns-Revised (QEWP-R) for the screening of binge eating disorder. Braz J Psychiatry. 2005 Dec;27(4):319–22. doi: 10.1590/s1516-44462005000400012. PMID: 16358115. Exclusion Code: X4.16358115
133 Bossert S, Schnabel E, Krieg JC. Effects and limitations of cognitive behavior therapy in bulimia inpatients. Psychother Psychosom. 1989;51(2):77–82. doi: 10.1159/000288139. PMID: 2626528. Exclusion Code: X8.2626528
134 Boujut E, Gana K. Relationship between depressive mood and eating disorders in a non-clinical young female sample: a one-year longitudinal analysis of cross-lagged and simultaneous effects. Eat Behav. 2014 Aug;15(3):434–40. doi: 10.1016/j.eatbeh.2014.04.018. PMID: 25064295. Exclusion Code: X9.25064295
135 Bradford R, Rutherford D. The Eating Disorder Belief Questionnaire: In-patient adolescent scores. Clin Child Psychol Psychiatry. 2001;6(4):513–8. doi: 10.1177/1359104501006004005. PMID: 2001-05552-003. Exclusion Code: X3.
136 Brambilla F, Garcia CS, Fassino S, . Olanzapine therapy in anorexia nervosa: psychobiological effects. Int Clin Psychopharmacol. 2007 Jul;22(4):197–204. doi: 10.1097/YIC.0b013e328080ca31. PMID: 17519642. Exclusion Code: X3.17519642
137 Brambilla F, Monteleone P, Maj M. Olanzapine-induced weight gain in anorexia nervosa: involvement of leptin and ghrelin secretion? Psychoneuroendocrinology. 2007 May;32(4):402–6. doi: 10.1016/j.psyneuen.2007.02.005. PMID: 17395395. Exclusion Code: X7.17395395
138 Brambilla F, Samek L, Company M, . Multivariate therapeutic approach to binge-eating disorder: combined nutritional, psychological and pharmacological treatment. Int Clin Psychopharmacol. 2009 Nov;24(6):312–7. doi: 10.1097/YIC.0b013e32832ac828. PMID: 19794312. Exclusion Code: X7.19794312
139 Brennan BP, Roberts JL, Fogarty KV, . Memantine in the treatment of binge eating disorder: an open-label, prospective trial. Int J Eat Disord. 2008 Sep;41(6):520–6. doi: 10.1002/eat.20541. PMID: 18433015. Exclusion Code: X9.18433015
140 Bretz WA, Krahn DD, Drury M, . Effects of fluoxetine on the oral environment of bulimics. Oral Microbiol Immunol. 1993;8(1):62–4. doi: 10.1111/j.1399-302x.1993.tb00545.x. PMID: CN-00093758. Exclusion Code: X7.8510986
141 Brewerton TD, Murphy DL, Jimerson DC. Testmeal responses following m-chlorophenylpiperazine and L-tryptophan in bulimics and controls. Neuropsychopharmacology. 1994 Aug;11(1):63–71. doi: 10.1038/npp.1994.36. PMID: 7945745. Exclusion Code: X3.7945745
142 Brewin N, Baggott J, Dugard P, . Clinical normative data for eating disorder examination questionnaire and eating disorder inventory for DSM-5 feeding and eating disorder classifications: a retrospective study of patients formerly diagnosed via DSM-IV. Eur Eat Disord Rev. 2014 Jul;22(4):299–305. doi: 10.1002/erv.2301. PMID: 24888670. Exclusion Code: X7.24888670
143 Brockmeyer T, Friederich HC, Küppers C, . Approach bias modification training in bulimia nervosa and binge-eating disorder: A pilot randomized controlled trial. Int J Eat Disord. 2019 May;52(5):520–9. doi: 10.1002/eat.23024. PMID: 30689229. Exclusion Code: X5.30689229
144 Brockmeyer T, Ingenerf K, Walther S, . Training cognitive flexibility in patients with anorexia nervosa: a pilot randomized controlled trial of cognitive remediation therapy. Int J Eat Disord. 2014 Jan;47(1):24–31. doi: 10.1002/eat.22206. PMID: 24166941. Exclusion Code: X3.24166941
145 Brockmeyer T, Schmidt U, Friederich HC. The ABBA study - approach bias modification in bulimia nervosa and binge eating disorder: study protocol for a randomised controlled trial. Trials. 2016 Sep 26;17(1):466. doi: 10.1186/s13063-016-1596-6. PMID: 27670138. Exclusion Code: X7.27670138
146 Brown TA, Forney KJ, Pinner D, . A randomized controlled trial of The Body Project: More Than Muscles for men with body dissatisfaction. Int J Eat Disord. 2017 Aug;50(8):873–83. doi: 10.1002/eat.22724. PMID: 28481431. Exclusion Code: X2.28481431
147 Brown TA, Holland LA, Keel PK. Comparing operational definitions of DSM-5 anorexia nervosa for research contexts. Int J Eat Disord. 2014;47(1):76–84. doi: 10.1002/eat.22184. PMID: 2013-43517-010. Exclusion Code: X4.24013875
148 Brown TA, Keel PK. A randomized controlled trial of a peer co-led dissonance-based eating disorder prevention program for gay men. Behav Res Ther. 2015 Nov;74:1–10. doi: 10.1016/j.brat.2015.08.008. PMID: 26342904. Exclusion Code: X5.26342904
149 Brownley KA, Von Holle A, Hamer RM, . A double-blind, randomized pilot trial of chromium picolinate for binge eating disorder: Results of the binge eating and chromium (BEACh) study. J Psychosom Res. 2013;75(1):36–42. doi: 10.1016/j.jpsychores.2013.03.092. PMID: 2013-20976-006. Exclusion Code: X5.23751236
150 Bryant-Waugh R, Micali N, Cooke L, . Development of the Pica, ARFID, and Rumination Disorder Interview, a multi-informant, semi-structured interview of feeding disorders across the lifespan: A pilot study for ages 10-22. Int J Eat Disord. 2019 Apr;52(4):378–87. doi: 10.1002/eat.22958. PMID: 30312485. Exclusion Code: X9.30312485
151 Bryant-Waugh R, Micali N, Cooke L, . Development of the pica, arfid, and rumination disorder interview, a multi-informant, semi-structured interview of feeding disorders across the lifespan: A pilot study for ages 10–22. Int J Eat Disord. 2018doi: 10.1002/eat.22958. PMID: 2018-51816-001. Exclusion Code: X4.
152 Bucceri JM, Roberson-Nay R, Strong DR, . Construct validity and reliability of the College Oriented Eating Disorders Screen (COEDS). Eat Behav. 2005 Dec;6(4):393–402. doi: 10.1016/j.eatbeh.2005.03.001. PMID: 16257812. Exclusion Code: X7.16257812
153 Buddeberg-Fischer B, Reed V. Prevention of disturbed eating behavior: An intervention program in Swiss high school classes. Eating Disorders: The Journal of Treatment & Prevention. 2001 Sum 2001;9(2):109–24. doi: 10.1080/10640260127723. PMID: 2001-06756-002. Exclusion Code: X7.
154 Buerger A, Ernst V, Wolter V, . Treating eating disorders in the real world - MaiStep: A skill-based universal prevention for schools. Prev Med. 2019 Jun;123:324–32. doi: 10.1016/j.ypmed.2019.04.008. PMID: 31004619. Exclusion Code: X5.31004619
155 Bulik CM, Sullivan PF, Carter FA, . The role of exposure with response prevention in the cognitive-behavioural therapy for bulimia nervosa. Psychol Med. 1998 May;28(3):611–23. doi: 10.1017/s0033291798006618. PMID: 9626717. Exclusion Code: X4.9626717
156 Bulik CM, Von Holle A, Hamer R, . Patterns of remission, continuation and incidence of broadly defined eating disorders during early pregnancy in the Norwegian Mother and Child Cohort Study (MoBa). Psychol Med. 2007 Aug;37(8):1109–18. doi: 10.1017/s0033291707000724. PMID: 17493296. Exclusion Code: X9.17493296
157 Burton AL, Hay P, Kleitman S, . Confirmatory factor analysis and examination of the psychometric properties of the eating beliefs questionnaire. BMC Psychiatry. 2017 Jul 3;17(1):237. doi: 10.1186/s12888-017-1394-z. PMID: 28673268. Exclusion Code: X4.28673268
158 Burton AL, Mitchison D, Hay P, . Beliefs about binge eating: psychometric properties of the Eating Beliefs Questionnaire (EBQ-18) in eating disorder, obese, and community samples. Nutrients. 2018 Sep 14;10(9)doi: 10.3390/nu10091306. PMID: 30223500. Exclusion Code: X4.30223500
159 Burton AL, Smith E, Abbott MJ. Assessing the clinical utility of the Eating Beliefs Questionnaire: Results from receiver operating characteristic curve analysis with a clinical sample. Eur J Psychol Assess. 2020;36(2):421–6. doi: 10.1027/1015-5759/a000496 10.1027/1015-5759/a000496 (Supplemental). PMID: 2018-52100-001. Exclusion Code: X4.
160 Burton E, Stice E. Evaluation of a healthy-weight treatment program for bulimia nervosa: a preliminary randomized trial. Behav Res Ther. 2006 Dec;44(12):1727–38. doi: 10.1016/j.brat.2005.12.008. PMID: 16458252. Exclusion Code: X5.16458252
161 Burton E, Stice E, Bearman SK, . Experimental test of the affect-regulation theory of bulimic symptoms and substance use: a randomized trial. Int J Eat Disord. 2007 Jan;40(1):27–36. doi: 10.1002/eat.20292. PMID: 16958129. Exclusion Code: X3.16958129
162 Bustin LA, Lane-Loney SE, Hollenbeak CS, . Motivational stage of change in young patients undergoing day treatment for eating disorders. Int J Adolesc Med Health. 2013;25(2):151–6. doi: 10.1515/ijamh-2013-0023. PMID: 23337045. Exclusion Code: X7.23337045
163 Button EJ, Sonuga-Barke EJ, Davies J, . A prospective study of self-esteem in the prediction of eating problems in adolescent schoolgirls: questionnaire findings. Br J Clin Psychol. 1996 May;35(2):193–203. doi: 10.1111/j.2044-8260.1996.tb01176.x. PMID: 8773797. Exclusion Code: X4.8773797
164 Byford S, Barrett B, Roberts C, . Economic evaluation of a randomised controlled trial for anorexia nervosa in adolescents. Br J Psychiatry. 2007;191(5):436–40. doi: 10.1192/bjp.bp.107.036806. PMID: 2008-11368-013. Exclusion Code: X7.17978324
165 Byrne CE, Accurso EC, Arnow KD, . An exploratory examination of patient and parental self-efficacy as predictors of weight gain in adolescents with anorexia nervosa. Int J Eat Disord. 2015 Nov;48(7):883–8. doi: 10.1002/eat.22376. PMID: 25808269. Exclusion Code: X7.25808269
166 Byrne CE, Wonderlich JA, Curby T, . Using bivariate latent basis growth curve analysis to better understand treatment outcome in youth with anorexia nervosa. Eur Eat Disord Rev. 2018;26(5):483–8. doi: 10.1002/erv.2596. PMID: 2018-18973-001. Exclusion Code: X7.29691947
167 Byrne S, Wade T, Hay P, . A randomised controlled trial of three psychological treatments for anorexia nervosa. Psychol Med. 2017;47(16):2823–33. doi: 10.1017/S0033291717001349. PMID: 2017-23860-001. Exclusion Code: X7.28552083
168 Byrne SM, Allen KL, Lampard AM, . The factor structure of the eating disorder examination in clinical and community samples. Int J Eat Disord. 2010 Apr;43(3):260–5. doi: 10.1002/eat.20681. PMID: 19350647. Exclusion Code: X7.19350647
169 Byrne SM, Fursland A, Allen KL, . The effectiveness of enhanced cognitive behavioural therapy for eating disorders: An open trial. Behav Res Ther. 2011;49(4):219–26. doi: 10.1016/j.brat.2011.01.006. PMID: 2011-05856-002. Exclusion Code: X7.21345418
170 Cadwallader JS, Godart N, Chastang J, . Detecting eating disorder patients in a general practice setting: A systematic review of heterogeneous data on clinical outcomes and care trajectories. Eat Weight Disord. 2016;21(3):365–81. doi: 10.1007/s40519-016-0273-9. PMID: 2016-43422-003. Exclusion Code: X9.27043947
171 Calugi S, Milanese C, Sartirana M, . The Eating Disorder Examination Questionnaire: reliability and validity of the Italian version. Eat Weight Disord. 2017 Sep;22(3):509–14. doi: 10.1007/s40519-016-0276-6. PMID: 27039107. Exclusion Code: X4.27039107
172 Calugi S, Pace CS, Muzi S, . Psychometric proprieties of the Italian version of the questionnaire on eating and weight patterns (QEWP-5) and its accuracy in screening for binge-eating disorder in patients seeking treatment for obesity. Eat Weight Disord. 2019 Nov 29doi: 10.1007/s40519-019-00818-1. PMID: 31784945. Exclusion Code: X4.31784945
173 Calugi S, Ricca V, Castellini G, . The eating disorder examination: reliability and validity of the Italian version. Eat Weight Disord. 2015 Dec;20(4):505–11. doi: 10.1007/s40519-015-0191-2. PMID: 25850414. Exclusion Code: X7.25850414
174 Canals J, Carbajo G, Fernández-Ballart J. Discriminant validity of the Eating Attitudes Test according to American Psychiatric Association and World Health Organization criteria of eating disorders. Psychol Rep. 2002 Dec;91(3 Pt 2):1052–6. doi: 10.2466/pr0.2002.91.3f.1052. PMID: 12585511. Exclusion Code: X4.12585511
175 Candy CM, Fee VE. Underlying dimensions and psychometric properties of the Eating Behaviors and Body Image Test for preadolescent girls. J Clin Child Psychol. 1998 Mar;27(1):117–27. doi: 10.1207/s15374424jccp2701_13. PMID: 9561944. Exclusion Code: X7.9561944
176 Cantwell R, Steel JM. Screening for eating disorders in diabetes mellitus. J Psychosom Res. 1996 Jan;40(1):15–20. doi: 10.1016/0022-3999(95)00534-x. PMID: 8730640. Exclusion Code: X7.8730640
177 Carbonneau E, Carbonneau N, Lamarche B, . Validation of a French-Canadian adaptation of the Intuitive Eating Scale-2 for the adult population. Appetite. 2016 Oct 1;105:37–45. doi: 10.1016/j.appet.2016.05.001. PMID: 27179938. Exclusion Code: X4.27179938
178 Cardi V, Ambwani S, Crosby R, . Self-Help And Recovery guide for Eating Disorders (SHARED): study protocol for a randomized controlled trial. Trials. 2015;16:165. doi: 10.1186/s13063-015-0701-6. PMID: CN-01171109. Exclusion Code: X7.25885697
179 Carr MM, Catak PD, Pejsa-Reitz MC, . Measurement invariance of the Yale Food Addiction Scale 20 across gender and racial groups. Psychol Assess. 2017;29(8):1044–52. doi: 10.1037/pas0000403. PMID: 2016-57455-001. Exclusion Code: X4.27893229
180 Carrard I, Crépin C, Rouget P, . Randomised controlled trial of a guided self-help treatment on the internet for binge eating disorder. Behav Res Ther. 2011;49(8):482–91. doi: 10.1016/j.brat.2011.05.004. PMID: 2011-11595-001. Exclusion Code: X14.21641580
181 Carrard I, Fernandez-Aranda F, Lam T, . Evaluation of a guided internet self-treatment programme for bulimia nervosa in several European countries. Eur Eat Disord Rev. 2011 Mar–Apr;19(2):138–49. doi: 10.1002/erv.1043. PMID: 20859989. Exclusion Code: X9.20859989
182 Carrard I, Rebetez MM, Mobbs O, . Factor structure of a French version of the Eating Disorder Examination-Questionnaire among women with and without binge eating disorder symptoms. Eat Weight Disord. 2015 Mar;20(1):137–44. doi: 10.1007/s40519-014-0148-x. PMID: 25194301. Exclusion Code: X4.25194301
183 Carruba MO, Cuzzolaro M, Riva L, . Efficacy and tolerability of moclobemide in bulimia nervosa: a placebo-controlled trial. Int Clin Psychopharmacol. 2001 Jan;16(1):27–32. doi: 10.1097/00004850-200101000-00003. PMID: 11195257. Exclusion Code: X5.11195257
184 Carter FA, Boden JM, Jordan J, . Weight suppression predicts total weight gain and rate of weight gain in outpatients with anorexia nervosa. Int J Eat Disord. 2015 Nov;48(7):912–8. doi: 10.1002/eat.22425. PMID: 26010980. Exclusion Code: X7.26010980
185 Carter FA, Bulik CM, McIntosh VV, . Changes in cue reactivity following treatment for bulimia nervosa. Int J Eat Disord. 2001 Apr;29(3):336–44. doi: 10.1002/eat.1027. PMID: 11262514. Exclusion Code: X7.11262514
186 Carter FA, Bulik CM, McIntosh VV, . Cue reactivity as a predictor of outcome with bulimia nervosa. Int J Eat Disord. 2002 Apr;31(3):240–50. doi: 10.1002/eat.10041. PMID: 11920985. Exclusion Code: X7.11920985
187 Carter FA, Jordan J, McIntosh VV, . The long-term efficacy of three psychotherapies for anorexia nervosa: a randomized, controlled trial. Int J Eat Disord. 2011 Nov;44(7):647–54. doi: 10.1002/eat.20879. PMID: 21997429. Exclusion Code: X7.21997429
188 Carter FA, McIntosh VV, Frampton CM, . Predictors of childbirth following treatment for bulimia nervosa. Int J Eat Disord. 2003 Nov;34(3):337–42. doi: 10.1002/eat.10218. PMID: 12949925. Exclusion Code: X7.12949925
189 Carter FA, McIntosh VV, Joyce PR, . Cue reactivity in bulimia nervosa: a useful self-report approach. Int J Eat Disord. 2006 Dec;39(8):694–9. doi: 10.1002/eat.20331. PMID: 16927381. Exclusion Code: X7.16927381
190 Carter FA, McIntosh VV, Joyce PR, . Patterns of weight change after treatment for bulimia nervosa. Int J Eat Disord. 2004 Jul;36(1):12–21. doi: 10.1002/eat.20021. PMID: 15185267. Exclusion Code: X7.15185267
191 Carter FA, McIntosh VVW, Joyce PR, . Impact of pre-treatment weight on weight trajectory in women treated for bulimia nervosa. Eur Eat Disord Rev. 2004;12(6):387–91. doi: 10.1002/erv.600. PMID: CN-01752041. Exclusion Code: X7.
192 Carter JC, Aimé AA, Mills JS. Assessment of bulimia nervosa: a comparison of interview and self-report questionnaire methods. Int J Eat Disord. 2001 Sep;30(2):187–92. doi: 10.1002/eat.1071. PMID: 11449452. Exclusion Code: X4.11449452
193 Carter JC, Fairburn CG. Cognitive-behavioral self-help for binge eating disorder: a controlled effectiveness study. J Consult Clin Psychol. 1998 Aug;66(4):616–23. doi: 10.1037//0022-006x.66.4.616. PMID: 9735577. Exclusion Code: X14.9735577
194 Carter PI, Moss RA. Screening for anorexia and bulimia nervosa in a college population: problems and limitations. Addict Behav. 1984;9(4):417–9. doi: 10.1016/0306-4603(84)90045-5. PMID: 6598003. Exclusion Code: X9.6598003
195 Caselli G, Spada MM. The Desire Thinking Questionnaire: development and psychometric properties. Addict Behav. 2011 Nov;36(11):1061–7. doi: 10.1016/j.addbeh.2011.06.013. PMID: 21741178. Exclusion Code: X4.21741178
196 Cassin SE, von Ranson KM, Heng K, . Adapted motivational interviewing for women with binge eating disorder: a randomized controlled trial. Psychol Addict Behav. 2008;22(3):417–25. doi: 10.1037/0893-164X.22.3.417. PMID: CN-00650981. Exclusion Code: X7.18778135
197 Castelnuovo G, Manzoni GM, Villa V, . Brief strategic therapy vs cognitive behavioral therapy for the inpatient and telephone-based outpatient treatment of binge eating disorder: the STRATOB randomized controlled clinical trial. Clin Pract Epidemiol Ment Health. 2011;7:29–37. doi: 10.2174/1745017901107010029. PMID: CN-00851861. Exclusion Code: X7.21559234
198 Castillo I, Solano S, Sepúlveda AR. A controlled study of an integrated prevention program for improving disordered eating and body image among Mexican university students: A 3-month follow-up. Eur Eat Disord Rev. 2019 Sep;27(5):541–56. doi: 10.1002/erv.2674. PMID: 30997721. Exclusion Code: X3.30997721
199 Castro-Fornieles J, Bigorra A, Martinez-Mallen E, . Motivation to change in adolescents with bulimia nervosa mediates clinical change after treatment. Eur Eat Disord Rev. 2011 Jan–Feb;19(1):46–54. doi: 10.1002/erv.1045. PMID: 20872926. Exclusion Code: X7.20872926
200 Catalan-Matamoros D, Helvik-Skjaerven L, Labajos-Manzanares MT, . A pilot study on the effect of Basic Body Awareness Therapy in patients with eating disorders: a randomized controlled trial. Clin Rehabil. 2011 Jul;25(7):617–26. doi: 10.1177/0269215510394223. PMID: 21402650. Exclusion Code: X3.21402650
201 Cebolla A, Barrada JR, van Strien T, . Validation of the Dutch Eating Behavior Questionnaire (DEBQ) in a sample of Spanish women. Appetite. 2014 Feb;73:58–64. doi: 10.1016/j.appet.2013.10.014. PMID: 24177441. Exclusion Code: X7.24177441
202 Ceccherini-Nelli A, Guidi L. Fluoxetine: the relationship between response, adverse events, and plasma concentrations in the treatment of bulimia nervosa. Int Clin Psychopharmacol. 1993 Winter;8(4):311–3. PMID: 8277153. Exclusion Code: X7.8277153
203 Celio AA, Wilfley DE, Crow SJ, . A comparison of the binge eating scale, questionnaire for eating and weight patterns-revised, and eating disorder examination questionnaire with instructions with the eating disorder examination in the assessment of binge eating disorder and its symptoms. Int J Eat Disord. 2004 Dec;36(4):434–44. doi: 10.1002/eat.20057. PMID: 15558644. Exclusion Code: X3.15558644
204 Celio AA, Winzelberg AJ, Wilfley DE, . Reducing risk factors for eating disorders: comparison of an Internet- and a classroom-delivered psychoeducational program. J Consult Clin Psychol. 2000 Aug;68(4):650–7. PMID: 10965640. Exclusion Code: X3.10965640
205 Chamberlain SR, Mogg K, Bradley BP, . Effects of mu opioid receptor antagonism on cognition in obese binge-eating individuals. Psychopharmacology (Berl). 2012 Dec;224(4):501–9. doi: 10.1007/s00213-012-2778-x. PMID: 22752384. Exclusion Code: X7.22752384
206 Chan CW, Leung SF. Validation of the Eating Disorder Examination Questionnaire: an online version. J Hum Nutr Diet. 2015 Dec;28(6):659–65. doi: 10.1111/jhn.12275. PMID: 25234124. Exclusion Code: X7.25234124
207 Chan CY, Lee AM, Koh YW, . Course, risk factors, and adverse outcomes of disordered eating in pregnancy. Int J Eat Disord. 2019 Jun;52(6):652–8. doi: 10.1002/eat.23065. PMID: 30821851. Exclusion Code: X9.30821851
208 Channon S, de Silva P, Hemsley D, . A controlled trial of cognitive-behavioural and behavioural treatment of anorexia nervosa. Behav Res Ther. 1989;27(5):529–35. doi: 10.1016/0005-7967(89)90087-9. PMID: 2684134. Exclusion Code: X7.2684134
209 Chao AM, Wadden TA, Gorin AA, . Binge Eating and Weight Loss Outcomes in Individuals with Type 2 Diabetes: 4-Year Results from the Look AHEAD Study. Obesity (Silver Spring). 2017 Nov;25(11):1830–7. doi: 10.1002/oby.21975. PMID: 29086498. Exclusion Code: X5.29086498
210 Chard CA, Hilzendegen C, Barthels F, . Psychometric evaluation of the English version of the Düsseldorf Orthorexie Scale (DOS) and the prevalence of orthorexia nervosa among a U.S. student sample. Eat Weight Disord. 2019 Apr;24(2):275–81. doi: 10.1007/s40519-018-0570-6. PMID: 30196526. Exclusion Code: X2.30196526
211 Chen EY, Cacioppo J, Fettich K, . An adaptive randomized trial of dialectical behavior therapy and cognitive behavior therapy for binge-eating. Psychol Med. 2017 Mar;47(4):703–17. doi: 10.1017/s0033291716002543. PMID: 27852348. Exclusion Code: X7.27852348
212 Chiba H, Nagamitsu S, Sakurai R, . Children’s Eating Attitudes Test: Reliability and validation in Japanese adolescents. Eat Behav. 2016 Dec;23:120–5. doi: 10.1016/j.eatbeh.2016.09.001. PMID: 27643567. Exclusion Code: X3.27643567
213 Chithambo TP, Huey SJ, Jr. Internet-delivered eating disorder prevention: A randomized controlled trial of dissonance-based and cognitive-behavioral interventions. Int J Eat Disord. 2017 Oct;50(10):1142–51. doi: 10.1002/eat.22762. PMID: 28801926. Exclusion Code: X3.28801926
214 Ciao AC, Accurso EC, Fitzsimmons-Craft EE, . Family functioning in two treatments for adolescent anorexia nervosa. Int J Eat Disord. 2015 Jan;48(1):81–90. doi: 10.1002/eat.22314. PMID: 24902822. Exclusion Code: X7.24902822
215 Cihan B, Bozo Ö, Schaefer LM, . Psychometric properties of the Sociocultural Attitudes Towards Appearance Questionnaire-4-Revised (SATAQ-4R) in Turkish women. Eat Behav. 2016 Apr;21:168–71. doi: 10.1016/j.eatbeh.2016.03.003. PMID: 26970730. Exclusion Code: X4.26970730
216 Claudino AM, de Oliveira IR, Appolinario JC, . Double-blind, randomized, placebo-controlled trial of topiramate plus cognitive-behavior therapy in binge-eating disorder. J Clin Psychiatry. 2007 Sep;68(9):1324–32. doi: 10.4088/jcp.v68n0901. PMID: 17915969. Exclusion Code: X7.17915969
217 Clausen L. Time to remission for eating disorder patients: a 2(1/2)-year follow-up study of outcome and predictors. Nord J Psychiatry. 2008;62(2):151–9. doi: 10.1080/08039480801984875. PMID: 18569780. Exclusion Code: X7.18569780
218 Clausen L, Rokkedal K, Rosenvinge JH. Validating the eating disorder inventory (EDI-2) in two Danish samples: a comparison between female eating disorder patients and females from the general population. Eur Eat Disord Rev. 2009 Nov;17(6):462–7. doi: 10.1002/erv.945. PMID: 19504471. Exclusion Code: X7.19504471
219 Clausen L, Rosenvinge JH, Friborg O, . Validating the Eating Disorder Inventory-3 (EDI-3): A comparison between 561 female eating disorders patients and 878 females from the general population. J Psychopathol Behav Assess. 2011;33(1):101–10. doi: 10.1007/s10862-010-9207-4. PMID: 2011-04160-012. Exclusion Code: X3.21472023
220 Clinton D, Birgegård A. Classifying empirically valid and clinically meaningful change in eating disorders using the Eating Disorders Inventory, version 2 (EDI-2). Eat Behav. 2017 Aug;26:99–103. doi: 10.1016/j.eatbeh.2017.02.001. PMID: 28213339. Exclusion Code: X9.28213339
221 Cockroft MC, Bartlett TR, Wallace DC. Sleep, nutrition, disordered eating, problematic tobacco and alcohol use, and exercise in college students with and without diabetes. J Psychosoc Nurs Ment Health Serv. 2019 Dec 1;57(12):23–32. doi: 10.3928/02793695-20190919-04. PMID: 31566702. Exclusion Code: X7.31566702
222 Colton PA, Olmsted MP, Rodin GM. Eating disturbances in a school population of preteen girls: assessment and screening. Int J Eat Disord. 2007 Jul;40(5):435–40. doi: 10.1002/eat.20386. PMID: 17497707. Exclusion Code: X4.17497707
223 Compte EJ, Nagata JM, Sepúlveda AR, . Confirmatory factor analysis and measurement invariance of the eating disorders examination-questionnaire across four male samples in Argentina. Int J Eat Disord. 2019 Jun;52(6):740–5. doi: 10.1002/eat.23075. PMID: 30912863. Exclusion Code: X7.30912863
224 Coniglio KA, Becker KR, Tabri N, . Factorial integrity and validation of the Eating Pathology Symptoms Inventory (EPSI). Eat Behav. 2018 Dec;31:1–7. doi: 10.1016/j.eatbeh.2018.07.004. PMID: 30025234. Exclusion Code: X4.30025234
225 Conley A, Boardman JD. Weight overestimation as an indicator of disordered eating behaviors among young women in the United States. Int J Eat Disord. 2007 Jul;40(5):441–5. doi: 10.1002/eat.20383. PMID: 17497706. Exclusion Code: X7.17497706
226 Connors ME, Johnson CL, Stuckey MK. Treatment of bulimia with brief psychoeducational group therapy. Am J Psychiatry. 1984 Dec;141(12):1512–6. doi: 10.1176/ajp.141.12.1512. PMID: 6391211. Exclusion Code: X7.6391211
227 Constantino MJ, Arnow BA, Blasey C, . The association between patient characteristics and the therapeutic alliance in cognitive-behavioral and interpersonal therapy for bulimia nervosa. J Consult Clin Psychol. 2005 Apr;73(2):203–11. doi: 10.1037/0022-006x.73.2.203. PMID: 15796627. Exclusion Code: X7.15796627
228 Conti MA, Ferreira ME, de Carvalho PH, . Stunkard figure rating scale for Brazilian men. Eat Weight Disord. 2013 Sep;18(3):317–22. doi: 10.1007/s40519-013-0037-8. PMID: 23775630. Exclusion Code: X4.23775630
229 Cooley E, Toray T. Disordered eating in college freshman women: a prospective study. J Am Coll Health. 2001 Mar;49(5):229–35. doi: 10.1080/07448480109596308. PMID: 11337898. Exclusion Code: X7.11337898
230 Cooley E, Toray T. Body image and personality predictors of eating disorder symptoms during the college years. Int J Eat Disord. 2001 Jul;30(1):28–36. doi: 10.1002/eat.1051. PMID: 11439406. Exclusion Code: X7.11439406
231 Cooper PJ, Watkins B, Bryant-Waugh R, . The nosological status of early onset anorexia nervosa. Psychol Med. 2002 Jul;32(5):873–80. doi: 10.1017/s0033291702005664. PMID: 12171381. Exclusion Code: X7.12171381
232 Cooper Z, Calugi S, Dalle Grave R. Controlling binge eating and weight: a treatment for binge eating disorder worth researching? Eat Weight Disord. 2019 Jun 18doi: 10.1007/s40519-019-00734-4. PMID: 31214963. Exclusion Code: X9.31214963
233 Cooper Z, Cooper PJ, Fairburn CG. The specificity of the Eating Disorder Inventory. Br J Clin Psychol. 1985 May;24 (Pt 2):129–30. doi: 10.1111/j.2044-8260.1985.tb01324.x. PMID: 3859342. Exclusion Code: X12.3859342
234 Corazon SS, Sidenius U, Vammen KS, . The Tree Is My Anchor: a Pilot Study on the Treatment of BED through Nature-Based Therapy. Int J Environ Res Public Health. 2018;15(11) (no pagination)doi: 10.3390/ijerph15112486. PMID: CN-01667739. Exclusion Code: X5.
235 Cordero ED, Julian AK, Murray KE. Measurement of disordered eating in Latina college women. Eat Behav. 2013 Apr;14(2):220–3. doi: 10.1016/j.eatbeh.2012.12.006. PMID: 23557825. Exclusion Code: X4.23557825
236 Corwin RL, Boan J, Peters KF, . Baclofen reduces binge eating in a double-blind, placebo-controlled, crossover study. Behav Pharmacol. 2012 Sep;23(5–6):616–25. doi: 10.1097/FBP.0b013e328357bd62. PMID: 22854310. Exclusion Code: X14.22854310
237 Courbasson C, Nishikawa Y, Dixon L. Outcome of dialectical behaviour therapy for concurrent eating and substance use disorders. Clin Psychol Psychother. 2012 Sep;19(5):434–49. doi: 10.1002/cpp.748. PMID: 21416557. Exclusion Code: X7.21416557
238 Court A, Mulder C, Kerr M, . Investigating the effectiveness, safety and tolerability of quetiapine in the treatment of anorexia nervosa in young people: a pilot study. J Psychiatr Res. 2010 Nov;44(15):1027–34. doi: 10.1016/j.jpsychires.2010.03.011. PMID: 20447652. Exclusion Code: X7.20447652
239 Couturier J, Lock J, Forsberg S, . The addition of parent and clinician component to the eating disorder examination for children and adolescents. Int J Eat Disord. 2007;40(5):472–5. doi: 10.1002/eat.20379. PMID: 2007-09610-012. Exclusion Code: X4.17726771
240 Couturier J, Lock J, Forsberg S, . The addition of a parent and clinician component to the eating disorder examination for children and adolescents. Int J Eat Disord. 2007 Jul;40(5):472–5. doi: 10.1002/eat.20379. PMID: 17726771. Exclusion Code: X7.17726771
241 Cragun D, DeBate RD, Ata RN, . Psychometric properties of the Body Esteem Scale for adolescents and adults in an early adolescent sample. Eat Weight Disord. 2013;18(3):275–82. doi: 10.1007/s40519-013-0031-1. PMID: 2014-25675-006. Exclusion Code: X4.23760907
242 Crisp AH, Norton K, Gowers S, . A controlled study of the effect of therapies aimed at adolescent and family psychopathology in anorexia nervosa. Br J Psychiatry. 1991 Sep;159:325–33. doi: 10.1192/bjp.159.3.325. PMID: 1958942. Exclusion Code: X3.1958942
243 Crow SJ, Stewart Agras W, Halmi K, . Full syndromal versus subthreshold anorexia nervosa, bulimia nervosa, and binge eating disorder: a multicenter study. Int J Eat Disord. 2002 Nov;32(3):309–18. doi: 10.1002/eat.10088. PMID: 12210645. Exclusion Code: X7.12210645
244 Cuneo JG, Godfrey KM, Wright LJ, . Feasibility, acceptability, and exploratory outcomes of acceptance and commitment therapy for binge eating symptoms in veterans: A preliminary clinic-based study. J Cogn Psychother. 2018;32(3):155–70. doi: 10.1891/0889-8391.32.3.155. PMID: 2018-67280-001. Exclusion Code: X7.32746432
245 Da Porto A, Casarsa V, Colussi G, . Dulaglutide reduces binge episodes in type 2 diabetic patients with binge eating disorder: A pilot study. Diabetes Metab Syndr. 2020 Mar 31;14(4):289–92. doi: 10.1016/j.dsx.2020.03.009. PMID: 32289741. Exclusion Code: X7.32289741
246 Dahlgren CL, Stedal K, Rø Ø. Eating Disorder Examination Questionnaire (EDE-Q) and Clinical Impairment Assessment (CIA): clinical norms and functional impairment in male and female adults with eating disorders. Nord J Psychiatry. 2017 May;71(4):256–61. doi: 10.1080/08039488.2016.1271452. PMID: 28084126. Exclusion Code: X4.28084126
247 Dahlsgaard KK, Bodie J. The (extremely) picky eaters clinic: A pilot trial of a seven-session group behavioral intervention for parents of children with avoidant/restrictive food intake disorder. Cogn Behav Pract. 2019;26(3):492–505. doi: 10.1016/j.cbpra.2018.11.001. PMID: 2019-05228-001. Exclusion Code: X9.
248 Dakanalis A, Bartoli F, Caslini M, . Validity and clinical utility of the DSM-5 severity specifier for bulimia nervosa: results from a multisite sample of patients who received evidence-based treatment. Eur Arch Psychiatry Clin Neurosci. 2017 Dec;267(8):823–9. doi: 10.1007/s00406-016-0712-7. PMID: 27435722. Exclusion Code: X3.27435722
249 Dakanalis A, Carrà G, Calogero R, . The social appearance anxiety scale in Italian adolescent populations: construct validation and group discrimination in community and Clinical Eating Disorders Samples. Child Psychiatry Hum Dev. 2016 Feb;47(1):133–50. doi: 10.1007/s10578-015-0551-1. PMID: 25976291. Exclusion Code: X7.25976291
250 Dakanalis A, Clerici M, Carrà G. Narcissistic vulnerability and grandiosity as mediators between insecure attachment and future eating disordered behaviors: a prospective analysis of over 2,000 freshmen. J Clin Psychol. 2016;72(3):279–92. doi: 10.1002/jclp.22237. PMID: 2015-54194-001. Exclusion Code: X7.26613236
251 Dakanalis A, Timko A, Serino S, . Prospective psychosocial predictors of onset and cessation of eating pathology amongst college women. Eur Eat Disord Rev. 2016;24(3):251–6. doi: 10.1002/erv.2433. PMID: 2016-06314-001. Exclusion Code: X7.26842985
252 Dalle Grave R, Calugi S, Sartirana M, . Transdiagnostic cognitive behaviour therapy for adolescents with an eating disorder who are not underweight. Behav Res Ther. 2015;73:79–82. doi: 10.1016/j.brat.2015.07.014. PMID: 2015-43144-012. Exclusion Code: X7.26275760
253 Dalle Grave R, Sartirana M, Calugi S. Enhanced cognitive behavioral therapy for adolescents with anorexia nervosa: Outcomes and predictors of change in a real-world setting. Int J Eat Disord. 2019 Sep;52(9):1042–6. doi: 10.1002/eat.23122. PMID: 31199022. Exclusion Code: X7.31199022
254 Dalle Grave R, Sartirana M, Milanese C, . Validity and reliability of the Eating Problem Checklist. Eat Disord. 2019 Jul–Aug;27(4):384–99. doi: 10.1080/10640266.2018.1528084. PMID: 30346888. Exclusion Code: X3.30346888
255 Dally P, Sargant W. Treatment and outcome of anorexia nervosa. Br Med J. 1966 Oct 1;2(5517):793–5. doi: 10.1136/bmj.2.5517.793. PMID: 5918777. Exclusion Code: X3.5918777
256 Dally PJ. Anorexia nervosa-long-term follow up and effects of treatment. J Psychosom Res. 1967 Jun;11(1):151–5. doi: 10.1016/0022-3999(67)90067-0. PMID: 6049026. Exclusion Code: X12.6049026
257 Dalton B, Bartholdy S, McClelland J, . Randomised controlled feasibility trial of real versus sham repetitive transcranial magnetic stimulation treatment in adults with severe and enduring anorexia nervosa: the TIARA study. BMJ Open. 2018 Jul 16;8(7):e021531. doi: 10.1136/bmjopen-2018-021531. PMID: 30012789. Exclusion Code: X3.30012789
258 Daniel SIF, Lunn S, Poulsen S. Autobiographical memory narratives in treatment for bulimia nervosa: The effect of client attachment, depression, and therapy type. Narrative Inquiry. 2014;24(1):153–74. doi: 10.1075/ni.24.1.08dan. PMID: 2014-52095-008. Exclusion Code: X7.
259 Danner UN, Evers C, Sternheim L, . Influence of negative affect on choice behavior in individuals with binge eating pathology. Psychiatry Res. 2013;207(1–2):100–6. doi: 10.1016/j.psychres.2012.10.016. PMID: 2012-31319-001. Exclusion Code: X5.23167986
260 Dare C, Eisler I, Russell G, . Psychological therapies for adults with anorexia nervosa: randomised controlled trial of out-patient treatments. Br J Psychiatry. 2001 Mar;178:216–21. doi: 10.1192/bjp.178.3.216. PMID: 11230031. Exclusion Code: X7.11230031
261 Davidsen AH, Poulsen S, Lindschou J, . Feedback in group psychotherapy for eating disorders: A randomized clinical trial. J Consult Clin Psychol. 2017 May;85(5):484–94. doi: 10.1037/ccp0000173. PMID: 28333513. Exclusion Code: X7.28333513
262 Davidsen AH, Poulsen S, Waaddegaard M, . Feedback versus no feedback in improving patient outcome in group psychotherapy for eating disorders (F-EAT): protocol for a randomized clinical trial. Trials. 2014 Apr 23;15:138. doi: 10.1186/1745-6215-15-138. PMID: 24754974. Exclusion Code: X7.24754974
263 Davis BA, Kennedy SH, Durden DA, . The effect of the MAO-A selective inhibitor brofaromine on the plasma and urine concentrations of some biogenic amines and their acidic metabolites in bulimia nervosa. Prog Neuropsychopharmacol Biol Psychiatry. 1993;17(5):747–63. doi: 10.1016/0278-5846(93)90057-Y. PMID: 1994-18635-001. Exclusion Code: X7.7504824
264 Davis C, Levitan RD, Kaplan AS, . Sex differences in subjective and objective responses to a stimulant medication (methylphenidate): Comparisons between overweight/obese adults with and without binge-eating disorder. Int J Eat Disord. 2016 May;49(5):473–81. doi: 10.1002/eat.22493. PMID: 26691428. Exclusion Code: X5.26691428
265 Davis R, Olmsted M, Rockert W, . Group psychoeducation for bulimia nervosa with and without additional psychotherapy process sessions. Int J Eat Disord. 1997 Jul;22(1):25–34. doi: 10.1002/(sici)1098-108x(199707)22:1<25::aid-eat3>3.0.co;2-4. PMID: 9140732. Exclusion Code: X7.9140732
266 Dawkins H, Watson HJ, Egan SJ, . Weight suppression in bulimia nervosa: relationship with cognitive behavioral therapy outcome. Int J Eat Disord. 2013 Sep;46(6):586–93. doi: 10.1002/eat.22137. PMID: 23606241. Exclusion Code: X7.23606241
267 De Filippo E, Signorini A, Bracale R, . Hospital admission and mortality rates in anorexia nervosa: experience from an integrated medical-psychiatric outpatient treatment. Eat Weight Disord. 2000 Dec;5(4):211–6. doi: 10.1007/bf03354448. PMID: 11216129. Exclusion Code: X7.11216129
268 de Jong M, Korrelboom K, van der Meer I, . Effectiveness of enhanced cognitive behavioral therapy (CBT-E) for eating disorders: study protocol for a randomized controlled trial. Trials. 2016 Dec 3;17(1):573. doi: 10.1186/s13063-016-1716-3. PMID: 27914473. Exclusion Code: X7.27914473
269 de Jong M, Spinhoven P, Korrelboom K, . Effectiveness of enhanced cognitive behavior therapy for eating disorders: A randomized controlled trial. Int J Eat Disord. 2020 May;53(5):447–57. doi: 10.1002/eat.23239. PMID: 32040244. Exclusion Code: X7.32040244
270 de Man Lapidoth J, Ghaderi A, Halvarsson-Edlund K, . Psychometric properties of the Eating Disorders in Obesity questionnaire: validating against the Eating Disorder Examination interview. Eat Weight Disord. 2007 Dec;12(4):168–75. doi: 10.1007/bf03327594. PMID: 18227638. Exclusion Code: X7.18227638
271 De Young KP, Anderson DA. An interactive, graphical tool for retrospectively assessing symptom frequency and severity: an illustration with eating disorder behaviors, body weight, and stress. Assessment. 2017 Oct;24(7):835–52. doi: 10.1177/1073191116668629. PMID: 27637739. Exclusion Code: X4.27637739
272 de Zwaan M, Herpertz S, Zipfel S, . Effect of Internet-Based Guided Self-help vs Individual Face-to-Face Treatment on Full or Subsyndromal Binge Eating Disorder in Overweight or Obese Patients: The INTERBED Randomized Clinical Trial. JAMA Psychiatry. 2017 Oct 1;74(10):987–95. doi: 10.1001/jamapsychiatry.2017.2150. PMID: 28768334. Exclusion Code: X7.28768334
273 de Zwaan M, Herpertz S, Zipfel S, . INTERBED: internet-based guided self-help for overweight and obese patients with full or subsyndromal binge eating disorder. A multicenter randomized controlled trial. Trials. 2012;13:220. doi: 10.1186/1745-6215-13-220. PMID: CN-00966766. Exclusion Code: X7.23171536
274 De Zwaan M, Mitchell JE, Crosby RD, . Short-term cognitive behavioral treatment does not improve outcome of a comprehensive very-low-calorie diet program in obese women with binge eating disorder. Behav Ther. 2005;36(1):89–99. doi: 10.1016/S0005-7894(05)80057-7. PMID: CN-00549008. Exclusion Code: X7.
275 Deal LS, Wirth RJ, Gasior M, . Validation of the yale-brown obsessive compulsive scale modified for binge eating. Int J Eat Disord. 2015 Nov;48(7):994–1004. doi: 10.1002/eat.22407. PMID: 26032442. Exclusion Code: X4.26032442
276 DeBar LL, Striegel-Moore RH, Wilson GT, . Guided self-help treatment for recurrent binge eating: replication and extension. Psychiatr Serv. 2011 Apr;62(4):367–73. doi: 10.1176/ps.62.4.pss6204_0367. PMID: 21459987. Exclusion Code: X14.21459987
277 DeBar LL, Wilson GT, Yarborough BJ, . Cognitive behavioral treatment for recurrent binge eating in adolescent girls: A pilot trial. Cogn Behav Pract. 2013;20(2):147–61. doi: 10.1016/j.cbpra.2012.04.001. PMID: 2012-15354-001. Exclusion Code: X14.23645978
278 DeBar LL, Yarborough BJ, Striegel-Moore RH, . Recruitment for a guided self-help binge eating trial: potential lessons for implementing programs in everyday practice settings. Contemp Clin Trials. 2009;30(4):326–33. doi: 10.1016/j.cct.2009.02.007. PMID: CN-01776587. Exclusion Code: X7.19275947
279 Deborde AS, Berthoz S, Wallier JM, . The Bermond-Vorst Alexithymia Questionnaire cutoff scores: a study in eating-disordered and control subjects. Psychopathology. 2008;41(1):43–9. doi: 10.1159/000109955. PMID: 17952021. Exclusion Code: X7.17952021
280 Decaluwé V, Braet C. Assessment of eating disorder psychopathology in obese children and adolescents: interview versus self-report questionnaire. Behav Res Ther. 2004 Jul;42(7):799–811. doi: 10.1016/j.brat.2003.07.008. PMID: 15149900. Exclusion Code: X7.15149900
281 del Valle MF, Pérez M, Santana-Sosa E, . Does resistance training improve the functional capacity and well being of very young anorexic patients? A randomized controlled trial. J Adolesc Health. 2010 Apr;46(4):352–8. doi: 10.1016/j.jadohealth.2009.09.001. PMID: 20307824. Exclusion Code: X7.20307824
282 Delaney DW, Silber TJ. Treatment of anorexia nervosa in a pediatric program. Pediatr Ann. 1984 Nov;13(11):860–4. PMID: 6514432. Exclusion Code: X7.6514432
283 Denison-Day J, Muir S, Newell C, . A web-based intervention (MotivATE) to increase attendance at an eating disorder service assessment appointment: Zelen randomized controlled trial. J Med Internet Res. 2019;21(2)PMID: 2019-13166-001. Exclusion Code: X7.
284 DePalma MT, Koszewski WM, Romani W, . Identifying college athletes at risk for pathogenic eating. Br J Sports Med. 2002 Feb;36(1):45–50. doi: 10.1136/bjsm.36.1.45. PMID: 11867492. Exclusion Code: X7.11867492
285 DeSocio JE, O’Toole JK, He H, . Rating of eating disorder severity interview for children: psychometric properties and comparison with EDI-2 symptom index. Eur Eat Disord Rev. 2012 Jan;20(1):e70–7. doi: 10.1002/erv.1115. PMID: 21751297. Exclusion Code: X4.21751297
286 Deter HC, Schellberg D, Köpp W, . Predictability of a favorable outcome in anorexia nervosa. Eur Psychiatry. 2005 Mar;20(2):165–72. doi: 10.1016/j.eurpsy.2004.09.006. PMID: 15797702. Exclusion Code: X7.15797702
287 Devlin MJ, Goldfein JA, Petkova E, . Cognitive behavioral therapy and fluoxetine as adjuncts to group behavioral therapy for binge eating disorder. Obes Res. 2005 Jun;13(6):1077–88. doi: 10.1038/oby.2005.126. PMID: 15976151. Exclusion Code: X3.15976151
288 Devlin MJ, Goldfein JA, Petkova E, . Cognitive behavioral therapy and fluoxetine for binge eating disorder: two-year follow-up. Obesity (Silver Spring). 2007 Jul;15(7):1702–9. doi: 10.1038/oby.2007.203. PMID: 17636088. Exclusion Code: X7.17636088
289 Dhokia R, Hinrichsen H, Meyer C, . Clinical and psychometric validation of an extended version of the Testable Assumptions Questionnaire (TAQ-ED-R). Eat Behav. 2009 Jan;10(1):62–4. doi: 10.1016/j.eatbeh.2008.10.005. PMID: 19171322. Exclusion Code: X4.19171322
290 Díaz-Ferrer S, Rodríguez-Ruiz S, Ortega-Roldán B, . Testing the efficacy of pure versus guided mirror exposure in women with bulimia nervosa: A combination of neuroendocrine and psychological indices. J Behav Ther Exp Psychiatry. 2015 Sep;48:1–8. doi: 10.1016/j.jbtep.2015.01.003. PMID: 25665513. Exclusion Code: X7.25665513
291 Dingemans AE, Danner UN, Donker JM, . The effectiveness of cognitive remediation therapy in patients with a severe or enduring eating disorder: a randomized controlled trial. Psychother Psychosom. 2014;83(1):29–36. doi: 10.1159/000355240. PMID: 24281361. Exclusion Code: X7.24281361
292 Dittmer N, Voderholzer U, Mönch C, . Efficacy of a Specialized Group Intervention for Compulsive Exercise in Inpatients with Anorexia Nervosa: A Randomized Controlled Trial. Psychother Psychosom. 2020;89(3):161–73. doi: 10.1159/000504583. PMID: 32036375. Exclusion Code: X3.32036375
293 DiVasta AD, Feldman HA, Rubin CT, . The ability of low-magnitude mechanical signals to normalize bone turnover in adolescents hospitalized for anorexia nervosa. Osteoporos Int. 2017 Apr;28(4):1255–63. doi: 10.1007/s00198-016-3851-9. PMID: 27909781. Exclusion Code: X3.27909781
294 Dixon KN, Kiecolt-Glaser J. Group therapy for bulimia. Hillside J Clin Psychiatry. 1984;6(2):156–70. PMID: 6597125. Exclusion Code: X7.6597125
295 Docman K. Screening for adolescent eating disorders in a school-based health center using the Scoff Questionnaire: ProQuest Information & Learning; 2019. Exclusion Code: X9.
296 Domoff SE, Meers MR, Koball AM, . The validity of the Dutch Eating Behavior Questionnaire: Some critical remarks. Eat Weight Disord. 2014;19(2):137–44. doi: 10.1007/s40519-013-0087-y. PMID: 2016-24285-001. Exclusion Code: X9.24338490
297 Dotti A, Lazzari R. Validation and reliability of the Italian EAT-26. Eat Weight Disord. 1998 Dec;3(4):188–94. doi: 10.1007/bf03340009. PMID: 10728170. Exclusion Code: X4.10728170
298 Dovey TM, Aldridge VK, Martin CI, . Screening Avoidant/Restrictive Food Intake Disorder (ARFID) in children: Outcomes from utilitarian versus specialist psychometrics. Eat Behav. 2016 Dec;23:162–7. doi: 10.1016/j.eatbeh.2016.10.004. PMID: 27794273. Exclusion Code: X3.27794273
299 Dovey TM, Kumari V, Blissett J. Eating behaviour, behavioural problems and sensory profiles of children with avoidant/restrictive food intake disorder (ARFID), autistic spectrum disorders or picky eating: Same or different? Eur Psychiatry. 2019 Sep;61:56–62. doi: 10.1016/j.eurpsy.2019.06.008. PMID: 31310945. Exclusion Code: X9.31310945
300 Downe KA, Goldfein JA, Devlin MJ. Restraint, hunger, and disinhibition following treatment for binge-eating disorder. Int J Eat Disord. 2009 Sep;42(6):498–504. doi: 10.1002/eat.20639. PMID: 19130489. Exclusion Code: X7.19130489
301 Dowson J, Henderson L. The validity of a short version of the Body Shape Questionnaire. Psychiatry Res. 2001 Jul 24;102(3):263–71. doi: 10.1016/s0165-1781(01)00254-2. PMID: 11440777. Exclusion Code: X4.11440777
302 Doyle AC, Goldschmidt A, Huang C, . Reduction of overweight and eating disorder symptoms via the Internet in adolescents: A randomized controlled trial. J Adolesc Health. 2008;43(2):172–9. doi: 10.1016/j.jadohealth.2008.01.011. PMID: 2008-10134-012. Exclusion Code: X3.18639791
303 Doyle AC, le Grange D, Goldschmidt A, . Psychosocial and physical impairment in overweight adolescents at high risk for eating disorders. Obesity (Silver Spring). 2007 Jan;15(1):145–54. doi: 10.1038/oby.2007.515. PMID: 17228042. Exclusion Code: X7.17228042
304 Drewnowski A, Krahn DD, Demitrack MA, . Naloxone, an opiate blocker, reduces the consumption of sweet high-fat foods in obese and lean female binge eaters. Am J Clin Nutr. 1995 Jun;61(6):1206–12. doi: 10.1093/ajcn/61.6.1206. PMID: 7762518. Exclusion Code: X7.7762518
305 Drewnowski A, Yee DK, Kurth CL, . Eating pathology and DSM-III-R bulimia nervosa: a continuum of behavior. Am J Psychiatry. 1994 Aug;151(8):1217–9. doi: 10.1176/ajp.151.8.1217. PMID: 8037258. Exclusion Code: X7.8037258
306 Duarte C, Pinto-Gouveia J, Ferreira C. Expanding binge eating assessment: Validity and screening value of the Binge Eating Scale in women from the general population. Eat Behav. 2015 Aug;18:41–7. doi: 10.1016/j.eatbeh.2015.03.007. PMID: 25880043. Exclusion Code: X14.25880043
307 Duarte C, Pinto-Gouveia J, Stubbs RJ. Compassionate Attention and Regulation of Eating Behaviour: A pilot study of a brief low-intensity intervention for binge eating. Clin Psychol Psychother. 2017 Nov;24(6):O1437–o47. doi: 10.1002/cpp.2094. PMID: 28612453. Exclusion Code: X14.28612453
308 Duarte C, Pinto-Gouveia J, Stubbs RJ. The prospective associations between bullying experiences, body image shame and disordered eating in a sample of adolescent girls. Pers Individ Dif. 2017;116:319–25. doi: 10.1016/j.paid.2017.05.003. PMID: 2017-25354-050. Exclusion Code: X4.
309 Dugue R, Renner F, Austermann M, . Imagery rescripting in individuals with binge-eating behavior: an experimental proof-of-concept study. Int J Eat Disord. 2019;52(2):183–8. doi: 10.1002/eat.22995. PMID: CN-01792982. Exclusion Code: X7.30597583
310 Duncombe Lowe K, Barnes TL, Martell C, . Youth with Avoidant/Restrictive Food Intake Disorder: Examining Differences by Age, Weight Status, and Symptom Duration. Nutrients. 2019 Aug 20;11(8)doi: 10.3390/nu11081955. PMID: 31434268. Exclusion Code: X9.31434268
311 Dunn EC, Neighbors C, Larimer ME. Motivational enhancement therapy and self-help treatment for binge eaters. Psychol Addict Behav. 2006 Mar;20(1):44–52. doi: 10.1037/0893-164x.20.1.44. PMID: 16536664. Exclusion Code: X7.16536664
312 East P, Startup H, Roberts C, . Expressive writing and eating disorder features: a preliminary trial in a student sample of the impact of three writing tasks on eating disorder symptoms and associated cognitive, affective and interpersonal factors. Eur Eat Disord Rev. 2010 May;18(3):180–96. doi: 10.1002/erv.978. PMID: 20191662. Exclusion Code: X5.20191662
313 Eckert ED, Goldberg SC, Halmi KA, . Behaviour therapy in anorexia nervosa. Br J Psychiatry. 1979;134:55–9. doi: 10.1192/bjp.134.1.55. PMID: CN-00019656. Exclusion Code: X7.760924
314 Eddy KT, Tanofsky-Kraff M, Thompson-Brenner H, . Eating disorder pathology among overweight treatment-seeking youth: clinical correlates and cross-sectional risk modeling. Behav Res Ther. 2007 Oct;45(10):2360–71. doi: 10.1016/j.brat.2007.03.017. PMID: 17509523. Exclusion Code: X7.17509523
315 Edelstein CK, Yager J, Gitlin M, . A clinical study of anti-depressant medications in the treatment of bulimia. Psychiatr Med. 1989;7(3):111–21. PMID: 2813828. Exclusion Code: X3.2813828
316 Egger N, Wild B, Zipfel S, . Cost-effectiveness of focal psychodynamic therapy and enhanced cognitive-behavioural therapy in out-patients with anorexia nervosa. Psychol Med. 2016 Dec;46(16):3291–301. doi: 10.1017/s0033291716002002. PMID: 27609525. Exclusion Code: X7.27609525
317 Eichen DM, Lent MR, Goldbacher E, . Exploration of ‘food addiction’ in overweight and obese treatment-seeking adults. Appetite. 2013;67:22–4. doi: 10.1016/j.appet.2013.03.008. PMID: 2013-18253-007. Exclusion Code: X7.23535004
318 Eilander MM, de Wit M, Rotteveel J, . Disturbed eating behaviors in adolescents with type 1 diabetes. How to screen for yellow flags in clinical practice? Pediatr Diabetes. 2017 Aug;18(5):376–83. doi: 10.1111/pedi.12400. PMID: 27357496. Exclusion Code: X3.27357496
319 Eisenberg Colman MH, Quick VM, Lipsky LM, . Disordered Eating Behaviors Are Not Increased by an Intervention to Improve Diet Quality but Are Associated With Poorer Glycemic Control Among Youth With Type 1 Diabetes. Diabetes Care. 2018 Apr;41(4):869–75. doi: 10.2337/dc17-0090. PMID: 29371234. Exclusion Code: X3.29371234
320 Eisler I, Dare C, Hodes M, . Family therapy for adolescent anorexia nervosa: the results of a controlled comparison of two family interventions. J Child Psychol Psychiatry. 2000 Sep;41(6):727–36. PMID: 11039685. Exclusion Code: X7.11039685
321 Eisler I, Dare C, Russell GF, . Family and individual therapy in anorexia nervosa. A 5-year follow-up. Arch Gen Psychiatry. 1997 Nov;54(11):1025–30. doi: 10.1001/archpsyc.1997.01830230063008. PMID: 9366659. Exclusion Code: X8.9366659
322 Eisler I, Simic M, Russell GF, . A randomised controlled treatment trial of two forms of family therapy in adolescent anorexia nervosa: a five-year follow-up. J Child Psychol Psychiatry. 2007 Jun;48(6):552–60. doi: 10.1111/j.1469-7610.2007.01726.x. PMID: 17537071. Exclusion Code: X3.17537071
323 Ekeroth K, Birgegård A. Evaluating reliable and clinically significant change in eating disorders: comparisons to changes in DSM-IV diagnoses. Psychiatry Res. 2014 May 15;216(2):248–54. doi: 10.1016/j.psychres.2014.02.008. PMID: 24582504. Exclusion Code: X7.24582504
324 Elder KA, Grilo CM. The Spanish language version of the Eating Disorder Examination Questionnaire: comparison with the Spanish language version of the eating disorder examination and test-retest reliability. Behav Res Ther. 2007 Jun;45(6):1369–77. doi: 10.1016/j.brat.2006.08.012. PMID: 17014823. Exclusion Code: X3.17014823
325 Elder KA, Grilo CM, Masheb RM, . Comparison of two self-report instruments for assessing binge eating in bariatric surgery candidates. Behav Res Ther. 2006 Apr;44(4):545–60. doi: 10.1016/j.brat.2005.04.003. PMID: 15993381. Exclusion Code: X3.15993381
326 Eldredge KL, Stewart Agras W, Arnow B, . The effects of extending cognitive-behavioral therapy for binge eating disorder among initial treatment nonresponders. Int J Eat Disord. 1997 May;21(4):347–52. doi: 10.1002/(sici)1098-108x(1997)21:4<347::aid-eat7>3.0.co;2-o. PMID: 9138046. Exclusion Code: X3.9138046
327 Ellison JM, Simonich HK, Wonderlich SA, . Meal patterning in the treatment of bulimia nervosa. Eat Behav. 2016 Jan;20:39–42. doi: 10.1016/j.eatbeh.2015.11.008. PMID: 26630618. Exclusion Code: X7.26630618
328 Elsadek AM, Hamid MS, Allison KC. Psychometric characteristics of the Night Eating Questionnaire in a Middle East population. Int J Eat Disord. 2014 Sep;47(6):660–5. doi: 10.1002/eat.22285. PMID: 24733495. Exclusion Code: X7.24733495
329 Engelsen BK. Multidimensionality in adolescent eating problems. A two-phase measurement study. Eat Weight Disord. 1999 Jun;4(2):63–75. doi: 10.1007/bf03339720. PMID: 11234244. Exclusion Code: X7.11234244
330 Engelsen BK, Hagtvet KA. The dimensionality of the 12-item version of the Eating Attitudes Test. Confirmatory factor analyses. Scand J Psychol. 1999 Dec;40(4):293–300. doi: 10.1111/1467-9450.404129. PMID: 10658513. Exclusion Code: X7.10658513
331 Engelsen BK, Laberg JC. A comparison of three questionnaires (EAT-12, EDI, and EDE-Q) for assessment of eating problems in healthy female adolescents. Nord J Psychiatry. 2001;55(2):129–35. doi: 10.1080/08039480151108589. PMID: 11802911. Exclusion Code: X7.11802911
332 Engman-Bredvik S, Carballeira Suarez N, Levi R, . Multi-family therapy in anorexia nervosa-A qualitative study of parental experiences. Eat Disord. 2016;24(2):186–97. doi: 10.1080/10640266.2015.1034053. PMID: 25879257. Exclusion Code: X9.25879257
333 Enrique A, Bretón-López J, Molinari G, . Implementation of a positive technology application in patients with eating disorders: A pilot randomized control trial. Front Psychol. 2018;9doi: 10.3389/fpsyg.2018.00934. PMID: 2018-29641-001. Exclusion Code: X3.
334 Epstein LH, Paluch RA, Saelens BE, . Changes in eating disorder symptoms with pediatric obesity treatment. J Pediatr. 2001 Jul;139(1):58–65. doi: 10.1067/mpd.2001.115022. PMID: 11445795. Exclusion Code: X7.11445795
335 Erickson SJ, Gerstle M. Developmental considerations in measuring children’s disordered eating attitudes and behaviors. Eat Behav. 2007 Apr;8(2):224–35. doi: 10.1016/j.eatbeh.2006.06.003. PMID: 17336792. Exclusion Code: X7.17336792
336 Escandón-Nagel N, Peró M, Grau A, . Emotional eating and cognitive conflicts as predictors of binge eating disorder in patients with obesity. Int J Clin Health Psychol. 2018;18(1):52–9. doi: 10.1016/j.ijchp.2017.09.003. PMID: 2019-05141-007. Exclusion Code: X7.30487910
337 Escoto Ponce de León MdC, Bosques-Brugada LE, Camacho Ruiz EJ, . Psychometric evaluation of the muscle appearance satisfaction scale in a Mexican male sample. Eat Weight Disord. 2018;23(5):695–703. doi: 10.1007/s40519-017-0366-0. PMID: 2017-10263-001. Exclusion Code: X4.28255662
338 Espelage DL, Mazzeo SE, Aggen SH, . Examining the construct validity of the Eating Disorder Inventory. Psychol Assess. 2003 Mar;15(1):71–80. doi: 10.1037/1040-3590.15.1.71. PMID: 12674726. Exclusion Code: X3.12674726
339 Esplen MJ, Garfinkel PE, Olmsted M, . A randomized controlled trial of guided imagery in bulimia nervosa. Psychol Med. 1998 Nov;28(6):1347–57. doi: 10.1017/s0033291798007405. PMID: 9854276. Exclusion Code: X7.9854276
340 Evans C, Dolan B. Body Shape Questionnaire: derivation of shortened “alternate forms”. Int J Eat Disord. 1993 Apr;13(3):315–21. doi: 10.1002/1098-108x(199304)13:3<315::aid-eat2260130310>3.0.co;2-3. PMID: 8477304. Exclusion Code: X2.8477304
341 Evans C, Dolan B. Body shape questionnaire: derivation of shortened ‘alternative forms’. Int J Eat Disord. 1993;13(3):315–21. doi: 10.1002/1098-108X(199304)13:3<315::AID-EAT2260130310>3.0.CO;2-3. PMID: 1994-31914-001. Exclusion Code: X7.8477304
342 Fabian LJ, Thompson JK. Body image and eating disturbance in young females. Int J Eat Disord. 1989;8(1):63–74. doi: 10.1002/1098-108X(198901)8:1<63::AID-EAT2260080107>3.0.CO;2-9. PMID: 1989-26485-001. Exclusion Code: X4.
343 Fagundo AB, Via E, Sánchez I, . Physiological and brain activity after a combined cognitive behavioral treatment plus video game therapy for emotional regulation in bulimia nervosa: A case report. J Med Internet Res. 2014;16(8):34–43. doi: 10.2196/jmir.3243. PMID: 2014-34041-003. Exclusion Code: X9.
344 Fahy TA, Eisler I, Russell GF. A placebo-controlled trial of d-fenfluramine in bulimia nervosa. Br J Psychiatry. 1993 May;162:597–603. doi: 10.1192/bjp.162.5.597. PMID: 8149110. Exclusion Code: X7.8149110
345 Faija CL, Fox JR, Tierney S, . Development and Validation of the Pride in Eating Pathology Scale (PEP-S). Clin Psychol Psychother. 2017 Jan;24(1):126–38. doi: 10.1002/cpp.1988. PMID: 26503108. Exclusion Code: X4.26503108
346 Fairburn C. A cognitive behavioural approach to the treatment of bulimia. Psychol Med. 1981 Nov;11(4):707–11. doi: 10.1017/s0033291700041209. PMID: 6948316. Exclusion Code: X7.6948316
347 Fairburn CG, Cooper Z, Doll HA, . Enhanced cognitive behaviour therapy for adults with anorexia nervosa: a UK-Italy study. Behav Res Ther. 2013 Jan;51(1):R2–8. doi: 10.1016/j.brat.2012.09.010. PMID: 23084515. Exclusion Code: X7.23084515
348 Fairburn CG, Kirk J, O’Connor M, . A comparison of two psychological treatments for bulimia nervosa. Behav Res Ther. 1986;24(6):629–43. doi: 10.1016/0005-7967(86)90058-6. PMID: 3800834. Exclusion Code: X7.3800834
349 Fairburn CG, Norman PA, Welch SL, . A prospective study of outcome in bulimia nervosa and the long-term effects of three psychological treatments. Arch Gen Psychiatry. 1995 Apr;52(4):304–12. doi: 10.1001/archpsyc.1995.03950160054010. PMID: 7702447. Exclusion Code: X7.7702447
350 Faris PL, Kim SW, Meller WH, . Effect of ondansetron, a 5-ht3 receptor antagonist, on the dynamic association between bulimic behaviors and pain thresholds. Pain. 1998;77(3):297–303. PMID: CN-00214376. Exclusion Code: X7.9808355
351 Faris PL, Kim SW, Meller WH, . Effect of decreasing afferent vagal activity with ondansetron on symptoms of bulimia nervosa: a randomised, double-blind trial. Lancet. 2000 Mar 4;355(9206):792–7. doi: 10.1016/s0140-6736(99)09062-5. PMID: 10711927. Exclusion Code: X3.10711927
352 Fassino S, Leombruni P, Daga G, . Efficacy of citalopram in anorexia nervosa: a pilot study. Eur Neuropsychopharmacol. 2002 Oct;12(5):453–9. doi: 10.1016/s0924-977x(02)00058-5. PMID: 12208563. Exclusion Code: X7.12208563
353 Fazeli PK, Lawson EA, Faje AT, . Treatment With a Ghrelin Agonist in Outpatient Women With Anorexia Nervosa: A Randomized Clinical Trial. J Clin Psychiatry. 2018 Jan/Feb;79(1)doi: 10.4088/JCP.17m11585. PMID: 29325236. Exclusion Code: X5.29325236
354 Fernàndez-Aranda F, Álvarez-Moya EM, Martínez-Viana C, . Predictors of early change in bulimia nervosa after a brief psychoeducational therapy. Appetite. 2009 Jun;52(3):805–8. doi: 10.1016/j.appet.2009.03.013. PMID: 19501787. Exclusion Code: X9.19501787
355 Fernández-Aranda F, Krug I, Jiménez-Murcia S, . Male eating disorders and therapy: a controlled pilot study with one year follow-up. J Behav Ther Exp Psychiatry. 2009 Sep;40(3):479–86. doi: 10.1016/j.jbtep.2009.06.004. PMID: 19595294. Exclusion Code: X7.19595294
356 Fernández-del-Valle M, Larumbe-Zabala E, Morande-Lavin G, . Muscle function and body composition profile in adolescents with restrictive anorexia nervosa: does resistance training help? Disabil Rehabil. 2016;38(4):346–53. doi: 10.3109/09638288.2015.1041612. PMID: 26084569. Exclusion Code: X5.26084569
357 Fernandez-del-Valle M, Larumbe-Zabala E, Villaseñor-Montarroso A, . Resistance training enhances muscular performance in patients with anorexia nervosa: a randomized controlled trial. Int J Eat Disord. 2014 Sep;47(6):601–9. doi: 10.1002/eat.22251. PMID: 24810684. Exclusion Code: X5.24810684
358 Ferreira C, Trindade IA, Duarte C, . Getting entangled with body image: development and validation of a new measure. Psychol Psychother. 2015 Sep;88(3):304–16. doi: 10.1111/papt.12047. PMID: 25409920. Exclusion Code: X7.25409920
359 Ferreiro F, Seoane G, Senra C. A prospective study of risk factors for the development of depression and disordered eating in adolescents. J Clin Child Adolesc Psychol. 2011;40(3):500–5. doi: 10.1080/15374416.2011.563465. PMID: 21534061. Exclusion Code: X7.21534061
360 Ferrer-Garcia M, Pla-Sanjuanelo J, Dakanalis A, . A Randomized Trial of Virtual Reality-Based Cue Exposure Second-Level Therapy and Cognitive Behavior Second-Level Therapy for Bulimia Nervosa and Binge-Eating Disorder: outcome at Six-Month Followup. Cyberpsychology, behavior and social networking. 2019;22(1):60–8. doi: 10.1089/cyber.2017.0675. PMID: CN-01708043. Exclusion Code: X7.
361 Fichter M, Quadflieg N. The structured interview for anorexic and bulimic disorders for DSM-IV and ICD-10 (SIAB-EX): reliability and validity. Eur Psychiatry. 2001 Feb;16(1):38–48. doi: 10.1016/s0924-9338(00)00534-4. PMID: 11246291. Exclusion Code: X8.11246291
362 Fichter MM, Herpertz S, Quadflieg N, . Structured Interview for Anorexic and Bulimic disorders for DSM-IV and ICD-10: updated (third) revision. Int J Eat Disord. 1998 Nov;24(3):227–49. doi: 10.1002/(sici)1098-108x(199811)24:3<227::aid-eat1>3.0.co;2-o. PMID: 9741034. Exclusion Code: X4.9741034
363 Fichter MM, Leibl C, Krüger R, . Effects of fluvoxamine on depression, anxiety, and other areas of general psychopathology in bulimia nervosa. Pharmacopsychiatry. 1997 May;30(3):85–92. doi: 10.1055/s-2007-979488. PMID: 9211569. Exclusion Code: X3.9211569
364 Fichter MM, Leibl K, Rief W, . Fluoxetine versus placebo: a double-blind study with bulimic inpatients undergoing intensive psychotherapy. Pharmacopsychiatry. 1991 Jan;24(1):1–7. doi: 10.1055/s-2007-1014424. PMID: 2011615. Exclusion Code: X7.2011615
365 Fichter MM, Quadflieg N. Comparing self- and expert rating: a self-report screening version (SIAB-S) of the structured interview for anorexic and bulimic syndromes for DSM-IV and ICD-10 (SIAB-EX). Eur Arch Psychiatry Clin Neurosci. 2000;250(4):175–85. doi: 10.1007/s004060070022. PMID: 11009070. Exclusion Code: X4.11009070
366 Fichter MM, Quadflieg N. Twelve-year course and outcome of bulimia nervosa. Psychol Med. 2004;34(8):1395–406. doi: 10.1017/S0033291704002673. PMID: 2004-21995-003. Exclusion Code: X7.15724871
367 Fichter MM, Quadflieg N, Gierk B, . The Munich eating and feeding disorder questionnaire (Munich ED-Quest) DSM-5/ICD-10: validity, reliability, sensitivity to change and norms. Eur Eat Disord Rev. 2015 May;23(3):229–40. doi: 10.1002/erv.2348. PMID: 25677676. Exclusion Code: X3.25677676
368 Fichter MM, Quadflieg N, Hedlund S. Twelve-year course and outcome predictors of anorexia nervosa. Int J Eat Disord. 2006 Mar;39(2):87–100. doi: 10.1002/eat.20215. PMID: 16231345. Exclusion Code: X8.16231345
369 Fichter MM, Quadflieg N, Rehm J. Predicting the outcome of eating disorders using structural equation modeling. Int J Eat Disord. 2003 Nov;34(3):292–313. doi: 10.1002/eat.10193. PMID: 12949921. Exclusion Code: X9.12949921
370 Field AE, Sonneville KR, Micali N, . Prospective association of common eating disorders and adverse outcomes. Pediatrics. 2012 Aug;130(2):e289–95. doi: 10.1542/peds.2011-3663. PMID: 22802602. Exclusion Code: X7.22802602
371 Field AE, Taylor CB, Celio A, . Comparison of self-report to interview assessment of bulimic behaviors among preadolescent and adolescent girls and boys. Int J Eat Disord. 2004 Jan;35(1):86–92. doi: 10.1002/eat.10220. PMID: 14705161. Exclusion Code: X7.14705161
372 Fischer S, Meyer AH, Dremmel D, . Short-term cognitive-behavioral therapy for binge eating disorder: long-term efficacy and predictors of long-term treatment success. Behav Res Ther. 2014 Jul;58:36–42. doi: 10.1016/j.brat.2014.04.007. PMID: 24929926. Exclusion Code: X7.24929926
373 Fitzsimmons-Craft EE, Balantekin KN, Eichen DM, . Screening and offering online programs for eating disorders: reach, pathology, and differences across eating disorder status groups at 28 uS Universities. Int J Eat Disord. 2019doi: 10.1002/eat.23134. PMID: 2019-37873-001. Exclusion Code: X7.
374 Fitzsimmons-Craft EE, Balantekin KN, Graham AK, . Results of disseminating an online screen for eating disorders across the U.S.: Reach, respondent characteristics, and unmet treatment need. Int J Eat Dis. 2019;52(6):721–9. doi: 10.1002/eat.23043. PMID: 30761560. Exclusion Code: X9.30761560
375 Fitzsimmons-Craft EE, Bardone-Cone AM. One-year temporal stability and predictive and incremental validity of the body, eating, and exercise comparison orientation measure (BEECOM) among college women. Body Image. 2014 Jan;11(1):27–35. doi: 10.1016/j.bodyim.2013.09.003. PMID: 24120182. Exclusion Code: X7.24120182
376 Fitzsimmons-Craft EE, Eichen DM, Kass AE, . Reciprocal longitudinal relations between weight/shape concern and comorbid pathology among women at very high risk for eating disorder onset. Eat Weight Disord. 2019;24(6):1189–98. doi: 10.1007/s40519-017-0469-7. PMID: 2017-58715-001. Exclusion Code: X2.29285745
377 Flament MF, Buchholz A, Henderson K, . Comparative distribution and validity of DSM-IV and DSM-5 diagnoses of eating disorders in adolescents from the community. Eur Eat Disord Rev. 2015 Mar;23(2):100–10. doi: 10.1002/erv.2339. PMID: 25524758. Exclusion Code: X4.25524758
378 Fogelholm M, Kukkonen-Harjula K, Oja P. Eating control and physical activity as determinants of short-term weight maintenance after a very-low-calorie diet among obese women. Int J Obes Relat Metab Disord. 1999 Feb;23(2):203–10. doi: 10.1038/sj.ijo.0800825. PMID: 10078857. Exclusion Code: X3.10078857
379 Fogelkvist M, Gustafsson SA, Kjellin L, . Acceptance and commitment therapy to reduce eating disorder symptoms and body image problems in patients with residual eating disorder symptoms: A randomized controlled trial. Body Image. 2020;32:155–66. doi: 10.1016/j.bodyim.2020.01.002. PMID: 2020-17082-022. Exclusion Code: X3.32000093
380 Forbush KT, Hilderbrand LA, Bohrer BK, . Test-retest reliability of common measures of eating disorder symptoms in men versus women. Assessment. 2019 Apr;26(3):419–31. doi: 10.1177/1073191117700267. PMID: 28372483. Exclusion Code: X7.28372483
381 Forbush KT, Siew CS, Vitevitch MS. Application of network analysis to identify interactive systems of eating disorder psychopathology. Psychol Med. 2016 Sep;46(12):2667–77. doi: 10.1017/s003329171600012x. PMID: 27387196. Exclusion Code: X7.27387196
382 Forbush KT, Wildes JE, Hunt TK. Gender norms, psychometric properties, and validity for the Eating Pathology Symptoms Inventory. Int J Eat Disord. 2014 Jan;47(1):85–91. doi: 10.1002/eat.22180. PMID: 23996154. Exclusion Code: X4.23996154
383 Forbush KT, Wildes JE, Pollack LO, . Development and validation of the Eating Pathology Symptoms Inventory (EPSI). Psychol Assess. 2013 Sep;25(3):859–78. doi: 10.1037/a0032639. PMID: 23815116. Exclusion Code: X4.23815116
384 Formby P, Watson HJ, Hilyard A, . Psychometric properties of the Compulsive Exercise Test in an adolescent eating disorder population. Eat Behav. 2014 Dec;15(4):555–7. doi: 10.1016/j.eatbeh.2014.08.013. PMID: 25200383. Exclusion Code: X4.25200383
385 Fortes LdS, Almeida SdS, Ferreira MEC. Psychometric analysis of Disordered Eating in Sports Scale (DES). Paidéia. 2016;26(64):171–80. doi: 10.1590/1982-43272664201603. PMID: 2016-26344-004. Exclusion Code: X7.
386 Frampton I, Wisting L, Øverås M, . Reliability and validity of the Norwegian translation of the Child Eating Disorder Examination (ChEDE). Scand J Psychol. 2011 Apr;52(2):196–9. doi: 10.1111/j.1467-9450.2010.00833.x. PMID: 20584151. Exclusion Code: X4.20584151
387 Frank GK, Kaye WH, Weltzin TE, . Altered response to meta-chlorophenylpiperazine in anorexia nervosa: support for a persistent alteration of serotonin activity after short-term weight restoration. Int J Eat Disord. 2001 Jul;30(1):57–68. doi: 10.1002/eat.1054. PMID: 11439409. Exclusion Code: X3.11439409
388 Frank GK, Shott ME, Hagman JO, . The partial dopamine D2 receptor agonist aripiprazole is associated with weight gain in adolescent anorexia nervosa. Int J Eat Disord. 2017 Apr;50(4):447–50. doi: 10.1002/eat.22704. PMID: 28334444. Exclusion Code: X7.28334444
389 Franklin EV, Simpson V, Berthet-Miron M, . A Pilot Study Evaluating a Binge-Eating Screener in Children: Development of the Children’s Brief Binge-Eating Questionnaire in a Pediatric Obesity Clinic. Clin Pediatr (Phila). 2019 Sep;58(10):1063–71. doi: 10.1177/0009922819863664. PMID: 31331196. Exclusion Code: X14.31331196
390 Franko DL, Jenkins A, Roehrig JP, . Psychometric properties of measures of eating disorder risk in Latina college women. Int J Eat Disord. 2012 May;45(4):592–6. doi: 10.1002/eat.20979. PMID: 22271562. Exclusion Code: X4.22271562
391 Franko DL, Mintz LB, Villapiano M, . Food, mood, and attitude: reducing risk for eating disorders in college women. Health Psychol. 2005 Nov;24(6):567–78. doi: 10.1037/0278-6133.24.6.567. PMID: 16287402. Exclusion Code: X5.16287402
392 Franko DL, Striegel-Moore RH, Barton BA, . Measuring eating concerns in Black and White adolescent girls. Int J Eat Disord. 2004 Mar;35(2):179–89. doi: 10.1002/eat.10251. PMID: 14994355. Exclusion Code: X9.14994355
393 Franko DL, Zuroff DC. The Bulimic Automatic Thoughts Test: initial reliability and validity data. J Clin Psychol. 1992 Jul;48(4):505–9. doi: 10.1002/1097-4679(199207)48:4<505::aid-jclp2270480411>3.0.co;2-b. PMID: 1517444. Exclusion Code: X4.1517444
394 Franzoni E, Monti M, Pellicciari A, . SAFA: a new measure to evaluate psychiatric symptoms detected in a sample of children and adolescents affected by eating disorders Correlations with risk factors. Neuropsychiatr Dis Treat. 2009;5 PMID: 2013-11329-001. Exclusion Code: X7.
395 Freeman C, Sinclair F, Turnbull J, . Psychotherapy for bulimia: a controlled study. J Psychiatr Res. 1985;19(2–3):373–8. PMID: 3900361. Exclusion Code: X7.3900361
396 Freeman CP, Barry F, Dunkeld-Turnbull J, . Controlled trial of psychotherapy for bulimia nervosa. Br Med J (Clin Res Ed). 1988 Feb 20;296(6621):521–5. doi: 10.1136/bmj.296.6621.521. PMID: 3126890. Exclusion Code: X10.3126890
397 Freeman RK, Walker MK, Ben-Tovim DI. Low levels of interrater reliability in a standard measure of outcome in eating disorders (the modified Morgan-Russell Assessment Schedule). Int J Eat Disord. 1996 Jul;20(1):51–6. doi: 10.1002/(sici)1098-108x(199607)20:1<51::aid-eat6>3.0.co;2-3. PMID: 8807352. Exclusion Code: X7.8807352
398 Freitas SR, Lopes CS, Appolinario JC, . The assessment of binge eating disorder in obese women: a comparison of the binge eating scale with the structured clinical interview for the DSM-IV. Eat Behav. 2006 Aug;7(3):282–9. doi: 10.1016/j.eatbeh.2005.09.002. PMID: 16843232. Exclusion Code: X11.16843232
399 Freund KM, Boss RD, Handleman EK, . Secret patterns: validation of a screening tool to detect bulimia. J Womens Health Gend Based Med. 1999 Dec;8(10):1281–4. doi: 10.1089/jwh.1.1999.8.1281. PMID: 10643836. Exclusion Code: X14.10643836
400 Freund KM, Graham SM, Lesky LG, . Detection of bulimia in a primary care setting. J Gen Intern Med. 1993 May;8(5):236–42. doi: 10.1007/bf02600088. PMID: 8505681. Exclusion Code: X4.8505681
401 Friborg O, Clausen L, Rosenvinge JH. A five-item screening version of the Eating Disorder Inventory (EDI-3). Compr Psychiatry. 2013 Nov;54(8):1222–8. doi: 10.1016/j.comppsych.2013.05.004. PMID: 23756110. Exclusion Code: X9.23756110
402 Fukunishi I, Akimoto M. Development of the eating Attitude Inventory for Diabetes Mellitus. Psychol Rep. 1997 Jun;80(3 Pt 2):1363–71. doi: 10.2466/pr0.1997.80.3c.1363. PMID: 9246901. Exclusion Code: X4.9246901
403 Fukutomi A, Austin A, McClelland J, . First episode rapid early intervention for eating disorders: A two-year follow-up. Early Intervention in Psychiatry. 2019doi: 10.1111/eip.12881. PMID: 2019-62324-001. Exclusion Code: X7.
404 Fukutomi A, Austin A, McClelland J, . First episode rapid early intervention for eating disorders: A two-year follow-up. Early Interv Psychiatry. 2020 Feb;14(1):137–41. doi: 10.1111/eip.12881. PMID: 31617325. Exclusion Code: X9.31617325
405 Fursland A, Erceg-Hurn DM, Byrne SM, . A single session assessment and psychoeducational intervention for eating disorders: Impact on treatment waitlists and eating disorder symptoms. Int J Eat Disord. 2018 Dec;51(12):1373–7. doi: 10.1002/eat.22983. PMID: 30584661. Exclusion Code: X9.30584661
406 Gamble C, Bryant-Waugh R, Turner H, . An investigation into the psychometric properties of the Stirling Eating Disorder Scales. Eat Behav. 2006 Nov;7(4):395–403. doi: 10.1016/j.eatbeh.2005.12.005. PMID: 17056417. Exclusion Code: X7.17056417
407 Garcia FD, Grigioni S, Allais E, . Detection of eating disorders in patients: validity and reliability of the French version of the SCOFF questionnaire. Clin Nutr. 2011 Apr;30(2):178–81. doi: 10.1016/j.clnu.2010.09.007. PMID: 20971536. Exclusion Code: X3.20971536
408 Garcia-Campayo J, Sanz-Carrillo C, Ibañez JA, . Validation of the Spanish version of the SCOFF questionnaire for the screening of eating disorders in primary care. J Psychosom Res. 2005 Aug;59(2):51–5. doi: 10.1016/j.jpsychores.2004.06.005. PMID: 16185998. Exclusion Code: X3.16185998
409 García-García E, Vázquez-Velázquez V, López-Alvarenga JC, . Internal validity and diagnostic utility of the Eating Disorder Inventory in Mexican women. Salud Publica Mex. 2003;45(3):206–10. PMID: CN-00439437. Exclusion Code: X1.12870422
410 Garfinkel PE, Kline SA, Stancer HC. Treatment of anorexia nervosa using operant conditioning techniques. J Nerv Ment Dis. 1973 Dec;157(6):428–33. doi: 10.1097/00005053-197312000-00004. PMID: 4758746. Exclusion Code: X8.4758746
411 Garfinkel PE, Lin E, Goering P, . Should amenorrhoea be necessary for the diagnosis of anorexia nervosa? Evidence from a Canadian community sample. Br J Psychiatry. 1996 Apr;168(4):500–6. doi: 10.1192/bjp.168.4.500. PMID: 8730948. Exclusion Code: X7.8730948
412 Garrett AS, Lock J, Datta N, . Predicting clinical outcome using brain activation associated with set-shifting and central coherence skills in Anorexia Nervosa. J Psychiatr Res. 2014;57:26–33. doi: 10.1016/j.jpsychires.2014.06.013. PMID: CN-01090672. Exclusion Code: X7.25027478
413 Gearhardt AN, Corbin WR, Brownell KD. Preliminary validation of the Yale Food Addiction Scale. Appetite. 2009 Apr;52(2):430–6. doi: 10.1016/j.appet.2008.12.003. PMID: 19121351. Exclusion Code: X4.19121351
414 Gearhardt AN, Roberto CA, Seamans MJ, . Preliminary validation of the Yale Food Addiction Scale for children. Eat Behav. 2013 Dec;14(4):508–12. doi: 10.1016/j.eatbeh.2013.07.002. PMID: 24183146. Exclusion Code: X3.24183146
415 Gelabert E, García-Esteve L, Martín-Santos R, . Psychometric properties of the Spanish version of the Frost Multidimensional Perfectionism Scale in women. Psicothema. 2011;23(1):133–9. PMID: 2011-01716-021. Exclusion Code: X9.21266154
416 Gelber D, Levine J, Belmaker RH. Effect of inositol on bulimia nervosa and binge eating. Int J Eat Disord. 2001 Apr;29(3):345–8. doi: 10.1002/eat.1028. PMID: 11262515. Exclusion Code: X3.11262515
417 Geller J, Brown KE, Srikameswaran S. The efficacy of a brief motivational intervention for individuals with eating disorders: a randomized control trial. Int J Eat Disord. 2011 Sep;44(6):497–505. doi: 10.1002/eat.20847. PMID: 20872758. Exclusion Code: X7.20872758
418 Geller J, Brown KE, Srikameswaran S, . The psychometric properties of the Readiness and Motivation Questionnaire: a symptom-specific measure of readiness for change in the eating disorders. Psychol Assess. 2013 Sep;25(3):759–68. doi: 10.1037/a0032539. PMID: 23647034. Exclusion Code: X4.23647034
419 Geller J, Johnston C, Madsen K, . Shape- and weight-based self-esteem and the eating disorders. Int J Eat Disord. 1998 Nov;24(3):285–98. doi: 10.1002/(sici)1098-108x(199811)24:3<285::aid-eat6>3.0.co;2-i. PMID: 9741039. Exclusion Code: X4.9741039
420 Gentile AJ, La Lima C, Flygare O, . Internet-based, therapist-guided, cognitive-behavioural therapy for body dysmorphic disorder with global eligibility for inclusion: an uncontrolled pilot study. BMJ Open. 2019 Mar 23;9(3):e024693. doi: 10.1136/bmjopen-2018-024693. PMID: 30904854. Exclusion Code: X2.30904854
421 Ghaderi A, Scott B. The preliminary reliability and validity of the Survey for Eating Disorders (SEDs): A self-report questionnaire for diagnosing eating disorders. Eur Eat Disord Rev. 2002;10(1):61–76. doi: 10.1002/erv.425. PMID: 2002-02089-005. Exclusion Code: X9.
422 Ghaderi A, Scott B. Pure and guided self-help for full and sub-threshold bulimia nervosa and binge eating disorder. Br J Clin Psychol. 2003 Sep;42(Pt 3):257–69. doi: 10.1348/01446650360703375. PMID: 14565892. Exclusion Code: X7.14565892
423 Ghaderi A, Stice E, Andersson G, . A randomized controlled trial of the effectiveness of virtually delivered Body Project (vBP) groups to prevent eating disorders. J Consult Clin Psychol. 2020;88(7):643–56. doi: 10.1037/ccp0000506. PMID: 2020-43103-003. Exclusion Code: X5.32551736
424 Gideon N, Hawkes N, Mond J, . ‘Development and psychometric validation of the EDE-QS, a 12 Item short form of the Eating Disorder Examination Questionnaire (EDE-Q)’: Correction. PLoS One. 2018;13(11)PMID: 2018-56553-001. Exclusion Code: X12.
425 Giel KE, Speer E, Schag K, . Effects of a food-specific inhibition training in individuals with binge eating disorder-findings from a randomized controlled proof-of-concept study. Eat Weight Disord. 2017 Jun;22(2):345–51. doi: 10.1007/s40519-017-0371-3. PMID: 28271453. Exclusion Code: X10.28271453
426 Gila A, Castro J, Gómez MJ, . The Body Attitude Test: validation of the Spanish version. Eat Weight Disord. 1999 Dec;4(4):175–8. doi: 10.1007/bf03339733. PMID: 10728178. Exclusion Code: X9.10728178
427 Gilbert N, Arcelus J, Cashmore R, . Should I ask about eating? Patients’ disclosure of eating disorder symptoms and help-seeking behaviour. Eur Eat Disord Rev. 2012 Jan;20(1):80–5. doi: 10.1002/erv.1143. PMID: 21800399. Exclusion Code: X7.21800399
428 Gladis MM, Wadden TA, Foster GD, . A comparison of two approaches to the assessment of binge eating in obesity. Int J Eat Disord. 1998 Jan;23(1):17–26. doi: 10.1002/(sici)1098-108x(199801)23:1<17::aid-eat3>3.0.co;2-4. PMID: 9429915. Exclusion Code: X7.9429915
429 Glashouwer KA, Neimeijer RAM, de Koning ML, . Evaluative conditioning as a body image intervention for adolescents with eating disorders. J Consult Clin Psychol. 2018 Dec;86(12):1046–55. doi: 10.1037/ccp0000311. PMID: 30507229. Exclusion Code: X3.30507229
430 Gluck ME, Geliebter A, Lorence M. Cortisol stress response is positively correlated with central obesity in obese women with binge eating disorder (BED) before and after cognitive-behavioral treatment. Ann N Y Acad Sci. 2004 Dec;1032:202–7. doi: 10.1196/annals.1314.021. PMID: 15677411. Exclusion Code: X3.15677411
431 Godart N, Berthoz S, Curt F, . A randomized controlled trial of adjunctive family therapy and treatment as usual following inpatient treatment for anorexia nervosa adolescents. PLoS One. 2012;7(1):e28249. doi: 10.1371/journal.pone.0028249. PMID: 22238574. Exclusion Code: X3.22238574
432 Godier LR, Park RJ. A novel measure of compulsive food restriction in anorexia nervosa: validation of the Self-Starvation Scale (SS). Eat Behav. 2015 Apr;17:10–3. doi: 10.1016/j.eatbeh.2014.12.004. PMID: 25528717. Exclusion Code: X4.25528717
433 Gokee-LaRose J, Gorin AA, Wing RR. Behavioral self-regulation for weight loss in young adults: A randomized controlled trial. Int J Behav Nutr Phys Act. 2009;6doi: 10.1186/1479-5868-6-10. PMID: 2012-30450-001. Exclusion Code: X5.
434 Golay A, Laurent-Jaccard A, Habicht F, . Effect of Orlistat in Obese Patients with Binge Eating Disorder. Obes Res. 2005;13(10):1701–8. doi: 10.1038/oby.2005.208. PMID: 2005-15566-005. Exclusion Code: X14.16286517
435 Goldberg SC, Halmi KA, Eckert ED, . Cyproheptadine in anorexia nervosa. Br J Psychiatry. 1979;134:67–70. doi: 10.1192/bjp.134.1.67. PMID: CN-00019657. Exclusion Code: X3.367480
436 Goldbloom DS, Olmsted MP. Pharmacotherapy of bulimia nervosa with fluoxetine: assessment of clinically significant attitudinal change. Am J Psychiatry. 1993 May;150(5):770–4. doi: 10.1176/ajp.150.5.770. PMID: 8480824. Exclusion Code: X7.8480824
437 Goldfein JA, Devlin MJ, Kamenetz C. Eating Disorder Examination-Questionnaire with and without instruction to assess binge eating in patients with binge eating disorder. Int J Eat Disord. 2005 Mar;37(2):107–11. doi: 10.1002/eat.20075. PMID: 15732081. Exclusion Code: X4.15732081
438 Goldschmidt AB, Accurso EC, Crosby RD, . Association between objective and subjective binge eating and psychopathology during a psychological treatment trial for bulimic symptoms. Appetite. 2016 Dec 1;107:471–7. doi: 10.1016/j.appet.2016.08.104. PMID: 27554184. Exclusion Code: X9.27554184
439 Goldschmidt AB, Doyle AC, Wilfley DE. Assessment of binge eating in overweight youth using a questionnaire version of the Child Eating Disorder Examination with Instructions. Int J Eat Disord. 2007 Jul;40(5):460–7. doi: 10.1002/eat.20387. PMID: 17497710. Exclusion Code: X7.17497710
440 Goldstein DJ, Wilson MG, Ascroft RC, . Effectiveness of fluoxetine therapy in bulimia nervosa regardless of comorbid depression. Int J Eat Disord. 1999 Jan;25(1):19–27. doi: 10.1002/(sici)1098-108x(199901)25:1<19::aid-eat3>3.0.co;2-3. PMID: 9924649. Exclusion Code: X10.9924649
441 Goldstein DJ, Wilson MG, Thompson VL, . Long-term fluoxetine treatment of bulimia nervosa. Fluoxetine Bulimia Nervosa Research Group. Br J Psychiatry. 1995 May;166(5):660–6. doi: 10.1192/bjp.166.5.660. PMID: 7620754. Exclusion Code: X14.7620754
442 Gomez Penedo JM, Constantino MJ, Coyne AE, . Patient baseline interpersonal problems as moderators of outcome in two psychotherapies for bulimia nervosa. Psychother Res. 2019 Aug;29(6):799–811. doi: 10.1080/10503307.2018.1425931. PMID: 29347888. Exclusion Code: X7.29347888
443 Goode RW, Kalarchian MA, Craighead L, . The feasibility of a binge eating intervention in Black women with obesity. Eat Behav. 2018;29:83–90. doi: 10.1016/j.eatbeh.2018.03.005. PMID: 2018-20814-016. Exclusion Code: X5.29549863
444 Goodman R, Ford T, Simmons H, . Using the Strengths and Difficulties Questionnaire (SDQ) to screen for child psychiatric disorders in a community sample. Br J Psychiatry. 2000 Dec;177:534–9. doi: 10.1192/bjp.177.6.534. PMID: 11102329. Exclusion Code: X9.11102329
445 Goodrick GK, Pendleton VR, Kimball KT, . Binge eating severity, self-concept, dieting self-efficacy and social support during treatment of binge eating disorder. Int J Eat Disord. 1999 Nov;26(3):295–300. doi: 10.1002/(sici)1098-108x(199911)26:3<295::aid-eat7>3.0.co;2-7. PMID: 10441245. Exclusion Code: X9.10441245
446 Goodrick GK, Poston WS, Kimball KT, . Nondieting versus dieting treatment for overweight binge-eating women. J Consult Clin Psychol. 1998;66(2):363–8. doi: 10.1037//0022-006x.66.2.363. PMID: CN-00684060. Exclusion Code: X3.9583339
447 Goossens L, Braet C. Screening for eating pathology in the pediatric field. Int J Pediatr Obes. 2010 Dec;5(6):483–90. doi: 10.3109/17477160903571995. PMID: 20233148. Exclusion Code: X4.20233148
448 Goossens L, Braet C, Bosmans G, . Loss of control over eating in pre-adolescent youth: the role of attachment and self-esteem. Eat Behav. 2011 Dec;12(4):289–95. doi: 10.1016/j.eatbeh.2011.07.005. PMID: 22051362. Exclusion Code: X7.22051362
449 Goossens L, Braet C, Verbeken S, . Long-term outcome of pediatric eating pathology and predictors for the onset of loss of control over eating following weight-loss treatment. Int J Eat Disord. 2011 Jul;44(5):397–405. doi: 10.1002/eat.20848. PMID: 20872756. Exclusion Code: X7.20872756
450 Gordon SM, Johnson JA, Greenfield SF, . Assessment and treatment of co-occurring eating disorders in publicly funded addiction treatment programs. Psychiatr Serv. 2008 Sep;59(9):1056–9. doi: 10.1176/appi.ps.59.9.1056. PMID: 18757602. Exclusion Code: X7.18757602
451 Gorin AA, Le Grange D, Stone AA. Effectiveness of spouse involvement in cognitive behavioral therapy for binge eating disorder. Int J Eat Disord. 2003 May;33(4):421–33. doi: 10.1002/eat.10152. PMID: 12658672. Exclusion Code: X7.12658672
452 Gormally J, Black S, Daston S, . The assessment of binge eating severity among obese persons. Addict Behav. 1982;7(1):47–55. doi: 10.1016/0306-4603(82)90024-7. PMID: 7080884. Exclusion Code: X9.7080884
453 Gorrell S, Matheson BE, Lock J, . Remission in adolescents with bulimia nervosa: empirical evaluation of current conceptual models. Eur Eat Disord Rev. 2020doi: 10.1002/erv.2729. PMID: CN-02098109. Exclusion Code: X7.
454 Götestam KG, Agras WS. General population-based epidemiological study of eating disorders in Norway. Int J Eat Disord. 1995 Sep;18(2):119–26. doi: 10.1002/1098-108x(199509)18:2<119::aid-eat2260180203>3.0.co;2-u. PMID: 7581413. Exclusion Code: X9.7581413
455 Gowers S, Claxton M, Rowlands L, . Drug prescribing in child and adolescent eating disorder services. Child Adolesc Ment Health. 2010;15(1):18–22. doi: 10.1111/j.1475-3588.2009.00535.x. PMID: 2010-00183-003. Exclusion Code: X9.32847208
456 Gowers S, Norton K, Halek C, . Outcome of outpatient psychotherapy in a random allocation treatment study of anorexia nervosa. Int J Eat Disord. 1994 Mar;15(2):165–77. doi: 10.1002/1098-108x(199403)15:2<165::aid-eat2260150208>3.0.co;2-0. PMID: 8173562. Exclusion Code: X9.8173562
457 Gowers SG, Clark AF, Roberts C, . A randomised controlled multicentre trial of treatments for adolescent anorexia nervosa including assessment of cost-effectiveness and patient acceptability - the TOuCAN trial. Health Technol Assess. 2010 Mar;14(15):1–98. doi: 10.3310/hta14150. PMID: 20334748. Exclusion Code: X7.20334748
458 Graber JA, Brooks-Gunn J, Paikoff RL, . Prediction of eating problems: an 8-year study of adolescent girls. Dev Psychol. 1994;30(6):823–34. doi: 10.1037/0012-1649.30.6.823. PMID: 1995-10022-001. Exclusion Code: X7.
459 Graell M, de Andrés P, Sepúlveda AR, . The adolescent onset anorexia nervosa study (ANABEL): Design and baseline results. Int J Methods Psychiatr Res. 2018 Sep;27(3):e1739. doi: 10.1002/mpr.1739. PMID: 30133037. Exclusion Code: X9.30133037
460 Grammer AC, Tanofsky-Kraff M, Burke NL, . An examination of the associations between pediatric loss of control eating, anxiety, and body composition in children and adolescents. Eat Behav. 2018 Aug;30:109–14. doi: 10.1016/j.eatbeh.2018.06.007. PMID: 29990651. Exclusion Code: X7.29990651
461 Grange DL. Family-based treatment for adolescents with bulimia nervosa. ANZJFT Australian and New Zealand Journal of Family Therapy. 2010;31(2):165–75. doi: 10.1375/anft.31.2.165. PMID: 2010-12350-005. Exclusion Code: X12.
462 Green MA, Willis M, Fernandez-Kong K, . Dissonance-based eating disorder program reduces cardiac risk: A preliminary trial. Health Psychol. 2017 Apr;36(4):346–55. doi: 10.1037/hea0000438. PMID: 27808527. Exclusion Code: X14.27808527
463 Green MA, Willis M, Fernandez-Kong K, . A Controlled Randomized Preliminary Trial of a Modified Dissonance-Based Eating Disorder Intervention Program. J Clin Psychol. 2017 Dec;73(12):1612–28. doi: 10.1002/jclp.22468. PMID: 28249107. Exclusion Code: X14.28249107
464 Greeno CG, Marcus MD, Wing RR. Diagnosis of binge eating disorder: discrepancies between a questionnaire and clinical interview. Int J Eat Disord. 1995 Mar;17(2):153–60. doi: 10.1002/1098-108x(199503)17:2<153::aid-eat2260170208>3.0.co;2-v. PMID: 7757096. Exclusion Code: X4.7757096
465 Greeno CG, Wing RR. A double-blind, placebo-controlled trial of the effect of fluoxetine on dietary intake in overweight women with and without binge-eating disorder. Am J Clin Nutr. 1996 Sep;64(3):267–73. doi: 10.1093/ajcn/64.3.267. PMID: 8780333. Exclusion Code: X7.8780333
466 Gregorowski C, Seedat S, Jordaan GP. A clinical approach to the assessment and management of co-morbid eating disorders and substance use disorders. BMC Psychiatry. 2013;13doi: 10.1186/1471-244X-13-289. PMID: 2013-44289-001. Exclusion Code: X9.
467 Grilo C. Controlled comparison of stepped-care multi-modal treatment versus behavioral weight loss for binge eating disorder in patients with obesity. Obesity facts. 2017;10:15-. doi: 10.1159/000468958. PMID: CN-01766753. Exclusion Code: X13.
468 Grilo CM, Crosby RD, Wilson GT, . 12-month follow-up of fluoxetine and cognitive behavioral therapy for binge eating disorder. J Consult Clin Psychol. 2012 Dec;80(6):1108–13. doi: 10.1037/a0030061. PMID: 22985205. Exclusion Code: X7.22985205
469 Grilo CM, Lozano C, Elder KA. Inter-rater and test-retest reliability of the Spanish language version of the eating disorder examination interview: clinical and research implications. J Psychiatr Pract. 2005 Jul;11(4):231–40. doi: 10.1097/00131746-200507000-00003. PMID: 16041233. Exclusion Code: X9.16041233
470 Grilo CM, Masheb RM. A randomized controlled comparison of guided self-help cognitive behavioral therapy and behavioral weight loss for binge eating disorder. Behav Res Ther. 2005;43(11):1509–25. doi: 10.1016/j.brat.2004.11.010. PMID: 2005-14324-008. Exclusion Code: X7.16159592
471 Grilo CM, Masheb RM. Rapid response predicts binge eating and weight loss in binge eating disorder: Findings from a controlled trial of orlistat with guided self-help cognitive behavioral therapy. Behav Res Ther. 2007;45(11):2537–50. doi: 10.1016/j.brat.2007.05.010. PMID: 2007-15364-003. Exclusion Code: X7.17659254
472 Grilo CM, Masheb RM, Crosby RD. Predictors and moderators of response to cognitive behavioral therapy and medication for the treatment of binge eating disorder. J Consult Clin Psychol. 2012;80(5):897–906. doi: 10.1037/a0027001. PMID: 2012-02228-001. Exclusion Code: X7.22289130
473 Grilo CM, Masheb RM, Lozano-Blanco C, . Reliability of the Eating Disorder Examination in patients with binge eating disorder. Int J Eat Disord. 2004 Jan;35(1):80–5. doi: 10.1002/eat.10238. PMID: 14705160. Exclusion Code: X4.14705160
474 Grilo CM, Masheb RM, Salant SL. Cognitive behavioral therapy guided self-help and orlistat for the treatment of binge eating disorder: a randomized, double-blind, placebo-controlled trial. Biol Psychiatry. 2005 May 15;57(10):1193–201. doi: 10.1016/j.biopsych.2005.03.001. PMID: 15866560. Exclusion Code: X7.15866560
475 Grilo CM, Masheb RM, Wilson GT. A comparison of different methods for assessing the features of eating disorders in patients with binge eating disorder. J Consult Clin Psychol. 2001 Apr;69(2):317–22. doi: 10.1037//0022-006x.69.2.317. PMID: 11393608. Exclusion Code: X7.11393608
476 Grilo CM, Masheb RM, Wilson GT. Different methods for assessing the features of eating disorders in patients with binge eating disorder: a replication. Obes Res. 2001 Jul;9(7):418–22. doi: 10.1038/oby.2001.55. PMID: 11445665. Exclusion Code: X5.11445665
477 Grilo CM, Masheb RM, Wilson GT. Rapid response to treatment for binge eating disorder. J Consult Clin Psychol. 2006;74(3):602–13. doi: 10.1037/0022-006X.74.3.602. PMID: 2006-08433-019. Exclusion Code: X7.16822116
478 Grilo CM, Masheb RM, Wilson GT, . Cognitive-behavioral therapy, behavioral weight loss, and sequential treatment for obese patients with binge-eating disorder: a randomized controlled trial. J Consult Clin Psychol. 2011 Oct;79(5):675–85. doi: 10.1037/a0025049. PMID: 21859185. Exclusion Code: X7.21859185
479 Grilo CM, White MA. A controlled evaluation of the distress criterion for binge eating disorder. J Consult Clin Psychol. 2011;79(4):509–14. doi: 10.1037/a0024259. PMID: 2011-13213-001. Exclusion Code: X7.21707133
480 Grilo CM, White MA. Orlistat with behavioral weight loss for obesity with versus without binge eating disorder: Randomized placebo-controlled trial at a community mental health center serving educationally and economically disadvantaged Latino/as. Behav Res Ther. 2013;51(3):167–75. doi: 10.1016/j.brat.2013.01.002. PMID: 2013-04843-009. Exclusion Code: X7.23376451
481 Grilo CM, White MA, Masheb RM, . Predicting meaningful outcomes to medication and self-help treatments for binge-eating disorder in primary care: The significance of early rapid response. J Consult Clin Psychol. 2015;83(2):387–94. doi: 10.1037/a0038635. PMID: 2015-02674-001. Exclusion Code: X7.25622201
482 Grilo CM, White MA, Masheb RM, . Randomized controlled trial testing the effectiveness of adaptive ‘SMART’ stepped-care treatment for adults with binge-eating disorder comorbid with obesity. Am Psychol. 2020;75(2):204–18. doi: 10.1037/amp0000534. PMID: 2020-09435-007. Exclusion Code: X7.32052995
483 Grob S, Pizzagalli DA, Dutra SJ, . Dopamine-related deficit in reward learning after catecholamine depletion in unmedicated, remitted subjects with bulimia nervosa. Neuropsychopharmacology. 2012 Jul;37(8):1945–52. doi: 10.1038/npp.2012.41. PMID: 22491353. Exclusion Code: X3.22491353
484 Groesz LM, Stice E. An experimental test of the effects of dieting on bulimic symptoms: The impact of eating episode frequency. Behav Res Ther. 2007;45(1):49–62. doi: 10.1016/j.brat.2006.01.010. PMID: 2006-21165-005. Exclusion Code: X3.16529712
485 Groff Stephens S, Wilke DJ. Sexual violence, weight perception, and eating disorder indicators in college females. J Am Coll Health. 2016;64(1):38–47. doi: 10.1080/07448481.2015.1074237. PMID: 26502797. Exclusion Code: X9.26502797
486 Gross H, Ebert MH, Faden VB. A double blind trial of Deltasup 9-tetrahydrocannabinol in primary anorexia nervosa. J Clin Psychopharmacol. 1983;3(3):165–71. PMID: CN-00187354. Exclusion Code: X5.6308069
487 Gross H, Ebert MH, Faden VB, . A double-blind trial of delta 9-tetrahydrocannabinol in primary anorexia nervosa. J Clin Psychopharmacol. 1983 Jun;3(3):165–71. PMID: 6308069. Exclusion Code: X3.6308069
488 Gross HA, Ebert MH, Faden VB. A double-blind controlled trial of lithium carbonate in primary anorexia nervosa. J Clin Psychopharmacol. 1981;1(6):376–81. PMID: CN-00190593. Exclusion Code: X3.6801096
489 Gross HA, Ebert MH, Faden VB, . A double-blind controlled trial of lithium carbonate primary anorexia nervosa. J Clin Psychopharmacol. 1981 Nov;1(6):376–81. doi: 10.1097/00004714-198111000-00005. PMID: 6801096. Exclusion Code: X7.6801096
490 Grover M, Naumann U, Mohammad-Dar L, . A randomized controlled trial of an Internet-based cognitive-behavioural skills package for carers of people with anorexia nervosa. Psychol Med. 2011 Dec;41(12):2581–91. doi: 10.1017/s0033291711000766. PMID: 21733215. Exclusion Code: X3.21733215
491 Gualandi M, Simoni M, Manzato E, . Reassessment of patients with Eating Disorders after moving from DSM-IV towards DSM-5: a retrospective study in a clinical sample. Eat Weight Disord. 2016 Dec;21(4):617–24. doi: 10.1007/s40519-016-0314-4. PMID: 27573908. Exclusion Code: X4.27573908
492 Guerdjikova AI, Blom TJ, Mori N, . N-acetylcysteine in bulimia nervosa-open-label trial. Eat Behav. 2013 Jan;14(1):87–9. doi: 10.1016/j.eatbeh.2012.11.001. PMID: 23265409. Exclusion Code: X7.23265409
493 Guerdjikova AI, McElroy SL, Welge JA, . Lamotrigine in the treatment of binge-eating disorder with obesity: a randomized, placebo-controlled monotherapy trial. Int Clin Psychopharmacol. 2009 May;24(3):150–8. doi: 10.1097/YIC.0b013e328329c7b5. PMID: 19357528. Exclusion Code: X14.19357528
494 Guerdjikova AI, Walsh B, Shan K, . Concurrent Improvement in Both Binge Eating and Depressive Symptoms with Naltrexone/Bupropion Therapy in Overweight or Obese Subjects with Major Depressive Disorder in an Open-Label, Uncontrolled Study. Adv Ther. 2017 Oct;34(10):2307–15. doi: 10.1007/s12325-017-0613-9. PMID: 28918581. Exclusion Code: X7.28918581
495 Guest T. Using the eating disorder examination in the assessment of bulimia and anorexia: issues of reliability and validity. Soc Work Health Care. 2000;31(4):71–83. doi: 10.1300/J010v31n04_05. PMID: 2000-12746-005. Exclusion Code: X7.11140344
496 Gulec H, Moessner M, Túry F, . A randomized controlled trial of an internet-based posttreatment care for patients with eating disorders. Telemed J E Health. 2014 Oct;20(10):916–22. doi: 10.1089/tmj.2013.0353. PMID: 25188398. Exclusion Code: X3.25188398
497 Gumz A, Weigel A, Daubmann A, . Efficacy of a prevention program for eating disorders in schools: A cluster-randomized controlled trial. BMC Psychiatry. 2017;17 PMID: 2017-35191-001. Exclusion Code: X5.
498 Hach I, Ruhl UE, Rentsch A, . Recognition and therapy of eating disorders in young women in primary care. J Public Health. 2005;13(3):160–5. doi: 10.1007/s10389-005-0102-5. PMID: 2006-01586-006. Exclusion Code: X7.
499 Hagman J, Gralla J, Sigel E, . A double-blind, placebo-controlled study of risperidone for the treatment of adolescents and young adults with anorexia nervosa: a pilot study. J Am Acad Child Adolesc Psychiatry. 2011 Sep;50(9):915–24. doi: 10.1016/j.jaac.2011.06.009. PMID: 21871373. Exclusion Code: X3.21871373
500 Haines J, Ziyadeh NJ, Franko DL, . Screening high school students for eating disorders: validity of brief behavioral and attitudinal measures. J Sch Health. 2011 Sep;81(9):530–5. doi: 10.1111/j.1746-1561.2011.00623.x. PMID: 21831065. Exclusion Code: X7.21831065
501 Halford JCG, Boyland EJ, Cooper SJ, . The effects of sibutramine on the microstructure of eating behaviour and energy expenditure in obese women. Journal of Psychopharmacology. 2010;24(1):99–109. doi: 10.1177/0269881108095195. PMID: 2010-02773-010. Exclusion Code: X2.18755818
502 Hall A, Crisp AH. Brief psychotherapy in the treatment of anorexia nervosa. Outcome at one year. Br J Psychiatry. 1987 Aug;151:185–91. doi: 10.1192/bjp.151.2.185. PMID: 3690108. Exclusion Code: X3.3690108
503 Halmi KA, Eckert E, LaDu TJ, . Anorexia nervosa. Treatment efficacy of cyproheptadine and amitriptyline. Arch Gen Psychiatry. 1986 Feb;43(2):177–81. doi: 10.1001/archpsyc.1986.01800020087011. PMID: 3511877. Exclusion Code: X8.3511877
504 Halvorsen I, Andersen A, Heyerdahl S. Good outcome of adolescent onset anorexia nervosa after systematic treatment. Intermediate to long-term follow-up of a representative county-sample. Eur Child Adolesc Psychiatry. 2004 Oct;13(5):295–306. doi: 10.1007/s00787-004-0408-9. PMID: 15490277. Exclusion Code: X9.15490277
505 Harden KP, Mendle J, Kretsch N. Environmental and genetic pathways between early pubertal timing and dieting in adolescence: distinguishing between objective and subjective timing. Psychol Med. 2012 Jan;42(1):183–93. doi: 10.1017/s0033291711000961. PMID: 21676282. Exclusion Code: X7.21676282
506 Harper J, Leung M, Birmingham CL. A blinded laxative taper for patients with eating disorders. Eat Weight Disord. 2004 Jun;9(2):147–50. doi: 10.1007/bf03325059. PMID: 15330083. Exclusion Code: X5.15330083
507 Hartmann A, Orlinsky D, Weber S, . Session and intersession experience related to treatment outcome in bulimia nervosa. Psychotherapy (Chic). 2010 Sep;47(3):355–70. doi: 10.1037/a0021166. PMID: 22402092. Exclusion Code: X3.22402092
508 Hartmann A, Zeeck A, Herzog W, . The intersession process in psychotherapy for anorexia nervosa: characteristics and relation to outcome. J Clin Psychol. 2016 Sep;72(9):861–79. doi: 10.1002/jclp.22293. PMID: 27199179. Exclusion Code: X7.27199179
509 Hartmann C, Siegrist M. Development and validation of the Food Disgust Scale. Food Qual Prefer. 2018;63:38–50. doi: 10.1016/j.foodqual.2017.07.013. PMID: 2017-43139-007. Exclusion Code: X4.
510 Hasler WL. 5-HT(3) antagonist therapy of bulimia nervosa: a peripherally active agent for a central nervous system eating disorder? Gastroenterology. 2000 Jul;119(1):271–2. doi: 10.1016/s0016-5085(00)70064-3. PMID: 10889184. Exclusion Code: X7.10889184
511 Hautala L, Junnila J, Helenius H, . Adolescents with fluctuating symptoms of eating disorders: a 1-year prospective study. J Adv Nurs. 2008 Jun;62(6):674–80. doi: 10.1111/j.1365-2648.2008.04697.x. PMID: 18503651. Exclusion Code: X7.18503651
512 Hautala LA, Junnila J, Helenius H, . Towards understanding gender differences in disordered eating among adolescents. J Clin Nurs. 2008 Jul;17(13):1803–13. doi: 10.1111/j.1365-2702.2007.02143.x. PMID: 18592628. Exclusion Code: X7.18592628
513 Hay P, Bacaltchuk J, Claudino A, . Individual psychotherapy in the outpatient treatment of adults with anorexia nervosa. Cochrane Database Syst Rev. 2003(4):Cd003909. doi: 10.1002/14651858.cd003909. PMID: 14583998. Exclusion Code: X9.14583998
514 Hay P, Mond J, Paxton S, . What are the effects of providing evidence-based information on eating disorders and their treatments? A randomized controlled trial in a symptomatic community sample. Early Interv Psychiatry. 2007 Nov;1(4):316–24. doi: 10.1111/j.1751-7893.2007.00044.x. PMID: 21352119. Exclusion Code: X5.21352119
515 Hay P, Touyz S, Arcelus J, . A randomized controlled trial of the compuLsive Exercise Activity TheraPy (LEAP): A new approach to compulsive exercise in anorexia nervosa. Int J Eat Disord. 2018 Aug;51(8):999–1004. doi: 10.1002/eat.22920. PMID: 30051623. Exclusion Code: X7.30051623
516 Haynos AF, Pearson CM, Utzinger LM, . Empirically derived personality subtyping for predicting clinical symptoms and treatment response in bulimia nervosa. Int J Eat Disord. 2017 May;50(5):506–14. doi: 10.1002/eat.22622. PMID: 27611235. Exclusion Code: X7.27611235
517 He J, Ma H, Barthels F, . Psychometric properties of the Chinese version of the Düsseldorf Orthorexia Scale: prevalence and demographic correlates of orthorexia nervosa among Chinese university students. Eat Weight Disord. 2019 Jun;24(3):453–63. doi: 10.1007/s40519-019-00656-1. PMID: 30796740. Exclusion Code: X3.30796740
518 Heatherton TF, Nichols P, Mahamedi F, . Body weight, dieting, and eating disorder symptoms among college students, 1982 to 1992. Am J Psychiatry. 1995 Nov;152(11):1623–9. doi: 10.1176/ajp.152.11.1623. PMID: 7485625. Exclusion Code: X7.7485625
519 Hedges DW, Reimherr FW, Hoopes SP, . Treatment of bulimia nervosa with topiramate in a randomized, double-blind, placebo-controlled trial, part 2: improvement in psychiatric measures. J Clin Psychiatry. 2003 Dec;64(12):1449–54. doi: 10.4088/jcp.v64n1208. PMID: 14728106. Exclusion Code: X14.14728106
520 Heinberg LJ, Coughlin JW, Pinto AM, . Validation and predictive utility of the Sociocultural Attitudes Toward Appearance Questionnaire for Eating Disorders (SATAQ-ED): internalization of sociocultural ideals predicts weight gain. Body Image. 2008 Sep;5(3):279–90. doi: 10.1016/j.bodyim.2008.02.001. PMID: 18640081. Exclusion Code: X3.18640081
521 Heinberg LJ, Thompson JK, Stormer S. Development and validation of the Sociocultural Attitudes Towards Appearance Questionnaire. Int J Eat Disord. 1995 Jan;17(1):81–9. doi: 10.1002/1098-108x(199501)17:1<81::aid-eat2260170111>3.0.co;2-y. PMID: 7894457. Exclusion Code: X4.7894457
522 Heinicke BE, Paxton SJ, McLean SA, . Internet-delivered targeted group intervention for body dissatisfaction and disordered eating in adolescent girls: a randomized controlled trial. J Abnorm Child Psychol. 2007 Jun;35(3):379–91. doi: 10.1007/s10802-006-9097-9. PMID: 17243014. Exclusion Code: X3.17243014
523 Herbrich L, van Noort B, Pfeiffer E, . Follow-up Assessment of Cognitive Remediation Therapy in Adolescent Anorexia Nervosa: A Pilot Study. Eur Eat Disord Rev. 2017 Mar;25(2):104–13. doi: 10.1002/erv.2501. PMID: 28217880. Exclusion Code: X7.28217880
524 Herman BK, Deal LS, Di Benedetti DB, . The use and value of the 7-Item Binge Eating Disorder Screener in clinical practice. CNS Spectr. 2017;22(1):107–8. doi: 10.1017/S1092852916000900. PMID: CN-01429999. Exclusion Code: X13.
525 Herman BK, Deal LS, DiBenedetti DB, . Development of the 7-Item Binge-Eating Disorder Screener (BEDS-7). Prim Care Companion CNS Disord. 2016;18(2)doi: 10.4088/PCC.15m01896. PMID: 27486542. Exclusion Code: X9.27486542
526 Herpertz-Dahlmann B, Dempfle A, Konrad K, . Eating disorder symptoms do not just disappear: the implications of adolescent eating-disordered behaviour for body weight and mental health in young adulthood. Eur Child Adolesc Psychiatry. 2015 Jun;24(6):675–84. doi: 10.1007/s00787-014-0610-3. PMID: 25209691. Exclusion Code: X7.25209691
527 Herscovici CR, Kovalskys I, Orellana L. An Exploratory Evaluation of the Family Meal Intervention for Adolescent Anorexia Nervosa. Fam Process. 2017 Jun;56(2):364–75. doi: 10.1111/famp.12199. PMID: 26596997. Exclusion Code: X7.26596997
528 Herzog DB, Field AE, Keller MB, . Subtyping eating disorders: is it justified? J Am Acad Child Adolesc Psychiatry. 1996 Jul;35(7):928–36. doi: 10.1097/00004583-199607000-00020. PMID: 8768354. Exclusion Code: X5.8768354
529 Herzog DB, Hopkins JD, Burns CD. A follow-up study of 33 subdiagnostic eating disordered women. Int J Eat Disord. 1993 Nov;14(3):261–7. doi: 10.1002/1098-108x(199311)14:3<261::aid-eat2260140304>3.0.co;2-n. PMID: 8275062. Exclusion Code: X7.8275062
530 Hilbert A. Cognitive-behavioral therapy for binge eating disorder in adolescents: study protocol for a randomized controlled trial. Trials. 2013 Sep 25;14:312. doi: 10.1186/1745-6215-14-312. PMID: 24066704. Exclusion Code: X7.24066704
531 Hilbert A, Buerger A, Hartmann AS, . Psychometric evaluation of the eating disorder examination adapted for children. Eur Eat Disord Rev. 2013 Jul;21(4):330–9. doi: 10.1002/erv.2221. PMID: 23456853. Exclusion Code: X9.23456853
532 Hilbert A, Herpertz S, Zipfel S, . Early Change Trajectories in Cognitive-Behavioral Therapy for Binge-Eating Disorder. Behav Ther. 2019 Jan;50(1):115–25. doi: 10.1016/j.beth.2018.03.013. PMID: 30661552. Exclusion Code: X7.30661552
533 Hilbert A, Saelens BE, Stein RI, . Pretreatment and process predictors of outcome in interpersonal and cognitive behavioral psychotherapy for binge eating disorder. J Consult Clin Psychol. 2007;75(4):645–51. doi: 10.1037/0022-006X.75.4.645. PMID: 2007-11558-013. Exclusion Code: X7.17663618
534 Hildebrandt T, Loeb K, Troupe S, . Adjunctive mirror exposure for eating disorders: a randomized controlled pilot study. Behav Res Ther. 2012 Dec;50(12):797–804. doi: 10.1016/j.brat.2012.09.004. PMID: 23089085. Exclusion Code: X7.23089085
535 Hildebrandt T, Michaeledes A, Mayhew M, . Randomized controlled trial comparing health coach-delivered smartphone-guided self-help with standard care for adults with binge eating. The American Journal of Psychiatry. 2020;177(2):134–42. doi: 10.1176/appi.ajp.2019.19020184. PMID: 2020-09861-004. Exclusion Code: X7.32008396
536 Hillen S, Dempfle A, Seitz J, . Motivation to change and perceptions of the admission process with respect to outcome in adolescent anorexia nervosa. BMC Psychiatry. 2015 Jul 2;15:140. doi: 10.1186/s12888-015-0516-8. PMID: 26134628. Exclusion Code: X8.26134628
537 Hobbs M, Birtchnell S, Harte A, . Therapeutic factors in short-term group therapy for women with bulimia. Int J Eat Disord. 1989;8(6):623–33. doi: 10.1002/1098-108X(198911)8:6<623::AID-EAT2260080603>3.0.CO;2-X. PMID: 1990-10415-001. Exclusion Code: X7.
538 Hochkogler CM, Liszt K, Lieder B, . Appetite-Inducing Effects of Homoeriodictyol: Two Randomized, Cross-Over Interventions. Mol Nutr Food Res. 2017 Dec;61(12)doi: 10.1002/mnfr.201700459. PMID: 28834253. Exclusion Code: X3.28834253
539 Hodsoll J, Rhind C, Micali N, . A Pilot, Multicentre Pragmatic Randomised Trial to Explore the Impact of Carer Skills Training on Carer and Patient Behaviours: Testing the Cognitive Interpersonal Model in Adolescent Anorexia Nervosa. Eur Eat Disord Rev. 2017 Nov;25(6):551–61. doi: 10.1002/erv.2540. PMID: 28948663. Exclusion Code: X7.28948663
540 Hofer M, Pozzi A, Joray M, . Safe refeeding management of anorexia nervosa inpatients: an evidence-based protocol. Nutrition. 2014 May;30(5):524–30. doi: 10.1016/j.nut.2013.09.019. PMID: 24698345. Exclusion Code: X3.24698345
541 Hogdahl L, Levallius J, Bjorck C, . Personality predicts drop-out from therapist-guided internet-based cognitive behavioural therapy for eating disorders. Results from a randomized controlled trial. Internet interventions. 2016;5:44–50. doi: 10.1016/j.invent.2016.07.002. PMID: CN-01197547. Exclusion Code: X7.30135806
542 Holland LA, Brown TA, Keel PK. Defining features of unhealthy exercise associated with disordered eating and eating disorder diagnoses. Psychol Sport Exerc. 2014 Jan 1;15(1)doi: 10.1016/j.psychsport.2013.10.005. PMID: 24391457. Exclusion Code: X7.24391457
543 Holtkamp K, Konrad K, Kaiser N, . A retrospective study of SSRI treatment in adolescent anorexia nervosa: insufficient evidence for efficacy. J Psychiatr Res. 2005 May;39(3):303–10. doi: 10.1016/j.jpsychires.2004.08.001. PMID: 15725429. Exclusion Code: X8.15725429
544 Homan KJ, Sim LA, Crowley SL, . Medical Assessment and Triage of Pediatric Patients with Anorexia Nervosa in Primary Care. J Dev Behav Pediatr. 2019 Feb/Mar;40(2):92–8. doi: 10.1097/dbp.0000000000000629. PMID: 30747833. Exclusion Code: X9.30747833
545 Homan P, Grob S, Milos G, . The role of BDNF, leptin, and catecholamines in reward learning in bulimia nervosa. Int J Neuropsychopharmacol. 2014 Dec 7;18(5)doi: 10.1093/ijnp/pyu092. PMID: 25522424. Exclusion Code: X3.25522424
546 Hoopes SP, Reimherr FW, Hedges DW, . Treatment of bulimia nervosa with topiramate in a randomized, double-blind, placebo-controlled trial, part 1: improvement in binge and purge measures. J Clin Psychiatry. 2003 Nov;64(11):1335–41. doi: 10.4088/jcp.v64n1109. PMID: 14658948. Exclusion Code: X14.14658948
547 Hopwood CJ, Nye CD, Blomquist KK, . Confirmatory validation and measurement equivalence of the Eating Loss of Control Scale in binge eating and non-clinical samples. J Psychopathol Behav Assess. 2018;40(3):476–83. doi: 10.1007/s10862-018-9643-0. PMID: 2018-02950-001. Exclusion Code: X7.
548 Hormes JM, Meule A. Psychometric properties of the English Food Cravings Questionnaire-Trait-reduced (FCQ-T-r). Eat Behav. 2016 Jan;20:34–8. doi: 10.1016/j.eatbeh.2015.11.011. PMID: 26609669. Exclusion Code: X4.26609669
549 Horne RL, Ferguson JM, Pope HG, Jr., . Treatment of bulimia with bupropion: a multicenter controlled trial. J Clin Psychiatry. 1988 Jul;49(7):262–6. PMID: 3134343. Exclusion Code: X14.3134343
550 Horney AC. The impact of a dissonance-based prevention program on eating disorder developmental trajectories: ProQuest Information & Learning; 2017. Exclusion Code: X9.
551 Hoste RR, Hewell K, le Grange D. Family interaction among White and ethnic minority adolescents with bulimia nervosa and their parents. Eur Eat Disord Rev. 2007;15(2):152–8. doi: 10.1002/erv.743. PMID: 2007-04866-008. Exclusion Code: X7.17676684
552 Hötzel K, von Brachel R, Schmidt U, . An Internet-based program to enhance motivation to change in females with symptoms of an eating disorder: a randomized controlled trial. Psychol Med. 2014 Jul;44(9):1947–63. doi: 10.1017/s0033291713002481. PMID: 24128818. Exclusion Code: X10.24128818
553 Hoyle D, Slater J, Williams C, . Evaluation of a web-based skills intervention for carers of people with anorexia nervosa: a randomized controlled trial. Int J Eat Disord. 2013 Sep;46(6):634–8. doi: 10.1002/eat.22144. PMID: 23712500. Exclusion Code: X7.23712500
554 Hsu LK, Clement L, Santhouse R, . Treatment of bulimia nervosa with lithium carbonate. A controlled study. J Nerv Ment Dis. 1991 Jun;179(6):351–5. doi: 10.1097/00005053-199106000-00008. PMID: 1904908. Exclusion Code: X3.1904908
555 Hsu LK, Rand W, Sullivan S, . Cognitive therapy, nutritional therapy and their combination in the treatment of bulimia nervosa. Psychol Med. 2001 Jul;31(5):871–9. doi: 10.1017/s003329170100410x. PMID: 11459384. Exclusion Code: X7.11459384
556 Hudson J, McElroy S, Ferreira-Cornwell C, . A double-blind, placebo-controlled, randomized-withdrawal study of lisdexamfetamine dimesylate in adults with moderate to severe binge eating disorder. Neuropsychopharmacology. 2015;40:S135–S6. doi: 10.1038/npp.2015.325. PMID: CN-01163275. Exclusion Code: X7.
557 Hudson J, McElroy S, Ferreira-Cornwell MC, . A double-blind, placebo-controlled, randomizedwithdrawal study of lisdexamfetamine dimesylate in adults with moderate to severe binge eating disorder. CNS Spectr. 2017;22(1):108–9. doi: 10.1017/S1092852916000900. PMID: CN-01429998. Exclusion Code: X13.
558 Hudson JI, McElroy SL, Ferreira-Cornwell MC, . Efficacy of Lisdexamfetamine in Adults With Moderate to Severe Binge-Eating Disorder: A Randomized Clinical Trial. JAMA Psychiatry. 2017 Sep 1;74(9):903–10. doi: 10.1001/jamapsychiatry.2017.1889. PMID: 28700805. Exclusion Code: X3.28700805
559 Hudson JI, McElroy SL, Raymond NC, . Fluvoxamine in the treatment of binge-eating disorder: a multicenter placebo-controlled, double-blind trial. Am J Psychiatry. 1998 Dec;155(12):1756–62. doi: 10.1176/ajp.155.12.1756. PMID: 9842788. Exclusion Code: X14.9842788
560 Hudson JI, Pope HG, Jr., Jonas JM. Treatment of bulimia with antidepressants: theoretical considerations and clinical findings. Res Publ Assoc Res Nerv Ment Dis. 1984;62:259–73. PMID: 6420851. Exclusion Code: X3.6420851
561 Hudson JI, Pope HG, Jr., Keck PE, Jr., . Treatment of bulimia nervosa with trazodone: short-term response and long-term follow-up. Clin Neuropharmacol. 1989;12 Suppl 1:S38–46; Discussion S7-9. doi: 10.1097/00002826-198901001-00007. PMID: 2663152. Exclusion Code: X9.2663152
562 Hughes EK, Kerr JA, Patton GC, . Eating disorder symptoms across the weight spectrum in Australian adolescents. Int J Eat Disord. 2019 Aug;52(8):885–94. doi: 10.1002/eat.23118. PMID: 31215675. Exclusion Code: X9.31215675
563 Hughes EK, Le Grange D, Court A, . Parent-focused treatment for adolescent anorexia nervosa: a study protocol of a randomised controlled trial. BMC Psychiatry. 2014 Apr 8;14:105. doi: 10.1186/1471-244x-14-105. PMID: 24712855. Exclusion Code: X7.24712855
564 Hughes PL, Wells LA, Cunningham CJ, . Treating bulimia with desipramine. A double-blind, placebo-controlled study. Arch Gen Psychiatry. 1986 Feb;43(2):182–6. doi: 10.1001/archpsyc.1986.01800020092012. PMID: 3511878. Exclusion Code: X14.3511878
565 Hurley JB, Palmer RL, Stretch D. The specificity of the Eating Disorders Inventory: A reappraisal. Int J Eat Disord. 1990;9(4):419–24. doi: 10.1002/1098-108X(199007)9:4<419::AID-EAT2260090408>3.0.CO;2-O. PMID: 1990-29850-001. Exclusion Code: X4.
566 Hurst K, Zimmer-Gembeck M. Family-based treatment with cognitive behavioural therapy for anorexia. Clin Psychol. 2019;23(1):61–70. doi: 10.1111/cp.12152. PMID: 2018-18024-001. Exclusion Code: X7.
567 Imperatori C, Fabbricatore M, Lester D, . Psychometric properties of the modified Yale Food Addiction Scale Version 2.0 in an Italian non-clinical sample. Eat Weight Disord. 2019 Feb;24(1):37–45. doi: 10.1007/s40519-018-0607-x. PMID: 30414076. Exclusion Code: X4.30414076
568 Imperatori C, Innamorati M, Lamis DA, . Factor structure of the binge eating scale in a large sample of obese and overweight patients attending low energy diet therapy. Eur Eat Disord Rev. 2016 Mar;24(2):174–8. doi: 10.1002/erv.2384. PMID: 26147590. Exclusion Code: X7.26147590
569 Innamorati M, Imperatori C, Balsamo M, . Food Cravings Questionnaire-Trait (FCQ-T) discriminates between obese and overweight patients with and without binge eating tendencies: the Italian version of the FCQ-T. J Pers Assess. 2014;96(6):632–9. doi: 10.1080/00223891.2014.909449. PMID: 24793741. Exclusion Code: X7.24793741
570 Innamorati M, Imperatori C, Lester D, . Preliminary validation of the Italian Night Eating Questionnaire (I-NEQ-16): Item analysis and factor structure. Front Psychol. 2018;9doi: 10.3389/fpsyg.2018.02628. PMID: 2019-00345-001. Exclusion Code: X4.
571 Innamorati M, Imperatori C, Manzoni GM, . Psychometric properties of the Italian Yale Food Addiction Scale in overweight and obese patients. Eat Weight Disord. 2015 Mar;20(1):119–27. doi: 10.1007/s40519-014-0142-3. PMID: 25069837. Exclusion Code: X4.25069837
572 Iorio D, Margiotta N, D’Orsi P, . The Eating Disorder Inventory in evaluation of impaired eating behaviour in subjects requesting nutritional consultation. Eat Weight Disord. 2000 Dec;5(4):206–10. doi: 10.1007/bf03354447. PMID: 11216128. Exclusion Code: X4.11216128
573 Isomaa R, Lukkarila IL, Ollila T, . Development and preliminary validation of a Finnish version of the Eating Disorder Examination Questionnaire (EDE-Q). Nord J Psychiatry. 2016 Oct;70(7):542–6. doi: 10.1080/08039488.2016.1179340. PMID: 27152496. Exclusion Code: X4.27152496
574 Jackson JB, Pietrabissa G, Rossi A, . Brief strategic therapy and cognitive behavioral therapy for women with binge eating disorder and comorbid obesity: A randomized clinical trial one-year follow-up. J Consult Clin Psychol. 2018 Aug;86(8):688–701. doi: 10.1037/ccp0000313. PMID: 30035585. Exclusion Code: X7.30035585
575 Jackson T, Chen H. Identifying the eating disorder symptomatic in China: the role of sociocultural factors and culturally defined appearance concerns. J Psychosom Res. 2007 Feb;62(2):241–9. doi: 10.1016/j.jpsychores.2006.09.010. PMID: 17270583. Exclusion Code: X7.17270583
576 Jacobi C, Abascal L, Taylor CB. Screening for Eating Disorders and High-Risk Behavior: Caution. Int J Eat Disord. 2004;36(3):280–95. doi: 10.1002/eat.20048. PMID: 2004-20251-005. Exclusion Code: X9.15478137
577 Jacobi C, Hütter K, Völker U, . Efficacy of a Parent-Based, Indicated Prevention for Anorexia Nervosa: Randomized Controlled Trial. J Med Internet Res. 2018 Dec 14;20(12):e296. doi: 10.2196/jmir.9464. PMID: 30552078. Exclusion Code: X5.30552078
578 Jacobi C, Morris L, Beckers C, . Maintenance of internet-based prevention: a randomized controlled trial. Int J Eat Disord. 2007 Mar;40(2):114–9. doi: 10.1002/eat.20344. PMID: 17080447. Exclusion Code: X3.17080447
579 Jacobi C, Völker U, Trockel MT, . Effects of an Internet-based intervention for subthreshold eating disorders: a randomized controlled trial. Behav Res Ther. 2012 Feb;50(2):93–9. doi: 10.1016/j.brat.2011.09.013. PMID: 22137366. Exclusion Code: X14.22137366
580 Jankauskiene R, Baceviciene M. Body image and disturbed eating attitudes and behaviors in sport-involved adolescents: the role of gender and sport characteristics. Nutrients. 2019 Dec 14;11(12)doi: 10.3390/nu11123061. PMID: 31847410. Exclusion Code: X7.31847410
581 Jansen A, Nederkoorn C, Roefs A, . The proof of the pudding is in the eating: Is the DEBQ - External Eating Scale a valid measure of external eating? Int J Eat Disord. 2011;44(2):164–8. PMID: 2011-03922-009. Exclusion Code: X9.20127941
582 Järvelä-Reijonen E, Karhunen L, Sairanen E, . The effects of acceptance and commitment therapy on eating behavior and diet delivered through face-to-face contact and a mobile app: A randomized controlled trial. Int J Behav Nutr Phys Act. 2018;15 PMID: 2018-08735-001. Exclusion Code: X7.
583 Jáuregui I, Perez-Lancho C, Gomez-Capitan MJ, . Psychometric properties of the Spanish version of the Eating Behaviours and Body Image Test for Preadolescent Girls (EBBIT). Eat Weight Disord. 2009 Mar;14(1):e22–8. doi: 10.1007/bf03354624. PMID: 19367133. Exclusion Code: X7.19367133
584 Jáuregui Lobera I, Bolaños P, Carbonero R, . Psychometric properties of the Spanish version of Food Craving Inventory (FCI-SP). Nutr Hosp. 2010 Nov–Dec;25(6):984–92. PMID: 21519770. Exclusion Code: X4.21519770
585 Jáuregui Lobera I, Santed MA, Shafran R, . Psychometric properties of the Spanish version of the Thougth-Shape Fusion Questionnaire. Span J Psychol. 2012 Mar;15(1):410–23. doi: 10.5209/rev_sjop.2012.v15.n1.37347. PMID: 22379730. Exclusion Code: X3.22379730
586 Jáuregui-Lobera I, García-Cruz P, Carbonero-Carreño R, . Psychometric properties of Spanish version of the Three-Factor Eating Questionnaire-R18 (Tfeq-Sp) and its relationship with some eating- and body image-related variables. Nutrients. 2014 Dec 4;6(12):5619–35. doi: 10.3390/nu6125619. PMID: 25486370. Exclusion Code: X7.25486370
587 Jenkins PE. Psychometric validation of the Clinical Impairment Assessment in a UK eating disorder service. Eat Behav. 2013 Apr;14(2):241–3. doi: 10.1016/j.eatbeh.2012.12.001. PMID: 23557830. Exclusion Code: X4.23557830
588 Jenkins PE, Luck A, Burrows A, . Comparison of face-to-face versus email guided self-help for binge eating: study protocol for a randomised controlled trial. Trials. 2014;15:181. doi: 10.1186/1745-6215-15-181. PMID: CN-01116201. Exclusion Code: X7.24886555
589 Johnson WG, Kirk AA, Reed AE. Adolescent version of the questionnaire of eating and weight patterns: reliability and gender differences. Int J Eat Disord. 2001 Jan;29(1):94–6. doi: 10.1002/1098-108x(200101)29:1<94::aid-eat16>3.0.co;2-8. PMID: 11135341. Exclusion Code: X7.11135341
590 Johnston J, Shu CY, Hoiles KJ, . Perfectionism is associated with higher eating disorder symptoms and lower remission in children and adolescents diagnosed with eating disorders. Eat Behav. 2018 Aug;30:55–60. doi: 10.1016/j.eatbeh.2018.05.008. PMID: 29803120. Exclusion Code: X9.29803120
591 Johnston O, Fornai G, Cabrini S, . Feasibility and acceptability of screening for eating disorders in primary care. Fam Pract. 2007 Oct;24(5):511–7. doi: 10.1093/fampra/cmm029. PMID: 17591604. Exclusion Code: X7.17591604
592 Joiner TE, Jr., Heatherton TF, Keel PK. Ten-year stability and predictive validity of five bulimia-related indicators. Am J Psychiatry. 1997 Aug;154(8):1133–8. doi: 10.1176/ajp.154.8.1133. PMID: 9247401. Exclusion Code: X7.9247401
593 Joja O, Goldstein R, Popa M. Vasotocin effects in depressive patients with eating disorders. Rom J Endocrinol. 1993;31(3–4):171–7. PMID: 7697065. Exclusion Code: X3.7697065
594 Jones M, Luce KH, Osborne MI, . Randomized, controlled trial of an Internet-facilitated intervention for reducing binge eating and overweight in adolescents. Pediatrics. 2008;121(3):453–62. doi: 10.1542/peds.2007-1173. PMID: 2008-03157-001. Exclusion Code: X3.18310192
595 Jongenelis MI, Byrne SM, Pettigrew S, . A psychometric examination of a modified eight-item version of the children’s eating disorder examination. Psychol Assess. 2014 Mar;26(1):267–76. doi: 10.1037/a0034803. PMID: 24188154. Exclusion Code: X3.24188154
596 Jospe MR, Brown RC, Williams SM, . Self-monitoring has no adverse effect on disordered eating in adults seeking treatment for obesity. Obesity science and practice. 2018;4(3):283–8. doi: 10.1002/osp4.168. PMID: CN-01611420. Exclusion Code: X5.29951219
597 Junne F, Wild B, Resmark G, . The importance of body image disturbances for the outcome of outpatient psychotherapy in patients with anorexia nervosa: Results of the antop-study. Eur Eat Disord Rev. 2018doi: 10.1002/erv.2623. PMID: 2018-35109-001. Exclusion Code: X9.
598 Kafantaris V, Leigh E, Hertz S, . A placebo-controlled pilot study of adjunctive olanzapine for adolescents with anorexia nervosa. J Child Adolesc Psychopharmacol. 2011 Jun;21(3):207–12. doi: 10.1089/cap.2010.0139. PMID: 21663423. Exclusion Code: X7.21663423
599 Kalman D, Cascarano H, Krieger DR, . Frequency of binge eating disorder in an outpatient weight loss clinic. J Am Diet Assoc. 2002 May;102(5):697–9. doi: 10.1016/s0002-8223(02)90158-6. PMID: 12008996. Exclusion Code: X9.12008996
600 Kang Q, Chan RCK, Li X, . Psychometric Properties of the Chinese Version of the Eating Attitudes Test in Young Female Patients with Eating Disorders in Mainland China. Eur Eat Disord Rev. 2017 Nov;25(6):613–7. doi: 10.1002/erv.2560. PMID: 28994215. Exclusion Code: X3.28994215
601 Kaplan AS, Garfinkel PE, Darby PL, . Carbamazepine in the treatment of bulimia. Am J Psychiatry. 1983 Sep;140(9):1225–6. doi: 10.1176/ajp.140.9.1225. PMID: 6577802. Exclusion Code: X3.6577802
602 Karlson KA, Becker CB, Merkur A. Prevalence of eating disordered behavior in collegiate lightweight women rowers and distance runners. Clin J Sport Med. 2001 Jan;11(1):32–7. doi: 10.1097/00042752-200101000-00006. PMID: 11176143. Exclusion Code: X7.11176143
603 Karlsson GP, Clinton D, Nevonen L. Prediction of weight increase in anorexia nervosa. Nord J Psychiatry. 2013 Dec;67(6):424–32. doi: 10.3109/08039488.2012.754051. PMID: 23301630. Exclusion Code: X5.23301630
604 Kass AE, Theim Hurst K, Kolko RP, . Psychometric evaluation of the youth eating disorder examination questionnaire in children with overweight or obesity. Int J Eat Disord. 2017 Jul;50(7):776–80. doi: 10.1002/eat.22693. PMID: 28205275. Exclusion Code: X3.28205275
605 Kass AE, Wang AZ, Kolko RP, . Identification as overweight by medical professionals: relation to eating disorder diagnosis and risk. Eat Behav. 2015 Apr;17:62–8. doi: 10.1016/j.eatbeh.2014.12.013. PMID: 25602172. Exclusion Code: X7.25602172
606 Katzman MA, Bara-Carril N, Rabe-Hesketh S, . A randomized controlled two-stage trial in the treatment of bulimia nervosa, comparing CBT versus motivational enhancement in Phase 1 followed by group versus individual CBT in Phase 2. Psychosom Med. 2010 Sep;72(7):656–63. doi: 10.1097/PSY.0b013e3181ec5373. PMID: 20668284. Exclusion Code: X7.20668284
607 Keating L, Tasca GA, Gick M, . Change in attachment to the therapy group generalizes to change in individual attachment among women with binge eating disorder. Psychotherapy (Chic). 2014 Mar;51(1):78–87. doi: 10.1037/a0031099. PMID: 23398033. Exclusion Code: X7.23398033
608 Keel PK, Crow S, Davis TL, . Assessment of eating disorders: comparison of interview and questionnaire data from a long-term follow-up study of bulimia nervosa. J Psychosom Res. 2002 Nov;53(5):1043–7. doi: 10.1016/s0022-3999(02)00491-9. PMID: 12445594. Exclusion Code: X7.12445594
609 Keel PK, Forney KJ, Brown TA, . Influence of college peers on disordered eating in women and men at 10-year follow-up. J Abnorm Psychol. 2013 Feb;122(1):105–10. doi: 10.1037/a0030081. PMID: 23025666. Exclusion Code: X7.23025666
610 Keel PK, Heatherton TF, Dorer DJ, . Point prevalence of bulimia nervosa in 1982, 1992, and 2002. Psychol Med. 2006 Jan;36(1):119–27. doi: 10.1017/s0033291705006148. PMID: 16202192. Exclusion Code: X7.16202192
611 Keel PK, Mitchell JE, Davis TL, . Long-term impact of treatment in women diagnosed with bulimia nervosa. Int J Eat Disord. 2002 Mar;31(2):151–8. doi: 10.1002/eat.10017. PMID: 11920976. Exclusion Code: X14.11920976
612 Kells M, Kelly-Weeder S. Binge eating behavior among a cohort of normal weight college women. J Am Assoc Nurse Pract. 2019 Dec;31(12):741–6. doi: 10.1097/jxx.0000000000000317. PMID: 31738272. Exclusion Code: X9.31738272
613 Kelly AC, Carter JC, Zuroff DC, . Self-compassion and fear of self-compassion interact to predict response to eating disorders treatment: a preliminary investigation. Psychother Res. 2013;23(3):252–64. doi: 10.1080/10503307.2012.717310. PMID: 22917037. Exclusion Code: X9.22917037
614 Kelly AC, Wisniewski L, Martin-Wagar C, . Group-Based Compassion-Focused Therapy as an Adjunct to Outpatient Treatment for Eating Disorders: A Pilot Randomized Controlled Trial. Clin Psychol Psychother. 2017 Mar;24(2):475–87. doi: 10.1002/cpp.2018. PMID: 27237928. Exclusion Code: X7.27237928
615 Kelly NR, Mitchell KS, Gow RW, . An evaluation of the reliability and construct validity of eating disorder measures in white and black women. Psychol Assess. 2012 Sep;24(3):608–17. doi: 10.1037/a0026457. PMID: 22149327. Exclusion Code: X3.22149327
616 Kenardy J, Mensch M, Bowen K, . Group therapy for binge eating in Type 2 diabetes: a randomized trial. Diabet Med. 2002;19(3):234–9. doi: 10.1046/j.1464-5491.2002.00679.x. PMID: CN-00390667. Exclusion Code: X3.12162246
617 Kennedy SH, Goldbloom DS, Ralevski E, . Is there a role for selective monoamine oxidase inhibitor therapy in bulimia nervosa? A placebo-controlled trial of brofaromine. J Clin Psychopharmacol. 1993 Dec;13(6):415–22. PMID: 8120155. Exclusion Code: X5.8120155
618 Kennedy SH, Piran N, Garfinkel PE. Monoamine oxidase inhibitor therapy for anorexia nervosa and bulimia: a preliminary trial of isocarboxazid. J Clin Psychopharmacol. 1985 Oct;5(5):279–85. doi: 10.1097/00004714-198510000-00005. PMID: 3862680. Exclusion Code: X7.3862680
619 Kennedy SH, Piran N, Warsh JJ, . A trial of isocarboxazid in the treatment of bulimia nervosa. J Clin Psychopharmacol. 1988;8(6):391–6. doi: 10.1097/00004714-198812000-00002. PMID: 1989-23410-001. Exclusion Code: X5.3069879
620 Kenny TE, Singleton C, Carter JC. Testing predictions of the emotion regulation model of binge-eating disorder. Int J Eat Disord. 2017 Nov;50(11):1297–305. doi: 10.1002/eat.22787. PMID: 29052240. Exclusion Code: X7.29052240
621 Keski-Rahkonen A, Hoek HW, Susser ES, . Epidemiology and course of anorexia nervosa in the community. Am J Psychiatry. 2007 Aug;164(8):1259–65. doi: 10.1176/appi.ajp.2007.06081388. PMID: 17671290. Exclusion Code: X9.17671290
622 Keski-Rahkonen A, Sihvola E, Raevuori A, . Reliability of self-reported eating disorders: Optimizing population screening. Int J Eat Disord. 2006 Dec;39(8):754–62. doi: 10.1002/eat.20277. PMID: 16937380. Exclusion Code: X4.16937380
623 Kessler RC, Berglund PA, Chiu WT, . The prevalence and correlates of binge eating disorder in the World Health Organization World Mental Health Surveys. Biol Psychiatry. 2013 May 1;73(9):904–14. doi: 10.1016/j.biopsych.2012.11.020. PMID: 23290497. Exclusion Code: X9.23290497
624 Kim YR, Eom JS, Leppanen J, . Effects of intranasal oxytocin on the attentional bias to emotional stimuli in patients with bulimia nervosa. Psychoneuroendocrinology. 2018 May;91:75–8. doi: 10.1016/j.psyneuen.2018.02.029. PMID: 29529522. Exclusion Code: X3.29529522
625 Kim YR, Eom JS, Yang JW, . The Impact of Oxytocin on Food Intake and Emotion Recognition in Patients with Eating Disorders: A Double Blind Single Dose Within-Subject Cross-Over Design. PLoS One. 2015;10(9):e0137514. doi: 10.1371/journal.pone.0137514. PMID: 26402337. Exclusion Code: X3.26402337
626 Kim YR, Tyrer P, Lee HS, . Schedule for personality assessment from notes and documents (SPAN-DOC): Preliminary validation, links to the ICD-11 classification of personality disorder, and use in eating disorders. Personal Ment Health. 2016 May;10(2):106–17. doi: 10.1002/pmh.1335. PMID: 27120421. Exclusion Code: X3.27120421
627 Kim Y-R, Kim C-H, Cardi V, . Intranasal oxytocin attenuates attentional bias for eating and fat shape stimuli in patients with anorexia nervosa. Psychoneuroendocrinology. 2014;44:133–42. doi: 10.1016/j.psyneuen.2014.02.019. PMID: 2014-12385-001. Exclusion Code: X3.24703429
628 Kim Y-R, Kim C-H, Park JH, . The impact of intranasal oxytocin on attention to social emotional stimuli in patients with anorexia nervosa: A double blind within-subject cross-over experiment. PLoS One. 2014;9(3)PMID: 2014-14947-001. Exclusion Code: X3.
629 Kimball A, Schorr M, Meenaghan E, . A Randomized Placebo-Controlled Trial of Low-Dose Testosterone Therapy in Women With Anorexia Nervosa. J Clin Endocrinol Metab. 2019 Oct 1;104(10):4347–55. doi: 10.1210/jc.2019-00828. PMID: 31219558. Exclusion Code: X3.31219558
630 King MB. Eating disorders in a general practice population. Prevalence, characteristics and follow-up at 12 to 18 months. Psychol Med Monogr Suppl. 1989;14:1–34. doi: 10.1017/s0264180100000515. PMID: 2788294. Exclusion Code: X7.2788294
631 Kirkley BG, Schneider JA, Agras WS, . Comparison of two group treatments for bulimia. J Consult Clin Psychol. 1985 Feb;53(1):43–8. doi: 10.1037//0022-006x.53.1.43. PMID: 3856582. Exclusion Code: X7.3856582
632 Kirsch AC, Shapiro JB, Conley CS, . Explaining the pathway from familial and peer social support to disordered eating: Is body dissatisfaction the link for male and female adolescents? Eat Behav. 2016 Aug;22:175–81. doi: 10.1016/j.eatbeh.2016.06.018. PMID: 27289524. Exclusion Code: X9.27289524
633 Kjelsås E, Augestad LB, Flanders D. Screening of males with eating disorders. Eat Weight Disord. 2003 Dec;8(4):304–10. doi: 10.1007/bf03325030. PMID: 15018380. Exclusion Code: X4.15018380
634 Kleifield EI, Sunday S, Hurt S, . Psychometric validation of the Tridimensional Personality Questionnaire: application to subgroups of eating disorders. Compr Psychiatry. 1993 Jul–Aug;34(4):249–53. doi: 10.1016/0010-440x(93)90006-p. PMID: 8348803. Exclusion Code: X4.8348803
635 Klein AS, Skinner JB, Hawley KM. Targeting binge eating through components of dialectical behavior therapy: preliminary outcomes for individually supported diary card self-monitoring versus group-based DBT. Psychotherapy (Chic). 2013 Dec;50(4):543–52. doi: 10.1037/a0033130. PMID: 24295464. Exclusion Code: X7.24295464
636 Kliem S, Mößle T, Zenger M, . The eating disorder examination-questionnaire 8: a brief measure of eating disorder psychopathology (EDE-Q8). Int J Eat Disord. 2016 Jun;49(6):613–6. doi: 10.1002/eat.22487. PMID: 26711183. Exclusion Code: X7.26711183
637 Ko C, Cohen H. Intraethnic comparison of eating attitudes in native Koreans and Korean Americans using a Korean translation of the eating attitudes test. J Nerv Ment Dis. 1998 Oct;186(10):631–6. doi: 10.1097/00005053-199810000-00007. PMID: 9788640. Exclusion Code: X7.9788640
638 Kobak KA, Taylor Lv, Dottl SL, . A computer-administered telephone interview to identify mental disorders. JAMA: Journal of the American Medical Association. 1997;278(11):905–10. doi: 10.1001/jama.278.11.905. PMID: 2000-03942-001. Exclusion Code: X3.9302242
639 Kolar DR, Hammerle F, Jenetzky E, . Smartphone-Enhanced Low-Threshold Intervention for adolescents with Anorexia Nervosa (SELTIAN) waiting for outpatient psychotherapy: study protocol of a randomised controlled trial. BMJ Open. 2017 Oct 22;7(10):e018049. doi: 10.1136/bmjopen-2017-018049. PMID: 29061627. Exclusion Code: X7.29061627
640 Kong F, Zhang Y, Chen H. The construct validity of the Restraint Scale among mainland Chinese women. Eat Behav. 2013 Aug;14(3):356–60. doi: 10.1016/j.eatbeh.2013.06.009. PMID: 23910780. Exclusion Code: X4.23910780
641 Kordy H, Krämer B, Palmer RL, . Remission, recovery, relapse, and recurrence in eating disorders: conceptualization and illustration of a validation strategy. J Clin Psychol. 2002 Jul;58(7):833–46. doi: 10.1002/jclp.2013. PMID: 12205723. Exclusion Code: X7.12205723
642 Kornstein SG, Bliss C, Kando J, . Clinical characteristics and treatment response to lisdexamfetamine dimesylate versus placebo in adults with binge eating disorder: Analysis by Gender and Age. J Clin Psychiatry. 2019 Feb 26;80(2)doi: 10.4088/JCP.18m12378. PMID: 30817099. Exclusion Code: X7.30817099
643 Korrelboom K, de Jong M, Huijbrechts I, . Competitive memory training (COMET) for treating low self-esteem in patients with eating disorders: A randomized clinical trial. J Consult Clin Psychol. 2009 Oct;77(5):974–80. doi: 10.1037/a0016742. PMID: 19803576. Exclusion Code: X3.19803576
644 Kotarski BA. Eating disorder screening via electronic medical record: ProQuest Information & Learning; 2019. Exclusion Code: X4.
645 Kotwal R, Guerdjikova A, McElroy SL, . Lithium augmentation of topiramate for bipolar disorder with comorbid binge eating disorder and obesity. Hum Psychopharmacol. 2006 Oct;21(7):425–31. doi: 10.1002/hup.783. PMID: 16941522. Exclusion Code: X9.16941522
646 Krabbenborg MA, Danner UN, Larsen JK, . The Eating Disorder Diagnostic Scale: psychometric features within a clinical population and a cut-off point to differentiate clinical patients from healthy controls. Eur Eat Disord Rev. 2012 Jul;20(4):315–20. doi: 10.1002/erv.1144. PMID: 21805535. Exclusion Code: X3.21805535
647 Krishna M, Lepping P, Sharma VK, . Epidemiological and clinical use of GMHAT-PC (Global Mental Health Assessment Tool—Primary Care) in cardiac patients. Clin Pract Epidemiol Ment Health. 2009;5doi: 10.1186/1745-0179-5-7. PMID: 2009-08044-001. Exclusion Code: X4.
648 Kristeller JL, Rodin J. Identifying eating patterns in male and female undergraduates using cluster analysis. Addict Behav. 1989;14(6):631–42. doi: 10.1016/0306-4603(89)90005-1. PMID: 2618846. Exclusion Code: X7.2618846
649 Kurth CL, Krahn DD, Nairn K, . The severity of dieting and bingeing behaviors in college women: interview validation of survey data. J Psychiatr Res. 1995 May–Jun;29(3):211–25. doi: 10.1016/0022-3956(95)00002-m. PMID: 7473297. Exclusion Code: X7.7473297
650 Laberg S, Andersson G. Autobiographical Memories in Patients Treated for Bulimia Nervosa. Eur Eat Disord Rev. 2004;12(1):34–41. doi: 10.1002/erv.534. PMID: 2004-12024-005. Exclusion Code: X3.
651 Lai BP, Tang CS, Tse WK. A longitudinal study investigating disordered eating during the transition to motherhood among Chinese women in Hong Kong. Int J Eat Disord. 2006 May;39(4):303–11. doi: 10.1002/eat.20266. PMID: 16528680. Exclusion Code: X7.16528680
652 Lam RW, Goldner EM, Solyom L, . A controlled study of light therapy for bulimia nervosa. Am J Psychiatry. 1994 May;151(5):744–50. doi: 10.1176/ajp.151.5.744. PMID: 8166318. Exclusion Code: X5.8166318
653 Lantzouni E, Frank GR, Golden NH, . Reversibility of growth stunting in early onset anorexia nervosa: a prospective study. J Adolesc Health. 2002 Aug;31(2):162–5. doi: 10.1016/s1054-139x(02)00342-7. PMID: 12127386. Exclusion Code: X7.12127386
654 Larrañaga A, Fluiters E, Docet MF, . Comparative study of cognitive-behavioral psychotherapy and nutritional support in patients with different types of eating disorders. Med Clin (Barc). 2014 Sep 9;143(5):196–200. doi: 10.1016/j.medcli.2013.05.042. PMID: 24035412. Exclusion Code: X9.24035412
655 Las Hayas C, Calvete E, Gómez del Barrio A, . Resilience Scale-25 Spanish version: validation and assessment in eating disorders. Eat Behav. 2014 Aug;15(3):460–3. doi: 10.1016/j.eatbeh.2014.06.010. PMID: 25064300. Exclusion Code: X4.25064300
656 Las Hayas C, Quintana JM, Padierna A, . The new questionnaire health-related quality of life for eating disorders showed good validity and reliability. J Clin Epidemiol. 2006 Feb;59(2):192–200. doi: 10.1016/j.jclinepi.2005.06.005. PMID: 16426955. Exclusion Code: X4.16426955
657 Latner JD, Wilson GT. Self-monitoring and the assessment of binge eating. Behav Ther. 2002 Sum 2002;33(3):465–77. doi: 10.1016/S0005-7894(02)80039-9. PMID: 2002-06398-008. Exclusion Code: X7.
658 Lau LLS, Lee S, Lee E, . Cross-cultural validity of the Eating Disorder Examination: A study of Chinese outpatients with eating disorders in Hong Kong. Hong Kong Journal of Psychiatry. 2006;16(4):132–6. PMID: 2007-15599-003. Exclusion Code: X4.
659 Lauder TD, Williams MV, Campbell CS, . Abnormal eating behaviors in military women. Med Sci Sports Exerc. 1999 Sep;31(9):1265–71. doi: 10.1097/00005768-199909000-00006. PMID: 10487367. Exclusion Code: X7.10487367
660 Laumer U, Bauer M, Fichter M, . Therapeutic effects of the Feldenkrais method “awareness through movement” in patients with eating disorders. Psychother Psychosom Med Psychol. 1997;47(5):170–80. PMID: CN-00140908. Exclusion Code: X1.9265198
661 Le Grange D. Family-based treatment for adolescent anorexia nervosa: A promising approach? Clin Psychol. 2004;8(2):56–63. doi: 10.1080/13284200412331304018. PMID: 2005-01249-002. Exclusion Code: X9.
662 le Grange D, Crosby RD, Rathouz PJ, . A randomized controlled comparison of family-based treatment and supportive psychotherapy for adolescent bulimia nervosa. Arch Gen Psychiatry. 2007 Sep;64(9):1049–56. doi: 10.1001/archpsyc.64.9.1049. PMID: 17768270. Exclusion Code: X7.17768270
663 le Grange D, Doyle P, Crosby RD, . Early response to treatment in adolescent bulimia nervosa. Int J Eat Disord. 2008 Dec;41(8):755–7. doi: 10.1002/eat.20566. PMID: 18570193. Exclusion Code: X7.18570193
664 Le Grange D, Gorrell S, Hughes EK, . Delivery of family-based treatment for adolescent anorexia nervosa in a public health care setting: Research versus non-research specialty care. Frontiers in Psychiatry. 2020;10doi: 10.3389/fpsyt.2019.01001. PMID: 2020-08734-001. Exclusion Code: X7.
665 le Grange D, Lock J. Bulimia nervosa in adolescents: treatment, eating pathology and comorbidity. South African Psychiatry Review. 2002;5(3):19–22. PMID: 2002-06101-004. Exclusion Code: X7.
666 Le Grange D, Lock J, Agras WS, . Randomized Clinical Trial of Family-Based Treatment and Cognitive-Behavioral Therapy for Adolescent Bulimia Nervosa. J Am Acad Child Adolesc Psychiatry. 2015 Nov;54(11):886–94.e2. doi: 10.1016/j.jaac.2015.08.008. PMID: 26506579. Exclusion Code: X7.26506579
667 Le Grange D, Lock J, Agras WS, . Moderators and mediators of remission in family-based treatment and adolescent focused therapy for anorexia nervosa. Behav Res Ther. 2012 Feb;50(2):85–92. doi: 10.1016/j.brat.2011.11.003. PMID: 22172564. Exclusion Code: X7.22172564
668 Leacy KA, Cane JN. Effect of non-select menus on weight and eating concern in adolescents hospitalized with anorexia nervosa. Eat Disord. 2012;20(2):159–67. doi: 10.1080/10640266.2012.654060. PMID: 22364346. Exclusion Code: X3.22364346
669 Lechien JR, Cavelier G, Thill MP, . Validity and reliability of the French version of Eating Assessment Tool (EAT-10). Eur Arch Otorhinolaryngol. 2019 Jun;276(6):1727–36. doi: 10.1007/s00405-019-05429-1. PMID: 31006058. Exclusion Code: X4.31006058
670 Lee KS, Vaillancourt T. A Four-Year Prospective Study of Bullying, Anxiety, and Disordered Eating Behavior Across Early Adolescence. Child Psychiatry Hum Dev. 2019 Oct;50(5):815–25. doi: 10.1007/s10578-019-00884-7. PMID: 30915621. Exclusion Code: X9.30915621
671 Lee S, Lee AM, Leung T. Cross-cultural validity of the Eating Disorder Inventory: a study of Chinese patients with eating disorders in Hong Kong. Int J Eat Disord. 1998 Mar;23(2):177–88. doi: 10.1002/(sici)1098-108x(199803)23:2<177::aid-eat8>3.0.co;2-h. PMID: 9503243. Exclusion Code: X4.9503243
672 Lee S, Lee AM, Leung T, . Psychometric properties of the Eating Disorders Inventory (EDI-1) in a nonclinical Chinese population in Hong Kong. Int J Eat Disord. 1997 Mar;21(2):187–94. doi: 10.1002/(sici)1098-108x(199703)21:2<187::aid-eat10>3.0.co;2-#. PMID: 9062843. Exclusion Code: X9.9062843
673 Lee SW, Stewart SM, Striegel-Moore RH, . Validation of the eating disorder diagnostic scale for use with Hong Kong adolescents. Int J Eat Disord. 2007 Sep;40(6):569–74. doi: 10.1002/eat.20413. PMID: 17584872. Exclusion Code: X7.17584872
674 Leombruni P, Pierò A, Lavagnino L, . A randomized, double-blind trial comparing sertraline and fluoxetine 6-month treatment in obese patients with Binge Eating Disorder. Prog Neuropsychopharmacol Biol Psychiatry. 2008 Aug 1;32(6):1599–605. doi: 10.1016/j.pnpbp.2008.06.005. PMID: 18598735. Exclusion Code: X7.18598735
675 Leppanen J, Cardi V, Ng KW, . The effects of intranasal oxytocin on smoothie intake, cortisol and attentional bias in anorexia nervosa. Psychoneuroendocrinology. 2017;79:167–74. doi: 10.1016/j.psyneuen.2017.01.017. PMID: 2017-14665-021. Exclusion Code: X7.28288443
676 Leppanen J, Cardi V, Ng KW, . Effects of intranasal oxytocin on the interpretation and expression of emotions in anorexia nervosa. J Neuroendocrinol. 2017;29(3):1–13. doi: 10.1111/jne.12458. PMID: 2017-13522-002. Exclusion Code: 7.
677 Levallius J, Clinton D, Högdahl L, . Personality as predictor of outcome in internet-based treatment of bulimic eating disorders. Eat Behav. 2020;36doi: 10.1016/j.eatbeh.2019.101360. PMID: 2020-14466-001. Exclusion Code: X7.
678 Levine MD, Marcus MD, Moulton P. Exercise in the treatment of binge eating disorder. Int J Eat Disord. 1996 Mar;19(2):171–7. doi: 10.1002/(sici)1098-108x(199603)19:2<171::aid-eat7>3.0.co;2-k. PMID: 8932555. Exclusion Code: X5.8932555
679 Levine MD, Ringham RM, Kalarchian MA, . Overeating among seriously overweight children seeking treatment: results of the children’s eating disorder examination. Int J Eat Disord. 2006 Mar;39(2):135–40. doi: 10.1002/eat.20218. PMID: 16231347. Exclusion Code: X7.16231347
680 Levinson CA, Rodebaugh TL, Fewell L, . D-Cycloserine facilitation of exposure therapy improves weight regain in patients with anorexia nervosa: a pilot randomized controlled trial. J Clin Psychiatry. 2015 Jun;76(6):e787–93. doi: 10.4088/JCP.14m09299. PMID: 26132687. Exclusion Code: X8.26132687
681 Levinson CA, Vanzhula IA, Christian C. Development and validation of the eating disorder fear questionnaire and interview: Preliminary investigation of eating disorder fears. Eat Behav. 2019 Dec;35:101320. doi: 10.1016/j.eatbeh.2019.101320. PMID: 31445189. Exclusion Code: X4.31445189
682 Levitan RD, Kaplan AS, Joffe RT, . Hormonal and subjective responses to intravenous meta-chlorophenylpiperazine in bulimia nervosa. Arch Gen Psychiatry. 1997 Jun;54(6):521–7. doi: 10.1001/archpsyc.1997.01830180027004. PMID: 9193192. Exclusion Code: X3.9193192
683 Lewinsohn PM, Striegel-Moore RH, Seeley JR. Epidemiology and natural course of eating disorders in young women from adolescence to young adulthood. J Am Acad Child Adolesc Psychiatry. 2000 Oct;39(10):1284–92. doi: 10.1097/00004583-200010000-00016. PMID: 11026183. Exclusion Code: X7.11026183
684 Lewis DM, Cachelin FM. Body image, body dissatisfaction, and eating attitudes in midlife and elderly women. Eating Disorders: The Journal of Treatment & Prevention. 2001 Spr 2001;9(1):29–39. doi: 10.1080/106402601300187713. PMID: 2001-00379-003. Exclusion Code: X9.
685 Lichtenstein MB, Hemmingsen SD, Støving RK. Identification of eating disorder symptoms in Danish adolescents with the SCOFF questionnaire. Nord J Psychiatry. 2017 Jul;71(5):340–7. doi: 10.1080/08039488.2017.1300322. PMID: 28290749. Exclusion Code: X3.28290749
686 Liedtke R, Jäger B, Lempa W, . Therapy outcome of two treatment models for bulimia nervosa: preliminary results of a controlled study. Psychother Psychosom. 1991;56(1–2):56–63. doi: 10.1159/000288531. PMID: 1891582. Exclusion Code: X7.1891582
687 Limbers CA, Young D, Beaujean AA. The Emotional Eating Scale adapted for children and adolescents: Factorial invariance across adolescent males and females. Eat Behav. 2016 Aug;22:164–9. doi: 10.1016/j.eatbeh.2016.06.012. PMID: 27289523. Exclusion Code: X7.27289523
688 Limbert C. The Eating Disorder Inventory: a test of the factor structure and internal consistency in a nonclinical sample. Health Care Women Int. 2004 Feb;25(2):165–78. doi: 10.1080/07399330490267486. PMID: 14766431. Exclusion Code: X4.14766431
689 Linardon J, Fairburn CG, Fitzsimmons-Craft EE, . The empirical status of the third-wave behaviour therapies for the treatment of eating disorders: A systematic review. Clin Psychol Rev. 2017;58:125–40. doi: 10.1016/j.cpr.2017.10.005. PMID: 2017-49071-001. Exclusion Code: X9.29089145
690 Linardon J, Messer M, Lee S, . Testing the measurement invariance of the Body Image Acceptance and Action Questionnaire between women with and without binge-eating disorder symptomatology: Further evidence for an abbreviated five-item version. Psychol Assess. 2019 Nov;31(11):1368–76. doi: 10.1037/pas0000761. PMID: 31343209. Exclusion Code: X4.31343209
691 Linde JA, Jeffery RW, Levy RL, . Binge eating disorder, weight control self-efficacy, and depression in overweight men and women. Int J Obes Relat Metab Disord. 2004 Mar;28(3):418–25. doi: 10.1038/sj.ijo.0802570. PMID: 14724662. Exclusion Code: X3.14724662
692 L’Insalata A, Trainor C, Bohon C, . Confirming the Efficacy of an Adaptive Component to Family-Based Treatment for Adolescent Anorexia Nervosa: study Protocol for a Randomized Controlled Trial. Frontiers in psychiatry. 2020;11doi: 10.3389/fpsyt.2020.00041. PMID: CN-02099186. Exclusion Code: X7.
693 Linville D, Cobb E, Lenee-Bluhm T, . Effectiveness of an eating disorder preventative intervention in primary care medical settings. Behav Res Ther. 2015 Dec;75:32–9. doi: 10.1016/j.brat.2015.10.004. PMID: 26523886. Exclusion Code: X9.26523886
694 Lipson SK, Sonneville KR. Understanding suicide risk and eating disorders in college student populations: results from a National Study. Int J Eat Disord. 2019doi: 10.1002/eat.23188. PMID: CN-02007568. Exclusion Code: X9.
695 Lobera IJ, Santed MA, Shafran R, . Psychometric properties of the Spanish version of the Thought-Shape Fusion Questionnaire. The Spanish Journal of Psychology. 2012;15(1):410–23. doi: 10.5209/rev_SJOP.2012.v15.n1.37347. PMID: 2012-04317-039. Exclusion Code: X3.22379730
696 Lock J, Agras WS, Bryson SW, . Does family-based treatment reduce the need for hospitalization in adolescent anorexia nervosa? Int J Eat Disord. 2016 Sep;49(9):891–4. doi: 10.1002/eat.22536. PMID: 27062400. Exclusion Code: X7.27062400
697 Lock J, Brandt H, Woodside B, . Challenges in conducting a multi-site randomized clinical trial comparing treatments for adolescent anorexia nervosa. Int J Eat Disord. 2012 Mar;45(2):202–13. doi: 10.1002/eat.20923. PMID: 21495052. Exclusion Code: X7.21495052
698 Lock J, Le Grange D. Can family based treatment of anorexia nervosa be manualized? J Psychother Pract Res. 2001 Fal 2001;10(4):253–61. PMID: 2001-05185-007. Exclusion Code: X3.11696652
699 Lock J, Le Grange D, Agras WS, . Can adaptive treatment improve outcomes in family-based therapy for adolescents with anorexia nervosa? Feasibility and treatment effects of a multi-site treatment study. Behav Res Ther. 2015 Oct;73:90–5. doi: 10.1016/j.brat.2015.07.015. PMID: 26276704. Exclusion Code: X7.26276704
700 Lock J, Sadeh-Sharvit S, L’Insalata A. Feasibility of conducting a randomized clinical trial using family-based treatment for avoidant/restrictive food intake disorder. Int J Eat Disord. 2019 Jun;52(6):746–51. doi: 10.1002/eat.23077. PMID: 30924958. Exclusion Code: X3.30924958
701 Lockwood R, Serpell L, Waller G. Moderators of weight gain in the early stages of outpatient cognitive behavioral therapy for adults with anorexia nervosa. Int J Eat Disord. 2012;45(1):51–6. doi: 10.1002/eat.20885. PMID: 2011-29222-006. Exclusion Code: X7.22170020
702 Loeb KL, Le Grange D, Hildebrandt T, . Eating disorders in youth: diagnostic variability and predictive validity. Int J Eat Disord. 2011 Dec;44(8):692–702. doi: 10.1002/eat.20872. PMID: 22072406. Exclusion Code: X7.22072406
703 Loeb KL, Wilson GT, Gilbert JS, . Guided and unguided self-help for binge eating. Behav Res Ther. 2000 Mar;38(3):259–72. doi: 10.1016/s0005-7967(99)00041-8. PMID: 10665159. Exclusion Code: X7.10665159
704 Loeb KL, Wilson GT, Labouvie E, . Therapeutic alliance and treatment adherence in two interventions for bulimia nervosa: a study of process and outcome. J Consult Clin Psychol. 2005 Dec;73(6):1097–107. doi: 10.1037/0022-006x.73.6.1097. PMID: 16392983. Exclusion Code: X9.16392983
705 Lombardo C, Cuzzolaro M, Vetrone G, . Concurrent validity of the Disordered Eating Questionnaire (DEQ) with the Eating Disorder Examination (EDE) clinical interview in clinical and non clinical samples. Eat Weight Disord. 2011 Sep;16(3):e188–98. doi: 10.1007/bf03325131. PMID: 22290035. Exclusion Code: X3.22290035
706 Lombardo C, Iani L, Barbaranelli C. Validation of an Italian version of the Food Craving Questionnaire-State: Factor structure and sensitivity to manipulation. Eat Behav. 2016 Aug;22:182–7. doi: 10.1016/j.eatbeh.2016.06.003. PMID: 27294790. Exclusion Code: X2.27294790
707 Lombardo C, Russo PM, Lucidi F, . Internal consistency, convergent validity and reliability of a brief questionnaire on disordered eating (DEQ). Eat Weight Disord. 2004 Jun;9(2):91–8. doi: 10.1007/bf03325051. PMID: 15330075. Exclusion Code: X7.15330075
708 Long S, Meyer C, Leung N, . Effects of distraction and focused attention on actual and perceived food intake in females with non-clinical eating psychopathology. Appetite. 2011 Apr;56(2):350–6. doi: 10.1016/j.appet.2010.12.018. PMID: 21185894. Exclusion Code: X3.21185894
709 López-Guimerà G, Fauquet J, Sánchez-Carracedo D, . Psychometric properties of the Perception of Teasing Scale in a Spanish adolescent sample: POTS-S. Eat Weight Disord. 2012 Sep;17(3):e210–8. doi: 10.3275/8245. PMID: 22314275. Exclusion Code: X4.22314275
710 Loria-Kohen V, Gómez-Candela C, Palma-Milla S, . A pilot study of folic acid supplementation for improving homocysteine levels, cognitive and depressive status in eating disorders. Nutr Hosp. 2013 May–Jun;28(3):807–15. doi: 10.3305/nh.2013.28.3.6335. PMID: 23848107. Exclusion Code: X5.23848107
711 Low KG, Charanasomboon S, Lesser J, . Effectiveness of a computer-based interactive eating disorders prevention program at long-term follow-up. Eat Disord. 2006 Jan–Feb;14(1):17–30. doi: 10.1080/10640260500403816. PMID: 16757446. Exclusion Code: X5.16757446
712 Luce KH, Crowther JH. The reliability of the Eating Disorder Examination-Self-Report Questionnaire Version (EDE-Q). Int J Eat Disord. 1999 Apr;25(3):349–51. doi: 10.1002/(sici)1098-108x(199904)25:3<349::aid-eat15>3.0.co;2-m. PMID: 10192002. Exclusion Code: X7.10192002
713 Lucena-Santos P, Trindade IA, Oliveira M, . Cognitive Fusion Questionnaire-Body Image: Psychometric Properties and Its Incremental Power in the Prediction of Binge Eating Severity. J Psychol. 2017 May 19;151(4):379–92. doi: 10.1080/00223980.2017.1305322. PMID: 28388342. Exclusion Code: X4.28388342
714 Lund C, Jørgensen J, Stage KB, . Interrater reliability of a Danish version of the Morgan Russell scale for assessment of anorexia nervosa. Int J Eat Disord. 1999 Jan;25(1):105–8. doi: 10.1002/(sici)1098-108x(199901)25:1<105::aid-eat13>3.0.co;2-k. PMID: 9924659. Exclusion Code: X8.9924659
715 Lunn S, Poulsen S, Daniel SIF. A multiple case study of psychoanalytic therapies for clients with bulimia nervosa. Nordic Psychology. 2012;64(2):87–102. doi: 10.1080/19012276.2012.726814. PMID: 2012-31708-003. Exclusion Code: X7.
716 Lydecker JA, Gueorguieva R, Masheb R, . Examining race as a predictor and moderator of treatment outcomes for binge-eating disorder: analysis of aggregated randomized controlled trials. J Consult Clin Psychol. 2019 Jun;87(6):530–40. doi: 10.1037/ccp0000404. PMID: 31008634. Exclusion Code: X7.31008634
717 Lydecker JA, Gueorguieva R, Masheb R, . Examining sex as a predictor and moderator of treatment outcomes for binge-eating disorder: Analysis of aggregated randomized controlled trials. Int J Eat Disord. 2020 Jan;53(1):20–30. doi: 10.1002/eat.23167. PMID: 31497876. Exclusion Code: X9.31497876
718 Lydecker JA, Ivezaj V, Grilo CM. Testing the validity and clinical utility of the severity specifiers for binge-eating disorder for predicting treatment outcomes. J Consult Clin Psychol. 2020;88(2):172–8. doi: 10.1037/ccp0000464. PMID: 2019-80727-005. Exclusion Code: X7.31894997
719 Lydecker JA, White MA, Grilo CM. Black patients with binge-eating disorder: comparison of different assessment methods. Psychol Assess. 2016 Oct;28(10):1319–24. doi: 10.1037/pas0000246. PMID: 26569466. Exclusion Code: X7.26569466
720 MacDonald DE, McFarlane TL, Dionne MM, . Rapid response to intensive treatment for bulimia nervosa and purging disorder: A randomized controlled trial of a CBT intervention to facilitate early behavior change. J Consult Clin Psychol. 2017 Sep;85(9):896–908. doi: 10.1037/ccp0000221. PMID: 28569520. Exclusion Code: X8.28569520
721 Macdonald P, Rhind C, Hibbs R, . Carers’ assessment, skills and information sharing (CASIS) trial: a qualitative study of the experiential perspective of caregivers and patients. Eur Eat Disord Rev. 2014 Nov;22(6):430–8. doi: 10.1002/erv.2320. PMID: 25267532. Exclusion Code: X7.25267532
722 Machado PP, Grilo CM, Crosby RD. Evaluation of the DSM-5 severity indicator for anorexia nervosa. Eur Eat Disord Rev. 2017 May;25(3):221–3. doi: 10.1002/erv.2508. PMID: 28402070. Exclusion Code: X7.28402070
723 Machado PP, Martins C, Vaz AR, . Eating disorder examination questionnaire: psychometric properties and norms for the Portuguese population. Eur Eat Disord Rev. 2014 Nov;22(6):448–53. doi: 10.1002/erv.2318. PMID: 25175299. Exclusion Code: X3.25175299
724 Machado PPP, Grilo CM, Crosby RD. Replication of a Modified Factor Structure for the Eating Disorder Examination-Questionnaire: Extension to Clinical Eating Disorder and Non-clinical Samples in Portugal. Eur Eat Disord Rev. 2018 Jan;26(1):75–80. doi: 10.1002/erv.2569. PMID: 29152813. Exclusion Code: X3.29152813
725 Machado PPP, Grilo CM, Rodrigues TF, . Eating Disorder Examination - Questionnaire short forms: A comparison. Int J Eat Disord. 2020 Jun;53(6):937–44. doi: 10.1002/eat.23275. PMID: 32282096. Exclusion Code: X3.32282096
726 Maguire S, Touyz S, Surgenor L, . The clinician administered staging instrument for anorexia nervosa: development and psychometric properties. Int J Eat Disord. 2012 Apr;45(3):390–9. doi: 10.1002/eat.20951. PMID: 22407867. Exclusion Code: X7.22407867
727 Maïano C, Morin AJ, Lanfranchi MC, . The Eating Attitudes Test-26 revisited using exploratory structural equation modeling. J Abnorm Child Psychol. 2013 Jul;41(5):775–88. doi: 10.1007/s10802-013-9718-z. PMID: 23344702. Exclusion Code: X4.23344702
728 Maïano C, Morin AJ, Monthuy-Blanc J, . Development and validity of a very short form of the Eating Disorder Inventory. Compr Psychiatry. 2016 Feb;65:141–9. doi: 10.1016/j.comppsych.2015.11.004. PMID: 26774003. Exclusion Code: X7.26774003
729 Maier A, Ernst JP, Müller S, . Self-perceived stigmatization in female patients with anorexia nervosa-results from an explorative retrospective pilot study of adolescents. Psychopathology. 2014;47(2):127–32. doi: 10.1159/000350505. PMID: 24008842. Exclusion Code: X4.24008842
730 Mallorquí-Bagué N, Vintró-Alcaraz C, Sánchez I, . Emotion regulation as a transdiagnostic feature among eating disorders: Cross-sectional and longitudinal approach. Eur Eat Disord Rev. 2018;26(1):53–61. doi: 10.1002/erv.2570. PMID: 2017-53075-001. Exclusion Code: X7.29168283
731 Mann T, Nolen-Hoeksema S, Huang K, . Are two interventions worse than none? Joint primary and secondary prevention of eating disorders in college females. Health Psychol. 1997;16(3):215–25. doi: 10.1037/0278-6133.16.3.215. PMID: 1997-06152-003. Exclusion Code: X5.9152699
732 Mannucci E, Ricca V, Barciulli E, . Quality of life and overweight: the obesity related well-being (Orwell 97) questionnaire. Addict Behav. 1999 May–Jun;24(3):345–57. doi: 10.1016/s0306-4603(98)00055-0. PMID: 10400274. Exclusion Code: X7.10400274
733 Mannucci E, Ricca V, Di Bernardo M, . Psychometric properties of EDE 12.0D in obese adult patients without binge eating disorder. Eat Weight Disord. 1997 Sep;2(3):144–9. doi: 10.1007/bf03339965. PMID: 14655838. Exclusion Code: X9.14655838
734 Maraldo T. Factor structure and psychometric properties of the Clinical Impairment Assessment 30 (CIA 30) in a clinical eating disorder sample: ProQuest Information & Learning; 2018. Exclusion Code: X3.
735 Marchesini G, Natale S, Chierici S, . Effects of cognitive-behavioural therapy on health-related quality of life in obese subjects with and without binge eating disorder. Int J Obes Relat Metab Disord. 2002 Sep;26(9):1261–7. doi: 10.1038/sj.ijo.0802073. PMID: 12187405. Exclusion Code: X9.12187405
736 Marco JH, Cañabate M, García-Alandete J, . Body image and nonsuicidal self-injury: Validation of the Body Investment Scale in participants with eating disorders. Clin Psychol Psychother. 2018 Jan;25(1):173–80. doi: 10.1002/cpp.2142. PMID: 28924984. Exclusion Code: X4.28924984
737 Marco JH, Perpiñá C, Botella C. Effectiveness of cognitive behavioral therapy supported by virtual reality in the treatment of body image in eating disorders: one year follow-up. Psychiatry Res. 2013 Oct 30;209(3):619–25. doi: 10.1016/j.psychres.2013.02.023. PMID: 23499231. Exclusion Code: X7.23499231
738 Marcoulides OK, Waller G. Nonspecific predictors of weight gain in the early stages of outpatient cognitive behavioral therapy for adults with anorexia nervosa: Replication and extension. Int J Eat Disord. 2012;45(6):746–50. doi: 10.1002/eat.22014. PMID: 2012-21605-003. Exclusion Code: X3.22422613
739 Marcus MD, Wing RR, Ewing L, . A double-blind, placebo-controlled trial of fluoxetine plus behavior modification in the treatment of obese binge-eaters and non-binge-eaters. Am J Psychiatry. 1990;147(7):876–81. doi: 10.1176/ajp.147.7.876. PMID: 1990-28878-001. Exclusion Code: X3.2192563
740 Markowitz JT, Butler DA, Volkening LK, . Brief screening tool for disordered eating in diabetes: internal consistency and external validity in a contemporary sample of pediatric patients with type 1 diabetes. Diabetes Care. 2010 Mar;33(3):495–500. doi: 10.2337/dc09-1890. PMID: 20032278. Exclusion Code: X7.20032278
741 Marmorstein NR, von Ranson KM, Iacono WG, . Prospective associations between depressive symptoms and eating disorder symptoms among adolescent girls. Int J Eat Disord. 2008 Mar;41(2):118–23. doi: 10.1002/eat.20477. PMID: 18008327. Exclusion Code: X9.18008327
742 Marrazzi MA, Bacon JP, Kinzie J, . Naltrexone use in the treatment of anorexia nervosa and bulimia nervosa. Int Clin Psychopharmacol. 1995 Sep;10(3):163–72. doi: 10.1097/00004850-199510030-00005. PMID: 8675969. Exclusion Code: X10.8675969
743 Marrazzi MA, Kinzie J, Luby ED. A detailed longitudinal analysis on the use of naltrexone in the treatment of bulimia. Int Clin Psychopharmacol. 1995 Sep;10(3):173–6. doi: 10.1097/00004850-199510030-00006. PMID: 8675970. Exclusion Code: X9.8675970
744 Marrazzi MA, Kinzie J, Luby ED. A detailed longitudinal analysis of the use of naltrexone in the treatment of bulimia. Int Clin Psychopharmacol. 1995;10(3):173–6. doi: 10.1097/00004850-199510030-00006. PMID: 1996-18016-001. Exclusion Code: X9.8675970
745 Marsh CL. To be thin is in. Or is it? Recognizing and measuring adolescent eating disorders. J Child Fam Nurs. 1999 Nov–Dec;2(6):447–52. PMID: 10847032. Exclusion Code: X12.10847032
746 Martin CK, Williamson DA, Thaw JM. Criterion validity of the multiaxial assessment of eating disorders symptoms. Int J Eat Disord. 2000 Nov;28(3):303–10. doi: 10.1002/1098-108x(200011)28:3<303::aid-eat7>3.0.co;2-i. PMID: 10942916. Exclusion Code: X7.10942916
747 Martín J, Padierna A, González N, . Evaluation of the psychometric characteristics of the Spanish version of the Anorectic Behaviour Observation Scale. Int J Clin Pract. 2014 Jan;68(1):83–93. doi: 10.1111/ijcp.12223. PMID: 24341302. Exclusion Code: X4.24341302
748 Martínez-González MA, Gual P, Lahortiga F, . Parental factors, mass media influences, and the onset of eating disorders in a prospective population-based cohort. Pediatrics. 2003 Feb;111(2):315–20. doi: 10.1542/peds.111.2.315. PMID: 12563057. Exclusion Code: X7.12563057
749 Martín-García M, Vila-Maldonado S, Rodríguez-Gómez I, . The Spanish version of the Three Factor Eating Questionnaire-R21 for children and adolescents (TFEQ-R21C): Psychometric analysis and relationships with body composition and fitness variables. Physiol Behav. 2016 Oct 15;165:350–7. doi: 10.1016/j.physbeh.2016.08.015. PMID: 27538345. Exclusion Code: X7.27538345
750 Martinsen M, Holme I, Pensgaard AM, . The development of the brief eating disorder in athletes questionnaire. Med Sci Sports Exerc. 2014 Aug;46(8):1666–75. doi: 10.1249/mss.0000000000000276. PMID: 24504432. Exclusion Code: X9.24504432
751 Marzola E, Knatz S, Murray SB, . Short-term intensive family therapy for adolescent eating disorders: 30-month outcome. Eur Eat Disord Rev. 2015 May;23(3):210–8. doi: 10.1002/erv.2353. PMID: 25783849. Exclusion Code: X7.25783849
752 Masheb RM, Grilo CM. Emotional overeating and its associations with eating disorder psychopathology among overweight patients with binge eating disorder. Int J Eat Disord. 2006 Mar;39(2):141–6. doi: 10.1002/eat.20221. PMID: 16231349. Exclusion Code: X4.16231349
753 Matheson BE, Gorrell S, Bohon C, . Investigating early response to treatment in a multi-site study for adolescent bulimia nervosa. Frontiers in Psychiatry. 2020;11doi: 10.3389/fpsyt.2020.00092. PMID: 2020-19267-001. Exclusion Code: X7.
754 Mathisen TF, Bratland-Sanda S, Rosenvinge JH, . Treatment effects on compulsive exercise and physical activity in eating disorders. Journal of Eating Disorders. 2018;6doi: 10.1186/s40337-018-0215-1. PMID: 2018-64883-001. Exclusion Code: X7.
755 Mathisen TF, Rosenvinge JH, Friborg O, . Is physical exercise and dietary therapy a feasible alternative to cognitive behavior therapy in treatment of eating disorders? A randomized controlled trial of two group therapies. Int J Eat Disord. 2020 Apr;53(4):574–85. doi: 10.1002/eat.23228. PMID: 31944339. Exclusion Code: X7.31944339
756 Mathisen TF, Rosenvinge JH, Pettersen G, . The PED-t trial protocol: The effect of physical exercise -and dietary therapy compared with cognitive behavior therapy in treatment of bulimia nervosa and binge eating disorder. BMC Psychiatry. 2017 May 12;17(1):180. doi: 10.1186/s12888-017-1312-4. PMID: 28494809. Exclusion Code: X7.28494809
757 Matton A, Goossens L, Braet C, . Continuity in primary school children’s eating problems and the influence of parental feeding strategies. J Youth Adolesc. 2013 Jan;42(1):52–66. doi: 10.1007/s10964-012-9794-3. PMID: 22801806. Exclusion Code: X9.22801806
758 Matusek JA, Wendt SJ, Wiseman CV. Dissonance thin-ideal and didactic healthy behavior eating disorder prevention programs: results from a controlled trial. Int J Eat Disord. 2004 Dec;36(4):376–88. doi: 10.1002/eat.20059. PMID: 15558649. Exclusion Code: X5.15558649
759 Maxmen JS, Siberfarb PM, Ferrell RB. Anorexia nervosa. Practical initial management in a general hospital. JAMA. 1974 Aug 12;229(7):801–3. doi: 10.1001/jama.229.7.801. PMID: 4407862. Exclusion Code: X3.4407862
760 Maxwell H, Tasca GA, Ritchie K, . Change in attachment insecurity is related to improved outcomes 1-year post group therapy in women with binge eating disorder. Psychotherapy (Chic). 2014 Mar;51(1):57–65. doi: 10.1037/a0031100. PMID: 23398032. Exclusion Code: X7.23398032
761 Mayer B, Bos AER, Muris P, . Does disgust enhance eating disorder symptoms? Eat Behav. 2008;9(1):124–7. doi: 10.1016/j.eatbeh.2007.07.003. PMID: 2008-00303-015. Exclusion Code: X9.18167331
762 Mayer B, Muris P, Bos AE, . Disgust sensitivity and eating disorder symptoms in a non-clinical population. J Behav Ther Exp Psychiatry. 2008 Dec;39(4):504–14. doi: 10.1016/j.jbtep.2007.11.007. PMID: 18295745. Exclusion Code: X9.18295745
763 Mazure CM, Halmi KA, Sunday SR, . The Yale-Brown-Cornell Eating Disorder Scale: development, use, reliability and validity. J Psychiatr Res. 1994 Sep–Oct;28(5):425–45. doi: 10.1016/0022-3956(94)90002-7. PMID: 7897615. Exclusion Code: X8.7897615
764 Mazzeo SE, Kelly NR, Stern M, . LIBER8 design and methods: an integrative intervention for loss of control eating among African American and White adolescent girls. Contemp Clin Trials. 2013 Jan;34(1):174–85. doi: 10.1016/j.cct.2012.10.012. PMID: 23142669. Exclusion Code: X7.23142669
765 Mazzeo SE, Lydecker J, Harney M, . Development and preliminary effectiveness of an innovative treatment for binge eating in racially diverse adolescent girls. Eat Behav. 2016 Aug;22:199–205. doi: 10.1016/j.eatbeh.2016.06.014. PMID: 27299699. Exclusion Code: X7.27299699
766 McCann UD, Agras WS. Successful treatment of nonpurging bulimia nervosa with desipramine: A double-blind, placebo-controlled study. The American Journal of Psychiatry. 1990;147(11):1509–13. doi: 10.1176/ajp.147.11.1509. PMID: 1991-07992-001. Exclusion Code: X14.2221164
767 McCarthy DM, Simmons JR, Smith GT, . Reliability, stability, and factor structure of the Bulimia Test-Revised and Eating Disorder Inventory-2 scales in adolescence. Assessment. 2002 Dec;9(4):382–9. doi: 10.1177/1073191102238196. PMID: 12462758. Exclusion Code: X4.12462758
768 McCarthy MK, Goff DC, Baer L, . Dissociation, childhood trauma, and the response to fluoxetine in bulimic patients. Int J Eat Disord. 1994 Apr;15(3):219–26. doi: 10.1002/1098-108x(199404)15:3<219::aid-eat2260150304>3.0.co;2-f. PMID: 8199601. Exclusion Code: X7.8199601
769 McClelland J, Hodsoll J, Brown A, . A pilot evaluation of a novel First Episode and Rapid Early Intervention service for Eating Disorders (FREED). Eur Eat Disord Rev. 2018 Mar;26(2):129–40. doi: 10.1002/erv.2579. PMID: 29460477. Exclusion Code: X9.29460477
770 McComb JJ, Clopton JR. The effects of movement, relaxation, and education on the stress levels of women with subclinical levels of bulimia. Eat Behav. 2003;4(1):79–88. PMID: CN-00473546. Exclusion Code: X10.15000989
771 McElroy S, Hudson J, Ferreira-Cornwell MC, . Randomized controlled safety and efficacy trials of lisdexamfetamine dimesylate for adults with moderate to severe binge eating disorder. CNS Spectr. 2015;20(1):74-. doi: 10.1017/S1092852914000765. PMID: CN-01294688. Exclusion Code: X13.
772 McElroy S, Mitchell J, Wilfley D, . Efficacy and safety of lisdexamfetamine dimesylate in treatment of adults with binge eating disorder: a randomized double-blind, placebo-controlled trial. Neuropsychopharmacology. 2012;38:S333–S4. doi: 10.1038/npp.2012.221. PMID: CN-01058041. Exclusion Code: X13.
773 McElroy SL, Guerdjikova A, Kotwal R, . Atomoxetine in the treatment of binge-eating disorder: a randomized placebo-controlled trial. J Clin Psychiatry. 2007 Mar;68(3):390–8. doi: 10.4088/jcp.v68n0306. PMID: 17388708. Exclusion Code: X14.17388708
774 McElroy SL, Guerdjikova AI, Blom TJ, . A placebo-controlled pilot study of the novel opioid receptor antagonist ALKS-33 in binge eating disorder. Int J Eat Disord. 2013 Apr;46(3):239–45. doi: 10.1002/eat.22114. PMID: 23381803. Exclusion Code: X5.23381803
775 McElroy SL, Guerdjikova AI, Mori N, . Armodafinil in binge eating disorder: a randomized, placebo-controlled trial. Int Clin Psychopharmacol. 2015 Jul;30(4):209–15. doi: 10.1097/yic.0000000000000079. PMID: 26011779. Exclusion Code: X7.26011779
776 McElroy SL, Guerdjikova AI, Winstanley EL, . Acamprosate in the treatment of binge eating disorder: a placebo-controlled trial. Int J Eat Disord. 2011 Jan;44(1):81–90. doi: 10.1002/eat.20876. PMID: 21080416. Exclusion Code: X14.21080416
777 McElroy SL, Hudson JI, Gasior M, . Time course of the effects of lisdexamfetamine dimesylate in two phase 3, randomized, double-blind, placebo-controlled trials in adults with binge-eating disorder. Int J Eat Disord. 2017 Aug;50(8):884–92. doi: 10.1002/eat.22722. PMID: 28481434. Exclusion Code: X7.28481434
778 McElroy SL, Hudson JI, Malhotra S, . Citalopram in the treatment of binge-eating disorder: a placebo-controlled trial. J Clin Psychiatry. 2003 Jul;64(7):807–13. doi: 10.4088/jcp.v64n0711. PMID: 12934982. Exclusion Code: X14.12934982
779 McElroy SL, Kotwal R, Guerdjikova AI, . Zonisamide in the treatment of binge eating disorder with obesity: a randomized controlled trial. J Clin Psychiatry. 2006 Dec;67(12):1897–906. doi: 10.4088/jcp.v67n1209. PMID: 17194267. Exclusion Code: X14.17194267
780 McElroy SL, Shapira NA, Arnold LM, . Topiramate in the long-term treatment of binge-eating disorder associated with obesity. J Clin Psychiatry. 2004 Nov;65(11):1463–9. doi: 10.4088/jcp.v65n1104. PMID: 15554757. Exclusion Code: X7.15554757
781 McElroy SL, Shapira NA, Arnold LM, . ‘Topiramate in the long-term treatment of binge-eating disorder associated with obesity’: correction. J Clin Psychiatry. 2005;66(1):138-. PMID: 2005-00996-031. Exclusion Code: X7.
782 McEnery F, Fitzgerald A, McNicholas F, . Fit for Purpose, Psychometric Assessment of the Eating Attitudes Test-26 in an Irish Adolescent Sample. Eat Behav. 2016 Dec;23:52–7. doi: 10.1016/j.eatbeh.2016.07.006. PMID: 27497273. Exclusion Code: X7.27497273
783 McEvoy PM, Targowski K, McGrath D, . Efficacy of a brief group intervention for carers of individuals with eating disorders: A randomized control trial. Int J Eat Disord. 2019 Sep;52(9):987–95. doi: 10.1002/eat.23121. PMID: 31199017. Exclusion Code: X3.31199017
784 McIntosh VV, Carter FA, Bulik CM, . Five-year outcome of cognitive behavioral therapy and exposure with response prevention for bulimia nervosa. Psychol Med. 2011 May;41(5):1061–71. doi: 10.1017/s0033291710001583. PMID: 20810005. Exclusion Code: X7.20810005
785 McLester CN, Hardin R, Hoppe S. Susceptibility to eating disorders among collegiate female student-athletes. J Athl Train. 2014 May–Jun;49(3):406–10. doi: 10.4085/1062-6050-49.2.16. PMID: 24762233. Exclusion Code: X9.24762233
786 McNicolas F, Dooley B, Keogh L, . Eating problems in Irish children and adolescence—EPICA. Ir J Psychol Med. 2010;27(4):172–8. doi: 10.1017/S0790966700001476. PMID: 2010-26302-002. Exclusion Code: X7.30199926
787 McNulty KY, Adams CH, Anderson JM, . Development and validation of a screening tool to identify eating disorders in female athletes. J Am Diet Assoc. 2001 Aug;101(8):886–92; quiz 93-4. doi: 10.1016/s0002-8223(01)00218-8. PMID: 11501862. Exclusion Code: X4.11501862
788 McNulty PA. Prevalence and contributing factors of eating disorder behaviors in active duty Navy men. Mil Med. 1997 Nov;162(11):753–8. PMID: 9358723. Exclusion Code: X7.9358723
789 Melchior C, Desprez C, Riachi G, . Anxiety and depression profile is associated with eating disorders in patients with irritable bowel syndrome. Frontiers in Psychiatry. 2020;10doi: 10.3389/fpsyt.2019.00928. PMID: 2020-05292-001. Exclusion Code: X3.
790 Melin A, Tornberg AB, Skouby S, . The LEAF questionnaire: a screening tool for the identification of female athletes at risk for the female athlete triad. Br J Sports Med. 2014 Apr;48(7):540–5. doi: 10.1136/bjsports-2013-093240. PMID: 24563388. Exclusion Code: X2.24563388
791 Menzel JE, Thompson JK, Levine MP. Development and validation of the Physical Activity Body Experiences Questionnaire. Bull Menninger Clin. 2019 Winter;83(1):53–83. doi: 10.1521/bumc.2019.83.1.53. PMID: 30888853. Exclusion Code: X4.30888853
792 Meule A, Allison KC, Platte P. A German version of the Night Eating Questionnaire (NEQ): psychometric properties and correlates in a student sample. Eat Behav. 2014 Dec;15(4):523–7. doi: 10.1016/j.eatbeh.2014.07.002. PMID: 25094066. Exclusion Code: X2.25094066
793 Meule A, Freund R, Skirde AK, . Heart rate variability biofeedback reduces food cravings in high food cravers. Appl Psychophysiol Biofeedback. 2012 Dec;37(4):241–51. doi: 10.1007/s10484-012-9197-y. PMID: 22688890. Exclusion Code: X2.22688890
794 Micali N, Simonoff E, Treasure J. Infant feeding and weight in the first year of life in babies of women with eating disorders. J Ped. 2009;154(1):55–60. doi: 10.1016/j.jpeds.2008.07.003. PMID: 2010-06017-015. Exclusion Code: X3.
795 Milano W, Petrella C, Casella A, . Use of sibutramine, an inhibitor of the reuptake of serotonin and noradrenaline, in the treatment of binge eating disorder: a placebo-controlled study. Adv Ther. 2005 Jan–Feb;22(1):25–31. doi: 10.1007/bf02850181. PMID: 15943219. Exclusion Code: X5.15943219
796 Milano W, Petrella C, Sabatino C, . Treatment of bulimia nervosa with sertraline: a randomized controlled trial. Adv Ther. 2004 Jul–Aug;21(4):232–7. doi: 10.1007/bf02850155. PMID: 15605617. Exclusion Code: X14.15605617
797 Milano W, Siano C, Putrella C, . Treatment of bulimia nervosa with fluvoxamine: a randomized controlled trial. Adv Ther. 2005 May–Jun;22(3):278–83. doi: 10.1007/bf02849936. PMID: 16236688. Exclusion Code: X14.16236688
798 Miller KK, Grieco KA, Klibanski A. Testosterone administration in women with anorexia nervosa. J Clin Endocrinol Metab. 2005 Mar;90(3):1428–33. doi: 10.1210/jc.2004-1181. PMID: 15613421. Exclusion Code: X3.15613421
799 Mills IH, Park GR, Manara AR, . Treatment of compulsive behaviour in eating disorders with intermittent ketamine infusions. QJM. 1998 Jul;91(7):493–503. doi: 10.1093/qjmed/91.7.493. PMID: 9797933. Exclusion Code: X3.9797933
800 Mintz LB, O’Halloran MS. The Eating Attitudes Test: validation with DSM-IV eating disorder criteria. J Pers Assess. 2000 Jun;74(3):489–503. doi: 10.1207/s15327752jpa7403_11. PMID: 10900574. Exclusion Code: X4.10900574
801 Misra M, Katzman DK, Estella NM, . Impact of physiologic estrogen replacement on anxiety symptoms, body shape perception, and eating attitudes in adolescent girls with anorexia nervosa: data from a randomized controlled trial. J Clin Psychiatry. 2013 Aug;74(8):e765–71. doi: 10.4088/JCP.13m08365. PMID: 24021517. Exclusion Code: X10.24021517
802 Mitchell JE, Agras S, Crow S, . Stepped care and cognitive-behavioural therapy for bulimia nervosa: randomised trial. Br J Psychiatry. 2011 May;198(5):391–7. doi: 10.1192/bjp.bp.110.082172. PMID: 21415046. Exclusion Code: X7.21415046
803 Mitchell JE, Christenson G, Jennings J, . A placebo-controlled, double-blind crossover study of naltrexone hydrochloride in outpatients with normal weight bulimia. J Clin Psychopharmacol. 1989 Apr;9(2):94–7. doi: 10.1097/00004714-198904000-00004. PMID: 2656781. Exclusion Code: X14.2656781
804 Mitchell JE, Crosby RD, Wonderlich SA, . A randomized trial comparing the efficacy of cognitive-behavioral therapy for bulimia nervosa delivered via telemedicine versus face-to-face. Behav Res Ther. 2008 May;46(5):581–92. doi: 10.1016/j.brat.2008.02.004. PMID: 18374304. Exclusion Code: X7.18374304
805 Mitchell JE, Gosnell BA, Roerig JL, . Effects of sibutramine on binge eating, hunger, and fullness in a laboratory human feeding paradigm. Obes Res. 2003 May;11(5):599–602. doi: 10.1038/oby.2003.85. PMID: 12740447. Exclusion Code: X8.12740447
806 Mitchell JE, Groat R. A placebo-controlled, double-blind trial of amitriptyline in bulimia. J Clin Psychopharmacol. 1984 Aug;4(4):186–93. PMID: 6381556. Exclusion Code: X7.6381556
807 Mitchell JE, Pyle RL, Eckert ED, . Response to alternative antidepressants in imipramine nonresponders with bulimia nervosa. J Clin Psychopharmacol. 1989 Aug;9(4):291–3. PMID: 2671061. Exclusion Code: X5.2671061
808 Mitchell JE, Pyle RL, Eckert ED, . A comparison study of antidepressants and structured intensive group psychotherapy in the treatment of bulimia nervosa. Arch Gen Psychiatry. 1990 Feb;47(2):149–57. doi: 10.1001/archpsyc.1990.01810140049008. PMID: 2405806. Exclusion Code: X14.2405806
809 Mitchell JE, Pyle RL, Eckert ED, . Antidepressants vs. group therapy in the treatment of bulimia. Psychopharmacol Bull. 1987;23(1):41–4. PMID: 3602329. Exclusion Code: X7.3602329
810 Mitchell SA, Newton R, Harrison P, . Does collaborative case conceptualisation enhance engagement and outcome in the treatment of anorexia nervosa? Rational, design and methods. Contemp Clin Trials. 2016;47:296–303. doi: 10.1016/j.cct.2015.12.011. PMID: CN-01138125. Exclusion Code: X7.26707946
811 Mizes JS, Christiano B, Madison J, . Development of the mizes anorectic cognitions questionnaire-revised: psychometric properties and factor structure in a large sample of eating disorder patients. Int J Eat Disord. 2000 Dec;28(4):415–21. doi: 10.1002/1098-108x(200012)28:4<415::aid-eat9>3.0.co;2-z. PMID: 11054788. Exclusion Code: X4.11054788
812 Modi AC, Zeller MH. The IWQOL-Kids©: Establishing minimal clinically important difference scores and test-retest reliability. Int J Pediatr Obes. 2011;6(2–2):e94–e6. doi: 10.3109/17477166.2010.500391. PMID: 2011-14759-010. Exclusion Code: X9.20883106
813 Moessner M, Minarik C, Ozer F, . Effectiveness and Cost-effectiveness of School-based Dissemination Strategies of an Internet-based Program for the Prevention and Early Intervention in Eating Disorders: A Randomized Trial. Prev Sci. 2016 Apr;17(3):306–13. doi: 10.1007/s11121-015-0619-y. PMID: 26581198. Exclusion Code: X5.26581198
814 Molinari E, Baruffi M, Croci M, . Binge eating disorder in obesity: comparison of different therapeutic strategies. Eat Weight Disord. 2005 Sep;10(3):154–61. doi: 10.1007/bf03327542. PMID: 16277137. Exclusion Code: X7.16277137
815 Mond J, Hall A, Bentley C, . Eating-disordered behavior in adolescent boys: eating disorder examination questionnaire norms. Int J Eat Disord. 2014 May;47(4):335–41. doi: 10.1002/eat.22237. PMID: 24338639. Exclusion Code: X7.24338639
816 Mond JM, Hay PJ, Rodgers B, . Temporal stability of the Eating Disorder Examination Questionnaire. Int J Eat Disord. 2004 Sep;36(2):195–203. doi: 10.1002/eat.20017. PMID: 15282689. Exclusion Code: X9.15282689
817 Mond JM, Hay PJ, Rodgers B, . Validity of the Eating Disorder Examination Questionnaire (EDE-Q) in screening for eating disorders in community samples. Behav Res Ther. 2004 May;42(5):551–67. doi: 10.1016/s0005-7967(03)00161-x. PMID: 15033501. Exclusion Code: X4.15033501
818 Mond JM, Rodgers B, Hay PJ, . Mode of delivery, but not questionnaire length, affected response in an epidemiological study of eating-disordered behavior. J Clin Epidemiol. 2004 Nov;57(11):1167–71. doi: 10.1016/j.jclinepi.2004.02.017. PMID: 15567633. Exclusion Code: X7.15567633
819 Mondelli V, Gianotti L, Picu A, . Neuroendocrine effects of citalopram infusion in anorexia nervosa. Psychoneuroendocrinology. 2006 Nov;31(10):1139–48. doi: 10.1016/j.psyneuen.2006.08.006. PMID: 17045409. Exclusion Code: X9.17045409
820 Mondraty N, Birmingham CL, Touyz S, . Randomized controlled trial of olanzapine in the treatment of cognitions in anorexia nervosa. Australasian Psychiatry. 2005;13(1):72–5. doi: 10.1111/j.1440-1665.2004.02154.x. PMID: 2005-04795-012. Exclusion Code: X7.15777417
821 Monge MC, Forman SF, McKenzie NM, . Use of Psychopharmacologic Medications in Adolescents With Restrictive Eating Disorders: Analysis of Data From the National Eating Disorder Quality Improvement Collaborative. J Adolesc Health. 2015 Jul;57(1):66–72. doi: 10.1016/j.jadohealth.2015.03.021. PMID: 26095410. Exclusion Code: X9.26095410
822 Morgan HG, Purgold J, Welbourne J. Management and outcome in anorexia nervosa. A standardized prognostic study. Br J Psychiatry. 1983 Sep;143:282–7. doi: 10.1192/bjp.143.3.282. PMID: 6626842. Exclusion Code: X9.6626842
823 Mountford VA, Brown A, Bamford B, . BodyWise: evaluating a pilot body image group for patients with anorexia nervosa. Eur Eat Disord Rev. 2015 Jan;23(1):62–7. doi: 10.1002/erv.2332. PMID: 25382845. Exclusion Code: X8.25382845
824 Moya T, Fleitlich-Bilyk B, Goodman R, . The Eating Disorders Section of the Development and Well-Being Assessment (DAWBA): development and validation. Braz J Psychiatry. 2005 Mar;27(1):25–31. doi: 10.1590/s1516-44462005000100008. PMID: 15867980. Exclusion Code: X7.15867980
825 Mueller A, Holzapfel C, Hauner H, . Psychometric evaluation of the German version of the impact of weight on Quality of Life-Lite (IWQOL-Lite) questionnaire. Exp Clin Endocrinol Diabetes. 2011 Feb;119(2):69–74. doi: 10.1055/s-0030-1261922. PMID: 20658439. Exclusion Code: X7.20658439
826 Munkholm A, Olsen EM, Rask CU, . Eating behaviours in preadolescence are associated with body dissatisfaction and mental disorders - Results of the CCC2000 study. Appetite. 2016 Jun 1;101:46–54. doi: 10.1016/j.appet.2016.02.020. PMID: 26896837. Exclusion Code: X9.26896837
827 Munsch S, Biedert E, Meyer AH, . CCK, ghrelin, and PYY responses in individuals with binge eating disorder before and after a cognitive behavioral treatment (CBT). Physiol Behav. 2009 Apr 20;97(1):14–20. doi: 10.1016/j.physbeh.2009.01.015. PMID: 19419677. Exclusion Code: X7.19419677
828 Munsch S, Wyssen A, Vanhulst P, . Binge-eating disorder treatment goes online - feasibility, usability, and treatment outcome of an Internet-based treatment for binge-eating disorder: study protocol for a three-arm randomized controlled trial including an immediate treatment, a waitlist, and a placebo control group. Trials. 2019 Feb 13;20(1):128. doi: 10.1186/s13063-019-3192-z. PMID: 30760299. Exclusion Code: X7.30760299
829 Murati DA, Shamsi H, Knyahnytska Y, . Reward sensitivity, impulsivity, and treatment response in binge eating disorder. Canadian journal of diabetes. 2015;39:S27-. PMID: CN-01098361. Exclusion Code: X13.
830 Murray K, Schmidt U, Pombo-Carril M-G, . Does therapist guidance improve uptake, adherence and outcome from a CD-ROM based cognitive-behavioral intervention for the treatment of bulimia nervosa? Comput Human Behav. 2007;23(1):850–9. doi: 10.1016/j.chb.2004.11.014. PMID: 2006-11390-049. Exclusion Code: X7.
831 Murray SB, Brown TA, Blashill AJ, . The development and validation of the muscularity-oriented eating test: A novel measure of muscularity-oriented disordered eating. Int J Eat Disord. 2019 Dec;52(12):1389–98. doi: 10.1002/eat.23144. PMID: 31343090. Exclusion Code: X9.31343090
832 Mussell MP, Mitchell JE, Crosby RD, . Commitment to treatment goals in prediction of group cognitive-behavioral therapy treatment outcome for women with bulimia nervosa. J Consult Clin Psychol. 2000 Jun;68(3):432–7. doi: 10.1037//0022-006x.68.3.432. PMID: 10883560. Exclusion Code: X7.10883560
833 Mustelin L, Kärkkäinen U, Kaprio J, . The Eating Disorder Inventory in the screening for DSM-5 binge eating disorder. Eat Behav. 2016 Aug;22:145–8. doi: 10.1016/j.eatbeh.2016.06.011. PMID: 27289520. Exclusion Code: X4.27289520
834 Mustelin L, Lehtokari VL, Keski-Rahkonen A. Other specified and unspecified feeding or eating disorders among women in the community. Int J Eat Disord. 2016 Nov;49(11):1010–7. doi: 10.1002/eat.22586. PMID: 27442991. Exclusion Code: X7.27442991
835 Mustelin L, Silén Y, Raevuori A, . The DSM-5 diagnostic criteria for anorexia nervosa may change its population prevalence and prognostic value. J Psychiatr Res. 2016 Jun;77:85–91. doi: 10.1016/j.jpsychires.2016.03.003. PMID: 27014849. Exclusion Code: X9.27014849
836 Nagamitsu S, Fukai Y, Uchida S, . Validation of a childhood eating disorder outcome scale. Biopsychosoc Med. 2019;13doi: 10.1186/s13030-019-0162-3. PMID: 2019-55755-001. Exclusion Code: X9.
837 Nagel DL. Evaluation of a screening test to detect female college athletes with eating disorders and disordered eating: ProQuest Information & Learning; 2002. Exclusion Code: X9.
838 Nakano K. Confirmatory factor analysis of the eating disorder inventory. Psychol Rep. 2005 Aug;97(1):337–8. doi: 10.2466/pr0.97.1.337-338. PMID: 16279342. Exclusion Code: X7.16279342
839 Nangle DW, Johnson WG, Carr-Nangle RE, . Binge eating disorder and the proposed DSM-IV criteria: psychometric analysis of the Questionnaire of Eating and Weight Patterns. Int J Eat Disord. 1994 Sep;16(2):147–57. doi: 10.1002/1098-108x(199409)16:2<147::aid-eat2260160206>3.0.co;2-p. PMID: 7987349. Exclusion Code: X3.7987349
840 Naser N, Hudson J, McElroy S, . Lisdexamfetamine dimesylate in adults with moderate-to-severe binge eating disorder: a double-blind, placebo-controlled, randomized-withdrawal study. Aust N Z J Psychiatry. 2016;50:163-. doi: 10.1177/0004867416640967. PMID: CN-01766938. Exclusion Code: X13.
841 Naser N, McElroy S, Hudson J, . Lisdexamfetamine dimesylate for adults with moderate to severe binge eating disorder: results of two randomized controlled safety and efficacy trials. Australian and new zealand journal of psychiatry. 2015;49:116. doi: 10.1177/0004867415578344. PMID: CN-01100807. Exclusion Code: X13.
842 Nasser M. The validity of the Eating Attitude Test in a non-Western population. Acta Psychiatr Scand. 1986;73(1):109–10. doi: 10.1111/j.1600-0447.1986.tb02675.x. PMID: 1987-12338-001. Exclusion Code: X4.3457522
843 Nasser M. The psychometric properties of the Eating Attitude Test in a non-Western population. Soc Psychiatry Psychiatr Epidemiol. 1994 Apr;29(2):88–94. doi: 10.1007/bf00805628. PMID: 8009325. Exclusion Code: X7.8009325
844 Navarro-Haro MV, Botella C, Guillen V, . Dialectical behavior therapy in the treatment of borderline personality disorder and eating disorders comorbidity: A pilot study in a naturalistic setting. Cognit Ther Res. 2018;42(5):636–49. doi: 10.1007/s10608-018-9906-9. PMID: 2018-42944-001. Exclusion Code: X7.
845 Navia B, Hudson J, McElroy S, . Dasotraline for treatment of adults with moderate to severe binge-eating disorder: effect on behavioral outcomes. Neuropsychopharmacology. 2017;43:S360–S1. doi: 10.1038/npp.2017.265. PMID: CN-01439331. Exclusion Code: X13.
846 Navia B, Hudson JI, McElroy SL, . Dasotraline for the treatment of moderate to severe binge eating disorder in adults: results from a randomizeduble-blind, placebocontrolled study. CNS Spectr. 2018;23(1):72–3. doi: 10.1017/S1092852918000135. PMID: CN-01915159. Exclusion Code: X13.
847 Nederkoorn C, Smulders F, Havermans R, . Exposure to binge food in bulimia nervosa: Finger pulse amplitude as a potential measure of urge to eat and predictor of food intake. Appetite. 2004;42(2):125–30. doi: 10.1016/j.appet.2003.11.001. PMID: 2004-12315-001. Exclusion Code: X5.15010175
848 Neumark-Sztainer D, Eisenberg ME, Fulkerson JA, . Family meals and disordered eating in adolescents: longitudinal findings from project EAT. Arch Pediatr Adolesc Med. 2008 Jan;162(1):17–22. doi: 10.1001/archpediatrics.2007.9. PMID: 18180407. Exclusion Code: X9.18180407
849 Nevonen L, Broberg AG. Validating the Eating Disorder Inventory-2 (EDI-2) in Sweden. Eat Weight Disord. 2001 Jun;6(2):59–67. doi: 10.1007/bf03339754. PMID: 11456423. Exclusion Code: X9.11456423
850 Nevonen L, Broberg AG, Clinton D, . A measure for the assessment of eating disorders: reliability and validity studies of the Rating of Anorexia and Bulimia interview - revised version (RAB-R). Scand J Psychol. 2003 Sep;44(4):303–10. doi: 10.1111/1467-9450.00349. PMID: 12887551. Exclusion Code: X3.12887551
851 Nevonen L, Clinton D, Norring C. Validating the EDI-2 in three Swedish female samples: eating disorders patients, psychiatric outpatients and normal controls. Nord J Psychiatry. 2006;60(1):44–50. doi: 10.1080/08039480500504537. PMID: 16500799. Exclusion Code: X3.16500799
852 Nevonen L, Mark M, Levin B, . Evaluation of a new Internet-based self-help guide for patients with bulimic symptoms in Sweden. Nord J Psychiatry. 2006;60(6):463–8. doi: 10.1080/08039480601021993. PMID: 17162454. Exclusion Code: X9.17162454
853 Nicholls D, Chater R, Lask B. Children into DSM don’t go: a comparison of classification systems for eating disorders in childhood and early adolescence. Int J Eat Disord. 2000 Nov;28(3):317–24. doi: 10.1002/1098-108x(200011)28:3<317::aid-eat9>3.0.co;2-#. PMID: 10942918. Exclusion Code: X4.10942918
854 Nickel C, Tritt K, Muehlbacher M, . Topiramate treatment in bulimia nervosa patients: a randomized, double-blind, placebo-controlled trial. Int J Eat Disord. 2005 Dec;38(4):295–300. doi: 10.1002/eat.20202. PMID: 16231337. Exclusion Code: X10.16231337
855 Niemiec MA, Boswell JF, Hormes JM. Development and initial validation of the obsessive compulsive eating scale. Obesity (Silver Spring). 2016 Aug;24(8):1803–9. doi: 10.1002/oby.21529. PMID: 27296154. Exclusion Code: X4.27296154
856 Nilsson F, Madsen JOB, Jensen AK, . High prevalence of disordered eating behavior in Danish children and adolescents with type 1 diabetes. Pediatr Diabetes. 2020 May 16doi: 10.1111/pedi.13043. PMID: 32418266. Exclusion Code: X9.32418266
857 Nilsson K, Engström I, Hägglöf B. Family climate and recovery in adolescent onset eating disorders: a prospective study. Eur Eat Disord Rev. 2012 Jan;20(1):e96–102. doi: 10.1002/erv.1127. PMID: 21774042. Exclusion Code: X4.21774042
858 Niv N, Kaplan Z, Mitrani E, . Validity study of the EDI-2 in Israeli population. Isr J Psychiatry Relat Sci. 1998;35(4):287–92. PMID: 9988986. Exclusion Code: X4.9988986
859 Norris ML, Spettigue W, Buchholz A, . Olanzapine use for the adjunctive treatment of adolescents with anorexia nervosa. J Child Adolesc Psychopharmacol. 2011 Jun;21(3):213–20. doi: 10.1089/cap.2010.0131. PMID: 21510781. Exclusion Code: X7.21510781
860 North C, Gowers S. Anorexia nervosa, psychopathology, and outcome. Int J Eat Disord. 1999 Dec;26(4):386–91. doi: 10.1002/(sici)1098-108x(199912)26:4<386::aid-eat3>3.0.co;2-a. PMID: 10550778. Exclusion Code: X4.10550778
861 North C, Gowers S, Byram V. Family functioning and life events in the outcome of adolescent anorexia nervosa. Br J Psychiatry. 1997 Dec;171:545–9. doi: 10.1192/bjp.171.6.545. PMID: 9519094. Exclusion Code: X9.9519094
862 Nunes MA, Camey S, Olinto MT, . The validity and 4-year test-retest reliability of the Brazilian version of the Eating Attitudes Test-26. Braz J Med Biol Res. 2005 Nov;38(11):1655–62. doi: 10.1590/s0100-879x2005001100013. PMID: 16258635. Exclusion Code: X3.16258635
863 Nunes MA, Pinheiro AP, Camey SA, . Binge eating during pregnancy and birth outcomes: a cohort study in a disadvantaged population in Brazil. Int J Eat Disord. 2012 Nov;45(7):827–31. doi: 10.1002/eat.22024. PMID: 22531873. Exclusion Code: X7.22531873
864 Nunes-Neto PR, Köhler CA, Schuch FB, . Psychometric properties of the modified Yale Food Addiction Scale 20 in a large Brazilian sample. Brazilian Journal of Psychiatry. 2018;40(4):444–8. doi: 10.1590/1516-4446-2017-2432. PMID: 2019-03984-015. Exclusion Code: X9.29898195
865 Nussbaum M, Shenker IR, Baird D, . Follow-up investigation in patients with anorexia nervosa. J Pediatr. 1985 May;106(5):835–40. doi: 10.1016/s0022-3476(85)80369-3. PMID: 3998927. Exclusion Code: X8.3998927
866 Nyman-Carlsson E, Engström I, Norring C, . Eating Disorder Inventory-3, validation in Swedish patients with eating disorders, psychiatric outpatients and a normal control sample. Nord J Psychiatry. 2015 Feb;69(2):142–51. doi: 10.3109/08039488.2014.949305. PMID: 25434459. Exclusion Code: X7.25434459
867 Obeid N, Norris ML, Buchholz A, . Development of the Ottawa Disordered Eating Screen for Youth: The ODES-Y. J Pediatr. 2019 Dec;215:209–15. doi: 10.1016/j.jpeds.2019.08.018. PMID: 31610932. Exclusion Code: X9.31610932
868 O’Brien KM. Reducing maladaptive weight management practices: Developing a psychoeducational intervention program: ProQuest Information & Learning; 2005. Exclusion Code: X3.
869 O’Brien KM, LeBow MD. Reducing maladaptive weight management practices: developing a psychoeducational intervention program. Eat Behav. 2007 Apr;8(2):195–210. doi: 10.1016/j.eatbeh.2006.06.001. PMID: 17336790. Exclusion Code: X3.17336790
870 Ohara C, Sekiguchi A, Takakura S, . Effectiveness of enhanced cognitive behavior therapy for bulimia nervosa in Japan: A randomized controlled trial protocol. Biopsychosoc Med. 2020;14doi: 10.1186/s13030-020-0174-z. PMID: 2020-14896-001. Exclusion Code: X7.
871 Okamoto Y, Miyake Y, Nagasawa I, . Cohort survey of college students’ eating attitudes: Interventions for depressive symptoms and stress coping were key factors for preventing bulimia in a subthreshold group. Biopsychosoc Med. 2018;12doi: 10.1186/s13030-018-0127-y. PMID: 2018-25332-001. Exclusion Code: X9.
872 Oldershaw A, Lavender T, Schmidt U. Are socio-emotional and neurocognitive functioning predictors of therapeutic outcomes for adults with anorexia nervosa? Eur Eat Disord Rev. 2018 Jul;26(4):346–59. doi: 10.1002/erv.2602. PMID: 29744972. Exclusion Code: X7.29744972
873 Olmsted MP, Daneman D, Rydall AC, . The effects of psychoeducation on disturbed eating attitudes and behavior in young women with type 1 diabetes mellitus. Int J Eat Disord. 2002 Sep;32(2):230–9. doi: 10.1002/eat.10068. PMID: 12210667. Exclusion Code: X3.12210667
874 Olmsted MP, Davis R, Garner DM, . Efficacy of a brief group psychoeducational intervention for bulimia nervosa. Behav Res Ther. 1991;29(1):71–83. doi: 10.1016/s0005-7967(09)80009-0. PMID: 2012591. Exclusion Code: X7.2012591
875 O’Malley SS, Sinha R, Grilo CM, . Naltrexone and cognitive behavioral coping skills therapy for the treatment of alcohol drinking and eating disorder features in alcohol-dependent women: a randomized controlled trial. Alcohol Clin Exp Res. 2007 Apr;31(4):625–34. doi: 10.1111/j.1530-0277.2007.00347.x. PMID: 17374042. Exclusion Code: X3.17374042
876 Ong YL, Checkley SA, Russell GF. Suppression of bulimic symptoms with methylamphetamine. Br J Psychiatry. 1983;143:288–93. doi: 10.1192/bjp.143.3.288. PMID: 1984-10243-001. Exclusion Code: X7.6354341
877 Orbitello B, Ciano R, Corsaro M, . The EAT-26 as screening instrument for clinical nutrition unit attenders. Int J Obes (Lond). 2006 Jun;30(6):977–81. doi: 10.1038/sj.ijo.0803238. PMID: 16432540. Exclusion Code: X4.16432540
878 Ordman AM, Kirschenbaum DS. Cognitive-behavioral therapy for bulimia: an initial outcome study. J Consult Clin Psychol. 1985 Jun;53(3):305–13. doi: 10.1037//0022-006x.53.3.305. PMID: 3859502. Exclusion Code: X7.3859502
879 Orlandi E, Covezzi R, Galeazzi GM, . The Italian version of the Body Cathexis Scale. Eat Weight Disord. 2006 Sep;11(3):e79–84. doi: 10.1007/bf03327562. PMID: 17075233. Exclusion Code: X4.17075233
880 Orlandi E, Mannucci E, Cuzzolaro M. Bulimic Investigatory Test, Edinburgh (BITE). A validation study of the Italian version. Eat Weight Disord. 2005 Mar;10(1):e14–20. doi: 10.1007/bf03354662. PMID: 16682850. Exclusion Code: X4.16682850
881 Osman A, Chiros CE, Gutierrez PM, . Factor structure and psychometric properties of the brief Mizes Anorectic Cognitions questionnaire. J Clin Psychol. 2001 Jun;57(6):785–99. doi: 10.1002/jclp.1049. PMID: 11344465. Exclusion Code: X4.11344465
882 Pacanowski CR, Mason TB, Crosby RD, . Weight Change over the Course of Binge Eating Disorder Treatment: relationship to Binge Episodes and Psychological Factors. Obesity (silver spring, md.). 2018;(no pagination)doi: 10.1002/oby.22149. PMID: CN-01464371. Exclusion Code: X7.
883 Pacanowski CR, Senso MM, Oriogun K, . Binge eating behavior and weight loss maintenance over a 2-year period. J Obes. 2014;2014:249315. doi: 10.1155/2014/249315. PMID: 24891946. Exclusion Code: X7.24891946
884 Padierna A, Quintana JM, Arostegui I, . Changes in health related quality of life among patients treated for eating disorders. Qual Life Res. 2002 Sep;11(6):545–52. doi: 10.1023/a:1016324527729. PMID: 12206575. Exclusion Code: X7.12206575
885 Palavras MA, Hay P, Mannan H, . Integrated weight loss and cognitive behavioural therapy (CBT) for the treatment of recurrent binge eating and high body mass index: a randomized controlled trial. Eat Weight Disord. 2020 Jan 25doi: 10.1007/s40519-020-00846-2. PMID: 31983019. Exclusion Code: X7.31983019
886 Palmeira L, Cunha M, Pinto-Gouveia J, . New developments in the assessment of weight-related experiential avoidance (AAQW-Revised). Journal of Contextual Behavioral Science. 2016;5(3):193–200. doi: 10.1016/j.jcbs.2016.06.001. PMID: 2016-44115-009. Exclusion Code: X4.
887 Palmer RL, Birchall H, McGrain L, . Self-help for bulimic disorders: a randomised controlled trial comparing minimal guidance with face-to-face or telephone guidance. Br J Psychiatry. 2002 Sep;181:230–5. doi: 10.1192/bjp.181.3.230. PMID: 12204928. Exclusion Code: X7.12204928
888 Paslakis G, Maas S, Gebhardt B, . Prospective, randomized, double-blind, placebo-controlled phase IIa clinical trial on the effects of an estrogen-progestin combination as add-on to inpatient psychotherapy in adult female patients suffering from anorexia nervosa. BMC Psychiatry. 2018 Apr 10;18(1):93. doi: 10.1186/s12888-018-1683-1. PMID: 29631553. Exclusion Code: X8.29631553
889 Pasman L, Thompson JK. Body image and eating disturbance in obligatory runners, obligatory weightlifters, and sedentary individuals. Int J Eat Disord. 1988;7(6):759–69. doi: 10.1002/1098-108X(198811)7:6<759::AID-EAT2260070605>3.0.CO;2-G. PMID: 1989-23021-001.
890 Pataky Z, Gasteyger C, Ziegler O, . Efficacy of rimonabant in obese patients with binge eating disorder. Exp Clin Endocrinol Diabetes. 2013 Jan;121(1):20–6. doi: 10.1055/s-0032-1329957. PMID: 23147209. Exclusion Code: X7.23147209
891 Patjanasoontorn N, Paholpak S, Krisanaprakornkit T. Validity and reliability study of the Thai version of WHO Schedules for Clinical Assessment in Neuropsychiatry: Eating Disorders Section. J Med Assoc Thai. 2011 Apr;94(4):490–7. PMID: 21591536. Exclusion Code: X4.21591536
892 Patlaka C, Tubic B, Lång P, . Intensive weight gain therapy in patients with anorexia nervosa results in improved serum tartrate-resistant acid phosphatase (TRAP) 5a and 5b isoform protein levels. Eat Weight Disord. 2019 Sep 17doi: 10.1007/s40519-019-00776-8. PMID: 31531762. Exclusion Code: X3.31531762
893 Patton GC, Coffey C, Sawyer SM. The outcome of adolescent eating disorders: findings from the Victorian Adolescent Health Cohort Study. Eur Child Adolesc Psychiatry. 2003;12(Suppl 1):I25–9. doi: 10.1007/s00787-003-1104-x. PMID: 12567212. Exclusion Code: X7.12567212
894 Paxton AE, Strycker LA, Toobert DJ, . Starting the conversation: performance of a brief dietary assessment and intervention tool for health professionals. Am J Prev Med. 2011;40(1):67–71. doi: 10.1016/j.amepre.2010.10.009. PMID: 2015-13019-001. Exclusion Code: X4.21146770
895 Peak NJ, Mizes JS, Guillard RP, Jr. Investigating the use of the Mizes Anorectic Cognitions Questionnaire in a community sample of racially diverse high school males and females. Eat Behav. 2012 Apr;13(2):94–9. doi: 10.1016/j.eatbeh.2011.12.004. PMID: 22365789. Exclusion Code: X9.22365789
896 Pearson CM, Guller L, McPherson L, . Validation of an existing measure of eating disorder risk for use with early adolescents. Eat Behav. 2013 Apr;14(2):113–8. doi: 10.1016/j.eatbeh.2013.01.006. PMID: 23557805. Exclusion Code: X4.23557805
897 Pecsok EH, Fremouw WJ. Controlling laboratory binging among restrained eaters through self-monitoring and cognitive restructuring procedures. Addict Behav. 1988;13(1):37–44. doi: 10.1016/0306-4603(88)90023-8. PMID: 3364222. Exclusion Code: X2.3364222
898 Peláez-Fernández MA, Javier Labrador F, Raich RM. Validation of eating disorder examination questionnaire (EDE-Q)-Spanish version-for screening eating disorders. Span J Psychol. 2012 Jul;15(2):817–24. doi: 10.5209/rev_sjop.2012.v15.n2.38893. PMID: 22774455. Exclusion Code: X4.22774455
899 Peláez-Fernández MA, Labrador FJ, Raich RM. Comparison of single- and double-stage designs in the prevalence estimation of eating disorders in community samples. Span J Psychol. 2008 Nov;11(2):542–50. PMID: 18988439. Exclusion Code: X4.18988439
900 Pellicciari A, Gualandi S, Iero L, . Psychometric evaluation of SAFA P test for eating disorders in adolescents: comparative validation with EDI-2. Eur Eat Disord Rev. 2012 Jan;20(1):e108–13. doi: 10.1002/erv.1099. PMID: 21308872. Exclusion Code: X3.21308872
901 Pellicciari A, Gualandi S, Iero L, . Psychometric evaluation of SAFA B test for eating disorders in adolescents: Comparative validation with EDI-2. Eur Eat Disord Rev. 2012;20(1):e108–e13. doi: 10.1002/erv.1099. PMID: 2012-00197-026. Exclusion Code: X8.21308872
902 Penelo E, Negrete A, Portell M, . Psychometric properties of the Eating Disorder Examination Questionnaire (EDE-Q) and norms for rural and urban adolescent males and females in Mexico. PLoS One. 2013;8(12):e83245. doi: 10.1371/journal.pone.0083245. PMID: 24367587. Exclusion Code: X7.24367587
903 Pereira AT, Maia B, Bos S, . The Portuguese short form of the Eating Attitudes Test-40. Eur Eat Disord Rev. 2008 Jul;16(4):319–25. doi: 10.1002/erv.846. PMID: 18059073. Exclusion Code: X7.18059073
904 Perpiñá C, Cebolla A, Botella C, . Emotional Eating Scale for children and adolescents: psychometric characteristics in a Spanish sample. J Clin Child Adolesc Psychol. 2011;40(3):424–33. doi: 10.1080/15374416.2011.563468. PMID: 21534053. Exclusion Code: X4.21534053
905 Perpiñá C, Giraldo-O’Meara M, Roncero M, . Confirmatory factor analysis and psychometric properties of the Yale-Brown-Cornell Eating Disorders Scale Self-Report version (SR-YBC-EDS) in Spanish clinical and non-clinical samples. Eat Behav. 2015 Apr;17:6–9. doi: 10.1016/j.eatbeh.2014.12.005. PMID: 25528716. Exclusion Code: X3.25528716
906 Perpiñá C, Giraldo-O’Meara M, Roncero M, . Confirmatory factor analysis and psychometric properties of the Yale–Brown–Cornell Eeating Disorders Scale Self-Report version (SR-YBC-EDS) in Spanish clinical and non-clinical samples. Eat Behav. 2015;17:6–9. doi: 10.1016/j.eatbeh.2014.12.005. PMID: 2015-13595-003. Exclusion Code: X3.25528716
907 Perry L, Morgan J, Reid F, . Screening for symptoms of eating disorders: reliability of the SCOFF screening tool with written compared to oral delivery. Int J Eat Disord. 2002;32(4):466–72. doi: 10.1002/eat.10093. PMID: CN-00443957. Exclusion Code: X7.12386911
908 Peterson CB, Crosby RD, Wonderlich SA, . Psychometric properties of the eating disorder examination-questionnaire: factor structure and internal consistency. Int J Eat Disord. 2007 May;40(4):386–9. doi: 10.1002/eat.20373. PMID: 17304585. Exclusion Code: X4.17304585
909 Peterson CB, Crow SJ, Nugent S, . Predictors of treatment outcome for binge eating disorder. Int J Eat Disord. 2000 Sep;28(2):131–8. doi: 10.1002/1098-108x(200009)28:2<131::aid-eat1>3.0.co;2-6. PMID: 10897074. Exclusion Code: X7.10897074
910 Peterson CB, Mitchell JE, Crow SJ, . The efficacy of self-help group treatment and therapist-led group treatment for binge eating disorder. Am J Psychiatry. 2009 Dec;166(12):1347–54. doi: 10.1176/appi.ajp.2009.09030345. PMID: 19884223. Exclusion Code: X14.19884223
911 Peterson CB, Mitchell JE, Engbloom S, . Group cognitive-behavioral treatment of binge eating disorder: a comparison of therapist-led versus self-help formats. Int J Eat Disord. 1998 Sep;24(2):125–36. doi: 10.1002/(sici)1098-108x(199809)24:2<125::aid-eat2>3.0.co;2-g. PMID: 9697011. Exclusion Code: X14.9697011
912 Pettersen G, Rosenvinge JH, Bakland M, . Patients’ and therapists’ experiences with a new treatment programme for eating disorders that combines physical exercise and dietary therapy: the PED-t trial. A qualitative study protocol. BMJ Open. 2018 Jan 8;8(1):e018708. doi: 10.1136/bmjopen-2017-018708. PMID: 29317417. Exclusion Code: X9.29317417
913 Phillips KE, Jennings KM, Gregas M. Factor structure of the eating disorder examination-questionnaire in a clinical sample of adult women with anorexia nervosa. J Psychosoc Nurs Ment Health Serv. 2018 May 1;56(5):33–9. doi: 10.3928/02793695-20180108-03. PMID: 29328356. Exclusion Code: X4.29328356
914 Pike KM, Walsh BT, Vitousek K, . Cognitive behavior therapy in the posthospitalization treatment of anorexia nervosa. Am J Psychiatry. 2003 Nov;160(11):2046–9. doi: 10.1176/appi.ajp.160.11.2046. PMID: 14594754. Exclusion Code: X3.14594754
915 Pinna F, Diana E, Sanna L, . Assessment of eating disorders with the diabetes eating problems survey - revised (DEPS-R) in a representative sample of insulin-treated diabetic patients: a validation study in Italy. BMC Psychiatry. 2017 Jul 19;17(1):262. doi: 10.1186/s12888-017-1434-8. PMID: 28724422. Exclusion Code: X9.28724422
916 Pinna F, Milia P, Mereu A, . Validation of the Italian version of the Compensatory Eating and Behaviors in Response to Alcohol Consumption Scale (CEBRACS). Eat Behav. 2015 Dec;19:120–6. doi: 10.1016/j.eatbeh.2015.08.004. PMID: 26356633. Exclusion Code: X4.26356633
917 Pinto AM, Heinberg LJ, Coughlin JW, . The Eating Disorder Recovery Self-Efficacy Questionnaire (EDRSQ): change with treatment and prediction of outcome. Eat Behav. 2008 Apr;9(2):143–53. doi: 10.1016/j.eatbeh.2007.07.001. PMID: 18329592. Exclusion Code: X3.18329592
918 Pinto-Gouveia J, Carvalho SA, Palmeira L, . BEfree: A new psychological program for binge eating that integrates psychoeducation, mindfulness, and compassion. Clin Psychol Psychother. 2017 Sep;24(5):1090–8. doi: 10.1002/cpp.2072. PMID: 28124451. Exclusion Code: X9.28124451
919 Pisetsky EM, Durkin NE, Crosby RD, . Examination of early group dynamics and treatment outcome in a randomized controlled trial of group cognitive behavior therapy for binge eating disorder. Behav Res Ther. 2015 Oct;73:74–8. doi: 10.1016/j.brat.2015.07.013. PMID: 26264648. Exclusion Code: X7.26264648
920 Pitts S, Divasta A, Gordon CM. Percentage body fat by dual-energy X-ray absorptiometry is associated with menstrual recovery in adolescents with anorexia nervosa. J Adolesc Health. 2014;54(6):739–41. doi: 10.1016/j.jadohealth.2013.12.033. PMID: CN-01038688. Exclusion Code: X7.24613094
921 Plateau CR, Arcelus J, Meyer C. Detecting eating psychopathology in female athletes by asking about exercise: use of the compulsive exercise test. Eur Eat Disord Rev. 2017 Nov;25(6):618–24. doi: 10.1002/erv.2561. PMID: 29057602. Exclusion Code: X7.29057602
922 Pliatskidou S, Samakouri M, Kalamara E, . Validity of the Greek Eating Disorder Examination Questionnaire 6.0 (EDE-Q-6.0) among Greek adolescents. Psychiatriki. 2015 Jul–Sep;26(3):204–16. PMID: 26480225. Exclusion Code: X4.26480225
923 Podina IR, Fodor LA, Cosmoiu A, . An evidence-based gamified mHealth intervention for overweight young adults with maladaptive eating habits: study protocol for a randomized controlled trial. Trials. 2017;18(1):592. doi: 10.1186/s13063-017-2340-6. PMID: CN-01621677. Exclusion Code: X3.29233169
924 Pook M, Tuschen-Caffier B. Sensitivity to change of scales assessing symptoms of bulimia nervosa. Psychiatry Res. 2004 Aug 30;128(1):71–8. doi: 10.1016/j.psychres.2003.03.001. PMID: 15450916. Exclusion Code: X7.15450916
925 Pope HG, Hudson JI. Antidepressant drug therapy for bulimia: Current status. The Journal of Clinical Psychiatry. 1986;47(7):339–45. PMID: 1987-32219-001. Exclusion Code: X9.3087968
926 Pope HG, Jr., Hudson JI, Jonas JM, . Bulimia treated with imipramine: a placebo-controlled, double-blind study. Am J Psychiatry. 1983 May;140(5):554–8. doi: 10.1176/ajp.140.5.554. PMID: 6342421. Exclusion Code: X3.6342421
927 Pope HG, Jr., Keck PE, Jr., McElroy SL, . A placebo-controlled study of trazodone in bulimia nervosa. J Clin Psychopharmacol. 1989 Aug;9(4):254–9. PMID: 2671058. Exclusion Code: X14.2671058
928 Popkess-Vawter S, Owens V. Use of the BULIT bulimia screening questionnaire to assess risk and progress in weight management for overweight women who weight cycle. BULImia Test. Addict Behav. 1999 Jul–Aug;24(4):497–507. doi: 10.1016/s0306-4603(98)00101-4. PMID: 10466845. Exclusion Code: X4.10466845
929 Popkess-Vawter S, Owens V. Use of the BULIT bulimia screening questionnaire to assess risk and progress in weight management for overweight women who weight cycle. Addict Behav. 1999;24(4):497–507. doi: 10.1016/S0306-4603(98)00101-4. PMID: 1999-03493-004. Exclusion Code: X3.10466845
930 Powers MA, Richter S, Ackard D, . Development and validation of the Screen for Early Eating Disorder Signs (SEEDS) in persons with type 1 diabetes. Eat Disord. 2016 May–Jun;24(3):271–88. doi: 10.1080/10640266.2015.1090866. PMID: 26467220. Exclusion Code: X3.26467220
931 Powers PS, Klabunde M, Kaye W. Double-blind placebo-controlled trial of quetiapine in anorexia nervosa. Eur Eat Disord Rev. 2012 Jul;20(4):331–4. doi: 10.1002/erv.2169. PMID: 22535517. Exclusion Code: X3.22535517
932 Preuss H, Pinnow M, Schnicker K, . Improving Inhibitory Control Abilities (ImpulsE)-A Promising Approach to Treat Impulsive Eating? Eur Eat Disord Rev. 2017 Nov;25(6):533–43. doi: 10.1002/erv.2544. PMID: 28901678. Exclusion Code: X7.28901678
933 Prnjak K, Mitchison D, Griffiths S, . Further development of the 12-item EDE-QS: identifying a cut-off for screening purposes. BMC Psychiatry. 2020 Apr 3;20(1):146. doi: 10.1186/s12888-020-02565-5. PMID: 32245441. Exclusion Code: X9.32245441
934 Probst M, Pieters G, Vanderlinden J. Evaluation of body experience questionnaires in eating disorders in female patients (AN/BN) and nonclinical participants. Int J Eat Disord. 2008 Nov;41(7):657–65. doi: 10.1002/eat.20531. PMID: 18446834. Exclusion Code: X7.18446834
935 Probst M, Pieters G, Vanderlinden J. Body experience assessment in non-clinical male and female subjects. Eat Weight Disord. 2009 Mar;14(1):e16–21. doi: 10.1007/bf03354623. PMID: 19367132. Exclusion Code: X9.19367132
936 Probst M, Van Coppenolle H, Vandereycken W. Further experience with the Body Attitude Test. Eat Weight Disord. 1997 Jun;2(2):100–4. doi: 10.1007/bf03339956. PMID: 14655849. Exclusion Code: X3.14655849
937 Probst M, Vandereycken W, Van Coppenolle H, . Body experience in eating disorders before and after treatment: a follow-up study. Eur Psychiatry. 1999 Oct;14(6):333–40. doi: 10.1016/s0924-9338(99)00159-5. PMID: 10572365. Exclusion Code: X3.10572365
938 Provencher V, Bégin C, Tremblay A, . Short-term effects of a ‘Health-At-Every-Size’ approach on eating behaviors and appetite ratings. Obesity. 2007;15(4):957–66. doi: 10.1038/oby.2007.638. PMID: 2007-06200-006. Exclusion Code: X3.17426331
939 Provini F, Albani F, Vetrugno R, . A pilot double-blind placebo-controlled trial of low-dose pramipexole in sleep-related eating disorder. Eur J Neurol. 2005 Jun;12(6):432–6. doi: 10.1111/j.1468-1331.2005.01017.x. PMID: 15885046. Exclusion Code: X2.15885046
940 Pung MA. Motivational interviewing in the reduction of risk factors for eating disorders: A pilot study: ProQuest Information & Learning; 2004. Exclusion Code: X5.
941 Pyle RL, Mitchell JE, Eckert ED, . Maintenance treatment and 6-month outcome for bulimic patients who respond to initial treatment. Am J Psychiatry. 1990 Jul;147(7):871–5. doi: 10.1176/ajp.147.7.871. PMID: 2192562. Exclusion Code: X3.2192562
942 Quintana MI, Andreoli SB, Jorge MR, . The reliability of the Brazilian version of the Composite International Diagnostic Interview (CIDI 2.1). Braz J Med Biol Res. 2004 Nov;37(11):1739–45. doi: 10.1590/s0100-879x2004001100020. PMID: 15517091. Exclusion Code: X4.15517091
943 Quirk-Baillot D, Flament MF, Allen A, . The Attitudes and Patterns of Eating (APE) Questionnaire: Development and factor analysis in a US adolescent community sample. Eat Weight Disord. 2012;17(2):e147–e56. doi: 10.1007/BF03325341. PMID: 2014-25672-012. Exclusion Code: X4.23010787
944 Rahmani M, Omidi A, Asemi Z, . The effect of dialectical behaviour therapy on binge eating, difficulties in emotion regulation and BMI in overweight patients with binge-eating disorder: A randomized controlled trial. Mental Health and Prevention. 2018;9:13–8. doi: 10.1016/j.mhp.2017.11.002. PMID: 2018-08876-002. Exclusion Code: X11.
945 Ramsay R, Ward A, Treasure J, . Compulsory treatment in anorexia nervosa. Short-term benefits and long-term mortality. Br J Psychiatry. 1999 Aug;175:147–53. doi: 10.1192/bjp.175.2.147. PMID: 10627797. Exclusion Code: X3.10627797
946 Ranzenhofer LM, Wilhelmy M, Hochschild A, . Peer mentorship as an adjunct intervention for the treatment of eating disorders: A pilot randomized trial. Int J Eat Disord. 2020 May;53(5):497–509. doi: 10.1002/eat.23258. PMID: 32159243. Exclusion Code: X3.32159243
947 Råstam M, Gillberg IC, Gillberg C. Anorexia nervosa 6 years after onset: Part II. Comorbid psychiatric problems. Compr Psychiatry. 1995 Jan–Feb;36(1):70–6. doi: 10.1016/0010-440x(95)90101-z. PMID: 7705091. Exclusion Code: X9.7705091
948 Rathner G, Bönsch C, Maurer G, . The impact of a ‘guided self-help group’ on bulimic women: a prospective 15 month study of attenders and non-attenders. J Psychosom Res. 1993 May;37(4):389–96. doi: 10.1016/0022-3999(93)90141-2. PMID: 8510065. Exclusion Code: X7.8510065
949 Rathner G, Messner K. Detection of eating disorders in a small rural town: an epidemiological study. Psychol Med. 1993 Feb;23(1):175–84. doi: 10.1017/s0033291700038964. PMID: 8475206. Exclusion Code: X4.8475206
950 Rathner G, Rainer B. The factor structure of the Anorexia Nervosa Inventory for Self-Rating in a population-based sample and derivation of a shortened form. Eur Arch Psychiatry Clin Neurosci. 1998;248(4):171–9. doi: 10.1007/s004060050035. PMID: 9810480. Exclusion Code: X7.9810480
951 Rathner G, Rumpold G. Convergent validity of the eating disorder inventory and the anorexia nervosa inventory for self-rating in an Austrian nonclinical population. Int J Eat Disord. 1994 Dec;16(4):381–93. doi: 10.1002/1098-108x(199412)16:4<381::aid-eat2260160407>3.0.co;2-q. PMID: 7866417. Exclusion Code: X7.7866417
952 Rausch Herscovici C. Lunch session, weight gain and their interaction with the psychopathology of anorexia nervosa in adolescents. Vertex (buenos aires, argentina). 2006;17(65):7–15. PMID: CN-00563476. Exclusion Code: X1.
953 Ravaldi C, Vannacci A, Truglia E, . The Eating Disorder Examination as a retrospective interview. Eat Weight Disord. 2004 Sep;9(3):228–31. doi: 10.1007/bf03325072. PMID: 15656019. Exclusion Code: X4.15656019
954 Raymond NC, de Zwaan M, Mitchell JE, . Effect of a very low calorie diet on the diagnostic category of individuals with binge eating disorder. Int J Eat Disord. 2002 Jan;31(1):49–56. doi: 10.1002/eat.1110. PMID: 11835297. Exclusion Code: X7.11835297
955 Reas DL, Grilo CM, Masheb RM. Reliability of the Eating Disorder Examination-Questionnaire in patients with binge eating disorder. Behav Res Ther. 2006 Jan;44(1):43–51. doi: 10.1016/j.brat.2005.01.004. PMID: 16301013. Exclusion Code: X7.16301013
956 Reas DL, Øverås M, Rø O. Norms for the Eating Disorder Examination Questionnaire (EDE-Q) among high school and university men. Eat Disord. 2012;20(5):437–43. doi: 10.1080/10640266.2012.715523. PMID: 22985240. Exclusion Code: X7.22985240
957 Reas DL, Rø O, Kapstad H, . Psychometric properties of the clinical impairment assessment: norms for young adult women. Int J Eat Disord. 2010 Jan;43(1):72–6. doi: 10.1002/eat.20653. PMID: 19260038. Exclusion Code: X9.19260038
958 Reas DL, Stedal K, Lindvall Dahlgren C, . Impairment due to eating disorder pathology: Identifying the cut-off score on the Clinical Impairment Assessment in a clinical and community sample. Int J Eat Disord. 2016 Jun;49(6):635–8. doi: 10.1002/eat.22517. PMID: 26968998. Exclusion Code: X3.26968998
959 Reas DL, Wisting L, Kapstad H, . Convergent validity of the eating disorder examination and the eating disorder examination-questionnaire among university women in Norway. Eur Eat Disord Rev. 2011 Jul–Aug;19(4):357–61. doi: 10.1002/erv.1068. PMID: 21714040. Exclusion Code: X9.21714040
960 Reinking MF, Alexander LE. Prevalence of disordered-eating behaviors in undergraduate female collegiate athletes and nonathletes. Journal of Athletic Training. 2005;40(1):47–51. PMID: 2005-03889-001. Exclusion Code: X7.15902324
961 Reyes-Rodríguez ML, Gulisano M, Silva Y, . “Las penas con pan duelen menos”: The role of food and culture in Latinas with disordered eating behaviors. Appetite. 2016 May 1;100:102–9. doi: 10.1016/j.appet.2016.02.029. PMID: 26911262. Exclusion Code: X9.26911262
962 Rhind C, Hibbs R, Goddard E, . Experienced Carers Helping Others (ECHO): protocol for a pilot randomised controlled trial to examine a psycho-educational intervention for adolescents with anorexia nervosa and their carers. Eur Eat Disord Rev. 2014 Jul;22(4):267–77. doi: 10.1002/erv.2298. PMID: 24888426. Exclusion Code: X9.24888426
963 Rhodes P, Brown J, Madden S. The Maudsley model of family-based treatment for anorexia nervosa: a qualitative evaluation of parent-to-parent consultation. J Marital Fam Ther. 2009 Apr;35(2):181–92. doi: 10.1111/j.1752-0606.2009.00115.x. PMID: 19302516. Exclusion Code: X3.19302516
964 Ribaudo JM, Cella D, Hahn EA, . Re-validation and shortening of the Functional Assessment of Anorexia/Cachexia Therapy (FAACT) questionnaire. Qual Life Res. 2000;9(10):1137–46. doi: 10.1023/a:1016670403148. PMID: 11401046. Exclusion Code: X3.11401046
965 Ricca V, Mannucci E, Mezzani B, . Fluoxetine and fluvoxamine combined with individual cognitive-behaviour therapy in binge eating disorder: a one-year follow-up study. Psychother Psychosom. 2001 Nov–Dec;70(6):298–306. doi: 10.1159/000056270. PMID: 11598429. Exclusion Code: X7.11598429
966 Richards LK, McHugh RK, Pratt EM, . Readability and comprehension of self-report binge eating measures. Eat Behav. 2013;14(2):167–70. doi: 10.1016/j.eatbeh.2013.02.003. PMID: 2013-12053-014. Exclusion Code: X7.23557814
967 Richter F, Strauss B, Braehler E, . Screening disordered eating in a representative sample of the German population: Usefulness and psychometric properties of the German SCOFF questionnaire. Eat Behav. 2017 Apr;25:81–8. doi: 10.1016/j.eatbeh.2016.06.022. PMID: 27354266. Exclusion Code: X7.27354266
968 Richter F, Strauss B, Braehler E, . Psychometric properties of a short version of the Eating Attitudes Test (EAT-8) in a German representative sample. Eat Behav. 2016 Apr;21:198–204. doi: 10.1016/j.eatbeh.2016.03.006. PMID: 26978119. Exclusion Code: X7.26978119
969 Rienecke RD, Accurso EC, Lock J, . Expressed Emotion, Family Functioning, and Treatment Outcome for Adolescents with Anorexia Nervosa. Eur Eat Disord Rev. 2016 Jan;24(1):43–51. doi: 10.1002/erv.2389. PMID: 26201083. Exclusion Code: X9.26201083
970 Rigaud D, Brondel L, Poupard AT, . A randomized trial on the efficacy of a 2-month tube feeding regimen in anorexia nervosa: A 1-year follow-up study. Clin Nutr. 2007 Aug;26(4):421–9. doi: 10.1016/j.clnu.2007.03.012. PMID: 17499892. Exclusion Code: X5.17499892
971 Rissanen A, Naukkarinen H, Virkkunen M, . Fluoxetine normalizes increased cardiac vagal tone in bulimia nervosa. J Clin Psychopharmacol. 1998 Feb;18(1):26–32. doi: 10.1097/00004714-199802000-00005. PMID: 9472839. Exclusion Code: X7.9472839
972 Riva G, Bacchetta M, Baruffi M, . Virtual-reality-based multidimensional therapy for the treatment of body image disturbances in binge eating disorders: a preliminary controlled study. IEEE Trans Inf Technol Biomed. 2002 Sep;6(3):224–34. doi: 10.1109/titb.2002.802372. PMID: 12381039. Exclusion Code: X3.12381039
973 Rivas T, Bersabé R, Jiménez M, . The Eating Attitudes Test (EAT-26): reliability and validity in Spanish female samples. Span J Psychol. 2010 Nov;13(2):1044–56. doi: 10.1017/s1138741600002687. PMID: 20977051. Exclusion Code: X4.20977051
974 Rivas T, Franco K, Bersabé R, . Spanish version of the eating attitudes test 40: dimensionality, reliability, convergent and criterion validity. Span J Psychol. 2013;16:E59. doi: 10.1017/sjp.2013.61. PMID: 24230922. Exclusion Code: X3.24230922
975 Rizvi SL, Peterson CB, Crow SJ, . Test-retest reliability of the eating disorder examination. Int J Eat Disord. 2000 Nov;28(3):311–6. doi: 10.1002/1098-108x(200011)28:3<311::aid-eat8>3.0.co;2-k. PMID: 10942917. Exclusion Code: X4.10942917
976 Rø Ø, Reas DL, Stedal K. Eating Disorder Examination Questionnaire (EDE-Q) in Norwegian Adults: Discrimination between Female Controls and Eating Disorder Patients. Eur Eat Disord Rev. 2015 Sep;23(5):408–12. doi: 10.1002/erv.2372. PMID: 26094887. Exclusion Code: X4.26094887
977 Robert SA, Ghani RA, Zainuddin S, . The influence of a GLP-1 analogue, liraglutide on binge eating behaviour among obese healthy participants. Obesity research and clinical practice. 2013;7:e39. doi: 10.1016/j.orcp.2013.12.576. PMID: CN-01060707. Exclusion Code: X13.
978 Robertson B, Wu J, Fant RV, . Assessment of Amphetamine Withdrawal Symptoms of Lisdexamfetamine Dimesylate Treatment for Adults With Binge-Eating Disorder. Prim Care Companion CNS Disord. 2020 Mar 26;22(2)doi: 10.4088/PCC.19m02540. PMID: 32237290. Exclusion Code: X9.32237290
979 Robin AL, Siegel PT, Koepke T, . Family therapy versus individual therapy for adolescent females with anorexia nervosa. J Dev Behav Pediatr. 1994 Apr;15(2):111–6. PMID: 8034762. Exclusion Code: X7.8034762
980 Robinson AH, Safer DL. Moderators of dialectical behavior therapy for binge eating disorder: Results from a randomized controlled trial. Int J Eat Disord. 2012;45(4):597–602. doi: 10.1002/eat.20932. PMID: 2012-09430-016. Exclusion Code: X7.21500238
981 Robinson AL, Strahan E, Girz L, . ‘I know I can help you’: parental self-efficacy predicts adolescent outcomes in family-based therapy for eating disorders. Eur Eat Disord Rev. 2013 Mar;21(2):108–14. doi: 10.1002/erv.2180. PMID: 22556060. Exclusion Code: X7.22556060
982 Robinson P, Barrett B, Bateman A, . Study Protocol for a randomized controlled trial of mentalization based therapy against specialist supportive clinical management in patients with both eating disorders and symptoms of borderline personality disorder. BMC Psychiatry. 2014 Feb 21;14:51. doi: 10.1186/1471-244x-14-51. PMID: 24555511. Exclusion Code: X7.24555511
983 Robinson P, Hellier J, Barrett B, . The NOURISHED randomised controlled trial comparing mentalisation-based treatment for eating disorders (MBT-ED) with specialist supportive clinical management (SSCM-ED) for patients with eating disorders and symptoms of borderline personality disorder. Trials. 2016 Nov 17;17(1):549. doi: 10.1186/s13063-016-1606-8. PMID: 27855714. Exclusion Code: X7.27855714
984 Robinson P, Serfaty M. Getting better byte by byte: a pilot randomised controlled trial of email therapy for bulimia nervosa and binge eating disorder. Eur Eat Disord Rev. 2008 Mar;16(2):84–93. doi: 10.1002/erv.818. PMID: 17879223. Exclusion Code: X14.17879223
985 Robinson PH, Checkley SA, Russell GF. Suppression of eating by fenfluramine in patients with bulimia nervosa. Br J Psychiatry. 1985 Feb;146:169–76. doi: 10.1192/bjp.146.2.169. PMID: 3856458. Exclusion Code: X5.3856458
986 Robinson TN, Banda JA, Hale L, . Screen media exposure and obesity in children and adolescents. Pediatrics. 2017;140(5, Supp 2):S97–S101. doi: 10.1542/peds.2016-1758K. PMID: 2018-42994-010. Exclusion Code: X2.29093041
987 Rodgers RF, Schaefer LM, Thompson JK, . Psychometric properties of the Sociocultural Attitudes Towards Appearance Questionnaire-4 (SATAQ-4) in French women and men. Body Image. 2016 Jun;17:143–51. doi: 10.1016/j.bodyim.2016.03.002. PMID: 27081747. Exclusion Code: X4.27081747
988 Rodrigues T, Vaz AR, Silva C, . Eating Disorder-15 (ED-15): Factor structure, psychometric properties, and clinical validation. Eur Eat Disord Rev. 2019 Nov;27(6):682–91. doi: 10.1002/erv.2694. PMID: 31257707. Exclusion Code: X3.31257707
989 Rodríguez-Cano T, Beato-Fernández L, Belmonte-Llario A. New contributions to the prevalence of eating disorders in Spanish adolescents: detection of false negatives. Eur Psychiatry. 2005 Mar;20(2):173–8. doi: 10.1016/j.eurpsy.2004.04.002. PMID: 15797703. Exclusion Code: X7.15797703
990 Rodríguez-Fernández A, Axpe I, Goñi A. Psychometric properties of a shortened version of the Physical Self-Concept Questionnaire (PSQ-S). Actas Esp Psiquiatr. 2015 Jul–Aug;43(4):125–32. PMID: 26150056. Exclusion Code: X4.26150056
991 Roehrig M, Thompson JK, Brannick M, . Dissonance-based eating disorder prevention program: a preliminary dismantling investigation. Int J Eat Disord. 2006 Jan;39(1):1–10. doi: 10.1002/eat.20217. PMID: 16254869. Exclusion Code: X3.16254869
992 Rohrbach PJ, Dingemans AE, Spinhoven P, . A randomized controlled trial of an Internet-based intervention for eating disorders and the added value of expert-patient support: study protocol. Trials. 2019 Aug 16;20(1):509. doi: 10.1186/s13063-019-3574-2. PMID: 31420063. Exclusion Code: X7.31420063
993 Rojo-Moreno L, García-Miralles I, Plumed J, . Children’s eating attitudes test: validation in a sample of Spanish schoolchildren. Int J Eat Disord. 2011 Sep;44(6):540–6. doi: 10.1002/eat.20855. PMID: 20957702. Exclusion Code: X4.20957702
994 Romano SJ, Halmi KA, Sarkar NP, . A placebo-controlled study of fluoxetine in continued treatment of bulimia nervosa after successful acute fluoxetine treatment. Am J Psychiatry. 2002 Jan;159(1):96–102. doi: 10.1176/appi.ajp.159.1.96. PMID: 11772696. Exclusion Code: X3.11772696
995 Roncero M, Barrada JR, Perpiñá C. Measuring orthorexia nervosa: psychometric limitations of the ORTO-15. Span J Psychol. 2017 Sep 20;20:E41. doi: 10.1017/sjp.2017.36. PMID: 28929989. Exclusion Code: X2.28929989
996 Rorty M, Yager J, Buckwalter JG, . Development and validation of the Parental Intrusiveness Rating Scale among bulimic and comparison women. Int J Eat Disord. 2000 Sep;28(2):188–201. doi: 10.1002/1098-108x(200009)28:2<188::aid-eat8>3.0.co;2-x. PMID: 10897081. Exclusion Code: X4.10897081
997 Rose KS, Cooper MJ, Turner H. The eating disorder belief questionnaire: psychometric properties in an adolescent sample. Eat Behav. 2006 Nov;7(4):410–8. doi: 10.1016/j.eatbeh.2006.01.006. PMID: 17056419. Exclusion Code: X4.17056419
998 Rose M, Davis J, Frampton I, . The Ravello Profile: development of a global standard neuropsychological assessment for young people with anorexia nervosa. Clin Child Psychol Psychiatry. 2011 Apr;16(2):195–202. doi: 10.1177/1359104511401191. PMID: 21502218. Exclusion Code: X4.21502218
999 Rosen JC, Jones A, Ramirez E, . Body Shape Questionnaire: Studies of validity and reliability. Int J Eat Disord. 1996;20(3):315–9. doi: 10.1002/(SICI)1098-108X(199611)20:3<315::AID-EAT11>3.0.CO;2-Z. PMID: 1997-02125-011. Exclusion Code: X4.8912044
1000 Rosenvinge JH, Engvik HA. Construction and validation of an anorexia nervosa scale on the MMPI. Eat Weight Disord. 1997 Sep;2(3):125–9. doi: 10.1007/bf03339962. PMID: 14655835. Exclusion Code: X4.14655835
1001 Rosling A, Salonen Ros H, Swenne I. One-year outcome and incidence of anorexia nervosa and restrictive eating disorders among adolescent girls treated as out-patients in a family-based setting. Ups J Med Sci. 2016;121(1):50–9. doi: 10.3109/03009734.2016.1141810. PMID: 26915921. Exclusion Code: X9.26915921
1002 Ross S. Acculturative stress, coping skills, and binge eating in African American women: ProQuest Information & Learning; 2015. Exclusion Code: X7.
1003 Rossiter EM, Agras WS, Telch CF, . Cluster B personality disorder characteristics predict outcome in the treatment of bulimia nervosa. Int J Eat Disord. 1993 May;13(4):349–57. doi: 10.1002/1098-108x(199305)13:4<349::aid-eat2260130403>3.0.co;2-c. PMID: 8490637. Exclusion Code: X7.8490637
1004 Rothschild L, Stein D. Treatment monitoring: changes in affective distress and dependency following symptom alleviation of eating disorders. J Am Psychoanal Assoc. 2009 Apr;57(2):451–6. doi: 10.1177/00030651090570020908. PMID: 19516066. Exclusion Code: X3.19516066
1005 Rothschild R, Quitkin HM, Quitkin FM, . A double-blind placebo-controlled comparison of phenelzine and imipramine in the treatment of bulimia in atypical depressives. Int J Eat Disord. 1994 Jan;15(1):1–9. doi: 10.1002/1098-108x(199401)15:1<1::aid-eat2260150102>3.0.co;2-e. PMID: 8124322. Exclusion Code: X9.8124322
1006 Rouel M, Raman J, Hay P, . Validation of the Behaviour Rating Inventory of Executive Function - Adult Version (BRIEF-A) in the obese with and without binge eating disorder. Eat Behav. 2016 Dec;23:58–65. doi: 10.1016/j.eatbeh.2016.07.010. PMID: 27497274. Exclusion Code: X5.27497274
1007 Rowe S, Jordan J, McIntosh V, . Dimensional measures of personality as a predictor of outcome at 5-year follow-up in women with bulimia nervosa. Psychiatry Res. 2011 Feb 28;185(3):414–20. doi: 10.1016/j.psychres.2010.07.017. PMID: 20692708. Exclusion Code: X7.20692708
1008 Rowe SL, Jordan J, McIntosh VV, . Does avoidant personality disorder impact on the outcome of treatment for bulimia nervosa? Int J Eat Disord. 2010 Jul;43(5):420–7. doi: 10.1002/eat.20716. PMID: 19536877. Exclusion Code: X7.19536877
1009 Rucci P, Maser JD. Instrument development in the Italy-USA Collaborative Spectrum Project. Epidemiol Psichiatr Soc. 2000 Oct–Dec;9(4):249–56. doi: 10.1017/s1121189x00008381. PMID: 11256057. Exclusion Code: X7.11256057
1010 Ruddock HK, Christiansen P, Halford JCG, . The development and validation of the Addiction-like Eating Behaviour Scale. Int J Obes (Lond). 2017 Nov;41(11):1710–7. doi: 10.1038/ijo.2017.158. PMID: 28676680. Exclusion Code: X9.28676680
1011 Rueda-Jaimes GE, Camacho López PA, Rangel-Martínez-Villalba AM. Internal consistency and validity of the BITE for the screening of bulimia nervosa in university students, Colombia. Eat Weight Disord. 2008 Jun;13(2):e35–9. PMID: 18612252. Exclusion Code: X11.18612252
1012 Ruffault A, Carette C, Lurbe IPK, . Randomized controlled trial of a 12-month computerized mindfulness-based intervention for obese patients with binge eating disorder: the MindOb study protocol. Contemp Clin Trials. 2016;49:126–33. doi: 10.1016/j.cct.2016.06.012. PMID: CN-01177316. Exclusion Code: X7.27370231
1013 Ruggiero GM, Mauri MC, Omboni AC, . Nutritional management of anorexic patients with and without fluoxetine: 1-year follow-up. Prog Neuropsychopharmacol Biol Psychiatry. 2003 May;27(3):425–30. doi: 10.1016/s0278-5846(03)00029-0. PMID: 12691777. Exclusion Code: X7.12691777
1014 Ruiz-Lázaro PM, Zapata MA, Calvo AI. The manualized zarima intervention: a pilot study of primary prevention of eating disorders. Eur Child Adolesc Psychiatry. 2013;22(2):S310–S1. doi: 10.1007/s00787-013-0423-9. PMID: CN-01006215. Exclusion Code: X13.
1015 Runfola CD, Kirby JS, Baucom DH, . A pilot open trial of UNITE-BED: A couple-based intervention for binge-eating disorder. Int J Eat Disord. 2018 Sep;51(9):1107–12. doi: 10.1002/eat.22919. PMID: 30189106. Exclusion Code: X7.30189106
1016 Rush AJ, Zimmerman M, Wisniewski SR, . Comorbid psychiatric disorders in depressed outpatients: demographic and clinical features. J Affect Disord. 2005 Jul;87(1):43–55. doi: 10.1016/j.jad.2005.03.005. PMID: 15894381. Exclusion Code: X3.15894381
1017 Russell GF, Checkley SA, Feldman J, . A controlled trial of d-fenfluramine in bulimia nervosa. Clin Neuropharmacol. 1988;11 Suppl 1:S146–59. PMID: 3052813. Exclusion Code: X5.3052813
1018 Russell GF, Szmukler GI, Dare C, . An evaluation of family therapy in anorexia nervosa and bulimia nervosa. Arch Gen Psychiatry. 1987 Dec;44(12):1047–56. doi: 10.1001/archpsyc.1987.01800240021004. PMID: 3318754. Exclusion Code: X3.3318754
1019 Russell J, Maguire S, Hunt GE, . Intranasal oxytocin in the treatment of anorexia nervosa: Randomized controlled trial during re-feeding. Psychoneuroendocrinology. 2018 Jan;87:83–92. doi: 10.1016/j.psyneuen.2017.10.014. PMID: 29049935. Exclusion Code: X8.29049935
1020 Ruwaard J, Lange A, Broeksteeg J, . Online cognitive-behavioural treatment of bulimic symptoms: a randomized controlled trial. Clin Psychol Psychother. 2013 Jul–Aug;20(4):308–18. doi: 10.1002/cpp.1767. PMID: 22298417. Exclusion Code: X3.22298417
1021 Ryujin DH, Breaux C, Marks AD. Symptoms of eating disorders among female distance runners: can the inconsistencies be unraveled? Women Health. 1999;30(1):71–83. doi: 10.1300/j013v30n01_05. PMID: 10813268. Exclusion Code: X7.10813268
1022 Sabine EJ, Yonace A, Farrington AJ, . Bulimia nervosa: a placebo controlled double-blind therapeutic trial of mianserin. Br J Clin Pharmacol. 1983;15 Suppl 2(Suppl 2):195s–202s. doi: 10.1111/j.1365-2125.1983.tb05866.x. PMID: 6337607. Exclusion Code: X5.6337607
1023 Safai-Kutti S. Oral zinc supplementation in anorexia nervosa. Acta Psychiatr Scand Suppl. 1990;361:14–7. PMID: 2291418. Exclusion Code: X7.2291418
1024 Safer DL, Adler S, Dalai SS, . A randomized, placebo-controlled crossover trial of phentermine-topiramate er in patients with binge-eating disorder and bulimia nervosa. Int J Eat Disord. 2019doi: 10.1002/eat.23192. PMID: 2019-69468-001. Exclusion Code: X14.
1025 Safer DL, Adler S, Dalai SS, . A randomized, placebo-controlled crossover trial of phentermine-topiramate ER in patients with binge-eating disorder and bulimia nervosa. Int J Eat Disord. 2020 Feb;53(2):266–77. doi: 10.1002/eat.23192. PMID: 31721257. Exclusion Code: X3.31721257
1026 Safer DL, Joyce EE. Does rapid response to two group psychotherapies for binge eating disorder predict abstinence? Behav Res Ther. 2011 May;49(5):339–45. doi: 10.1016/j.brat.2011.03.001. PMID: 21459363. Exclusion Code: X7.21459363
1027 Safer DL, Robinson AH, Jo B. Outcome from a randomized controlled trial of group therapy for binge eating disorder: comparing dialectical behavior therapy adapted for binge eating to an active comparison group therapy. Behav Ther. 2010 Mar;41(1):106–20. doi: 10.1016/j.beth.2009.01.006. PMID: 20171332. Exclusion Code: X7.20171332
1028 Safer DL, Telch CF, Agras WS. Dialectical behavior therapy for bulimia nervosa. Am J Psychiatry. 2001 Apr;158(4):632–4. doi: 10.1176/appi.ajp.158.4.632. PMID: 11282700. Exclusion Code: X10.11282700
1029 Sala M, Breithaupt L, Bulik CM, . A Double-Blind, Randomized Pilot Trial of Chromium Picolinate for Overweight Individuals with Binge-Eating Disorder: Effects on Glucose Regulation. J Diet Suppl. 2017 Mar 4;14(2):191–9. doi: 10.1080/19390211.2016.1207124. PMID: 27835050. Exclusion Code: X5.27835050
1030 Salbach-Andrae H, Klinkowski N, Holzhausen M, . The German version of the Anorectic Behavior Observation Scale (ABOS). Eur Child Adolesc Psychiatry. 2009 May;18(5):321–5. doi: 10.1007/s00787-008-0732-6. PMID: 19165534. Exclusion Code: X3.19165534
1031 Sancanuto C, Jiménez-Rodríguez D, Tébar FJ, . Translation and validation of the Diabetes Eating Problem Survey to screen eating disorders in patients with type-1 diabetes mellitus. Med Clin (Barc). 2017 Jun 21;148(12):548–54. doi: 10.1016/j.medcli.2016.12.035. PMID: 28238335. Exclusion Code: X7.28238335
1032 Sanchez-Armass O, Raffaelli M, Andrade FCD, . Validation of the SCOFF questionnaire for screening of eating disorders among Mexican university students. Eat Weight Disord. 2017 Mar;22(1):153–60. doi: 10.1007/s40519-016-0259-7. PMID: 26928282. Exclusion Code: X11.26928282
1033 Sánchez-Ortiz VC, House J, Munro C, . “A computer isn’t gonna judge you”: a qualitative study of users’ views of an internet-based cognitive behavioural guided self-care treatment package for bulimia nervosa and related disorders. Eat Weight Disord. 2011 Jun;16(2):e93–e101. doi: 10.1007/bf03325314. PMID: 21989103. Exclusion Code: X9.21989103
1034 Sánchez-Ortiz VC, Munro C, Startup H, . The role of email guidance in internet-based cognitive-behavioural self-care treatment for bulimia nervosa. Eur Eat Disord Rev. 2011 Jul–Aug;19(4):342–8. doi: 10.1002/erv.1074. PMID: 21394832. Exclusion Code: X7.21394832
1035 Santonastaso P, Favaretto G, Canton G. Anorexia nervosa in Italy: clinical features and outcome in a long-term follow-up study. Psychopathology. 1987;20(1):8–17. doi: 10.1159/000284473. PMID: 3628677. Exclusion Code: X3.3628677
1036 Santonastaso P, Friederici S, Favaro A. Sertraline in the treatment of restricting anorexia nervosa: an open controlled trial. J Child Adolesc Psychopharmacol. 2001 Summer;11(2):143–50. doi: 10.1089/104454601750284045. PMID: 11436953. Exclusion Code: X7.11436953
1037 Santonastaso P, Zanetti T, Sala A, . Prevalence of eating disorders in Italy: a survey on a sample of 16-year-old female students. Psychother Psychosom. 1996;65(3):158–62. doi: 10.1159/000289069. PMID: 8784948. Exclusion Code: X7.8784948
1038 Santoncini CU, García FJ, Peresmitré GG. Psychometric Properties of the Attitudes Towards Body Figure Questionnaire in Mexican Female Students and Patients With Eating Disorders. Eur Eat Disord Rev. 2006;14(6):430–5. doi: 10.1002/erv.757. PMID: 2006-22617-011. Exclusion Code: X3.
1039 Sarto HM, Barcelo-Soler A, Herrera-Mercadal P, . Efficacy of a mindful-eating programme to reduce emotional eating in patients suffering from overweight or obesity in primary care settings: a cluster-randomised trial protocol. BMJ open. 2019;9(11)doi: 10.1136/bmjopen-2019-031327. PMID: CN-02052234. Exclusion Code: X7.
1040 Saunders JF, Eaton AA, Fitzsimmons-Craft EE. Body-, eating-, and exercise-related comparisons during eating disorder recovery and validation of the BEECOM-R. Psychol Women Q. 2019;43(4):494–508. doi: 10.1177/0361684319851718. PMID: 2019-75221-008. Exclusion Code: X4.
1041 Scagliusi FB, Polacow VO, Cordás TA, . Psychometric testing and applications of the Body Attitudes Questionnaire translated into Portuguese. Percept Mot Skills. 2005 Aug;101(1):25–41. doi: 10.2466/pms.101.1.25-41. PMID: 16350606. Exclusion Code: X9.16350606
1042 Scagliusi FB, Polacow VO, Cordás TA, . Test-retest reliability and discriminant validity of the Restraint Scale translated into Portuguese. Eat Behav. 2005 Jan;6(1):85–93. doi: 10.1016/j.eatbeh.2004.06.001. PMID: 15567114. Exclusion Code: X3.15567114
1043 Schacht M, Richter-Appelt H, Schulte-Markwort M, . Eating Pattern Inventory for Children: a new self-rating questionnaire for preadolescents. J Clin Psychol. 2006 Oct;62(10):1259–73. doi: 10.1002/jclp.20300. PMID: 16897691. Exclusion Code: X3.16897691
1044 Schaefer LM, Burke NL, Thompson JK. Thin-ideal internalization: how much is too much? Eat Weight Disord. 2019 Oct;24(5):933–7. doi: 10.1007/s40519-018-0498-x. PMID: 29549566. Exclusion Code: X9.29549566
1045 Schaefer LM, Burke NL, Thompson JK, . Development and validation of the Sociocultural Attitudes Towards Appearance Questionnaire-4 (SATAQ-4). Psychol Assess. 2015;27(1):54–67. doi: 10.1037/a0037917. PMID: 2014-41973-001. Exclusion Code: X4.25285718
1046 Schaefer LM, Harriger JA, Heinberg LJ, . Development and validation of the sociocultural attitudes towards appearance questionnaire-4-revised (SATAQ-4R). Int J Eat Disord. 2017 Feb;50(2):104–17. doi: 10.1002/eat.22590. PMID: 27539814. Exclusion Code: X4.27539814
1047 Schaefer LM, Smith KE, Leonard R, . Identifying a male clinical cutoff on the Eating Disorder Examination-Questionnaire (EDE-Q). Int J Eat Disord. 2018 Dec;51(12):1357–60. doi: 10.1002/eat.22972. PMID: 30480321. Exclusion Code: X3.30480321
1048 Schaefer LM, Thompson JK. The development and validation of the Physical Appearance Comparison Scale-Revised (PACS-R). Eat Behav. 2014 Apr;15(2):209–17. doi: 10.1016/j.eatbeh.2014.01.001. PMID: 24854806. Exclusion Code: X4.24854806
1049 Schaefer LM, Thompson JK. The development and validation of the Physical Appearance Comparison Scale-3 (PACS-3). Psychol Assess. 2018 Oct;30(10):1330–41. doi: 10.1037/pas0000576. PMID: 29781660. Exclusion Code: X4.29781660
1050 Schag K, Leehr EJ, Martus P, . Impulsivity-focused group intervention to reduce binge eating episodes in patients with binge eating disorder: study protocol of the randomised controlled IMPULS trial. BMJ open. 2015;5(12):e009445. doi: 10.1136/bmjopen-2015-009445. PMID: CN-01179743. Exclusion Code: X7
1051 Schaumberg K, Zerwas S, Goodman E, . Anxiety disorder symptoms at age 10 predict eating disorder symptoms and diagnoses in adolescence. J Child Psychol Psychiatry. 2019 Jun;60(6):686–96. doi: 10.1111/jcpp.12984. PMID: 30353925. Exclusion Code: X7.30353925
1052 Scheinberg Z, Koslowsky M, Bleich A, . Sensitivity, specificity, and positive predictive value as measures of prediction accuracy: The case of the EAT-26. Educ Psychol Meas. 1993 Fal 1993;53(3):831–9. doi: 10.1177/0013164493053003027. PMID: 1994-08059-001. Exclusion Code: X4.
1053 Schlegel S, Hartman A, Jagau F, . Handling secondary exercise dependence (SndExD): the Freiburg sport-therapy program for patients with eating disorders. Journal of behavioral addictions. 2018;7:140-. doi: 10.1556/JBA.7.2018.Suppl.1. PMID: CN-01646600. Exclusion Code: X13.
1054 Schlüter N, Schmidt R, Kittel R, . Loss of control eating in adolescents from the community. Int J Eat Disord. 2016 Apr;49(4):413–20. doi: 10.1002/eat.22488. PMID: 26711325. Exclusion Code: X7.26711325
1055 Schmidt J, Martin A. Neurofeedback reduces overeating episodes in female restrained eaters: A randomized controlled pilot-study. Appl Psychophysiol Biofeedback. 2015;40(4):283–95. doi: 10.1007/s10484-015-9297-6. PMID: 2015-31542-001. Exclusion Code: X5.26164414
1056 Schmidt J, Martin A. Neurofeedback against binge eating: A randomized controlled trial in a female subclinical threshold sample. Eur Eat Disord Rev. 2016;24(5):406–16. doi: 10.1002/erv.2453. PMID: 2016-38583-006. Exclusion Code: X3.27121224
1057 Schmidt R, Kirsten T, Hiemisch A, . Interview-based assessment of avoidant/restrictive food intake disorder (ARFID): a pilot study evaluating an ARFID module for the Eating Disorder Examination. Int J Eat Disord. 2019 Apr;52(4):388–97. doi: 10.1002/eat.23063. PMID: 30843618. Exclusion Code: X7.30843618
1058 Schmidt U, Lee S, Perkins S, . Do adolescents with eating disorder not otherwise specified or full-syndrome bulimia nervosa differ in clinical severity, comorbidity, risk factors, treatment outcome or cost? Int J Eat Disord. 2008;41(6):498–504. doi: 10.1002/eat.20533. PMID: 2008-11661-003. Exclusion Code: X7.18433024
1059 Schmidt U, Magill N, Renwick B, . The Maudsley Outpatient Study of Treatments for Anorexia Nervosa and Related Conditions (MOSAIC): Comparison of the Maudsley Model of Anorexia Nervosa Treatment for Adults (MANTRA) with specialist supportive clinical management (SSCM) in outpatients with broadly defined anorexia nervosa: A randomized controlled trial. J Consult Clin Psychol. 2015 Aug;83(4):796–807. doi: 10.1037/ccp0000019. PMID: 25984803. Exclusion Code: X7.25984803
1060 Schmidt U, Marks IM. Exposure plus prevention of bingeing vs. exposure plus prevention of vomiting in bulimia nervosa. A crossover study. J Nerv Ment Dis. 1989 May;177(5):259–66. doi: 10.1097/00005053-198905000-00002. PMID: 2708970. Exclusion Code: X7.2708970
1061 Schmidt U, Oldershaw A, Jichi F, . Out-patient psychological therapies for adults with anorexia nervosa: randomised controlled trial. Br J Psychiatry. 2012;201(5):392–9. doi: 10.1192/bjp.bp.112.112078. PMID: CN-00850487. Exclusion Code: X7.22995632
1062 Schmidt U, Renwick B, Lose A, . The MOSAIC study - comparison of the Maudsley Model of Treatment for Adults with Anorexia Nervosa (MANTRA) with Specialist Supportive Clinical Management (SSCM) in outpatients with anorexia nervosa or eating disorder not otherwise specified, anorexia nervosa type: study protocol for a randomized controlled trial. Trials. 2013 May 30;14:160. doi: 10.1186/1745-6215-14-160. PMID: 23721562. Exclusion Code: X7.23721562
1063 Schoemaker C, van Strien T, van der Staak C. Validation of the eating disorders inventory in a nonclinical population using transformed and untransformed responses. Int J Eat Disord. 1994 May;15(4):387–93. doi: 10.1002/eat.2260150409. PMID: 8032353. Exclusion Code: X4.8032353
1064 Schoemaker C, Verbraak M, Breteler R, . The discriminant validity of the Eating Disorder Inventory-2. Br J Clin Psychol. 1997 Nov;36(4):627–9. doi: 10.1111/j.2044-8260.1997.tb01268.x. PMID: 9403154. Exclusion Code: X3.9403154
1065 Schulte EM, Gearhardt AN. Development of the Modified Yale Food Addiction Scale Version 2.0. Eur Eat Disord Rev. 2017 Jul;25(4):302–8. doi: 10.1002/erv.2515. PMID: 28370722. Exclusion Code: X7.28370722
1066 Schützmann K, Schützmann M, Eckert J. The efficacy of outpatient client-centered psychotherapy for bulimia nervosa: results of a randomised controlled trial. Psychother Psychosom Med Psychol. 2010;60(2):52–63. doi: 10.1055/s-0029-1234134. PMID: CN-00742844. Exclusion Code: X1.19753509
1067 Schwitzer A, Hatfield T, Jones AR, . Confirmation among college women: the eating disorders not otherwise specified diagnostic profile. J Am Coll Health. 2008 May–Jun;56(6):607–15. doi: 10.3200/jach.56.6.607-616. PMID: 18477514. Exclusion Code: X7.18477514
1068 Sedgwick P. Measuring the performance of screening tests. BMJ. 2014 Jul 7;348:g4438. doi: 10.1136/bmj.g4438. PMID: 25001573. Exclusion Code: X12.25001573
1069 Segura-García C, Aloi M, Rania M, . Ability of EDI-2 and EDI-3 to correctly identify patients and subjects at risk for eating disorders. Eat Behav. 2015 Dec;19:20–3. doi: 10.1016/j.eatbeh.2015.06.010. PMID: 26162592. Exclusion Code: X4.26162592
1070 Sehm M, Warschburger P. The specificity of psychological factors associated with binge eating in adolescent boys and girls. J Abnorm Child Psychol. 2015;43(8):1563–71. doi: 10.1007/s10802-015-0026-7. PMID: 2015-20173-001. Exclusion Code: X7.25936287
1071 Sehm M, Warschburger P. Prospective associations between binge eating and psychological risk factors in adolescence. J Clin Child Adolesc Psychol. 2018 Sep–Oct;47(5):770–84. doi: 10.1080/15374416.2016.1178124. PMID: 27399285. Exclusion Code: X7.27399285
1072 Seidel M, Petermann J, Diestel S, . A naturalistic examination of negative affect and disorder-related rumination in anorexia nervosa. Eur Child Adolesc Psychiatry. 2016;25(11):1207–16. doi: 10.1007/s00787-016-0844-3. PMID: 2016-16357-001. Exclusion Code: X9.27033353
1073 Selzer R, Hamill C, Bowes G, . The branched eating disorders test: validity in a nonclinical population. Int J Eat Disord. 1996 Jul;20(1):57–64. doi: 10.1002/(sici)1098-108x(199607)20:1<57::aid-eat7>3.0.co;2-3. PMID: 8807353. Exclusion Code: X7.8807353
1074 Sepúlveda AR, Anastasiadou D, Parks M, . A controlled study of the Collaborative Care Skills Workshops versus Psycho-educational Workshops among Spanish caregivers of relatives with an eating disorder. Eur Eat Disord Rev. 2019 May;27(3):247–62. doi: 10.1002/erv.2658. PMID: 30549146. Exclusion Code: X5.30549146
1075 Sepúlveda AR, Compte EJ, Faya M, . Spanish validation of the Eating Disorder Examination Questionnaire for Adolescents (EDE-Q-A): confirmatory factor analyses among a clinical sample. Eat Disord. 2019 Nov–Dec;27(6):565–76. doi: 10.1080/10640266.2019.1567154. PMID: 30758263. Exclusion Code: X7.30758263
1076 Serfaty MA, Turkington D, Heap M, . Cognitive therapy versus dietary counselling in the outpatient treatment of anorexia nervosa: effects of the treatment phase. Eur Eat Disord Rev. 1999;7(5):334–50. doi: 10.1002/(SICI)1099-0968(199911)7:5<334::AID-ERV311>3.0.CO;2-H. PMID: CN-00270600. Exclusion Code: X7.
1077 Serier KN, Smith JE, Yeater EA. Confirmatory factor analysis and measurement invariance of the Eating Disorder Examination Questionnaire (EDE-Q) in a non-clinical sample of non-Hispanic White and Hispanic women. Eat Behav. 2018 Dec;31:53–9. doi: 10.1016/j.eatbeh.2018.08.004. PMID: 30142550. Exclusion Code: X4.30142550
1078 Serrano-Troncoso E, Cañas L, Carbonell X, . Diagnostic Distribution of eating disorders: Comparison between DSMIV- TR and DSM-5. Actas Esp Psiquiatr. 2017 Jan;45(1):32–8. PMID: 28186317. Exclusion Code: X4.28186317
1079 Shafi M, Salguero C, Finch SM. Anorexia à deux. Psychopathology and treatment of anorexia nervosa in latency-age siblings. J Am Acad Child Psychiatry. 1975 Autumn;14(4):617–32. doi: 10.1016/s0002-7138(09)61461-8. PMID: 1184857. Exclusion Code: X12.1184857
1080 Shapiro JR, Berkman ND, Brownley KA, . Bulimia nervosa treatment: a systematic review of randomized controlled trials. Int J Eat Disord. 2007;40(4):321–36. doi: 10.1002/eat.20372. PMID: CN-01720676. Exclusion Code: X9.17370288
1081 Shapiro JR, Reba-Harrelson L, Dymek-Valentine M, . Feasibility and acceptability of CD-ROM-based cognitive-behavioural treatment for binge-eating disorder. Eur Eat Disord Rev. 2007 May;15(3):175–84. doi: 10.1002/erv.787. PMID: 17676687. Exclusion Code: X10.17676687
1082 Shapiro JR, Woolson SL, Hamer RM, . Evaluating binge eating disorder in children: development of the children’s binge eating disorder scale (C-BEDS). Int J Eat Disord. 2007 Jan;40(1):82–9. doi: 10.1002/eat.20318. PMID: 16958120. Exclusion Code: X3.16958120
1083 Sheehan DV, Sheehan KH, Shytle RD, . Reliability and validity of the Mini International Neuropsychiatric Interview for Children and Adolescents (MINI-KID). J Clin Psychiatry. 2010 Mar;71(3):313–26. doi: 10.4088/JCP.09m05305whi. PMID: 20331933. Exclusion Code: X4.20331933
1084 Shelley-Ummenhofer J, MacMillan PD. Cognitive-behavioural treatment for women who binge eat. Can J Diet Pract Res. 2007 Autumn;68(3):139–42. doi: 10.3148/68.3.2007.139. PMID: 17784972. Exclusion Code: X7.17784972
1085 Sherry SB, Hewitt PL, Besser A, . Self-oriented and socially prescribed perfectionism in the Eating Disorder Inventory Perfectionism subscale. Int J Eat Disord. 2004 Jan;35(1):69–79. doi: 10.1002/eat.10237. PMID: 14705159. Exclusion Code: X7.14705159
1086 Shimura M, Horie H, Kumano H, . Reliability and validity of a Japanese version of the Eating Disorder Inventory. Psychol Rep. 2003 Feb;92(1):131–40. doi: 10.2466/pr0.2003.92.1.131. PMID: 12674271. Exclusion Code: X3.12674271
1087 Shingleton RM, Pratt EM, Gorman B, . Motivational Text Message Intervention for Eating Disorders: a Single-Case Alternating Treatment Design Using Ecological Momentary Assessment. Behav Ther. 2016;47(3):325–38. doi: 10.1016/j.beth.2016.01.005. PMID: CN-01137903. Exclusion Code: X9.27157027
1088 Shu CY, Watson HJ, Anderson RA, . A randomized controlled trial of unguided internet cognitive behaviour therapy for perfectionism in adolescents: Impact on risk for eating disorders. Behav Res Ther. 2019 Sep;120:103429. doi: 10.1016/j.brat.2019.103429. PMID: 31279221. Exclusion Code: X3.31279221
1089 Signorini R, Sheffield J, Rhodes N, . The Effectiveness of Enhanced Cognitive Behavioural Therapy (CBT-E): A Naturalistic Study within an Out-Patient Eating Disorder Service. Behav Cogn Psychother. 2018 Jan;46(1):21–34. doi: 10.1017/s1352465817000352. PMID: 28625196. Exclusion Code: X7.28625196
1090 Silbert MV. The weight gain effect of periactin in anorexic patients. S Afr Med J. 1971 Apr 3;45(14):374–7. PMID: 4928691. Exclusion Code: X3.4928691
1091 Silén Y, Sipilä PN, Raevuori A, . DSM-5 eating disorders among adolescents and young adults in Finland: A public health concern. Int J Eat Disord. 2020 May;53(5):520–31. doi: 10.1002/eat.23236. PMID: 31999001. Exclusion Code: X9.31999001
1092 Silva L, Gomes AR, Martins C. Psychological factors related to eating disordered behaviors: a study with Portuguese athletes. Span J Psychol. 2011 May;14(1):323–35. doi: 10.5209/rev_sjop.2011.v14.n1.29. PMID: 21568189. Exclusion Code: X7.21568189
1093 Simeonov L, Cawley E, Kamboj S, . P.848 The effects of cognitive bias modification alone versus during reconsolidation of binge-eating memories: electrophysiological and behavioural changes during response inhibition. Eur Neuropsychopharmacol. 2019;29:S565-. doi: 10.1016/j.euroneuro.2019.09.711. PMID: CN-02051749. Exclusion Code: X7.
1094 Simmons JR, Smith GT, Hill KK. Validation of eating and dieting expectancy measures in two adolescent samples. Int J Eat Disord. 2002 May;31(4):461–73. doi: 10.1002/eat.10034. PMID: 11948651. Exclusion Code: X7.11948651
1095 Simon W, Lambert MJ, Busath G, . Effects of providing patient progress feedback and clinical support tools to psychotherapists in an inpatient eating disorders treatment program: a randomized controlled study. Psychother Res. 2013;23(3):287–300. doi: 10.1080/10503307.2013.787497. PMID: 23656489. Exclusion Code: X8.23656489
1096 Siren A, Cleverley K, Strudwick G, . Modification and initial psychometric evaluation of the Physical Health Attitude Scale for use in the Canadian mental health and addictions context. Issues Ment Health Nurs. 2018;39(11):946–53. doi: 10.1080/01612840.2018.1475523. PMID: 2018-41669-001. Exclusion Code: X4.30111207
1097 Skinner HH, Haines J, Austin SB, . A prospective study of overeating, binge eating, and depressive symptoms among adolescent and young adult women. J Adolesc Health. 2012 May;50(5):478–83. doi: 10.1016/j.jadohealth.2011.10.002. PMID: 22525111. Exclusion Code: X7.22525111
1098 Sloan DM, Mizes JS, Helbok C, . Efficacy of Sertraline for Bulimia Nervosa. Int J Eat Disord. 2004;36(1):48–54. doi: 10.1002/eat.20018. PMID: 2004-15631-006. Exclusion Code: X9.15185271
1099 Sly R, Morgan JF, Mountford VA, . Predicting premature termination of hospitalised treatment for anorexia nervosa: the roles of therapeutic alliance, motivation, and behaviour change. Eat Behav. 2013 Apr;14(2):119–23. doi: 10.1016/j.eatbeh.2013.01.007. PMID: 23557806. Exclusion Code: X8.23557806
1100 Smink FR, van Hoeken D, Oldehinkel AJ, . Prevalence and severity of DSM-5 eating disorders in a community cohort of adolescents. Int J Eat Disord. 2014 Sep;47(6):610–9. doi: 10.1002/eat.22316. PMID: 24903034. Exclusion Code: X9.24903034
1101 Smith KA, Fairburn CG, Cowen PJ. Symptomatic relapse in bulimia nervosa following acute tryptophan depletion. Arch Gen Psychiatry. 1999 Feb;56(2):171–6. doi: 10.1001/archpsyc.56.2.171. PMID: 10025442. Exclusion Code: X3.10025442
1102 Smitka K, Papezova H, Vondra K, . Short-term exercise combined with Acipimox administration induces an increase in plasma ACTH and its subsequent fall in the recovery phase in bulimic women. Regul Pept. 2013 Mar 10;182:45–52. doi: 10.1016/j.regpep.2012.12.010. PMID: 23318497. Exclusion Code: X3.23318497
1103 Smolak L, Levine MP. Psychometric properties of the Children’s Eating Attitudes Test. Int J Eat Disord. 1994 Nov;16(3):275–82. doi: 10.1002/1098-108x(199411)16:3<275::aid-eat2260160308>3.0.co;2-u. PMID: 7833961. Exclusion Code: X9.7833961
1104 Soll E, Thomas B, Mitchell JE, . Lack of effect of naloxone on selection of nutrients by bulimic women. The American Journal of Psychiatry. 1989;146(6):803-. doi: 10.1176/ajp.146.6.803a. PMID: 1989-34107-001. Exclusion Code: X13.
1105 Solmi F, Hatch SL, Hotopf M, . Validation of the SCOFF questionnaire for eating disorders in a multiethnic general population sample. Int J Eat Disord. 2015 Apr;48(3):312–6. doi: 10.1002/eat.22373. PMID: 25504212. Exclusion Code: X14.25504212
1106 Spangler DL. The Change in Eating Disorder Symptoms scale: scale development and psychometric properties. Eat Behav. 2010 Aug;11(3):131–7. doi: 10.1016/j.eatbeh.2009.12.003. PMID: 20434058. Exclusion Code: X3.20434058
1107 Speranza M, Atger F, Corcos M, . Depressive psychopathology and adverse childhood experiences in eating disorders. Eur Psychiatry. 2003 Dec;18(8):377–83. doi: 10.1016/j.eurpsy.2003.04.001. PMID: 14680713. Exclusion Code: X9.14680713
1108 Sperry S, Thompson JK, Roehrig M, . The influence of communicator weight on psychoeducational message acceptance in females with high vs. low levels of body image disturbance. Eat Behav. 2005 Jun;6(3):247–58. doi: 10.1016/j.eatbeh.2005.01.002. PMID: 15854871. Exclusion Code: X3.15854871
1109 Spettigue W, Buchholz A, Henderson K, . Evaluation of the efficacy and safety of olanzapine as an adjunctive treatment for anorexia nervosa in adolescent females: a randomized, double-blind, placebo-controlled trial. BMC Pediatr. 2008 Jan 31;8:4. doi: 10.1186/1471-2431-8-4. PMID: 18234120. Exclusion Code: X3.18234120
1110 Spettigue W, Maras D, Obeid N, . A psycho-education intervention for parents of adolescents with eating disorders: a randomized controlled trial. Eat Disord. 2015;23(1):60–75. doi: 10.1080/10640266.2014.940790. PMID: 25090010. Exclusion Code: X7.25090010
1111 Squires C, Lalanne C, Murday N, . The influence of eating disorders on mothers’ sensitivity and adaptation during feeding: a longitudinal observational study. BMC Pregnancy Childbirth. 2014 Aug 14;14:274. doi: 10.1186/1471-2393-14-274. PMID: 25123354. Exclusion Code: X9.25123354
1112 Stacher G, Abatzi-Wenzel TA, Wiesnagrotzki S, . Gastric emptying, body weight and symptoms in primary anorexia nervosa. Long-term effects of cisapride. Br J Psychiatry. 1993 Mar;162:398–402. doi: 10.1192/bjp.162.3.398. PMID: 8453437. Exclusion Code: X3.8453437
1113 Stacher G, Bergmann H, Granser-Vacariu GV, . Lack of systematic effects of the 5-hydroxytryptamine 3 receptor antagonist ICS 205-930 on gastric emptying and antral motor activity in patients with primary anorexia nervosa. Br J Clin Pharmacol. 1991 Dec;32(6):685–9. PMID: 1768560. Exclusion Code: X8.1768560
1114 Stacher G, Bergmann H, Wiesnagrotzki S, . Intravenous cisapride accelerates delayed gastric emptying and increases antral contraction amplitude in patients with primary anorexia nervosa. Gastroenterology. 1987 Apr;92(4):1000–6. doi: 10.1016/0016-5085(87)90976-0. PMID: 3556983. Exclusion Code: X5.3556983
1115 Stacher G, Peeters TL, Bergmann H, . Erythromycin effects on gastric emptying, antral motility and plasma motilin and pancreatic polypeptide concentrations in anorexia nervosa. Gut. 1993 Feb;34(2):166–72. doi: 10.1136/gut.34.2.166. PMID: 8432466. Exclusion Code: X7.8432466
1116 Stanford SC, Lemberg R. Measuring eating disorders in men: development of the eating disorder assessment for men (EDAM). Eat Disord. 2012;20(5):427–36. doi: 10.1080/10640266.2012.715522. PMID: 22985239. Exclusion Code: X8.22985239
1117 Stanford SC, Lemberg R. A clinical comparison of men and women on the Eating Disorder Inventory-3 (EDI-3) and the Eating Disorder Assessment for Men (EDAM). Eating Disorders. 2012;20(5):379–94. doi: 10.1080/10640266.2012.715516. PMID: 2012-25668-006. Exclusion Code: X8.22985235
1118 Steele AL, Wade TD. A randomised trial investigating guided self-help to reduce perfectionism and its impact on bulimia nervosa: a pilot study. Behav Res Ther. 2008 Dec;46(12):1316–23. doi: 10.1016/j.brat.2008.09.006. PMID: 19007923. Exclusion Code: X7.19007923
1119 Stefano EC, Wagner AF, Mond JM, . Loss of Control Over Eating Scale (LOCES): Validation in undergraduate men and women with and without eating disorder symptoms. Eat Behav. 2016 Dec;23:137–40. doi: 10.1016/j.eatbeh.2016.09.005. PMID: 27679970. Exclusion Code: X4.27679970
1120 Stefano SC, Bacaltchuk J, Blay SL, . Antidepressants in short-term treatment of binge eating disorder: Systematic review and meta-analysis. Eat Behav. 2008;9(2):129–36. doi: 10.1016/j.eatbeh.2007.03.006. PMID: 2008-03043-001. Exclusion Code: X9.18329590
1121 Stefini A, Salzer S, Reich G, . Cognitive-Behavioral and Psychodynamic Therapy in Female Adolescents With Bulimia Nervosa: A Randomized Controlled Trial. J Am Acad Child Adolesc Psychiatry. 2017 Apr;56(4):329–35. doi: 10.1016/j.jaac.2017.01.019. PMID: 28335877. Exclusion Code: X7.28335877
1122 Steiger H, Joober R, Gauvin L, . Serotonin-system polymorphisms (5-HTTLPR and -1438G/A) and responses of patients with bulimic syndromes to multimodal treatments. The Journal of Clinical Psychiatry. 2008;69(10):1565–71. doi: 10.4088/JCP.v69n1006. PMID: 2009-02744-006. Exclusion Code: X7.19192439
1123 Stein A, Woolley H, Senior R, . Treating disturbances in the relationship between mothers with bulimic eating disorders and their infants: a randomized, controlled trial of video feedback. Am J Psychiatry. 2006 May;163(5):899–906. doi: 10.1176/ajp.2006.163.5.899. PMID: 16648333. Exclusion Code: X7.16648333
1124 Stein KF, Corte C, Chen DG, . A randomized clinical trial of an identity intervention programme for women with eating disorders. Eur Eat Disord Rev. 2013 Mar;21(2):130–42. doi: 10.1002/erv.2195. PMID: 23015537. Exclusion Code: X7.23015537
1125 Stein KF, Hedger KM. Body weight and shape self-cognitions, emotional distress, and disordered eating in middle adolescent girls. Arch Psychiatr Nurs. 1997 Oct;11(5):264–75. doi: 10.1016/s0883-9417(97)80017-9. PMID: 9336995. Exclusion Code: X7.9336995
1126 Stein KF, Wing J, Lewis A, . An eating disorder randomized clinical trial and attrition: Profiles and determinants of dropout. Int J Eat Disord. 2011;44(4):356–68. doi: 10.1002/eat.20800. PMID: 2011-08523-010. Exclusion Code: X7.21472754
1127 Steinglass JE, Albano AM, Simpson HB, . Confronting fear using exposure and response prevention for anorexia nervosa: A randomized controlled pilot study. Int J Eat Disord. 2014;47(2):174–80. doi: 10.1002/eat.22214. PMID: 2014-04326-008. Exclusion Code: X8.24488838
1128 Steinglass JE, Kaplan SC, Liu Y, . The (lack of) effect of alprazolam on eating behavior in anorexia nervosa: A preliminary report. Int J Eat Disord. 2014;47(8):901–4. doi: 10.1002/eat.22343. PMID: 2014-34886-001. Exclusion Code: X3.25139178
1129 Steinhausen HC. Outcome of anorexia nervosa in the younger patient. J Child Psychol Psychiatry. 1997 Mar;38(3):271–6. doi: 10.1111/j.1469-7610.1997.tb01511.x. PMID: 9232473. Exclusion Code: X12.9232473
1130 Stewart C, Voulgari S, Eisler I, . Multi-family therapy for bulimia nervosa in adolescence. In: Murray SB, Anderson LK, Cohn L, eds. Innovations in family therapy for eating disorders: Novel treatment developments, patient insights, and the role of carers. New York, NY: Routledge/Taylor & Francis Group; 2017:44–53. Exclusion Code: X12.
1131 Stewart DA, Carter JC, Drinkwater J, . Modification of eating attitudes and behavior in adolescent girls: a controlled study. Int J Eat Disord. 2001 Mar;29(2):107–18. doi: 10.1002/1098-108x(200103)29:2<107::aid-eat1000>3.0.co;2-1. PMID: 11429973. Exclusion Code: X7.11429973
1132 Stewart DE, Robinson E, Goldbloom DS, . Infertility and eating disorders. Am J Obstet Gynecol. 1990 Oct;163(4 Pt 1):1196–9. doi: 10.1016/0002-9378(90)90688-4. PMID: 2220927. Exclusion Code: X3.2220927
1133 Stewart TM, Pollard T, Hildebrandt T, . The Female Athlete Body project study: 18-month outcomes in eating disorder symptoms and risk factors. Int J Eat Disord. 2019 Nov;52(11):1291–300. doi: 10.1002/eat.23145. PMID: 31350934. Exclusion Code: X3.31350934
1134 Stice E, Chase A, Stormer S, . A randomized trial of a dissonance-based eating disorder prevention program. Int J Eat Disord. 2001 Apr;29(3):247–62. doi: 10.1002/eat.1016. PMID: 11262503. Exclusion Code: X7.11262503
1135 Stice E, Fisher M, Martinez E. Eating disorder diagnostic scale: additional evidence of reliability and validity. Psychol Assess. 2004 Mar;16(1):60–71. doi: 10.1037/1040-3590.16.1.60. PMID: 15023093. Exclusion Code: X4.15023093
1136 Stice E, Marti CN, Cheng ZH. Effectiveness of a dissonance-based eating disorder prevention program for ethnic groups in two randomized controlled trials. Behav Res Ther. 2014;55:54–64. doi: 10.1016/j.brat.2014.02.002. PMID: 2014-10093-008. Exclusion Code: X7.24655465
1137 Stice E, Marti CN, Spoor S, . Dissonance and healthy weight eating disorder prevention programs: long-term effects from a randomized efficacy trial. J Consult Clin Psychol. 2008 Apr;76(2):329–40. doi: 10.1037/0022-006x.76.2.329. PMID: 18377128. Exclusion Code: X5.18377128
1138 Stice E, Mazotti L, Weibel D, . Dissonance prevention program decreases thin-ideal internalization, body dissatisfaction, dieting, negative affect, and bulimic symptoms: A preliminary experiment. Int J Eat Disord. 2000 Mar;27(2):206–17. doi: 10.1002/(sici)1098-108x(200003)27:2<206::aid-eat9>3.0.co;2-d. PMID: 10657894. Exclusion Code: X5.10657894
1139 Stice E, Orjada K, Tristan J. Trial of a psychoeducational eating disturbance intervention for college women: a replication and extension. Int J Eat Disord. 2006 Apr;39(3):233–9. doi: 10.1002/eat.20252. PMID: 16498589. Exclusion Code: X3.16498589
1140 Stice E, Presnell K, Groesz L, . Effects of a weight maintenance diet on bulimic symptoms in adolescent girls: an experimental test of the dietary restraint theory. Health Psychol. 2005 Jul;24(4):402–12. doi: 10.1037/0278-6133.24.4.402. PMID: 16045376. Exclusion Code: X3.16045376
1141 Stice E, Rohde P, Butryn M, . Randomized controlled pilot trial of a novel dissonance-based group treatment for eating disorders. Behav Res Ther. 2015 Feb;65:67–75. doi: 10.1016/j.brat.2014.12.012. PMID: 25577189. Exclusion Code: X3.25577189
1142 Stice E, Rohde P, Butryn ML, . Effectiveness trial of a selective dissonance-based eating disorder prevention program with female college students: Effects at 2- and 3-year follow-up. Behav Res Ther. 2015 Aug;71:20–6. doi: 10.1016/j.brat.2015.05.012. PMID: 26056749. Exclusion Code: X3.26056749
1143 Stice E, Rohde P, Durant S, . A preliminary trial of a prototype Internet dissonance-based eating disorder prevention program for young women with body image concerns. J Consult Clin Psychol. 2012 Oct;80(5):907–16. doi: 10.1037/a0028016. PMID: 22506791. Exclusion Code: X3.22506791
1144 Stice E, Rohde P, Shaw H, . Clinician-led, peer-led, and internet-delivered dissonance-based eating disorder prevention programs: Acute effectiveness of these delivery modalities. J Consult Clin Psychol. 2017 Sep;85(9):883–95. doi: 10.1037/ccp0000211. PMID: 28425735. Exclusion Code: X5.28425735
1145 Stice E, Rohde P, Shaw H, . Randomized trial of a dissonance-based group treatment for eating disorders versus a supportive mindfulness group treatment. J Consult Clin Psychol. 2019 Jan;87(1):79–90. doi: 10.1037/ccp0000365. PMID: 30570303. Exclusion Code: X7.30570303
1146 Stice E, Rohde P, Shaw H, . Efficacy trial of a selective prevention program targeting both eating disorder symptoms and unhealthy weight gain among female college students. J Consult Clin Psychol. 2012 Feb;80(1):164–70. doi: 10.1037/a0026484. PMID: 22122289. Exclusion Code: X3.22122289
1147 Stice E, Rohde P, Shaw H, . Efficacy trial of a selective prevention program targeting both eating disorders and obesity among female college students: 1- and 2-year follow-up effects. J Consult Clin Psychol. 2013 Feb;81(1):183–9. doi: 10.1037/a0031235. PMID: 23231574. Exclusion Code: X3.23231574
1148 Stice E, Shaw H, Burton E, . Dissonance and healthy weight eating disorder prevention programs: a randomized efficacy trial. J Consult Clin Psychol. 2006 Apr;74(2):263–75. doi: 10.1037/0022-006x.74.2.263. PMID: 16649871. Exclusion Code: X3.16649871
1149 Stice E, Telch CF, Rizvi SL. Development and validation of the Eating Disorder Diagnostic Scale: a brief self-report measure of anorexia, bulimia, and binge-eating disorder. Psychol Assess. 2000 Jun;12(2):123–31. doi: 10.1037//1040-3590.12.2.123. PMID: 10887758. Exclusion Code: X4.10887758
1150 Stice E, Trost A, Chase A. Healthy weight control and dissonance-based eating disorder prevention programs: results from a controlled trial. Int J Eat Disord. 2003 Jan;33(1):10–21. doi: 10.1002/eat.10109. PMID: 12474195. Exclusion Code: X3.12474195
1151 Stice E, Yokum S, Rohde P, . Randomized trial of a dissonance-based transdiagnostic group treatment for eating disorders: An evaluation of target engagement. J Consult Clin Psychol. 2019 Sep;87(9):772–86. doi: 10.1037/ccp0000430. PMID: 31403814. Exclusion Code: X14.31403814
1152 Stiles-Shields C, DclinPsy BB, Lock J, . The effect of driven exercise on treatment outcomes for adolescents with anorexia and bulimia nervosa. Int J Eat Disord. 2015 May;48(4):392–6. doi: 10.1002/eat.22281. PMID: 24729068. Exclusion Code: X7.24729068
1153 Stiles-Shields C, Touyz S, Hay P, . Therapeutic alliance in two treatments for adults with severe and enduring anorexia nervosa. Int J Eat Disord. 2013 Dec;46(8):783–9. doi: 10.1002/eat.22187. PMID: 24014042. Exclusion Code: X7.24014042
1154 Støving RK, Andries A, Brixen KT, . Purging behavior in anorexia nervosa and eating disorder not otherwise specified: A retrospective cohort study. Psychiatry Res. 2012;198(2):253–8. doi: 10.1016/j.psychres.2011.10.009. PMID: 2012-06824-001. Exclusion Code: X3.22410588
1155 Strandskov SW, Ghaderi A, Andersson H, . Effects of Tailored and ACT-Influenced Internet-Based CBT for Eating Disorders and the Relation Between Knowledge Acquisition and Outcome: A Randomized Controlled Trial. Behav Ther. 2017 Sep;48(5):624–37. doi: 10.1016/j.beth.2017.02.002. PMID: 28711113. Exclusion Code: X3.28711113
1156 Strasser TJ, Pike KM, Walsh BT. The impact of prior substance abuse on treatment outcome for bulimia nervosa. Addict Behav. 1992;17(4):387–95. doi: 10.1016/0306-4603(92)90044-v. PMID: 1502972. Exclusion Code: X7.1502972
1157 Striegel-Moore RH, Dohm FA, Kraemer HC, . Eating disorders in white and black women. Am J Psychiatry. 2003 Jul;160(7):1326–31. doi: 10.1176/appi.ajp.160.7.1326. PMID: 12832249. Exclusion Code: X7.12832249
1158 Striegel-Moore RH, Rosselli F, Holtzman N, . Behavioral symptoms of eating disorders in Native Americans: results from the ADD Health Survey Wave III. Int J Eat Disord. 2011 Sep;44(6):561–6. doi: 10.1002/eat.20894. PMID: 21823140. Exclusion Code: X7.21823140
1159 Striegel-Moore RH, Schreiber GB, Lo A, . Eating disorder symptoms in a cohort of 11 to 16-year-old black and white girls: the NHLBI growth and health study. Int J Eat Disord. 2000 Jan;27(1):49–66. doi: 10.1002/(sici)1098-108x(200001)27:1<49::aid-eat6>3.0.co;2-e. PMID: 10590449. Exclusion Code: X4.10590449
1160 Striegel-Moore RH, Silberstein LR, Frensch P, . A prospective study of disordered eating among college students. Int J Eat Disord. 1989;8(5):499–509. doi: 10.1002/1098-108X(198909)8:5<499::AID-EAT2260080502>3.0.CO;2-A. PMID: 1990-07964-001. Exclusion Code: X7.
1161 Striegel-Moore RH, Wilson GT, DeBar L, . Cognitive behavioral guided self-help for the treatment of recurrent binge eating. J Consult Clin Psychol. 2010 Jun;78(3):312–21. doi: 10.1037/a0018915. PMID: 20515207. Exclusion Code: X7.20515207
1162 Striegel-Moore RH, Wilson GT, Wilfley DE, . Binge eating in an obese community sample. Int J Eat Disord. 1998 Jan;23(1):27–37. doi: 10.1002/(sici)1098-108x(199801)23:1<27::aid-eat4>3.0.co;2-3. PMID: 9429916. Exclusion Code: X9.9429916
1163 Strober M, Freeman R, Morrell W. Atypical anorexia nervosa: separation from typical cases in course and outcome in a long-term prospective study. Int J Eat Disord. 1999 Mar;25(2):135–42. doi: 10.1002/(sici)1098-108x(199903)25:2<135::aid-eat2>3.0.co;2-1. PMID: 10065390. Exclusion Code: X9.10065390
1164 Stuhldreher N, Konnopka A, König HH, . Cost-of-illness and its determinants in anorexia nervosa: baseline results from the ANTOP study. Journal of mental health policy and economics. 2013;16:S33–S4. PMID: CN-01011084. Exclusion Code: X9.
1165 Stunkard A, Berkowitz R, Tanrikut C, . d-fenfluramine treatment of binge eating disorder. Am J Psychiatry. 1996;153(11):1455–9. doi: 10.1176/ajp.153.11.1455. PMID: CN-00132701. Exclusion Code: X5.8890680
1166 Summers BJ, Cougle JR. Effects of an Appearance-Focused Interpretation Training Intervention on Eating Disorder Symptoms. Behav Cogn Psychother. 2018 Nov;46(6):676–89. doi: 10.1017/s1352465818000164. PMID: 29530107. Exclusion Code: X3.29530107
1167 Sundblad C, Landén M, Eriksson T, . Effects of the androgen antagonist flutamide and the serotonin reuptake inhibitor citalopram in bulimia nervosa: a placebo-controlled pilot study. J Clin Psychopharmacol. 2005 Feb;25(1):85–8. doi: 10.1097/01.jcp.0000150222.31007.a9. PMID: 15643104. Exclusion Code: X14.15643104
1168 Sundgot-Borgen J, Rosenvinge JH, Bahr R, . The effect of exercise, cognitive therapy, and nutritional counseling in treating bulimia nervosa. Med Sci Sports Exerc. 2002 Feb;34(2):190–5. doi: 10.1097/00005768-200202000-00002. PMID: 11828224. Exclusion Code: X7.11828224
1169 Svedlund NE, Norring C, Ginsberg Y, . Are treatment results for eating disorders affected by ADHD symptoms? A one-year follow-up of adult females. Eur Eat Disord Rev. 2018 Jul;26(4):337–45. doi: 10.1002/erv.2598. PMID: 29717794. Exclusion Code: X7.29717794
1170 Swami V, Stieger S, Harris AS, . Further investigation of the validity and reliability of the Photographic Figure Rating Scale for body image assessment. J Pers Assess. 2012;94(4):404–9. doi: 10.1080/00223891.2012.660293. PMID: 2012-16389-008. Exclusion Code: X9.22375603
1171 Swanson SA, Aloisio KM, Horton NJ, . Assessing eating disorder symptoms in adolescence: is there a role for multiple informants? Int J Eat Disord. 2014 Jul;47(5):475–82. doi: 10.1002/eat.22250. PMID: 24436213. Exclusion Code: X7.24436213
1172 Sweeney C. Screening for child and adolescent eating disorders in primary care settings: ProQuest Information & Learning; 2017. Exclusion Code: X12.
1173 Swenne I. Heart risk associated with weight loss in anorexia nervosa and eating disorders: electrocardiographic changes during the early phase of refeeding. Acta Paediatr. 2000 Apr;89(4):447–52. doi: 10.1080/080352500750028177. PMID: 10830458. Exclusion Code: X9.10830458
1174 Swenne I. Weight and growth requirements for menarche in teenage girls with eating disorders, weight loss and primary amenorrhea. Horm Res. 2008;69(3):146–51. doi: 10.1159/000112587. PMID: 18219217. Exclusion Code: X9.18219217
1175 Swenne I, Rosling A. No unexpected adverse events and biochemical side effects of olanzapine as adjunct treatment in adolescent girls with eating disorders. J Child Adolesc Psychopharmacol. 2011 Jun;21(3):221–7. doi: 10.1089/cap.2009.0098. PMID: 21663424. Exclusion Code: X7.21663424
1176 Sysko R, Hildebrandt T, Wilson GT, . Heterogeneity moderates treatment response among patients with binge eating disorder. J Consult Clin Psychol. 2010 Oct;78(5):681–90. doi: 10.1037/a0019735. PMID: 20873903. Exclusion Code: X7.20873903
1177 Sysko R, Roberto CA, Barnes RD, . Test-retest reliability of the proposed DSM-5 eating disorder diagnostic criteria. Psychiatry Res. 2012 Apr 30;196(2–3):302–8. doi: 10.1016/j.psychres.2011.12.021. PMID: 22401974. Exclusion Code: X4.22401974
1178 Sysko R, Sha N, Wang Y, . Early response to antidepressant treatment in bulimia nervosa. Psychol Med. 2010;40(6):999–1005. doi: 10.1017/S0033291709991218. PMID: 2010-10691-012. Exclusion Code: X7.20441691
1179 Sysko R, Walsh BT, Fairburn CG. Eating Disorder Examination-Questionnaire as a measure of change in patients with bulimia nervosa. Int J Eat Disord. 2005 Mar;37(2):100–6. doi: 10.1002/eat.20078. PMID: 15732070. Exclusion Code: X7.15732070
1180 Tabler J, Schmitz RM, Geist C, . Reproductive outcomes among women with eating disorders or disordered eating behavior: does methodological approach shape Research Findings? J Womens Health (Larchmt). 2018 Nov;27(11):1389–99. doi: 10.1089/jwh.2017.6755. PMID: 29963940. Exclusion Code: X7.29963940
1181 Tachikawa H, Yamaguchi N, Hatanaka K, . The Eating Disorder Inventory-2 in Japanese clinical and non-clinical samples: psychometric properties and cross-cultural implications. Eat Weight Disord. 2004 Jun;9(2):107–13. doi: 10.1007/bf03325053. PMID: 15330077. Exclusion Code: X9.15330077
1182 Tanofsky-Kraff M, Morgan CM, Yanovski SZ, . Comparison of assessments of children’s eating-disordered behaviors by interview and questionnaire. Int J Eat Disord. 2003 Mar;33(2):213–24. doi: 10.1002/eat.10128. PMID: 12616588. Exclusion Code: X4.12616588
1183 Tanofsky-Kraff M, Ranzenhofer LM, Yanovski SZ, . Psychometric properties of a new questionnaire to assess eating in the absence of hunger in children and adolescents. Appetite. 2008;51(1):148–55. doi: 10.1016/j.appet.2008.01.001. PMID: 2008-05781-024. Exclusion Code: X7.18342988
1184 Tanofsky-Kraff M, Schvey NA, Grilo CM. A developmental framework of binge-eating disorder based on pediatric loss of control eating. Am Psychol. 2020;75(2):189–203. doi: 10.1037/amp0000592. PMID: 2020-09435-006. Exclusion Code: X9.32052994
1185 Tanofsky-Kraff M, Shomaker LB, Wilfley DE, . Targeted prevention of excess weight gain and eating disorders in high-risk adolescent girls: a randomized controlled trial. Am J Clin Nutr. 2014 Oct;100(4):1010–8. doi: 10.3945/ajcn.114.092536. PMID: 25240070. Exclusion Code: X5.25240070
1186 Tantillo M, Sanftner J. The relationship between perceived mutuality and bulimic symptoms, depression, and therapeutic change in group. Eat Behav. 2003;3(4):349–64. PMID: CN-00473515. Exclusion Code: X7.15000996
1187 Tasca G, Balfour L, Ritchie K, . CHANGE IN ATTACHMENT ANXIETY IS ASSOCIATED WITH IMPROVED DEPRESSION AMONG WOMEN WITH BINGE EATING DISORDER. Psychotherapy (chicago, ill.). 2007;44(4):423–33. doi: 10.1037/0033-3204.44.4.423. PMID: CN-00708077. Exclusion Code: X7.
1188 Tasca GA, Illing V, Balfour L, . Psychometric properties of self-monitoring of eating disorder urges among treatment seeking women: ecological momentary assessment using a daily diary method. Eat Behav. 2009 Jan;10(1):59–61. doi: 10.1016/j.eatbeh.2008.10.004. PMID: 19171321. Exclusion Code: X7.19171321
1189 Tasca GA, Koszycki D, Brugnera A, . Testing a stepped care model for binge-eating disorder: A two-step randomized controlled trial. Psychol Med. 2019;49(4):598–606. doi: 10.1017/S0033291718001277. PMID: 2018-25204-001. Exclusion Code: X7.29792242
1190 Tasca GA, Ritchie K, Conrad G, . Attachment scales predict outcome in a randomized controlled trial of two group therapies for binge eating disorder: an aptitude by treatment interaction. Psychotherapy research. 2006;16(1):106–21. doi: 10.1080/10503300500090928. PMID: CN-00622530. Exclusion Code: X10.
1191 Tasca GA, Wood J, Demidenko N, . Using the PAI with an eating disordered population: scale characteristics, factor structure, and differences among diagnostic groups. J Pers Assess. 2002 Oct;79(2):337–56. doi: 10.1207/s15327752jpa7902_14. PMID: 12425395. Exclusion Code: X4.12425395
1192 Tavolacci MP, Gillibert A, Zhu Soubise A, . Screening four broad categories of eating disorders: suitability of a clinical algorithm adapted from the SCOFF questionnaire. BMC Psychiatry. 2019 Nov 21;19(1):366. doi: 10.1186/s12888-019-2338-6. PMID: 31752796. Exclusion Code: X4.31752796
1193 Taylor CB, Bryson S, Luce KH, . Prevention of eating disorders in at-risk college-age women. Arch Gen Psychiatry. 2006 Aug;63(8):881–8. doi: 10.1001/archpsyc.63.8.881. PMID: 16894064. Exclusion Code: X5.16894064
1194 Taylor CB, Kass AE, Trockel M, . Reducing eating disorder onset in a very high risk sample with significant comorbid depression: A randomized controlled trial. J Consult Clin Psychol. 2016 May;84(5):402–14. doi: 10.1037/ccp0000077. PMID: 26795936. Exclusion Code: X3.26795936
1195 Telch CF, Agras WS, Linehan MM. Dialectical behavior therapy for binge eating disorder. J Consult Clin Psychol. 2001 Dec;69(6):1061–5. doi: 10.1037//0022-006x.69.6.1061. PMID: 11777110. Exclusion Code: X14.11777110
1196 Ter Huurne ED, de Haan HA, Postel MG, . Long-term effectiveness of web-based cognitive behavioral therapy for patients with eating disorders. Eat Weight Disord. 2020 May 24doi: 10.1007/s40519-020-00929-0. PMID: 32449152. Exclusion Code: X9.32449152
1197 ter Huurne ED, de Haan HA, Postel MG, . Web-Based Cognitive Behavioral Therapy for Female Patients With Eating Disorders: Randomized Controlled Trial. J Med Internet Res. 2015 Jun 18;17(6):e152. doi: 10.2196/jmir.3946. PMID: 26088580. Exclusion Code: X3.26088580
1198 ter Huurne ED, de Haan HA, ten Napel-Schutz MC, . Is the Eating Disorder Questionnaire-Online (EDQ-O) a valid diagnostic instrument for the DSM-IV-TR classification of eating disorders? Compr Psychiatry. 2015 Feb;57:167–76. doi: 10.1016/j.comppsych.2014.10.019. PMID: 25464837. Exclusion Code: X4.25464837
1199 ter Huurne ED, Postel MG, de Haan HA, . Effectiveness of a web-based treatment program using intensive therapeutic support for female patients with bulimia nervosa, binge eating disorder and eating disorders not otherwise specified: study protocol of a randomized controlled trial. BMC Psychiatry. 2013 Nov 16;13:310. doi: 10.1186/1471-244x-13-310. PMID: 24238630. Exclusion Code: X7.24238630
1200 Tevendale HD. Physical appearance-related risk and protective factors for disordered eating among young adolescent White and African-American girls: ProQuest Information & Learning; 2004. Exclusion Code: X7.
1201 Thabrew H, D’Silva S, Darragh M, . Comparison of YouthCHAT, an Electronic Composite Psychosocial Screener, With a Clinician Interview Assessment for Young People: Randomized Controlled Trial. J Med Internet Res. 2019 Dec 3;21(12):e13911. doi: 10.2196/13911. PMID: 31793890. Exclusion Code: X7.31793890
1202 Thackwray DE, Smith MC, Bodfish JW, . A comparison of behavioral and cognitive-behavioral interventions for bulimia nervosa. J Consult Clin Psychol. 1993 Aug;61(4):639–45. doi: 10.1037//0022-006x.61.4.639. PMID: 8370859. Exclusion Code: X7.8370859
1203 Thaler L, Wilson S, Coelho JS, . Mandating weekly weight gain in a day treatment program for eating disorders. Int J Eat Disord. 2014 Jul;47(5):500–6. doi: 10.1002/eat.22246. PMID: 24431323. Exclusion Code: X7.24431323
1204 Theisen FM, Linden A, König IR, . Spectrum of binge eating symptomatology in patients treated with clozapine and olanzapine. J Neural Transm (Vienna). 2003 Jan;110(1):111–21. doi: 10.1007/s00702-002-0792-6. PMID: 12541016. Exclusion Code: X3.12541016
1205 Theuwis L, Moens E, Braet C. Psychometric quality of the Dutch version of the Children’s Eating Attitude Test in a community sample and a sample of overweight youngsters. Psychol Belg. 2009;49(4):311–30. doi: 10.5334/pb-49-4-311. PMID: 2010-13354-007. Exclusion Code: X4.
1206 Thiel A, Paul T. Test-retest reliability of the Eating Disorder Inventory 2. J Psychosom Res. 2006 Oct;61(4):567–9. doi: 10.1016/j.jpsychores.2006.02.015. PMID: 17011367. Exclusion Code: X7.17011367
1207 Thiels C, Deb KS. EDDA: An eating disorder diagnostic algorithm according to ICD-11. Eat Weight Disord. 2014;19(1):111–4. doi: 10.1007/s40519-014-0102-y. PMID: 2014-36576-014. Exclusion Code: X5.24474663
1208 Thien V, Thomas A, Markin D, . Pilot study of a graded exercise program for the treatment of anorexia nervosa. Int J Eat Disord. 2000 Jul;28(1):101–6. doi: 10.1002/(sici)1098-108x(200007)28:1<101::aid-eat12>3.0.co;2-v. PMID: 10800019. Exclusion Code: X5.10800019
1209 Thompson D, Cachelin F, Striegel-Moore RH, . How many therapists? Practical guidance on investigating therapist effects in randomized controlled trials for eating disorders. Int J Eat Disord. 2012;45(5):670–6. doi: 10.1002/eat.22009. PMID: 2012-15623-006. Exclusion Code: X7.22407965
1210 Thompson-Brenner H, Franko DL, Thompson DR, . Race/ethnicity, education, and treatment parameters as moderators and predictors of outcome in binge eating disorder. J Consult Clin Psychol. 2013;81(4):710–21. doi: 10.1037/a0032946. PMID: CN-00919293. Exclusion Code: X7.23647283
1211 Thompson-Brenner H, Shingleton RM, Sauer-Zavala S, . Multiple measures of rapid response as predictors of remission in cognitive behavior therapy for bulimia nervosa. Behav Res Ther. 2015 Jan;64:9–14. doi: 10.1016/j.brat.2014.11.004. PMID: 25462877. Exclusion Code: X7.25462877
1212 Thompson-Brenner H, Westen D. A naturalistic study of psychotherapy for bulimia nervosa, part 2: therapeutic interventions in the community. J Nerv Ment Dis. 2005 Sep;193(9):585–95. doi: 10.1097/01.nmd.0000178883.82580.18. PMID: 16131941. Exclusion Code: X9.16131941
1213 Thompson-Brenner H, Westen D. A naturalistic study of psychotherapy for bulimia nervosa, part 1: comorbidity and therapeutic outcome. J Nerv Ment Dis. 2005 Sep;193(9):573–84. doi: 10.1097/01.nmd.0000178843.81100.eb. PMID: 16131940. Exclusion Code: X9.16131940
1214 Thornton LM, Munn-Chernoff MA, Baker JH, . The Anorexia Nervosa Genetics Initiative (ANGI): Overview and methods. Contemp Clin Trials. 2018 Nov;74:61–9. doi: 10.1016/j.cct.2018.09.015. PMID: 30287268. Exclusion Code: X3.30287268
1215 Thoyre SM, Pados BF, Park J, . Development and content validation of the Pediatric Eating Assessment Tool (Pedi-EAT). Am J Speech Lang Pathol. 2014;23(1):46–59. doi: 10.1044/1058-0360(2013/12-0069). PMID: 2014-29887-005. Exclusion Code: X7.24097795
1216 Thoyre SM, Pados BF, Park J, . The Pediatric Eating Assessment Tool: Factor Structure and Psychometric Properties. J Pediatr Gastroenterol Nutr. 2018 Feb;66(2):299–305. doi: 10.1097/mpg.0000000000001765. PMID: 28953526. Exclusion Code: X4.28953526
1217 Thurfjell B, Edlund B, Arinell H, . Psychometric properties of Eating Disorder Inventory for Children (EDI-C) in Swedish girls with and without a known eating disorder. Eat Weight Disord. 2003 Dec;8(4):296–303. doi: 10.1007/bf03325029. PMID: 15018379. Exclusion Code: X4.15018379
1218 Timko CA, Fitzpatrick KK, Goulazian T, . Conducting a Pilot Randomized Controlled Trial on a Medical Inpatient Unit Utilizing Cognitive Remediation Therapy for Adolescents with Restrictive Eating Disorders: Protocol Updates and Reflections on Feasibility. J Clin Psychol Med Settings. 2020 Jun;27(2):226–34. doi: 10.1007/s10880-020-09704-w. PMID: 32052249. Exclusion Code: X3.32052249
1219 Tobin LN, Lacroix E, von Ranson KM. Evaluating an abbreviated three-factor version of the Eating Disorder Examination Questionnaire in three samples. Eat Behav. 2019 Jan;32:18–22. doi: 10.1016/j.eatbeh.2018.11.003. PMID: 30476704. Exclusion Code: X4.30476704
1220 Tod D, Morrison TG, Edwards C. Psychometric properties of Yelland and Tiggemann’s Drive for Muscularity Scale. Body Image. 2012;9(3):421–4. doi: 10.1016/j.bodyim.2012.03.003. PMID: 2012-11337-001. Exclusion Code: X4.22541667
1221 Todd L, Anthony S, Dipchand AI, . Body image and eating attitudes and behaviors among adolescent heart and lung transplant recipients: a brief report. Prog Transplant. 2012 Sep;22(3):259–63. doi: 10.7182/pit2012355. PMID: 22951503. Exclusion Code: X3.22951503
1222 Tong J, Shi J, Wang J, . Validity and reliability of the Chinese language version of the eating disorder examination (CEDE) in mainland China: Implications for the identity and nosology of the eating disorders. Int J Eat Disord. 2011 Jan;44(1):76–80. doi: 10.1002/eat.20742. PMID: 20069567. Exclusion Code: X3.20069567
1223 Torrent C, Vieta E, Garcia-Garcia M. Validation of the Barcelona Bipolar Eating Disorder Scale for bipolar patients with eating disturbances. Psychopathology. 2008;41(6):379–87. doi: 10.1159/000155216. PMID: 18787360. Exclusion Code: X3.18787360
1224 Tortorella A, Fabrazzo M, Monteleone AM, . The role of drug therapies in the treatment of anorexia and bulimia nervosa: A review of the literature. Journal of Psychopathology. 2014;20(1):50–65. PMID: 2014-24558-007. Exclusion Code: X9.
1225 Touyz S, Le Grange D, Lacey H, . Treating severe and enduring anorexia nervosa: a randomized control trial. Eur Psychiatry. 2015;30:357-. PMID: CN-01084659. Exclusion Code: X7.25725595
1226 Touyz S, Le Grange D, Lacey H, . Treating severe and enduring anorexia nervosa: a randomized controlled trial. Psychol Med. 2013 Dec;43(12):2501–11. doi: 10.1017/s0033291713000949. PMID: 23642330. Exclusion Code: X7.23642330
1227 Touyz SW, Lennerts W, Arthur B, . Anaerobic exercise as an adjunct to refeeding patients with anorexia nervosa: Does it compromise weight gain? Eur Eat Disord Rev. 1993;1(3):177–82. doi: 10.1002/erv.2400010306. PMID: 1999-00129-004. Exclusion Code: X3.
1228 Trainor C, Gorrell S, Hughes EK, . Family-based treatment for adolescent anorexia nervosa: What happens to rates of comorbid diagnoses? Eur Eat Disord Rev. 2020 May;28(3):351–7. doi: 10.1002/erv.2725. PMID: 31995262. Exclusion Code: X7.31995262
1229 Traviss GD, Heywood-Everett S, Hill AJ. Guided self-help for disordered eating: A randomised control trial. Behav Res Ther. 2011 Jan;49(1):25–31. doi: 10.1016/j.brat.2010.10.007. PMID: 21092933. Exclusion Code: X14.21092933
1230 Treasure J, Schmidt U, Troop N, . First step in managing bulimia nervosa: controlled trial of therapeutic manual. BMJ. 1994 Mar 12;308(6930):686–9. doi: 10.1136/bmj.308.6930.686. PMID: 8142791. Exclusion Code: X3.8142791
1231 Treasure J, Todd G, Brolly M, . A pilot study of randomised trial of cognitive analytical therapy vs educational behavioral therapy for adult anorexia nervosa. Behav Res Ther. 1995;33(4):363–7. doi: 10.1016/0005-7967(94)00070-Z. PMID: 1995-41258-001. Exclusion Code: X7.7755523
1232 Treasure J, Todd G, Brolly M, . A pilot study of a randomised trial of cognitive analytical therapy vs educational behavioral therapy for adult anorexia nervosa. Behav Res Ther. 1995;33(4):363–7. doi: 10.1016/0005-7967(94)00070-z. PMID: CN-00114290. Exclusion Code: X7.7755523
1233 Trottier K, McFarlane T, Olmsted MP, . The Weight Influenced Self-Esteem Questionnaire (WISE-Q): factor structure and psychometric properties. Body Image. 2013 Jan;10(1):112–20. doi: 10.1016/j.bodyim.2012.08.008. PMID: 23068567. Exclusion Code: X4.23068567
1234 Tsai J, Navia B, McElroy SL, . 170 Efficacy and Safety of Dasotraline in Adults with Binge-Eating Disorder: A Randomized, Double-blind, Fixed-dose Trial. CNS Spectr. 2020 Apr;25(2):308–9. doi: 10.1017/s1092852920000863. PMID: 32331033. Exclusion Code: X13.
1235 Tseng MC, Fang D, Chang CH, . Identifying high-school dance students who will develop an eating disorder: a 1-year prospective study. Psychiatry Res. 2013 Oct 30;209(3):611–8. doi: 10.1016/j.psychres.2013.04.008. PMID: 23664298. Exclusion Code: X9.23664298
1236 Tseng MC, Fang D, Lee MB. Comparative validity of the chinese versions of the bulimic inventory test edinburgh and eating attitudes test for DSM-IV eating disorders among high school dance and nondance students in Taiwan. Int J Eat Disord. 2014 Jan;47(1):105–11. doi: 10.1002/eat.22183. PMID: 24014499. Exclusion Code: X4.24014499
1237 Tseng MC, Yao G, Hu FC, . Psychometric properties of the eating disorder inventory in clinical and nonclinical populations in Taiwan. Assessment. 2014 Feb;21(1):50–9. doi: 10.1177/1073191111428761. PMID: 22104191. Exclusion Code: X7.22104191
1238 Tu C-Y, Tseng M-CM, Chang C-H, . Comparative validity of the Internet and paper-and-pencil versions of the Night Eating Questionnaire. Compr Psychiatry. 2017;75:53–61. doi: 10.1016/j.comppsych.2017.03.001. PMID: 2017-54080-011. Exclusion Code: X4.28314121
1239 Turkiewicz G, Pinzon V, Lock J, . Feasibility, acceptability, and effectiveness of family-based treatment for adolescent anorexia nervosa: an observational study conducted in Brazil. Braz J Psychiatry. 2010 Jun;32(2):169–72. doi: 10.1590/s1516-44462010005000001. PMID: 20414591. Exclusion Code: X7.20414591
1240 Turnbull SJ, Schmidt U, Troop NA, . Predictors of outcome for two treatments for bulimia nervosa: short and long-term. Int J Eat Disord. 1997;21(1):17–22. doi: 10.1002/(sici)1098-108x(199701)21:1<17::aid-eat2>3.0.co;2-6. PMID: CN-00193750. Exclusion Code: X7.8986513
1241 Turner J, Batik M, Palmer LJ, . Detection and importance of laxative use in adolescents with anorexia nervosa. J Am Acad Child Adolesc Psychiatry. 2000 Mar;39(3):378–85. doi: 10.1097/00004583-200003000-00021. PMID: 10714059. Exclusion Code: X7.10714059
1242 Tyler I, Birmingham CL. The interrater reliability of physical signs in patients with eating disorders. Int J Eat Disord. 2001 Nov;30(3):343–5. doi: 10.1002/eat.1094. PMID: 11767717. Exclusion Code: X4.11767717
1243 Uehara T, Kawashima Y, Goto M, . Psychoeducation for the families of patients with eating disorders and changes in expressed emotion: A preliminary study. Compr Psychiatry. 2001 Mar–Apr;42(2):132–8. doi: 10.1053/comp.2001.21215. PMID: 11244149. Exclusion Code: X7.11244149
1244 Uehara T, Takeuchi K, Ohmori I, . Factor-analytic study of the Anorectic Behavior Observation Scale in Japan: comparisons with the original Belgian study. Psychiatry Res. 2002 Aug 30;111(2–3):241–6. doi: 10.1016/s0165-1781(02)00143-9. PMID: 12374641. Exclusion Code: X7.12374641
1245 Ujiie T, Kono M. Eating attitudes test in Japan. Jpn J Psychiatry Neurol. 1994 Sep;48(3):557–65. doi: 10.1111/j.1440-1819.1994.tb03014.x. PMID: 7891418. Exclusion Code: X7.7891418
1246 Unikel Santoncini C, Bojorquez Chapela I, Díaz de León Vázquez C, . Validation of eating disorders examination questionnaire in Mexican women. Int J Eat Disord. 2018 Feb;51(2):146–54. doi: 10.1002/eat.22819. PMID: 29314174. Exclusion Code: X7.29314174
1247 Valentine EG, Bodill KO, Watson HJ, . A randomized controlled trial of unguided internet cognitive-behavioral treatment for perfectionism in individuals who engage in regular exercise. Int J Eat Disord. 2018 Aug;51(8):984–8. doi: 10.1002/eat.22888. PMID: 29984418. Exclusion Code: X3.29984418
1248 van den Berg E, Melisse B, Koenders J, . Online cognitive behavioral therapy enhanced for binge eating disorder: study protocol for a randomized controlled trial. BMC Psychiatry. 2020 Apr 29;20(1):190. doi: 10.1186/s12888-020-02604-1. PMID: 32349692. Exclusion Code: X7.32349692
1249 van Furth EF, van Strien DC, Martina LM, . Expressed emotion and the prediction of outcome in adolescent eating disorders. Int J Eat Disord. 1996 Jul;20(1):19–31. doi: 10.1002/(sici)1098-108x(199607)20:1<19::aid-eat3>3.0.co;2-7. PMID: 8807349. Exclusion Code: X4.8807349
1250 van Passel B, Danner U, Dingemans A, . Cognitive remediation therapy (CRT) as a treatment enhancer of eating disorders and obsessive compulsive disorders: study protocol for a randomized controlled trial. BMC Psychiatry. 2016 Nov 10;16(1):393. doi: 10.1186/s12888-016-1109-x. PMID: 27832747. Exclusion Code: X7.27832747
1251 van Passel B, Danner UN, Dingemans AE, . Cognitive Remediation Therapy Does Not Enhance Treatment Effect in Obsessive-Compulsive Disorder and Anorexia Nervosa: A Randomized Controlled Trial. Psychother Psychosom. 2020 Feb 19:1–14. doi: 10.1159/000505733. PMID: 32074624. Exclusion Code: X7.32074624
1252 van Strien T. The concurrent validity of a classification of dieters with low versus high susceptibility toward failure of restraint. Addict Behav. 1997 Sep–Oct;22(5):587–97. doi: 10.1016/s0306-4603(96)00069-x. PMID: 9347061. Exclusion Code: X7.9347061
1253 van Strien T. The concurrent validity of a classification of dieters with low versus high susceptiability toward failure of restraint. Addict Behav. 1997;22(5):587–97. doi: 10.1016/S0306-4603(96)00069-X. PMID: 1998-10850-002. Exclusion Code: X4.9347061
1254 van Strien T, Oosterveld P. The children’s DEBQ for assessment of restrained, emotional, and external eating in 7- to 12-year-old children. Int J Eat Disord. 2008;41(1):72–81. doi: 10.1002/eat.20424. PMID: 2007-19817-009. Exclusion Code: X3.17634965
1255 Vander Wal JS, Johnston KA, Dhurandhar NV. Psychometric properties of the State and Trait Food Cravings Questionnaires among overweight and obese persons. Eat Behav. 2007;8(2):211–23. doi: 10.1016/j.eatbeh.2006.06.002. PMID: 2007-03366-009. Exclusion Code: X4.17336791
1256 Vander Wal JS, Stein RI, Blashill AJ. The EDE-Q, BULIT-R, and BEDT as self-report measures of binge eating disorder. Eat Behav. 2011 Dec;12(4):267–71. doi: 10.1016/j.eatbeh.2011.07.006. PMID: 22051358. Exclusion Code: X4.22051358
1257 Vander Wal JS, Stein RI, Blashill AJ. The EDE-Q, BUILT-R, and BEDT as self-report measures of binge eating disorder. Eat Behav. 2011;12(4):267–71. doi: 10.1016/j.eatbeh.2011.07.006. PMID: 2011-18107-001. Exclusion Code: X9.22051358
1258 Vandereycken W. Neuroleptics in the short-term treatment of anorexia nervosa. A double-blind placebo-controlled study with sulpiride. Br J Psychiatry. 1984 Mar;144:288–92. doi: 10.1192/bjp.144.3.288. PMID: 6367876. Exclusion Code: X3.6367876
1259 Vandereycken W. The Eating Disorder Evaluation Scale (EDES). Eating Disorders: The Journal of Treatment & Prevention. 1993 Sum 1993;1(2):115–22. doi: 10.1080/10640269308248279. PMID: 1996-21710-001. Exclusion Code: X12.
1260 Vandereycken W, Pierloot R. Pimozide combined with behavior therapy in the short-term treatment of anorexia nervosa. A double-blind placebo-controlled cross-over study. Acta Psychiatr Scand. 1982 Dec;66(6):445–50. doi: 10.1111/j.1600-0447.1982.tb04501.x. PMID: 6758492. Exclusion Code: X3.6758492
1261 Vanderlinden J, Adriaensen A, Vancampfort D, . A cognitive-behavioral therapeutic program for patients with obesity and binge eating disorder: Short- and long-term follow-up data of a prospective study. Behav Modif. 2012;36(5):670–86. doi: 10.1177/0145445512439313. PMID: 2012-25476-004. Exclusion Code: X7.22544460
1262 Vannucci A, Ohannessian CM. Psychometric properties of the brief loss of control over eating scale (LOCES-B) in early adolescents. Int J Eat Disord. 2018 May;51(5):459–64. doi: 10.1002/eat.22845. PMID: 29469930. Exclusion Code: X4.29469930
1263 Veisy F, Ahmadi SM, Sadeghi K, . The psychometric properties of Body Shape Questionnaire 8C in women with eating disorders. Iranian Journal of Psychiatry and Clinical Psychology. 2018 Win 2018;23(4):480–93. doi: 10.29252/nirp.ijpcp.23.4.480. PMID: 2018-19124-007. Exclusion Code: X4.
1264 Vella-Zarb RA, Mills JS, Westra HA, . A randomized controlled trial of motivational interviewing + self-help versus psychoeducation + self-help for binge eating. Int J Eat Disord. 2015;48(3):328–32. doi: 10.1002/eat.22242. PMID: 2014-17633-001. Exclusion Code: X7.24753120
1265 Ventura M, Bauer B. Empowerment of women with purging-type bulimia nervosa through nutritional rehabilitation. Eat Weight Disord. 1999 Jun;4(2):55–62. doi: 10.1007/bf03339719. PMID: 11234243. Exclusion Code: X7.11234243
1266 Veron-Guidry S, Williamson DA. Development of a body image assessment procedure for children and preadolescents. Int J Eat Disord. 1996 Nov;20(3):287–93. doi: 10.1002/(sici)1098-108x(199611)20:3<287::aid-eat8>3.0.co;2-k. PMID: 8912041. Exclusion Code: X4.8912041
1267 Vervoort L, Naets T, De Guchtenaere A, . Using confidence interval-based estimation of relevance to explore bottom-up and top-down determinants of problematic eating behavior in children and adolescents with obesity from a dual pathway perspective. Appetite. 2020;150doi: 10.1016/j.appet.2020.104676. PMID: 2020-26882-001. Exclusion Code: X9.
1268 Vetrone G, Cuzzolaro M, Antonozzi I. Clinical and subthreshold eating disorders: case detection in adolescent schoolgirls. Eat Weight Disord. 1997 Mar;2(1):24–33. doi: 10.1007/bf03339946. PMID: 14655853. Exclusion Code: X4.14655853
1269 Vetrone G, Cuzzolaro M, Antonozzi I, . Screening for eating disorders: false negatives and eating disorders not otherwise specified. The European Journal of Psychiatry. 2006;20(1):13–20. doi: 10.4321/S0213-61632006000100002. PMID: 2006-08739-002. Exclusion Code: X4.
1270 Viglione V, Muratori F, Maestro S, . Denial of symptoms and psychopathology in adolescent anorexia nervosa. Psychopathology. 2006;39(5):255–60. doi: 10.1159/000094723. PMID: 16864997. Exclusion Code: X3.16864997
1271 Vignini A, D’Angelo M, Nanetti L, . Anorexia nervosa: a role for L-arginine supplementation in cardiovascular risk factors? Int J Eat Disord. 2010 Jul;43(5):464–71. doi: 10.1002/eat.20709. PMID: 19544555. Exclusion Code: X4.19544555
1272 Vincent MA, McCabe MP, Ricciardelli LA. Factorial validity of the Bulimia Test-Revised in adolescent boys and girls. Behav Res Ther. 1999 Nov;37(11):1129–40. doi: 10.1016/s0005-7967(98)00199-5. PMID: 10500325. Exclusion Code: X4.10500325
1273 Völker U, Jacobi C, Trockel MT, . Moderators and mediators of outcome in internet-based indicated prevention for eating disorders. Behav Res Ther. 2014;63:114–21. doi: 10.1016/j.brat.2014.09.008. PMID: 2014-55183-015. Exclusion Code: X5.25461786
1274 von Brachel R, Hirschfeld G, Berner A, . Long-Term Effectiveness of Cognitive Behavioral Therapy in Routine Outpatient Care: A 5- to 20-Year Follow-Up Study. Psychother Psychosom. 2019;88(4):225–35. doi: 10.1159/000500188. PMID: 31121580. Exclusion Code: X3.31121580
1275 von Ranson KM, Klump KL, Iacono WG, . The Minnesota Eating Behavior Survey: a brief measure of disordered eating attitudes and behaviors. Eat Behav. 2005 Dec;6(4):373–92. doi: 10.1016/j.eatbeh.2004.12.002. PMID: 16257811. Exclusion Code: X9.16257811
1276 Waasdorp CE, Caboot JB, Robinson CA, . Screening military dependent adolescent females for disordered eating. Mil Med. 2007 Sep;172(9):962–7. doi: 10.7205/milmed.172.9.962. PMID: 17937360. Exclusion Code: X7.17937360
1277 Wade T, Heath AC, Abraham S, . Assessing the prevalence of eating disorders in an Australian twin population. Aust N Z J Psychiatry. 1996 Dec;30(6):845–51. doi: 10.3109/00048679609065054. PMID: 9034476. Exclusion Code: X9.9034476
1278 Wade T, Tiggemann M, Martin N, . A comparison of the Eating Disorder Examination and a general psychiatric schedule. Aust N Z J Psychiatry. 1997;31(6):852–7. doi: 10.3109/00048679709065511. PMID: 1997-41467-006. Exclusion Code: X4.9483258
1279 Wade TD, Byrne S, Bryant-Waugh R. The eating disorder examination: norms and construct validity with young and middle adolescent girls. Int J Eat Disord. 2008 Sep;41(6):551–8. doi: 10.1002/eat.20526. PMID: 18433026. Exclusion Code: X4.18433026
1280 Wade TD, O’Shea A. DSM-5 unspecified feeding and eating disorders in adolescents: What do they look like and are they clinically significant? Int J Eat Disord. 2015;48(4):367–74. doi: 10.1002/eat.22303. PMID: 2014-21477-001. Exclusion Code: X7.24854848
1281 Wade TD, Tiggemann M, Bulik CM, . Shared temperament risk factors for anorexia nervosa: a twin study. Psychosom Med. 2008 Feb;70(2):239–44. doi: 10.1097/PSY.0b013e31815c40f1. PMID: 18158375. Exclusion Code: X7.18158375
1282 Wagner AJ, Erickson CD, Tierney DK, . The diagnostic accuracy of screening tools to detect eating disorders in female athletes. J Sport Rehab. 2016;25(4):395–8. doi: 10.1123/jsr.2014-0337. PMID: 2017-01394-004. Exclusion Code: X9.
1283 Wagner C, Equit M, Niemczyk J, . Obesity, overweight, and eating problems in children with incontinence. J Pediatr Urol. 2015 Aug;11(4):202–7. doi: 10.1016/j.jpurol.2015.05.019. PMID: 26143486. Exclusion Code: X9.26143486
1284 Wagner G, Penelo E, Wanner C, . Internet-delivered cognitive–behavioural therapy v conventional guided self-help for bulimia nervosa: Long-term evaluation of a randomised controlled trial. Br J Psychiatry. 2013;202(2):135–41. doi: 10.1192/bjp.bp.111.098582. PMID: 2013-07513-016. Exclusion Code: X7.23222037
1285 Walker T, Watson HJ, Leach DJ, . Comparative study of children and adolescents referred for eating disorder treatment at a specialist tertiary setting. Int J Eat Disord. 2014 Jan;47(1):47–53. doi: 10.1002/eat.22201. PMID: 24166891. Exclusion Code: X7.24166891
1286 Waller G. Bulimic attitudes in different eating disorders: Clinical utility of the BITE. Int J Eat Disord. 1992;11(1):73–8. doi: 10.1002/1098-108X(199201)11:1<73::AID-EAT2260110110>3.0.CO;2-3. PMID: 1992-18339-001. Exclusion Code: X3.
1287 Waller G, Evans J, Pugh M. Food for thought: a pilot study of the pros and cons of changing eating patterns within cognitive-behavioural therapy for the eating disorders. Behav Res Ther. 2013 Sep;51(9):519–25. doi: 10.1016/j.brat.2013.06.001. PMID: 23820156. Exclusion Code: X9.23820156
1288 Waller G, Osman S. Emotional eating and eating psychopathology among non-eating-disordered women. Int J Eat Disord. 1998 May;23(4):419–24. doi: 10.1002/(sici)1098-108x(199805)23:4<419::aid-eat9>3.0.co;2-l. PMID: 9561432. Exclusion Code: X4.9561432
1289 Wallis A. How Does Family Functioning Effect The Outcome of Family Based Treatment For Adolescents With Severe Anorexia Nervosa? J Adolesc Health. 2019;64(2):S51–S2. doi: 10.1016/j.jadohealth.2018.10.113. PMID: CN-01788013. Exclusion Code: X13.
1290 Wallis A, Miskovic-Wheatley J, Madden S, . Does continuing family-based treatment for adolescent anorexia nervosa improve outcomes in those not remitted after 20 sessions? Clin Child Psychol Psychiatry. 2018;23(4):592–600. doi: 10.1177/1359104518775145. PMID: 2018-48236-008. Exclusion Code: X8.29781302
1291 Wallis A, Miskovic-Wheatley J, Madden S, . How does family functioning effect the outcome of family based treatment for adolescents with severe anorexia nervosa? Journal of Eating Disorders. 2017;5doi: 10.1186/s40337-017-0184-9. PMID: 2017-56378-001. Exclusion Code: X7.
1292 Walsh BT. Medication in the treatment of bulimia. Adolesc Psychiatry. 1986;13:437–45. PMID: 3524294. Exclusion Code: X9.3524294
1293 Walsh BT, Agras WS, Devlin MJ, . Fluoxetine for bulimia nervosa following poor response to psychotherapy. Am J Psychiatry. 2000 Aug;157(8):1332–4. doi: 10.1176/appi.ajp.157.8.1332. PMID: 10910801. Exclusion Code: X3.10910801
1294 Walsh BT, Fairburn CG, Mickley D, . Treatment of bulimia nervosa in a primary care setting. Am J Psychiatry. 2004 Mar;161(3):556–61. doi: 10.1176/appi.ajp.161.3.556. PMID: 14992983. Exclusion Code: X14.14992983
1295 Walsh BT, Gladis M, Roose SP, . A controlled trial of phenelzine in bulimia. Psychopharmacol Bull. 1987;23(1):49–51. PMID: 3299445. Exclusion Code: X14.3299445
1296 Walsh BT, Gladis M, Roose SP, . Phenelzine vs placebo in 50 patients with bulimia. Arch Gen Psychiatry. 1988 May;45(5):471–5. doi: 10.1001/archpsyc.1988.01800290091011. PMID: 3282482. Exclusion Code: X5.3282482
1297 Walsh BT, Hadigan CM, Wong LM. Increased pulse and blood pressure associated with desipramine treatment of bulimia nervosa. J Clin Psychopharmacol. 1992 Jun;12(3):163–8. PMID: 1629381. Exclusion Code: X7.1629381
1298 Walsh BT, Stewart JW, Roose SP, . Treatment of bulimia with phenelzine. A double-blind, placebo-controlled study. Arch Gen Psychiatry. 1984 Nov;41(11):1105–9. doi: 10.1001/archpsyc.1983.01790220095015. PMID: 6388524. Exclusion Code: X5.6388524
1299 Walsh BT, Stewart JW, Roose SP, . A double-blind trial of phenelzine in bulimia. J Psychiatr Res. 1985;19(2–3):485–9. doi: 10.1016/0022-3956(85)90058-5. PMID: 3900362. Exclusion Code: X14.3900362
1300 Walsh BT, Wilson GT, Loeb KL, . Medication and psychotherapy in the treatment of bulimia nervosa. Am J Psychiatry. 1997 Apr;154(4):523–31. doi: 10.1176/ajp.154.4.523. PMID: 9090340. Exclusion Code: X7.9090340
1301 Ward A, Ramsay R, Russell G, . Follow-up mortality study of compulsorily treated patients with anorexia nervosa. Int J Eat Disord. 2015 Nov;48(7):860–5. doi: 10.1002/eat.22377. PMID: 25545619. Exclusion Code: X3.25545619
1302 Wardle J, Guthrie CA, Sanderson S, . Development of the Children’s Eating Behaviour Questionnaire. J Child Psychol Psychiatry. 2001 Oct;42(7):963–70. doi: 10.1111/1469-7610.00792. PMID: 11693591. Exclusion Code: X3.11693591
1303 Warren W. A study of anorexia nervosa in young girls. J Child Psychol Psychiatry. 1968 Oct;9(1):27–40. doi: 10.1111/j.1469-7610.1968.tb02205.x. PMID: 5729745. Exclusion Code: X9.5729745
1304 Watkins B, Frampton I, Lask B, . Reliability and validity of the child version of the Eating Disorder Examination: a preliminary investigation. Int J Eat Disord. 2005 Sep;38(2):183–7. doi: 10.1002/eat.20165. PMID: 16134106. Exclusion Code: X3.16134106
1305 Webb JB, Forman MJ. Evaluating the indirect effect of self-compassion on binge eating severity through cognitive-affective self-regulatory pathways. Eat Behav. 2013 Apr;14(2):224–8. doi: 10.1016/j.eatbeh.2012.12.005. PMID: 23557826. Exclusion Code: X7.23557826
1306 Weintraub M, Sundaresan PR, Madan M, . Long-term weight control study. I (weeks 0 to 34). The enhancement of behavior modification, caloric restriction, and exercise by fenfluramine plus phentermine versus placebo. Clin Pharmacol Ther. 1992 May;51(5):586–94. doi: 10.1038/clpt.1992.69. PMID: 1587072. Exclusion Code: X7.1587072
1307 Weintraub M, Sundaresan PR, Schuster B, . Long-term weight control study. V (weeks 190 to 210). Follow-up of participants after cessation of medication. Clin Pharmacol Ther. 1992 May;51(5):615–8. doi: 10.1038/clpt.1992.73. PMID: 1587076. Exclusion Code: X2.1587076
1308 Weisman HL, Patten E, Montanez-Leaks M, . Validation of a six-item male body image concerns scale (MBICS). Eat Disord. 2014;22(5):420–34. doi: 10.1080/10640266.2014.925768. PMID: 24964387. Exclusion Code: X4.24964387
1309 Weiss CV, Mills JS, Westra HA, . A preliminary study of motivational interviewing as a prelude to intensive treatment for an eating disorder. Journal of eating disorders. 2013;1(1)doi: 10.1186/2050-2974-1-34. PMID: CN-00980298. Exclusion Code: X7.
1310 Weiss L, Katzman M. Group treatment for bulimic women. Ariz Med. 1984 Feb;41(2):100–4. PMID: 6584098. Exclusion Code: X7.6584098
1311 Welch E, Birgegård A, Parling T, . Eating disorder examination questionnaire and clinical impairment assessment questionnaire: general population and clinical norms for young adult women in Sweden. Behav Res Ther. 2011 Feb;49(2):85–91. doi: 10.1016/j.brat.2010.10.010. PMID: 21185552. Exclusion Code: X7.21185552
1312 Welch E, Lagerström M, Ghaderi A. Body shape questionnaire: psychometric properties of the short version (BSQ-8C) and norms from the general Swedish population. Body Image. 2012 Sep;9(4):547–50. doi: 10.1016/j.bodyim.2012.04.009. PMID: 22721875. Exclusion Code: X4.22721875
1313 Welch G, Hall A. The reliability and discriminant validity of three potential measures of bulimic behaviours. J Psychiatr Res. 1989;23(2):125–33. doi: 10.1016/0022-3956(89)90003-4. PMID: 2585344. Exclusion Code: X3.2585344
1314 Welch G, Hall A. Is the prevalence of bulimia nervosa higher among tertiary education populations? N Z Med J. 1990 Oct 10;103(899):476–7. PMID: 2216131. Exclusion Code: X9.2216131
1315 Welch G, Thompson L, Hall A. The BULIT-R: its reliability and clinical validity as a screening tool for DSM-III-R bulimia nervosa in a female tertiary education population. Int J Eat Disord. 1993 Jul;14(1):95–105. doi: 10.1002/1098-108x(199307)14:1<95::aid-eat2260140113>3.0.co;2-z. PMID: 8339105. Exclusion Code: X4.8339105
1316 Wentz E, Gillberg IC, Anckarsäter H, . Adolescent-onset anorexia nervosa: 18-year outcome. Br J Psychiatry. 2009;194(2):168–74. doi: 10.1192/bjp.bp.107.048686. PMID: 2009-02230-012. Exclusion Code: X3.19182181
1317 Wentz E, Gillberg IC, Anckarsäter H, . Reproduction and offspring status 18 years after teenage-onset anorexia nervosa-a controlled community-based study. Int J Eat Disord. 2009 Sep;42(6):483–91. doi: 10.1002/eat.20664. PMID: 19197980. Exclusion Code: X9.19197980
1318 Wentz E, Gillberg IC, Anckarsäter H, . Somatic problems and self-injurious behaviour 18 years after teenage-onset anorexia nervosa. Eur Child Adolesc Psychiatry. 2012 Aug;21(8):421–32. doi: 10.1007/s00787-012-0274-9. PMID: 22484429. Exclusion Code: X3.22484429
1319 Wermuth BM, Davis KL, Hollister LE, . Phenytoin treatment of the binge-eating syndrome. Am J Psychiatry. 1977 Nov;134(11):1249–53. doi: 10.1176/ajp.134.11.1249. PMID: 333952. Exclusion Code: X3.333952
1320 Wever MCM, Dingemans AE, Geerets T, . Screening for Binge Eating Disorder in people with obesity. Obes Res Clin Pract. 2018 May–Jun;12(3):299–306. doi: 10.1016/j.orcp.2018.02.002. PMID: 29530586. Exclusion Code: X4.29530586
1321 White HJ, Haycraft E, Goodwin H, . Eating disorder examination questionnaire: factor structure for adolescent girls and boys. Int J Eat Disord. 2014 Jan;47(1):99–104. doi: 10.1002/eat.22199. PMID: 24323527. Exclusion Code: X4.24323527
1322 White JH. A comparison of two groups of women with bulimia nervosa on symptom onset. Issues Ment Health Nurs. 2000 Oct–Nov;21(7):671–90. doi: 10.1080/01612840050207608. PMID: 11855044. Exclusion Code: X9.11855044
1323 White MA, Grilo CM. Psychometric properties of the Food Craving Inventory among obese patients with binge eating disorder. Eat Behav. 2005 Jun;6(3):239–45. doi: 10.1016/j.eatbeh.2005.01.001. PMID: 15854870. Exclusion Code: X4.15854870
1324 White MA, Grilo CM. Diagnostic efficiency of DSM-IV indicators for binge eating episodes. J Consult Clin Psychol. 2011 Feb;79(1):75–83. doi: 10.1037/a0022210. PMID: 21261436. Exclusion Code: X4.21261436
1325 Wild B, Friederich HC, Gross G, . The ANTOP study: focal psychodynamic psychotherapy, cognitive-behavioural therapy, and treatment-as-usual in outpatients with anorexia nervosa-a randomized controlled trial. Trials. 2009 Apr 23;10:23. doi: 10.1186/1745-6215-10-23. PMID: 19389245. Exclusion Code: X9.19389245
1326 Wild B, Friederich HC, Zipfel S, . Predictors of outcomes in outpatients with anorexia nervosa - Results from the ANTOP study. Psychiatry Res. 2016 Oct 30;244:45–50. doi: 10.1016/j.psychres.2016.07.002. PMID: 27467700. Exclusion Code: X3.27467700
1327 Wildes JE, Marcus MD, Cheng Y, . Emotion acceptance behavior therapy for anorexia nervosa: a pilot study. Int J Eat Disord. 2014 Dec;47(8):870–3. doi: 10.1002/eat.22241. PMID: 24407934. Exclusion Code: X3.24407934
1328 Wildes JE, Marcus MD, Kalarchian MA, . Self-reported binge eating in severe pediatric obesity: impact on weight change in a randomized controlled trial of family-based treatment. Int J Obes (Lond). 2010 Jul;34(7):1143–8. doi: 10.1038/ijo.2010.35. PMID: 20157322. Exclusion Code: X3.20157322
1329 Wilfley D, Berkowitz R, Goebel-Fabbri A, . Binge eating, mood, and quality of life in youth with type 2 diabetes: baseline data from the today study. Diabetes Care. 2011 Apr;34(4):858–60. doi: 10.2337/dc10-1704. PMID: 21357794. Exclusion Code: X7.21357794
1330 Wilfley DE, Crow SJ, Hudson JI, . Efficacy of sibutramine for the treatment of binge eating disorder: a randomized multicenter placebo-controlled double-blind study. Am J Psychiatry. 2008 Jan;165(1):51–8. doi: 10.1176/appi.ajp.2007.06121970. PMID: 18056225. Exclusion Code: X5.18056225
1331 Wilfley DE, Friedman MA, Dounchis JZ, . Comorbid psychopathology in binge eating disorder: relation to eating disorder severity at baseline and following treatment. J Consult Clin Psychol. 2000 Aug;68(4):641–9. PMID: 10965639. Exclusion Code: X5.10965639
1332 Wilfley DE, Schreiber GB, Pike KM, . Eating disturbance and body image: a comparison of a community sample of adult black and white women. Int J Eat Disord. 1996 Dec;20(4):377–87. doi: 10.1002/(sici)1098-108x(199612)20:4<377::aid-eat5>3.0.co;2-k. PMID: 8953325. Exclusion Code: X7.8953325
1333 Wilksch SM, O’Shea A, Taylor CB, . Online prevention of disordered eating in at-risk young-adult women: a two-country pragmatic randomized controlled trial. Psychol Med. 2018 Sep;48(12):2034–44. doi: 10.1017/s0033291717003567. PMID: 29233196. Exclusion Code: X3.29233196
1334 Wilksch SM, O’Shea A, Wade TD. Depressive symptoms, alcohol and other drug use, and suicide risk: Prevention and treatment effects from a two-country online eating disorder risk reduction trial. Int J Eat Disord. 2018doi: 10.1002/eat.23005. PMID: 2018-66479-001. Exclusion Code: X3.
1335 Wilksch SM, Paxton SJ, Byrne SM, . Prevention Across the Spectrum: a randomized controlled trial of three programs to reduce risk factors for both eating disorders and obesity. Psychol Med. 2015 Jul;45(9):1811–23. doi: 10.1017/s003329171400289x. PMID: 25524249. Exclusion Code: X5.25524249
1336 Wilksch SM, Paxton SJ, Byrne SM, . Outcomes of three universal eating disorder risk reduction programs by participants with higher and lower baseline shape and weight concern. Int J Eat Disord. 2017;50(1):66–75. doi: 10.1002/eat.22642. PMID: 2016-51510-001. Exclusion Code: X5.27768806
1337 Williams CM, Tinley P, Curtin M, . Is idiopathic toe walking really idiopathic? The motor skills and sensory processing abilities associated with idiopathic toe walking gait. J Child Neurol. 2014;29(1):71–8. doi: 10.1177/0883073812470001. PMID: 2014-00237-013. Exclusion Code: X2.23349518
1338 Williams GJ, Power KG, Miller HR, . Development and validation of the Stirling Eating Disorder Scales. Int J Eat Disord. 1994 Jul;16(1):35–43. doi: 10.1002/1098-108x(199407)16:1<35::aid-eat2260160103>3.0.co;2-4. PMID: 7920579. Exclusion Code: X3.7920579
1339 Williams P, Hand DJ, Tarnopolsky A. The problem of screening for uncommon disorders: A comment on the Eating Attitudes Test. Psychol Med. 1982;12(2):431–4. doi: 10.1017/S003329170004678X. PMID: 1983-00117-001. Exclusion Code: X12.7100366
1340 Williamson DA, Gleaves DH, Watkins PC, . Validation of self-ideal body size discrepancy as a measure of body dissatisfaction. J Psychopathol Behav Assess. 1993;15(1):57–68. doi: 10.1007/BF00964324. PMID: 1993-45877-001. Exclusion Code: X4.
1341 Wilmskoetter J, Bonilha H, Hong I, . Construct validity of the Eating Assessment Tool (EAT-10). Disabil Rehabil. 2019 Mar;41(5):549–59. doi: 10.1080/09638288.2017.1398787. PMID: 29117726. Exclusion Code: X4.29117726
1342 Wilson GT, Loeb KL, Walsh BT, . Psychological versus pharmacological treatments of bulimia nervosa: predictors and processes of change. J Consult Clin Psychol. 1999 Aug;67(4):451–9. doi: 10.1037//0022-006x.67.4.451. PMID: 10450615. Exclusion Code: X7.10450615
1343 Wilson GT, Rossiter E, Kleifield EI, . Cognitive-behavioral treatment of bulimia nervosa: a controlled evaluation. Behav Res Ther. 1986;24(3):277–88. doi: 10.1016/0005-7967(86)90187-7. PMID: 3460591. Exclusion Code: X7.3460591
1344 Winkler LA, Bilenberg N, Hørder K, . Does specialization of treatment influence mortality in eating disorders?-A comparison of two retrospective cohorts. Psychiatry Res. 2015 Dec 15;230(2):165–71. doi: 10.1016/j.psychres.2015.08.032. PMID: 26391650. Exclusion Code: X9.26391650
1345 Winzelberg AJ, Eppstein D, Eldredge KL, . Effectiveness of an Internet-based program for reducing risk factors for eating disorders. J Consult Clin Psychol. 2000 Apr;68(2):346–50. doi: 10.1037//0022-006x.68.2.346. PMID: 10780136. Exclusion Code: X3.10780136
1346 Winzelberg AJ, Taylor CB, Sharpe T, . Evaluation of a computer-mediated eating disorder intervention program. Int J Eat Disord. 1998 Dec;24(4):339–49. doi: 10.1002/(sici)1098-108x(199812)24:4<339::aid-eat1>3.0.co;2-j. PMID: 9813759. Exclusion Code: X7.9813759
1347 Wong Y, Chang YJ, Tsai MR, . The body image, weight satisfaction, and eating disorder tendency of school children: the 2-year follow-up study. J Am Coll Nutr. 2011 Apr;30(2):126–33. doi: 10.1080/07315724.2011.10719951. PMID: 21730220. Exclusion Code: X9.21730220
1348 Woodside DB, Shekter-Wolfson L, Garfinkel PE, . Family interactions in bulimia nervosa: I Study design, comparisons to established population norms, and changes over the course of an intensive day hospital treatment program. Int J Eat Disord. 1995;17(2):105–15. doi: 10.1002/1098-108X(199503)17:2<105::AID-EAT2260170202>3.0.CO;2-P. PMID: 1995-34569-001. Exclusion Code: X9.7757090
1349 Wu M, Li Z, Yu JE, . Multi-centered clinical study on effects of nano-amomi paste in treating children’s anorexia. Chin J Integr Med. 2007 Mar;13(1):55–8. doi: 10.1007/s11655-007-0055-3. PMID: 17578320. Exclusion Code: X5.17578320
1350 Wu S, Cai T, Luo X. Validation of the Dutch Eating Behavior Questionnaire (DEBQ) in a sample of Chinese adolescents. Psychol Health Med. 2017 Mar;22(3):282–8. doi: 10.1080/13548506.2016.1173712. PMID: 27080537. Exclusion Code: X4.27080537
1351 Yager J, Landsverk J, Edelstein CK. A 20-month follow-up study of 628 women with eating disorders, I: Course and severity. Am J Psychiatry. 1987 Sep;144(9):1172–7. doi: 10.1176/ajp.144.9.1172. PMID: 3477104. Exclusion Code: X5.3477104
1352 Yager Z, O’Dea J. A controlled intervention to promote a healthy body image, reduce eating disorder risk and prevent excessive exercise among trainee health education and physical education teachers. Health Educ Res. 2010 Oct;25(5):841–52. doi: 10.1093/her/cyq036. PMID: 20656796. Exclusion Code: X5.20656796
1353 Yates AJ, Sambrailo F. Bulimia nervosa: a descriptive and therapeutic study. Behav Res Ther. 1984;22(5):503–17. doi: 10.1016/0005-7967(84)90054-8. PMID: 6594993. Exclusion Code: X7.6594993
1354 Yee K, Serrano D, Kando J, . A psychometric analysis and revalidation of the Yale-Brown Obsessive Compulsive Scale modified for Binge Eating in adults with binge eating disorder. Qual Life Res. 2019 Dec;28(12):3385–94. doi: 10.1007/s11136-019-02277-8. PMID: 31473907. Exclusion Code: X4.31473907
1355 Young S, Touyz S, Meyer C, . Validity of Exercise Measures in Adults with Anorexia Nervosa: The EDE, Compulsive Exercise Test and Other Self-Report Scales. Int J Eat Disord. 2017 May;50(5):533–41. doi: 10.1002/eat.22633. PMID: 27696468. Exclusion Code: X4.27696468
1356 Yu J, Stewart Agras W, Halmi KA, . A 1-year follow-up of a multi-center treatment trial of adults with anorexia nervosa. Eat Weight Disord. 2011 Sep;16(3):e177–81. doi: 10.1007/bf03325129. PMID: 22290033. Exclusion Code: X7.22290033
1357 Yucel B, Polat A, Ikiz T, . The Turkish version of the eating disorder examination questionnaire: reliability and validity in adolescents. Eur Eat Disord Rev. 2011 Nov–Dec;19(6):509–11. doi: 10.1002/erv.1104. PMID: 21400637. Exclusion Code: X9.21400637
1358 Zaitsoff SL, Doyle AC, Hoste RR, . How do adolescents with bulimia nervosa rate the acceptability and therapeutic relationship in family-based treatment? Int J Eat Disord. 2008 Jul;41(5):390–8. doi: 10.1002/eat.20515. PMID: 18306343. Exclusion Code: X7.18306343
1359 Zapata MA, Ruiz-Lázaro PM, Calvo AI, . Randomised controlled trial: results at 12 months follow-up. Eur Child Adolesc Psychiatry. 2015;24(1):S85-. doi: 10.1007/s00787-015-0714-4. PMID: CN-01098699. Exclusion Code: X13.
1360 Zenlea IS, Burton ET, Askins N, . Binge Eating at the Start of a Pediatric Weight Management Program. Clin Pediatr (Phila). 2015 Jun;54(6):585–8. doi: 10.1177/0009922814540042. PMID: 24961781. Exclusion Code: X9.24961781
1361 Zerwas SC, Watson HJ, Hofmeier SM, . CBT4BN: A randomized controlled trial of online chat and face-to-face group therapy for bulimia nervosa. Psychother Psychosom. 2016;86(1):47–53. doi: 10.1159/000449025. PMID: 2016-61424-007. Exclusion Code: X7.27883997
1362 Ziauddeen H, Chamberlain SR, Nathan PJ, . Effects of the mu-opioid receptor antagonist GSK1521498 on hedonic and consummatory eating behaviour: a proof of mechanism study in binge-eating obese subjects. Mol Psychiatry. 2013 Dec;18(12):1287–93. doi: 10.1038/mp.2012.154. PMID: 23147384. Exclusion Code: X5.23147384
1363 Zickgraf HF, Ellis JM. Initial validation of the Nine Item Avoidant/Restrictive Food Intake disorder screen (NIAS): a measure of three restrictive eating patterns. Appetite. 2018 Apr 1;123:32–42. doi: 10.1016/j.appet.2017.11.111. PMID: 29208483. Exclusion Code: X7.29208483
1364 Zickgraf HF, Lane-Loney S, Essayli JH, . Further support for diagnostically meaningful ARFID symptom presentations in an adolescent medicine partial hospitalization program. Int J Eat Disord. 2019 Apr;52(4):402–9. doi: 10.1002/eat.23016. PMID: 30632634. Exclusion Code: X9.30632634
1365 Ziegler R, Sours JA. A naturalistic study of patients with anorexia nervosa admitted to a university medical center. Compr Psychiatry. 1968 Nov;9(6):644–51. doi: 10.1016/s0010-440x(68)80060-4. PMID: 5703311. Exclusion Code: X8.5703311
1366 Zimmerman M, Mattia JI. The reliability and validity of a screening Questionnaire for 13 DSM-IV Axis I disorders (the Psychiatric Diagnostic Screening Questionnaire) in psychiatric outpatients. J Clin Psychiatry. 1999 Oct;60(10):677–83. doi: 10.4088/jcp.v60n1006. PMID: 10549684. Exclusion Code: X4.10549684
1367 Zimmerman M, Mattia JI. The Psychiatric Diagnostic Screening Questionnaire: development, reliability and validity. Compr Psychiatry. 2001 May–Jun;42(3):175–89. doi: 10.1053/comp.2001.23126. PMID: 11349235. Exclusion Code: X4.11349235
1368 Zipfel S, Wild B, Groß G, . Focal psychodynamic therapy, cognitive behaviour therapy, and optimised treatment as usual in outpatients with anorexia nervosa (ANTOP study): randomised controlled trial. Lancet. 2014 Jan 11;383(9912):127–37. doi: 10.1016/s0140-6736(13)61746-8. PMID: 24131861. Exclusion Code: X7.24131861
1369 Zohar AH, Lev-Ari L, Bachner-Melman R. The EDE-Q in Hebrew: structural and convergent/divergent validity in a population sample. Isr J Psychiatry Relat Sci. 2017;54(3):15–20. PMID: 29735808. Exclusion Code: X7.29735808
1370 Zunker C, Peterson CB, Cao L, . A receiver operator characteristics analysis of treatment outcome in binge eating disorder to identify patterns of rapid response. Behav Res Ther. 2010;48(12):1227–31. doi: 10.1016/j.brat.2010.08.007. PMID: 2010-23359-007. Exclusion Code: X7.20869041