# Appendix B Additional Methods Information

## Appendix B1 Original Search Strategies

PubMed, 6/18/2020

Total Unduplicated Yield = 8,570

Screening Benefits ( KQ 1 ) and Harms ( KQ 3 ) Searches

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | “Anorexia”[Mesh] OR “Anorexia Nervosa”[Mesh] OR “Avoidant Restrictive Food Intake Disorder”[Mesh] OR “Binge-Eating Disorder”[Mesh] OR Bulimia[Mesh] OR “Feeding and Eating Disorders”[Mesh:NoExp] OR anorexi*[tiab] OR “avoidant restrictive food intake disorder”[All Fields] OR ARFID[tiab] OR “binge-eating”[tiab] OR bulimia[tiab] OR bulimic[tiab] OR (eating[tiab] AND disorder*[tiab]) OR (feed*[tiab] AND disorder*[tiab]) OR (food*[tiab] AND neophobia*[tiab]) OR “night eating”[tiab] OR “purging disorder”[tiab] OR EDNOS[tiab] OR OSFED[tiab] | 75,958
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | “Surveys and Questionnaires”[Mesh] OR “Psychiatric Status Rating Scales”[Mesh] OR identifying[tiab] OR identification[tiab] OR instrument[tiab] OR instruments[tiab] OR measure[tiab] OR measures[tiab] OR questionnaire[tiab] OR questionnaires[tiab] OR inventory[tiab] OR inventories[tiab] OR scale[tiab] OR scales[tiab] OR screen[tiab] OR screening[tiab] | 4,075,629
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | #1 AND #2 | 22,089
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | “Adolescent Binge Eating Scale”[tiab] OR “Eating Attitudes Test”[tiab] OR “EAT-26”[tiab] OR “Eating Disorder Inventory”[tiab] OR “Eating Disorder Screen for Primary Care”[tiab] OR “EDS-PC”[tiab] OR “Primary Care Evaluation of Mental Disorders Patient Health Questionnaire”[tiab] OR SCOFF[tiab] OR “Sick, Control, One, Fat and Food”[tiab] OR “Dutch Eating Behavior Questionnaire”[tiab] OR DEBQ[tiab] OR “Eating Disorder Examination”[tiab] OR “Minnesota Eating Behavior Survey”[tiab] OR “Patient Health Questionnaire”[tiab] OR PHQ[tiab] OR PRIMEMD[tiab] OR “Screening for Disordered Eating”[tiab] | 9,472
#5 | #1 AND #4 | 2,683
#6 | #3 OR #5 | 22,285
#7 | #3 OR #5 Filters: English | 20,911
#8 | #3 OR #5 Filters: English, Child: 6-12 years | 2,783
#9 | #3 OR #5 Filters: English, Adolescent: 13-18 years, Child: 6-12 years | 8,454
#10 | #3 OR #5 Filters: English, Adult: 19+ years, Child: 6-12 years, Adolescent: 13-18 years | 14,932
#11 | #7 AND (publisher[sb] OR inprocess[sb] OR pubstatusaheadofprint) | 1,239
#12 | (#11 AND (adolescent[tiab] OR adolescents[tiab] OR adult[tiab] OR adults[tiab] OR elderly[tiab] OR teen[tiab] OR teens[tiab] OR teenage[tiab] OR teenaged[tiab])) OR (#11 NOT (newborn[tiab] OR newborns[tiab] OR infant[tiab] OR infants[tiab])) | 1,178
#13 | #10 OR #12 | 16,103
#14 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case control”[tw] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | 10,584,173
#15 | #13 NOT #14 | 14,483
#16 | “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR ((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract]) | 696,278
#17 | #15 AND #16 | 1,415
#18 | “Observational Study”[Publication Type] OR “Prospective Studies”[Mesh] OR “Cohort Studies”[Mesh] OR “observational study”[tiab] OR “observational studies”[tiab] OR prospective*[tiab] OR cohort*[tiab] | 2,545,433
#19 | #15 AND #18 | 3,083
#20 | #19 NOT #17 | 2,743

Screening Test Accuracy ( KQ 2 )

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | “Anorexia”[Mesh] OR “Anorexia Nervosa”[Mesh] OR “Avoidant Restrictive Food Intake Disorder”[Mesh] OR “Binge-Eating Disorder”[Mesh] OR Bulimia[Mesh] OR “Feeding and Eating Disorders”[Mesh:NoExp] OR anorexi*[tiab] OR “avoidant restrictive food intake disorder”[All Fields] OR ARFID[tiab] OR “binge-eating”[tiab] OR bulimia[tiab] OR bulimic[tiab] OR (eating[tiab] AND disorder*[tiab]) OR (feed*[tiab] AND disorder*[tiab]) OR (food*[tiab] AND neophobia*[tiab]) OR “night eating”[tiab] OR “purging disorder”[tiab] OR EDNOS[tiab] OR OSFED[tiab] | 75,958
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | “Surveys and Questionnaires”[Mesh] OR “Psychiatric Status Rating Scales”[Mesh] OR identifying[tiab] OR identification[tiab] OR instrument[tiab] OR instruments[tiab] OR measure[tiab] OR measures[tiab] OR questionnaire[tiab] OR questionnaires[tiab] OR inventory[tiab] OR inventories[tiab] OR scale[tiab] OR scales[tiab] OR screen[tiab] OR screening[tiab] | 4,075,629
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | #1 AND #2 | 22,089
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | “Adolescent Binge Eating Scale”[tiab] OR “Eating Attitudes Test”[tiab] OR “EAT-26”[tiab] OR “Eating Disorder Inventory”[tiab] OR “Eating Disorder Screen for Primary Care”[tiab] OR “EDS-PC”[tiab] OR “Primary Care Evaluation of Mental Disorders Patient Health Questionnaire”[tiab] OR SCOFF[tiab] OR “Sick, Control, One, Fat and Food”[tiab] OR “Dutch Eating Behavior Questionnaire”[tiab] OR DEBQ[tiab] OR “Eating Disorder Examination”[tiab] OR “Minnesota Eating Behavior Survey”[tiab] OR “Patient Health Questionnaire”[tiab] OR PHQ[tiab] OR PRIMEMD[tiab] OR “Screening for Disordered Eating”[tiab] | 9,472
#5 | #1 AND #4 | 2,683
#6 | #3 OR #5 | 22,285
#7 | #3 OR #5 Filters: English | 20,911
#8 | #3 OR #5 Filters: English, Child: 6-12 years | 2,783
#9 | #3 OR #5 Filters: English, Adolescent: 13-18 years, Child: 6-12 years | 8,454
#10 | #3 OR #5 Filters: English, Adult: 19+ years, Child: 6-12 years, Adolescent: 13-18 years | 14,932
#11 | #7 AND (publisher[sb] OR inprocess[sb] OR pubstatusaheadofprint) | 1,239
#12 | (#11 AND (adolescent[tiab] OR adolescents[tiab] OR adult[tiab] OR adults[tiab] OR elderly[tiab] OR teen[tiab] OR teens[tiab] OR teenage[tiab] OR teenaged[tiab])) OR (#11 NOT (newborn[tiab] OR newborns[tiab] OR infant[tiab] OR infants[tiab])) | 1,178
#13 | #10 OR #12 | 16,103
#14 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | 8,308,838
#15 | #13 NOT #14 | 15,938
#16 | “Sensitivity and Specificity”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “ROC Curve”[Mesh] OR “Reproducibility of Results”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR “predictive value”[tw] OR sensitivity[tw] OR specificity[tw] OR accuracy[tw] OR ROC[tw] OR reproducib*[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw] | 2,529,966
#17 | #15 AND #16 | 2,085

Intervention Benefits ( KQ 4 ) and Harms ( KQ 5 )

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | “Anorexia”[Mesh] OR “Anorexia Nervosa”[Mesh] OR “Avoidant Restrictive Food Intake Disorder”[Mesh] OR “Binge-Eating Disorder”[Mesh] OR “Bulimia”[Mesh] OR “Feeding and Eating Disorders”[Mesh:NoExp] OR anorexi*[tiab] OR “avoidant restrictive food intake disorder”[All Fields] OR ARFID[tiab] OR “binge-eating”[tiab] OR bulimia[tiab] OR bulimic[tiab] OR (eating[tiab] AND disorder*[tiab]) OR (feed*[tiab] AND disorder*[tiab]) OR (food*[tiab] AND neophobia*[tiab]) OR “night eating”[tiab] OR “purging disorder”[tiab] OR EDNOS[tiab] OR OSFED[tiab] | 75,992
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | “Cognitive Behavioral Therapy”[Mesh] OR “Dialectical Behavior Therapy”[Mesh] OR “Distance Counseling”[Mesh] OR “Emotion-Focused Therapy”[Mesh] OR “Family Therapy”[Mesh] OR “Internet-Based Intervention”[Mesh] OR Meditation[Mesh] OR Mindfulness[Mesh] OR “Physical Therapy Modalities”[Mesh] OR CBT[tiab] OR “cognitive behavior therapy”[tiab] OR “cognitive behavioral therapy”[tiab] OR “cognitive analytic therapy”[tiab] OR “cognitive orientation therapy”[tiab] OR “Dialectical Behavior Therapy”[tiab] OR “e-therapy”[tiab] OR (emotion*[tiab] AND therap*[tiab]) OR “exposure and response prevention therapy”[All Fields] OR “Family Therapy”[tiab] OR “group therapy”[tiab] OR “internet-based intervention*”[tiab] OR meditation[tiab] OR “Maudsley Method”[tiab] OR mindfulness[tiab] OR (nutrition*[tiab] AND counsel*[tiab]) OR “physical therapy”[tiab] OR psychotherap*[tiab] | 276,952
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | #1 AND #2 | 4,869
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | “drug therapy”[Subheading] OR “Early Medical Intervention”[Mesh] OR “Therapeutics”[Mesh] OR “therapy”[Subheading] OR treatment* OR intervention*[tiab] OR pharmacotherap*[tiab] | 11,098,758
#5 | #1 AND #4 | 42,286
#6 | “Antidepressive Agents, Second-Generation”[Mesh] OR (“Antipsychotic Agents”[Mesh] AND atypical) OR (antidepressant*[tiab] AND “second-generation”[tiab) OR (antidepressive* AND “second-generation”[tiab]) OR “atypical antipsychotic*”[tiab] OR lisdexamfetamine OR topiramate | 24,534
#7 | #1 AND #6 | 514
#8 | #3 OR #5 OR #7 | 42,658
#9 | #3 OR #5 Filters: English | 37,423
#10 | #3 OR #5 Filters: English, Child: 6-12 years | 4,000
#11 | #3 OR #5 Filters: English, Adolescent: 13-18 years, Child: 6-12 years | 9,856
#12 | #3 OR #5 Filters: English, Adult: 19+ years, Child: 6-12 years, Adolescent: 13-18 years | 20,296
#13 | #9 AND (publisher[sb] OR inprocess[sb] OR pubstatusaheadofprint) | 1,713
#14 | (#13 AND (adolescent[tiab] OR adolescents[tiab] OR adult[tiab] OR adults[tiab] OR elderly[tiab] OR teen[tiab] OR teens[tiab] OR teenage[tiab] OR teenaged[tiab])) OR (#13 NOT (newborn[tiab] OR newborns[tiab] OR infant[tiab] OR infants[tiab])) | 1,639
#15 | #12 OR #14 | 21,935
#16 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case control”[tw] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | 11,016,403
#17 | #15 NOT #16 | 16,165
#18 | “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR ((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract]) | 696,607
#19 | #17 AND #18 | 2,327
#20 | “Observational Study”[Publication Type] OR “Prospective Studies”[Mesh] OR “Cohort Studies”[Mesh] OR “observational study”[tiab] OR “observational studies”[tiab] OR prospective*[tiab] OR cohort*[tiab] | 2,547,404
#21 | #17 AND #20 | 3,959
#22 | #21 NOT #19 | 3,395

### Cochrane Review, 6/20/2020

KQ 2 Search for Diagnostic Accuracy, 6/20/2020

All results are trials = 269; 179 imported

Search Number | String | Yield
#1 | [mh “Anorexia”] OR [mh “Anorexia Nervosa”] OR [mh “Avoidant Restrictive Food Intake Disorder”] OR [mh “Binge-Eating Disorder”] OR [mh Bulimia] OR [mh ^”Feeding and Eating Disorders”] OR anorexi*:ti,ab OR “avoidant restrictive food intake disorder”:ti,ab,kw OR ARFID:ti,ab OR “binge-eating”:ti,ab OR bulimia:ti,ab OR bulimic:ti,ab OR (eating:ti,ab AND disorder*:ti,ab) OR (feed*:ti,ab AND disorder*:ti,ab) OR (food*:ti,ab AND neophobia*:ti,ab) OR “night eating”:ti,ab OR “purging disorder”:ti,ab OR EDNOS:ti,ab OR OSFED:ti,ab | 8581
#2 | [mh “Surveys and Questionnaires”] OR [mh “Psychiatric Status Rating Scales”] OR identifying:ti,ab OR identification:ti,ab OR instrument:ti,ab OR instruments:ti,ab OR measure:ti,ab OR measures:ti,ab OR questionnaire:ti,ab OR questionnaires:ti,ab OR inventory:ti,ab OR inventories:ti,ab OR scale:ti,ab OR scales:ti,ab OR screen:ti,ab OR screening:ti,ab | 433635
#3 | #1 AND #2 | 3978
#4 | “Adolescent Binge Eating Scale”:ti,ab OR “Eating Attitudes Test”:ti,ab OR “EAT-26”:ti,ab OR “Eating Disorder Inventory”:ti,ab OR “Eating Disorder Screen for Primary Care”:ti,ab OR “EDS-PC”:ti,ab OR “Primary Care Evaluation of Mental Disorders Patient Health Questionnaire”:ti,ab OR SCOFF:ti,ab OR “Sick, Control, One, Fat and Food”:ti,ab OR “Dutch Eating Behavior Questionnaire”:ti,ab OR DEBQ:ti,ab OR “Eating Disorder Examination”:ti,ab OR “Minnesota Eating Behavior Survey”:ti,ab OR “Patient Health Questionnaire”:ti,ab OR PHQ:ti,ab OR PRIMEMD:ti,ab OR “Screening for Disordered Eating”:ti,ab | 2944
#5 | #1 AND #4 | 523
#6 | #3 OR #5 | 4015
#7 | [mh child] OR [mh adolescent] OR [mh adult] | 120404
#8 | #6 AND #7 | 633
#9 | (#6 AND (adolescent:ti,ab OR adolescents:ti,ab OR adult:ti,ab OR adults:ti,ab OR elderly:ti,ab OR teen:ti,ab OR teens:ti,ab OR teenage:ti,ab OR teenaged:ti,ab)) OR (#6 NOT (newborn:ti,ab OR newborns:ti,ab OR infant:ti,ab OR infants:ti,ab)) | 3869
#10 | #8 OR #9 | 3870
#11 | address:pt OR “autobiography”:pt OR “bibliography”:pt OR “biography”:pt OR “case control” OR “case report” OR “case reports” OR “case series” OR “comment”:pt OR “comment on” OR congress:pt OR “cross-sectional” OR “dictionary”:pt OR “directory”:pt OR “editorial”:pt OR “festschrift”:pt OR “historical article”:pt OR “interview”:pt OR lecture:pt OR “legal case”:pt OR “legislation”:pt OR letter:pt OR “news”:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR “retrospective cohort” OR ([mh “Animals”] NOT [mh “Humans”]) OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae | 65740
#12 | #10 NOT #11 | 3714
#13 | [mh “Sensitivity and Specificity”] OR [mh “Predictive Value of Tests”] OR [mh “ROC Curve”] OR [mh “Reproducibility of Results”] OR [mh “False Negative Reactions”] OR [mh “False Positive Reactions”] OR “predictive value”:ti,ab,kw OR sensitivity:ti,ab,kw OR specificity:ti,ab,kw OR accuracy:ti,ab,kw OR ROC:ti,ab,kw OR reproducib*:ti,ab,kw OR “false positive”:ti,ab,kw OR “false negative”:ti,ab,kw OR “likelihood ratio”:ti,ab,kw | 92405
#14 | #12 AND #13 | 269
#15 | [mh “Anorexia”] OR [mh “Anorexia Nervosa”] OR [mh “Avoidant Restrictive Food Intake Disorder”] OR [mh “Binge-Eating Disorder”] OR [mh Bulimia] OR [mh ^”Feeding and Eating Disorders”] OR anorexi*:ti,ab OR “avoidant restrictive food intake disorder”:ti,ab,kw OR ARFID:ti,ab OR “binge-eating”:ti,ab OR bulimia:ti,ab OR bulimic:ti,ab OR (eating:ti,ab AND disorder*:ti,ab) OR (feed*:ti,ab AND disorder*:ti,ab) OR (food*:ti,ab AND neophobia*:ti,ab) OR “night eating”:ti,ab OR “purging disorder”:ti,ab OR EDNOS:ti,ab OR OSFED:ti,ab | 8581

### Cochrane Library, Screening, 6/20/2020

RCTs = 2,993; 1,735 imported

Observational (all are controlled trials): 34; 13 imported

Search Number | String | Yield
#1 | [mh “Anorexia”] OR [mh “Anorexia Nervosa”] OR [mh “Avoidant Restrictive Food Intake Disorder”] OR [mh “Binge-Eating Disorder”] OR [mh Bulimia] OR [mh ^”Feeding and Eating Disorders”] OR anorexi*:ti,ab OR “avoidant restrictive food intake disorder”:ti,ab,kw OR ARFID:ti,ab OR “binge-eating”:ti,ab OR bulimia:ti,ab OR bulimic:ti,ab OR (eating:ti,ab AND disorder*:ti,ab) OR (feed*:ti,ab AND disorder*:ti,ab) OR (food*:ti,ab AND neophobia*:ti,ab) OR “night eating”:ti,ab OR “purging disorder”:ti,ab OR EDNOS:ti,ab OR OSFED:ti,ab | 8581
#2 | [mh “Surveys and Questionnaires”] OR [mh “Psychiatric Status Rating Scales”] OR identifying:ti,ab OR identification:ti,ab OR instrument:ti,ab OR instruments:ti,ab OR measure:ti,ab OR measures:ti,ab OR questionnaire:ti,ab OR questionnaires:ti,ab OR inventory:ti,ab OR inventories:ti,ab OR scale:ti,ab OR scales:ti,ab OR screen:ti,ab OR screening:ti,ab | 433635
#3 | #1 AND #2 | 3978
#4 | “Adolescent Binge Eating Scale”:ti,ab OR “Eating Attitudes Test”:ti,ab OR “EAT-26”:ti,ab OR “Eating Disorder Inventory”:ti,ab OR “Eating Disorder Screen for Primary Care”:ti,ab OR “EDS-PC”:ti,ab OR “Primary Care Evaluation of Mental Disorders Patient Health Questionnaire”:ti,ab OR SCOFF:ti,ab OR “Sick, Control, One, Fat and Food”:ti,ab OR “Dutch Eating Behavior Questionnaire”:ti,ab OR DEBQ:ti,ab OR “Eating Disorder Examination”:ti,ab OR “Minnesota Eating Behavior Survey”:ti,ab OR “Patient Health Questionnaire”:ti,ab OR PHQ:ti,ab OR PRIMEMD:ti,ab OR “Screening for Disordered Eating”:ti,ab | 2944
#5 | #1 AND #4 | 523
#6 | #3 OR #5 | 4015
#7 | [mh child] OR [mh adolescent] OR [mh adult] | 120404
#8 | #6 AND #7 | 633
#9 | (#6 AND (adolescent:ti,ab OR adolescents:ti,ab OR adult:ti,ab OR adults:ti,ab OR elderly:ti,ab OR teen:ti,ab OR teens:ti,ab OR teenage:ti,ab OR teenaged:ti,ab)) OR (#6 NOT (newborn:ti,ab OR newborns:ti,ab OR infant:ti,ab OR infants:ti,ab)) | 3869
#10 | #8 OR #9 | 3870
#11 | address:pt OR “autobiography”:pt OR “bibliography”:pt OR “biography”:pt OR “case control” OR “case report” OR “case reports” OR “case series” OR “comment”:pt OR “comment on” OR congress:pt OR “cross-sectional” OR “dictionary”:pt OR “directory”:pt OR “editorial”:pt OR “festschrift”:pt OR “historical article”:pt OR “interview”:pt OR lecture:pt OR “legal case”:pt OR “legislation”:pt OR letter:pt OR “news”:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR “retrospective cohort” OR ([mh “Animals”] NOT [mh “Humans”]) OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae | 65740
#12 | #10 NOT #11 | 3714
#13 | #12 AND (“randomized controlled trial”:pt OR “randomized controlled trial as topic”:pt OR “single-blind method”:pt OR “double-blind method”:pt OR “random allocation”:pt OR (random* AND control* AND trial*) OR “single-blind” OR “double-blind” OR (random* AND allocat*)) | 2993
#14 | #12 AND ([mh “Cohort Studies”] OR [mh “Follow-Up Studies”] OR “prospective cohort” OR [mh “prospective studies”] OR (prospective* AND cohort AND (study OR studies)) OR (cohort AND (study OR studies)) OR (“follow-up” AND (study OR studies))) | 372
#15 | #14 NOT #13 | 34

### Cochrane Library, Interventions, 6/23/2020

RCTs = 2,134; 316 imported

Observational Studies (all are also trials): 564; 11 imported

Search Number | String | Yield
#1 | [mh “Anorexia”] OR [mh “Anorexia Nervosa”] OR [mh “Avoidant Restrictive Food Intake Disorder”] OR [mh “Binge-Eating Disorder”] OR [mh Bulimia] OR [mh ^”Feeding and Eating Disorders”] OR anorexi*:ti,ab OR “avoidant restrictive food intake disorder”:ti,ab,kw OR ARFID:ti,ab OR “binge-eating”:ti,ab OR bulimia:ti,ab OR bulimic:ti,ab OR (eating:ti,ab AND disorder*:ti,ab) OR (feed*:ti,ab AND disorder*:ti,ab) OR (food*:ti,ab AND neophobia*:ti,ab) OR “night eating”:ti,ab OR “purging disorder”:ti,ab OR EDNOS:ti,ab OR OSFED:ti,ab | 8581
#2 | [mh “Cognitive Behavioral Therapy”] OR [mh “Dialectical Behavior Therapy”] OR [mh “Distance Counseling”] OR [mh “Emotion-Focused Therapy”] OR [mh “Family Therapy”] OR [mh “Internet-Based Intervention”] OR [mh Meditation] OR [mh Mindfulness] OR [mh “Physical Therapy Modalities”] OR CBT:ti,ab OR “cognitive behavior therapy”:ti,ab OR “cognitive behavioral therapy”:ti,ab OR “cognitive analytic therapy”:ti,ab OR “cognitive orientation therapy”:ti,ab OR “Dialectical Behavior Therapy”:ti,ab OR e-therapy:ti,ab OR (emotion*:ti,ab AND therap*:ti,ab) OR “exposure and response prevention therapy”:ti,ab OR “Family Therapy”:ti,ab OR “group therapy”:ti,ab OR “internet-based intervention*”:ti,ab OR meditation:ti,ab OR “Maudsley Method”:ti,ab OR mindfulness:ti,ab OR (nutrition*:ti,ab AND counsel*:ti,ab) OR “physical therapy”:ti,ab OR psychotherap*:ti,ab | 63662
#3 | #1 AND #2 | 1666
#4 | [mh /DT] OR [mh “Early Medical Intervention”] OR [mh Therapeutics] OR [mh /TH] OR treatment* OR intervention*:ti,ab OR pharmacotherap*:ti,ab | 1070790
#5 | #1 AND #4 | 7147
#6 | [mh “Antidepressive Agents, Second-Generation”] OR ([mh “Antipsychotic Agents”] AND atypical) OR (antidepressant*:ti,ab AND “second-generation”:ti,ab) OR (antidepressive* AND “second-generation”:ti,ab) OR “atypical antipsychotic*”:ti,ab OR lisdexamfetamine OR topiramate | 4560
#7 | #1 AND #6 | 175
#8 | #3 OR #5 OR #7 | 7248
#9 | (#8 AND (adolescent:ti,ab OR adolescents:ti,ab OR adult:ti,ab OR adults:ti,ab OR elderly:ti,ab OR teen:ti,ab OR teens:ti,ab OR teenage:ti,ab OR teenaged:ti,ab)) OR (#8 NOT (newborn:ti,ab OR newborns:ti,ab OR infant:ti,ab OR infants:ti,ab)) | 7013
#10 | #8 AND ([mh child] OR [mh adolescent] OR [mh adult]) | 983
#11 | #9 OR #10 | 7017
#12 | Address:pt OR “autobiography”:pt OR “bibliography”:pt OR “biography”:pt OR “case control” OR “case report” OR “case reports” OR “case series” OR “comment”:pt OR “comment on” OR congress:pt OR “cross-sectional” OR “dictionary”:pt OR “directory”:pt OR “editorial”:pt OR “festschrift”:pt OR “historical article”:pt OR “interview”:pt OR lecture:pt OR “legal case”:pt OR “legislation”:pt OR letter:pt OR “news”:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR “retrospective cohort” OR ([mh “Animals”] NOT [mh “Humans”]) OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae | 65742
#13 | #11 NOT #12 | 6698
#14 | “randomized controlled trial”:pt OR “randomized controlled trial as topic”:pt OR “single-blind method”:pt OR “double-blind method”:pt OR “random allocation”:pt | 486307
#15 | #13 AND #14 | 2134
#16 | [mh “Cohort Studies”] OR [mh “Follow-Up Studies”] OR “prospective cohort” OR [mh “prospective studies”] OR (prospective* AND cohort AND (study OR studies)) | 156405
#17 | #13 AND #16 | 564

PsycInfo, all searches done 6/22/2020

KQ 2 Search for Diagnostic Accuracy, 6/22/2020

Results: 3,168; 2,109 imported

# | Query | Limiters/Expanders | Results
S1 | DE “Anorexia Nervosa” OR “Avoidant Restrictive Food Intake Disorder” OR DE “Binge Eating” OR DE “Binge Eating Disorder” OR DE “Bulimia” OR DE “Feeding Disorders” OR anorexi* OR “avoidant restrictive food intake disorder” OR ARFID OR “binge-eating” OR “binge eating” OR bulimia OR bulimic OR (eating AND disorder*) OR (feed* AND disorder*) OR (food* AND neophobia*) OR “night eating” OR “purging disorder” OR EDNOS OR OSFED | Search modes - Boolean/Phrase | 73,015
S2 | DE “Surveys” OR DE “Consumer Surveys” OR DE “Mail Surveys” OR DE “Online Surveys” OR DE “Questionnaires” OR DE “Telephone Surveys” OR DE “Psychiatric Evaluation” OR DE “Screening Tests” OR DE “Psychological Screening Inventory” OR questionnaire OR questionnaires OR identifying OR identification OR instrument OR instruments OR inventory OR inventories OR measure OR measures OR scale OR scales OR screen OR screening | Search modes - Boolean/Phrase | 1,526,313
S3 | S1 AND S2 | Search modes - Boolean/Phrase | 33,494
S4 | “Adolescent Binge Eating Scale” OR “Eating Attitudes Test” OR “EAT-26” OR “Eating Disorder Inventory” OR “Eating Disorder Screen for Primary Care” OR “EDS-PC” OR “Primary Care Evaluation of Mental Disorders Patient Health Questionnaire” OR SCOFF OR “Sick, Control, One, Fat and Food” OR “Dutch Eating Behavior Questionnaire” OR DEBQ OR “Eating Disorder Examination” OR “Minnesota Eating Behavior Survey” OR “Patient Health Questionnaire” OR PHQ OR PRIMEMD OR “Screening for Disordered Eating” | Search modes - Boolean/Phrase | 11,646
S5 | S1 AND S4 | Search modes - Boolean/Phrase | 6,909
S6 | S3 OR S5 | Search modes - Boolean/Phrase | 33,783
S7 | S6 | Limiters - English; Boolean/Phrase | 32,049
S8 | S7 | Limiters - Age Groups: School Age (6-12 yrs), Adolescence (13-17 yrs), Adulthood (18 yrs & older); Search modes - Boolean/Phrase | 26,131
S9 | (S7 AND (adolescent OR adolescents OR adult OR adults OR elderly OR teen OR teens OR teenage OR teenaged)) OR (S7 NOT (newborn OR newborns OR infant OR infants)) | Search modes - Boolean/Phrase | 30,274
S10 | S8 OR S9 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 31,728
S11 | PZ Abstract Collection OR PZ Bibliography OR PZ Column/Opinion OR PZ Comment/Reply OR PZ Editorial OR PZ Encyclopedia Entry OR PZ Letter OR PZ Obituary OR PZ Poetry OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 465,772
S12 | S10 NOT S11 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 30,783
S13 | S12 NOT (PO Animal NOT PO Human) | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 30,705
S14 | “predictive value” OR sensitivity OR specificity OR accuracy OR ROC OR reproducib* OR “false positive” OR “false negative” OR “likelihood ratio” | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 271,247
S15 | S13 AND S14 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 3,168

### PsycInfo, Screening, 6/22/2020

RCTs = 1,519; 1,122 imported

Observational Studies = 2,304; 1,551 imported

# | Query | Limiters/Expanders | Results
S1 | DE “Anorexia Nervosa” OR “Avoidant Restrictive Food Intake Disorder” OR DE “Binge Eating” OR DE “Binge Eating Disorder” OR DE “Bulimia” OR DE “Feeding Disorders” OR anorexi* OR “avoidant restrictive food intake disorder” OR ARFID OR “binge-eating” OR “binge eating” OR bulimia OR bulimic OR (eating AND disorder*) OR (feed* AND disorder*) OR (food* AND neophobia*) OR “night eating” OR “purging disorder” OR EDNOS OR OSFED | Search modes - Boolean/Phrase | 73,015
S2 | DE “Surveys” OR DE “Consumer Surveys” OR DE “Mail Surveys” OR DE “Online Surveys” OR DE “Questionnaires” OR DE “Telephone Surveys” OR DE “Psychiatric Evaluation” OR DE “Screening Tests” OR DE “Psychological Screening Inventory” OR questionnaire OR questionnaires OR identifying OR identification OR instrument OR instruments OR inventory OR inventories OR measure OR measures OR scale OR scales OR screen OR screening | Search modes - Boolean/Phrase | 1,526,313
S3 | S1 AND S2 | Search modes - Boolean/Phrase | 33,494
S4 | “Adolescent Binge Eating Scale” OR “Eating Attitudes Test” OR “EAT-26” OR “Eating Disorder Inventory” OR “Eating Disorder Screen for Primary Care” OR “EDS-PC” OR “Primary Care Evaluation of Mental Disorders Patient Health Questionnaire” OR SCOFF OR “Sick, Control, One, Fat and Food” OR “Dutch Eating Behavior Questionnaire” OR DEBQ OR “Eating Disorder Examination” OR “Minnesota Eating Behavior Survey” OR “Patient Health Questionnaire” OR PHQ OR PRIMEMD OR “Screening for Disordered Eating” | Search modes - Boolean/Phrase | 11,646
S5 | S1 AND S4 | Search modes - Boolean/Phrase | 6,909
S6 | S3 OR S5 | Search modes - Boolean/Phrase | 33,783
S7 | S6 | Limiters - English; Boolean/Phrase | 32,049
S8 | S7 | Limiters - Age Groups: School Age (6-12 yrs), Adolescence (13-17 yrs), Adulthood (18 yrs & older); Search modes - Boolean/Phrase | 26,131
S9 | (S7 AND (adolescent OR adolescents OR adult OR adults OR elderly OR teen OR teens OR teenage OR teenaged)) OR (S7 NOT (newborn OR newborns OR infant OR infants)) | Search modes - Boolean/Phrase | 31,460
S10 | S8 OR S9 | Search modes - Boolean/Phrase | 31,728
S11 | PZ Abstract Collection OR PZ Bibliography OR PZ Column/Opinion OR PZ Comment/Reply OR PZ Editorial OR PZ Encyclopedia Entry OR PZ Letter OR PZ Obituary OR PZ Poetry OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae | Search modes - Boolean/Phrase | 465,772
S12 | S10 NOT S11 | Search modes - Boolean/Phrase | 31,310
S13 | S12 NOT (PO Animal NOT PO Human) | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 30,705
S14 | DE “Randomized Controlled Trials” OR “Single-Blind” OR “Double-Blind” OR “Random Allocation” OR ((randomized OR randomised) AND controlled AND trial) | Search modes - Boolean/Phrase | 78,358
S15 | S13 AND S14 | Search modes - Boolean/Phrase | 1,519
S16 | DE “Observation Methods” OR DE “Direct Observation” OR DE “Prospective Studies” OR DE “Cohort Analysis” OR “observational study” OR “observational studies” OR prospective* OR cohort* | Search modes - Boolean/Phrase | 162,174
S17 | S13 AND S16 | Search modes - Boolean/Phrase | 2,402
S18 | S17 NOT S15 | Search modes - Boolean/Phrase | 2,304

### PsycInfo, Interventions, 6/22/2020

Line S17 - RCTs = 1,834; 470 imported

Line S20 - Observational Studies = 1,508; 398 imported

# | Query | Limiters/Expanders | Results
S1 | DE “Anorexia Nervosa” OR “Avoidant Restrictive Food Intake Disorder” OR DE “Binge Eating” OR DE “Binge Eating Disorder” OR DE “Bulimia” OR DE “Feeding Disorders” OR anorexi* OR “avoidant restrictive food intake disorder” OR ARFID OR “binge-eating” OR “binge eating” OR bulimia OR bulimic OR (eating AND disorder*) OR (feed* AND disorder*) OR (food* AND neophobia*) OR “night eating” OR “purging disorder” OR EDNOS OR OSFED | Search modes - Boolean/Phrase | 73,015
S2 | DE “Cognitive Behavior Therapy” OR DE “Cognitive Restructuring” OR DE “Dialectical Behavior Therapy” OR DE “Emotion Focused Therapy” OR DE “Family Therapy” OR DE “Group Psychotherapy” OR DE “Encounter Group Therapy” OR DE “Therapeutic Community” OR DE “Meditation” OR DE “Mindfulness” OR DE “Mindfulness-Based Interventions” OR DE “Online Therapy” OR DE “Physical Therapy” OR DE “Psychotherapeutic Counseling” OR DE “Psychotherapy” OR CBT OR “cognitive behavior therapy” OR “cognitive behavioral therapy” OR “cognitive analytic therapy” OR “cognitive orientation therapy” OR “Dialectical Behavior Therapy” OR “distance counseling” OR “e-therapy” OR (emotion* AND therap*) OR “exposure and response prevention therapy” OR “Family Therapy” OR “group therapy” OR “internet-based intervention*” OR meditation OR “Maudsley Method” OR mindfulness OR (nutrition* AND counsel*) OR “physical therapy” OR psychotherap* | Search modes - Boolean/Phrase | 392,450
S3 | S1 AND S2 | Search modes - Boolean/Phrase | 12,948
S4 | DE “Drug Therapy” OR DE “Early Intervention” OR DE “Intervention” OR DE “Prescribing (Drugs)” OR “drug therapy” OR therapeutics OR therapy OR treatment* OR intervention* OR pharmacotherap* | Search modes - Boolean/Phrase | 1,383,885
S5 | S1 AND S4 | Search modes - Boolean/Phrase | 38,158
S6 | DE “Antidepressant Drugs” OR ((DE “Neuroleptic Drugs” OR DE “Aripiprazole” OR DE “Clozapine” OR DE “Molindone” OR DE “Nialamide” OR DE “Olanzapine” OR DE “Quetiapine” OR DE “Reserpine” OR DE “Risperidone” OR DE “Spiroperidol” OR DE “Sulpiride” OR DE “Tetrabenazine”) AND atypical) OR “atypical antipsychotic*” OR lisdexamfetamine OR topiramate | Search modes - Boolean/Phrase | 29,682
S7 | S1 AND S6 | Search modes - Boolean/Phrase | 693
S8 | S1S3 OR S5 OR S7 | Search modes - Boolean/Phrase | 38,215
S9 | S8 | Limiters - English; Search modes - Boolean/Phrase | 35,903
S10 | S9 | Limiters - Age Groups: School Age (6-12 yrs), Adolescence (13-17 yrs), Adulthood (18 yrs & older); Search modes - Boolean/Phrase | 20,945
S11 | (S9 AND (adolescent OR adolescents OR adult OR adults OR elderly OR teen OR teens OR teenage OR teenaged)) OR (S9 NOT (newborn OR newborns OR infant OR infants)) | Search modes - Boolean/Phrase | 35,161
S12 | S10 OR S11 | Search modes - Boolean/Phrase | 35,403
S13 | PZ Abstract Collection OR PZ Bibliography OR PZ Column/Opinion OR AB “case control” OR TI “case control” OR DE “Case Report” OR AB “case series” OR TI “case series” OR PZ Comment/Reply OR PZ Editorial OR PZ Encyclopedia Entry OR PZ Letter OR MR NONCLINICAL CASE STUDY OR PZ Obituary OR PZ Poetry OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae | Search modes - Boolean/Phrase | 535,313
S14 | S12 NOT S13 | Search modes - Boolean/Phrase | 31,624
S15 | S14 NOT (PO Animal NOT PO Human) | Search modes - Boolean/Phrase | 31,467
S16 | DE “Randomized Controlled Trials” OR “Single-Blind Method” OR “Double-Blind Method” OR “Random Allocation” OR ((randomized OR randomised) AND controlled AND trial) | Search modes - Boolean/Phrase | 70,104
S17 | S15 AND S16 | Search modes - Boolean/Phrase | 1,834
S18 | DE “Observation Methods” OR DE “Direct Observation” OR DE “Prospective Studies” OR DE “Cohort Analysis” OR “observational study” OR “observational studies” OR prospective* OR cohort* | Search modes - Boolean/Phrase | 162,174
S19 | S15 AND S18 | Search modes - Boolean/Phrase | 1,621
S20 | S19 NOT S17 | Search modes - Boolean/Phrase | 1,508

### Gray Literature Searches, 6/23/2020

ClinicalTrials.gov Searches, 6/23/2020

Screening and KQ 2 Diagnostic Accuracy Search, 6/23/2020

214 results; 214 imported to EndNote

Condition box:

“Avoidant Restrictive Food Intake Disorder” OR Bulimia OR anorexi* OR ARFID OR “binge eating” OR “binge-eating” OR bulimia OR bulimic OR (eating AND disorder*) OR (feed* AND disorder*) OR (food* AND neophobia*) OR “night eating” OR “purging disorder” OR EDNOS OR OSFED

Other box:

(identifying OR identification OR instrument OR instruments OR measure OR measures OR questionnaire OR questionnaires OR inventory OR inventories OR scale OR scales OR screen OR screening OR survey OR surveys OR “Eating Attitudes Test” OR “EAT-26” OR “EDS-PC” OR “Primary Care Evaluation of Mental Disorders Patient Health Questionnaire” OR SCOFF OR “Sick, Control, One, Fat and Food” OR “Dutch Eating Behavior Questionnaire” OR DEBQ OR “Minnesota Eating Behavior Survey” OR PHQ OR PRIMEMD)

214 Studies found for: (identifying OR identification OR instrument OR instruments OR measure OR measures OR questionnaire OR questionnaires OR inventory OR inventories OR scale OR scales OR screen OR screening OR survey OR surveys OR EXPAND[Concept] “Eating Attitudes Test” OR EXPAND[Concept] “EAT-26” OR EXPAND[Concept] “EDS-PC” OR EXPAND[Concept] “Primary Care Evaluation of Mental Disorders Patient Health Questionnaire” OR SCOFF OR EXPAND[Concept] “Sick, Control, One, Fat and Food” OR EXPAND[Concept] “Dutch Eating Behavior Questionnaire” OR DEBQ OR EXPAND[Concept] “Minnesota Eating Behavior Survey” OR PHQ OR PRIMEMD) | EXPAND[Concept] “Avoidant Restrictive Food Intake Disorder” OR Bulimia OR anorexi* OR ARFID OR “binge eating” OR EXPAND[Concept] “binge-eating” OR bulimia OR bulimic OR eating AND disorder* OR feed* AND disorder* OR food* AND neophobia* OR EXPAND[Concept] “night eating” OR EXPAND[Concept] “purging disorder” OR EDNOS OR OSFED

Treatment (Interventions) Search, 6/23/2020

110 results; 30 imported to EndNote

Conditions box:

(“Avoidant Restrictive Food Intake Disorder” OR Bulimia OR anorexi* OR ARFID OR “binge eating” OR “binge-eating” OR bulimia OR bulimic OR (eating AND disorder*) OR (feed* AND disorder*) OR (food* AND neophobia*) OR “night eating” OR “purging disorder” OR EDNOS OR OSFED)

Interventions box:

(“Distance Counseling” OR CBT OR “cognitive behavior therapy” OR “cognitive behavioral therapy” OR “cognitive analytic therapy” OR “cognitive orientation therapy” OR “Dialectical Behavior Therapy” OR “e-therapy” OR (emotion* AND therap*) OR “exposure and response prevention therapy” OR “Family Therapy” OR “group therapy” OR “internet-based intervention*” OR meditation OR “Maudsley Method” OR mindfulness OR (nutrition* AND counsel*) OR “physical therapy” OR psychotherap* OR “Therapeutics” OR “therapy” OR treatment* OR intervention* OR pharmacotherap*)

110 Studies found for: EXPAND[Concept] “Avoidant Restrictive Food Intake Disorder” OR Bulimia OR anorexi* OR ARFID OR “binge eating” OR EXPAND[Concept] “binge-eating” OR bulimia OR bulimic OR eating AND disorder* OR feed* AND disorder* OR food* AND neophobia* OR EXPAND[Concept] “night eating” OR EXPAND[Concept] “purging disorder” OR EDNOS OR OSFED | “Distance Counseling” OR CBT OR “cognitive behavior therapy” OR “cognitive behavioral therapy” OR “cognitive analytic therapy” OR “cognitive orientation therapy” OR “Dialectical Behavior Therapy” OR “e-therapy” OR emotion* AND therap* OR “exposure and response prevention therapy” OR “Family Therapy” OR “group therapy” OR “internet-based intervention*” OR meditation OR “Maudsley Method” OR mindfulness OR nutrition* AND counsel* OR “physical therapy” OR psychotherap* OR “Therapeutics” OR “therapy” OR treatment* OR intervention* OR pharmacotherap*

Treatment (Interventions)

Condition box:

(“Avoidant Restrictive Food Intake Disorder” OR Bulimia OR anorexi* OR ARFID OR “binge eating” OR “binge-eating” OR bulimia OR bulimic OR (eating AND disorder*) OR (feed* AND disorder*) OR (food* AND neophobia*) OR “night eating” OR “purging disorder” OR EDNOS OR OSFED)

Intervention box:

(“Distance Counseling” OR CBT OR “cognitive behavior therapy” OR “cognitive behavioral therapy” OR “cognitive analytic therapy” OR “cognitive orientation therapy” OR “Dialectical Behavior Therapy” OR “e-therapy” OR (emotion* AND therap*) OR “exposure and response prevention therapy” OR “Family Therapy” OR “group therapy” OR “internet-based intervention*” OR meditation OR “Maudsley Method” OR mindfulness OR (nutrition* AND counsel*) OR “physical therapy” OR psychotherap* OR “Therapeutics” OR “therapy” OR treatment* OR intervention* OR pharmacotherap*)

## Appendix B2 Eligibility Criteria

| Include | Exclude
Condition definition | All KQs: Anorexia nervosa, bulimia nervosa, binge eating disorder, other specified feeding and eating disorder, and avoidant restrictive food intake disorder, based on DSM-5 criteria or other valid diagnostic criteria (e.g., DSM-IV); KQs 4, 5: Studies enrolling populations with subthreshold conditions (e.g., meeting most but not all diagnostic criteria for the disorders above, as defined by study authors) are also eligible | Other DSM-5 categories of eating disorders (e.g., pica, rumination disorder) or potentially unhealthy eating behaviors or syndromes not recognized by DSM-5 (e.g., orthorexia)
Populations | KQs 1–3: Unselected or explicitly asymptomatic adolescents and adults (age ≥10 years) without signs or symptoms of an eating disorder, including populations selected for increased risk of an eating disorder (e.g., based on age, sex, race/ethnicity, gender identity, or mental health comorbidity) and populations selected based on high BMI; KQs 2, 4, 5: Studies enrolling adolescents and adults (age ≥10 years) who screen positive for eating disorders in a primary care setting or are identified through other population-based screening; studies enrolling populations from specialty settings who have not been previously treated for eating disorders are also eligible | Studies limited to participants undergoing evaluation for bariatric surgery; studies limited to individuals who are underweight (BMI <18.5 kg/m^2^ for adults or BMI <5th percentile on growth charts for age and sex for adolescents) or with other physical signs or symptoms of an eating disorder
Screening | KQs 1–3: Screening questionnaires designed to detect eating disorders or risk of eating disorders that are feasible for use for screening in primary care (i.e., brief, easy to interpret) | KQs 1–3: Serologic screening (e.g., using leptin or other biomarkers)
Interventions | KQs 4, 5: Individual, group, or family therapy (cognitive behavioral therapy or other forms of psychotherapy); pharmacotherapy with FDA-approved medications | KQs 4, 5: Public awareness campaigns without specific interventions linked to screening, complementary and alternative therapies, or those considered to be adjunctive therapy (e.g., acupuncture, herbal supplements, massage, light therapy)
Comparisons | KQs 1, 3: Screened vs. nonscreened groups; KQ 2: Comparison with acceptable reference standard (structured or semistructured diagnostic interview or a nonbrief [>5 minutes] unstructured interview with mental health clinician); KQs 4, 5: No treatment, attention control, wait-list control, or minimal intervention (e.g., brief education about eating disorders); placebo-controlled studies of pharmacotherapy | KQs 4, 5: Head-to-head comparisons of two active interventions
Outcomes | KQs 1, 4: Eating disorder remission or symptom reduction, general health-related quality of life or function, eating disorder–related quality of life or function, depression, anxiety, suicide, and mortality; KQ 2: Sensitivity, specificity, positive and negative predictive values, positive and negative likelihood ratios, and diagnostic odds ratios; KQ 3: Anxiety, labeling, stigma, psychosocial harms, and false-positive results; KQ 5: Any harms that result as an effect of interventions such as increased depression, increased anxiety, worsening of the eating disorder, or adverse effects from medications | KQs 1, 4: Screening or referral rates, attitudes about screening; intermediate outcomes (e.g., weight change, frequency of menses, frequency of specific behaviors [e.g., change in frequency of binge eating episodes]); KQ 2: Theory or survey development and validation without correlation to eating disorder outcomes, studies that focus only on particular risk factors, or assessment of provider or participant attitudes toward the instrument
Study designs | All KQs: RCTs; KQ 2: Cross-sectional and cohort studies of screening test accuracy are also eligible; KQs 3, 5: Cohort studies with a concurrent control group are also eligible | All other study designs, including case-series and case-control studies, systematic reviews, and others
Clinical setting | All KQs: Primary care clinics or other settings applicable to primary care, including school-based health centers and other community settings; KQs 2, 4, 5: Settings referable from primary care are also eligible | Settings or institutions not applicable to primary care (e.g., school classrooms, bariatric surgery centers) or inpatient/residential settings
Country setting | Research conducted in the United States or in populations similar to U.S. populations with services and interventions applicable to U.S. practice (countries categorized as “very high” on the Human Development Index [as defined by the United Nations Development Programme]) | Research not relevant to the United States in countries categorized as less than “very high” on the Human Development Index
Language | Full text published in English | Non-English
Quality | Studies rated good or fair quality | Studies rated poor quality

[underlined: “Very high” on Human Development Index]: Andorra, Argentina, Australia, Austria, Bahamas, Bahrain, Barbados, Belarus, Belgium, Brunei Darussalam, Bulgaria, Canada, Chile, Croatia, Cyprus, Czechia, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong China (SAR), Hungary, Iceland, Ireland, Israel, Italy, Japan, Kazakhstan, Korea (Republic of), Kuwait, Latvia, Liechtenstein, Lithuania, Luxembourg, Malaysia, Malta, Montenegro, Netherlands, New Zealand, Norway, Oman, Poland, Portugal, Qatar, Romania, Russian Federation, Saudi Arabia, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States, Uruguay.

Abbreviations: BMI=body mass index; DSM-5=Diagnostic and Statistical Manual of Mental Disorders (5th edition); DSM-IV=Diagnostic and Statistical Manual of Mental Disorders (4th edition); FDA=U.S. Food and Drug Administration; KQ=key question; RCT=randomized, controlled trial.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements that are equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

Definition of Ratings Based on Above Criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.
Poor: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015 ^17^

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of Ratings Based on Above Criteria:

Good:: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (greater than 100) of broad-spectrum patients with and without disease.
Fair:: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
Poor:: Has a fatal flaw, such as: uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015 ^17^