# Appendix A Additional Background

## Detailed Summary of Diagnostic Criteria

Table 1 summarizes key diagnostic criteria of eating disorders likely to be undetected and thus relevant to screening in primary care based on the 5th edition of the Diagnostic and Statistical Manual of Mental Disorders (DSM-5).^1^ Two diagnoses in this diagnostic category of feeding and eating disorders (pica and rumination disorder) are not included below because their symptomatology is often readily identifiable and unlikely to benefit from early detection through routine screening.

Appendix A Table 1 Summary of DSM-5 Diagnostic Criteria for Eating Disorders

Diagnosis | Key Diagnostic Criteria
AN subtypes:; Restricting type; Binge-eating/purging type | - Restriction of energy intake relative to requirements, leading to a significantly low body weight in the context of age, sex, developmental trajectory, and physical health.; - Intense fear of gaining weight or of becoming fat, or persistent behavior that interferes with weight gain, even though at a significantly low weight.; - Disturbance in the way in which one’s body weight or shape is experienced, undue influence of body weight or shape on self-evaluation, or persistent lack of recognition of the seriousness of the current low body weight.
BN | - Recurrent episodes of binge eating that are characterized by both of the following:; ○ Eating, in a discrete period of time (e.g., within any 2-hour period), an amount of food that is definitely larger than what most individuals would eat in a similar period of time under similar circumstances; ○ A sense of lack of control overeating during the episode (e.g., a feeling that one cannot stop eating or control what or how much one is eating); - Recurrent inappropriate compensatory behaviors to prevent weight gain (e.g., self-induced vomiting; misuse of laxative, diuretics, or other medications; fasting; or excessive exercise); - Self-evaluation is unduly influenced by body shape and weight
BED | - Recurrent episodes of binge eating (as defined above); - Binge eating is associated with:; ○ Eating more rapidly than usual; ○ Eating until feeling uncomfortably full; ○ Eating large amounts of food when not feeling physically hungry; ○ Eating alone because of feeling embarrassed by how much one is eating; ○ Feeling disgusted with oneself, depressed, or very guilty afterward; - Marked distress about the binge-eating episodes
Other specified feeding and eating disorder | - An eating or feeding disturbance that causes clinically significant distress or impairment but does not meet the full criteria for any of the disorders in this diagnostic class. This might include (but is not limited to):; ○ Atypical AN; ○ BN or BED of low frequency or limited duration; ○ Purging disorder; ○ Night eating syndrome
Avoidant/restrictive food intake disorder | - An eating or feeding disturbance (e.g., apparent lack of interest in eating or food, avoidance based on sensory characteristics of food, concern about aversive consequences of eating) associated with one or more of the following:; ○ Significant weight loss or failure to achieve expected weight gain or faltering growth in children; ○ Significant nutritional deficiency; ○ Dependent on enteral feeding or oral nutritional supplements; ○ Marked interference with psychosocial functioning

Abbreviations: AN=anorexia nervosa; BED=binge-eating disorder; BN=bulimia nervosa; DSM-5=Diagnostic and Statistical Manual of Mental Disorders (5th edition).

## Detailed Summary of Eating Disorders’ Prevalence

Details of study cohorts and results of nationally representative surveys of eating disorders’ prevalence in the United States are summarized in Table 2.

Appendix A Table 2 Lifetime Prevalence Estimates of Eating Disorders in the United States

Study Cohort | Cohort Description | DSM | Study Population | Lifetime Prevalence % (SE) | Information on Survey Questions
National Comorbidity Replication Survey (NCS-R)^2^; (n=2,980) | Survey of the U.S. household population (2001 and 2003) based on a multistage clustered-area probability design. English-speaking adults ages 18 years or older. Subsample assessed for eating disorders. | DSM-IV | In the weighted sample^3^; Ages 18-34 years: 31.5%; Ages 35-49 years: 30.9%; Female: 5.30%; White: 72.3%; Black: 12.4%; Hispanic: 11.1% | Women; AN: 0.9% (0.3); BN: 1.5% (0.3); BED: 3.5% (0.5); Men; AN: 0.3% (0.1); BN: 0.5% (0.3); BED: 2.0% (0.5) | NCS-R diagnoses were based on Version 3.0 of the WHO Composite International Diagnostic Interview (CIDI), a structured lay-administered diagnostic interview that generates diagnoses according to both ICD-10 and DSM-IV criteria.^4,^*
National Comorbidity Survey Replication Adolescent Supplement (NCS-A)^5^; (n=10,123) | Nationally representative survey (2001 and 2004) of U.S. adolescents ages 13 to 17 years, extension of NCS-R.^6^ | DSM-IV | In the weighted sample^3^; Age 13: 20.7%; Age 17: 18.8%; Female: 48.8%; White: 65.5%; Black: 15.1%; Hispanic: 14.4% | Women; AN: 0.3% (0.1); BN: 1.3% (0.3); BED: 2.3% (0.4); Men; AN: 0.3% (0.1); BN: 0.5% (0.2); BED: 1.3% (0.4) | Although the version of the CIDI used in the NCS-A is very similar to the NCS-R version, a number of important modifications were made for the NCS-A to make sure the instrument was relevant to the special experiences and language of youth.^†^
Collaborative Psychiatric Epidemiology Surveys^7^; (n=12,337) | Comprising three nationally representative U.S. surveys: NCS-R, National Survey of American Life (NSAL), and National Latino and Asian American Study (NLAAS); NSC-R described above; NSAL is a survey of U.S. adults (2001 and 2003) self-identifying as African American or of Caribbean descent; NLAAS is a nationally representative survey (2001 and 2003) of Latinos and Asian Americans. | DSM-IV | In the weighted sample; Ages 18-24: 14-16%; Ages 25-34: 19%; Ages 35-44: 20-22%; Ages 45-54: 19-20%; Female: 58.7%; White: 58-59%; Black: 16-18%; Hispanic: 16-20% | Women; AN: 0.69%; BN: 1.68%; BED: 2.97%; Men; AN: 0.19%; BN: 0.55%; BED: 1.59% | All three of these surveys used similar versions of the WHO CIDI.
National Epidemiologic Survey on Alcohol and Related Conditions (NESARC-III)^8^; (n=36,309) | Nationally representative survey of non-institutionalized U.S. civilians, age 18 years or older, based on multistage, probabilistic sampling (2012 and 2013). | DSM-V | In the weighted sample^9^; Ages 18-24: 13.0%; Ages 25-34: 17.4%; Ages 35-44: 17.1%; Ages 45-54: 18.5%; Female: 51.9%; White: 66.2%; Black: 11.6%; Hispanic: 14.7% | Women; AN: 1.42% (0.12); BN: 0.46% (0.06); BED: 1.25% (0.10); Men; AN: 0.12% (0.04); BN: 0.08% (0.03); BED: 0.42% (0.06) | NESARC-III used the National Institute on Alcohol Abuse and Alcoholism Alcohol Use Disorder and Associated Disabilities Interview Schedule-5 (AUDADIS-5) (14) to assess DSM-5–defined psychiatric disorders and their criteria, including AN, BN, and BED.^†^

* Most of the CIDI questions closely paralleled DSM-IV criteria; the exception was BED, where DSM-IV required at least 6 months of regular eating binges compared with CIDI (3 months of symptoms).

† For an AN diagnosis, respondents were required to meet the following criteria: 1) had a self-reported lowest BMI of 18.5; 2) tried not to gain weight or restricted food intake despite low weight; 3) were afraid of gaining weight or “getting fat” despite low weight; and 4) reported at least one of the following while their BMI was lowest: a) thought they “looked fat,” b) thought their weight or shape was one of the most important things about them, c) did not think they might have been unhealthy, d) did not believe others who thought their weight was unhealthy, or e) were constantly weighing themselves or measuring body parts. For BN and BED diagnoses, respondents were required to report recurrent binge eating, which was defined by three criteria: 1) had ever eaten an unusually large amount of food within a 2-hour period, not including during the holidays; 2) had ever eaten unusually large amounts of food, on average, at least once weekly for at least 3 months; and 3) while eating an unusually large amount of food, had felt unable to stop eating or control how much or what they were eating. For a BN diagnosis, in addition to meeting criteria for recurrent binge eating, respondents were required to report whether during any of those times that they were binge eating they 1) tried to keep from gaining weight by vomiting; using enemas, laxatives, diuretics, or other medicines; fasting; or exercising excessively; 2) engaged in the weight compensatory behaviors at least once weekly for at least 3 months; or 3) thought their weight or shape was one of the most important things about them. For a BED diagnosis, in addition to meeting criteria for recurrent binge eating, respondents were required to report 1) eating an unusually large amount of food that made them very upset and 2) at least three of the following five features during the times they ate unusually large amounts of food: a) eating much more quickly than usual; b) eating until uncomfortably full; c) eating despite not being hungry; d) eating alone because they were embarrassed by how much they were eating; or e) feeling disgusted, depressed, or very guilty about the overeating.

Abbreviations: AN=anorexia nervosa; AUDADIS-5=Associated Disabilities Interview Schedule-5; BED=binge-eating disorder; BMI=body mass index; BN=bulimia nervosa; CIDI=Composite International Diagnostic Interview; DSM-IV=Statistical Manual of Mental Disorders, Version 4; ICD-10=International Classification of Diseases, 10th Revision; NCS-A=National Comorbidity Survey Replication Adolescent Supplement; NCS-R=National Comorbidity Replication Survey; NESARC-III=National Epidemiologic Survey on Alcohol and Related Conditions; NLAAS=National Latino and Asian American Study; NSAL=National Survey of American Life; SE=standard error; U.S.=United States; WHO=World Health Organization.

## Detailed Summary of Recommendations From Organizations

Table 3 summarizes recommendations from other organizations relevant to screening for eating disorders in clinical settings.

Appendix A Table 3 Current Recommendations From Other Organizations

Organization, Year | Screening Recommendation
AAP, 2020^10^ | Pediatricians should screen for eating disorders by monitoring and assessing risk factors and symptoms at annual and sports physicals. Pediatricians should monitor and identify changes in height, weight, BMI, and vital signs longitudinally. If findings indicate that an eating disorder may be present, the pediatrician should conduct thorough medical and psychological assessments to identify if an eating disorder diagnosis is appropriate. After diagnosis, the pediatrician may continue to monitor the patient, help set weight goals, refer the patient to eating disorder specialists ideally with expertise among this age group, and continue to care for the patient as part of a multidisciplinary team.
ACOG, 2018^11^ | ACOG recommends that practitioners be able to identify signs of disordered eating and screen at risk patients, especially considering the presence of many gynecological symptoms, including irregular menstrual cycles, amenorrhea, pelvic pain, atrophic vaginitis, and breast atrophy.
APA, 2012^12^ | The APA recommends that practitioners working with young athletes pay special attention to disordered eating. Assessment of weight, body image, amenorrhea, and nutrition can help screen and identify athletes suffering from or at risk for eating disorders.
NICE, 2017^13^ | Patients who present symptoms of eating disorders should be assessed and treated as soon as possible. Guidelines highlight that reliance on screening tools alone, such as SCOFF, is not sufficient for diagnosis.
AED, 2016^14^ | All high-risk patients should be monitored for symptoms of eating disorders, which may present in patients of any age, race, gender, or size. Screening with validated tools, such as SCOFF, can help identify patients who may need treatment or referral to specialty care.
SAHM, 2015^15^ | Guidelines state that medical providers should be able to recognize and diagnose eating disorders in adolescents and young adults and highlight the importance of medical providers in monitoring for medical complications in the context of multidisciplinary care for those with eating disorders.
AACAP, 2015^16^ | AACAP recommends mental health practitioners screen all preteen and adolescent patients for eating disorders through height and weight assessments and screener questions about eating patterns and body image. Concern about these results should lead to referral for further evaluation. For older patients, the following screening instruments are recommended: The Eating Disorder Examination Questionnaire, Eating Disorder Inventory, and Eating Attitudes Test. For younger children, the following screening instruments are recommended: The Kids’ Eating Disorder Survey, the Children’s Eating Disorder Questionnaire, the Child-Eating Attitudes Test, and the Eating Disorder Inventory for Children.

Abbreviations: AACAP=American Academy of Child and Adolescent Psychiatry; AAP=American Academy of Pediatrics; ACOG=American Congress of Obstetricians and Gynecologists; AED=Academy for Eating Disorders; APA=American Psychological Association; EDI=Eating Disorder Inventory; EDI-C=Eating Disorder Inventory-Children; NICE=National Institute for Health and Care Excellence; SAHM=Society for Adolescent Health and Medicine.