# References

1 Virani, S.S., A. Alonso, H.J. Aparicio, E.J. Benjamin, M.S. Bittencourt, ., Heart Disease and Stroke Statistics-2021 Update: A Report From the American Heart Association. Circulation, 2021. 143(8): p. e254–e743.33501848
2 Siegel, R.L., K.D. Miller, and A. Jemal, Cancer statistics, 2015. CA Cancer J Clin, 2015. 65(1): p. 5–29.25559415
3 Mariotto, A.B., K.R. Yabroff, Y. Shao, E.J. Feuer, and M.L. Brown, Projections of the cost of cancer care in the United States: 2010-2020. J Natl Cancer Inst, 2011. 103(2): p. 117–28.21228314
4 Yabroff, K.R., J. Lund, D. Kepka, and A. Mariotto, Economic burden of cancer in the United States: estimates, projections, and future research. Cancer Epidemiol Biomarkers Prev, 2011. 20(10): p. 2006–14.21980008
5 Bibbins-Domingo, K., Aspirin Use for the Primary Prevention of Cardiovascular Disease and Colorectal Cancer: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med, 2016. 164(12): p. 836–45.27064677
6 Guirguis-Blake, J.M., C.V. Evans, C.A. Senger, M.G. Rowland, E.A. O’Connor, ., in Aspirin for the Primary Prevention of Cardiovascular Events: A Systematic Evidence Review for the U.S. Preventive Services Task Force. 2015: Rockville (MD).
7 Guirguis-Blake, J.M., C.V. Evans, C.A. Senger, E.A. O’Connor, and E.P. Whitlock, Aspirin for the Primary Prevention of Cardiovascular Events: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Ann Intern Med, 2016. 164(12): p. 804–13.27064410
8 Chubak, J., A. Kamineni, D.S.M. Buist, M.L. Anderson, and E.P. Whitlock, in Aspirin Use for the Prevention of Colorectal Cancer: An Updated Systematic Evidence Review for the U.S. Preventive Services Task Force. 2015: Rockville (MD).
9 Chubak, J., E.P. Whitlock, S.B. Williams, A. Kamineni, B.U. Burda, ., Aspirin for the Prevention of Cancer Incidence and Mortality: Systematic Evidence Reviews for the U.S. Preventive Services Task Force. Ann Intern Med, 2016. 164(12): p. 814–25.27064482
10 Whitlock, E.P., S.B. Williams, B.U. Burda, A. Feightner, and T. Beil, in Aspirin Use in Adults: Cancer, All-Cause Mortality, and Harms: A Systematic Evidence Review for the U.S. Preventive Services Task Force. 2015: Rockville (MD).
11 Whitlock, E.P., B.U. Burda, S.B. Williams, J.M. Guirguis-Blake, and C.V. Evans, Bleeding Risks With Aspirin Use for Primary Prevention in Adults: A Systematic Review for the U.S. Preventive Services Task Force. Ann Intern Med, 2016. 164(12): p. 826–35.27064261
12 Dehmer, S.P., M.V. Maciosek, and T.J. Flottemesch, Aspirin Use to Prevent Cardiovascular Disease and Colorectal Cancer: A Decision Analysis. Evidence Synthesis No 131. AHRQ Publication No. 15-05229-EF-1. 2015: Rockville (MD); .
13 Dehmer, S.P., M.V. Maciosek, T.J. Flottemesch, A.B. LaFrance, and E.P. Whitlock, Aspirin for the Primary Prevention of Cardiovascular Disease and Colorectal Cancer: A Decision Analysis for the U.S. Preventive Services Task Force. Ann Intern Med, 2016. 164(12): p. 777–86.27064573
14 Ascend Study Collaborative Group, L. Bowman, M. Mafham, K. Wallendszus, W. Stevens, ., Effects of Aspirin for Primary Prevention in Persons with Diabetes Mellitus. N Engl J Med, 2018. 379(16): p. 1529–1539.30146931
15 Gaziano, J.M., C. Brotons, R. Coppolecchia, C. Cricelli, H. Darius, ., Use of aspirin to reduce risk of initial vascular events in patients at moderate risk of cardiovascular disease (ARRIVE): a randomised, double-blind, placebo-controlled trial. Lancet, 2018. 392(10152): p. 1036–1046.30158069
16 McNeil, J.J., R. Wolfe, R.L. Woods, A.M. Tonkin, G.A. Donnan, ., Effect of Aspirin on Cardiovascular Events and Bleeding in the Healthy Elderly. N Engl J Med, 2018. 379(16): p. 1509–1518.30221597
17 Guirguis-Blake, J.M., C.V. Evans, L.A. Perdue, S.I. Bean, and C.A. Senger, Aspirin Use to Prevent Cardiovascular Disease and Colorectal Cancer: An Evidence Update for the U.S. Preventive Services Task Force. Evidence Report. No. 211. AHRQ Publication No. 21-05283-EF-1. 2022, Agency for Healthcare Research and Quality: Rockville, MD.
18 Dehmer, S.P., M.V. Maciosek, A.B. LaFrance, and T.J. Flottemesch, Health Benefits and Cost-Effectiveness of Asymptomatic Screening for Hypertension and High Cholesterol and Aspirin Counseling for Primary Prevention. Ann Fam Med, 2017. 15(1): p. 23–36.28376458
19 Maciosek, M.V., A.B. LaFrance, S.P. Dehmer, D.A. McGree, T.J. Flottemesch, ., Updated Priorities Among Effective Clinical Preventive Services. Ann Fam Med, 2017. 15(1): p. 14–22.28376457
20 Dehmer, S.P., M.M. Baker-Goering, M.V. Maciosek, Y. Hong, T.E. Kottke, ., Modeled Health and Economic Impact of Team-Based Care for Hypertension. Am J Prev Med, 2016. 50(5 Suppl 1): p. S34–44.27102856
21 Overwyk, K.J., S.P. Dehmer, K. Roy, M.V. Maciosek, Y. Hong, ., Modeling the Health and Budgetary Impacts of a Team-based Hypertension Care Intervention That Includes Pharmacists. Med Care, 2019. 57(11): p. 882–889.31567863
22 Dehmer, S.P., M.E. Cogswell, M.D. Ritchey, Y. Hong, M.V. Maciosek, ., Health and Budgetary Impact of Achieving 10-Year U.S. Sodium Reduction Targets. Am J Prev Med, 2020. 59(2): p. 211–218.32532672
23 Margolis, K.L., S.P. Dehmer, J. Sperl-Hillen, P.J. O’Connor, S.E. Asche, ., Cardiovascular Events and Costs With Home Blood Pressure Telemonitoring and Pharmacist Management for Uncontrolled Hypertension. Hypertension, 2020. 76(4): p. 1097–1103.32862713
24 Maciosek, M.V., B.S. Armour, S.D. Babb, S.P. Dehmer, E.S. Grossman, ., Budgetary impact from multiple perspectives of sustained antitobacco national media campaigns to reduce the harms of cigarette smoking. Tob Control, 2020.
25 Maciosek, M.V., A.B. LaFrance, S.P. Dehmer, D.A. McGree, Z. Xu, ., Health Benefits and Cost-Effectiveness of Brief Clinician Tobacco Counseling for Youth and Adults. Ann Fam Med, 2017. 15(1): p. 37–47.28376459
26 Framingham Heart Study-Cohort. 2010, Biologic Specimen and Data Repository Information Coordinating Center, National Institutes of Health.
27 Framingham Heart Study-Offspring. 2010, Biologic Specimen and Data Repository Information Coordinating Center, National Institutes of Health.
28 Centers for Disease Control and Prevention, Behavioral Risk Factor Surveillance System Survey Data (2009). 2010, Atlanta, Georgia: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention.
29 National Center for Health Statistics, National Health Interview Survey, 2015-18. 2020: Hyattsville, Maryland: National Center for Health Statistics, Centers for Disease Control and Prevention.
30 Hughes, J.R., J.P. Keely, R.S. Niaura, D.J. Ossip-Klein, R.L. Richmond, ., Measures of abstinence in clinical trials: issues and recommendations. Nicotine Tob Res, 2003. 5(1): p. 13–25.12745503
31 Wetter, D.W., L. Cofta-Gunn, R.T. Fouladi, P.M. Cinciripini, D. Sui, ., Late relapse/sustained abstinence among former smokers: a longitudinal study. Prev Med, 2004. 39(6): p. 1156–63.15539050
32 Herd, N., R. Borland, and A. Hyland, Predictors of smoking relapse by duration of abstinence: findings from the International Tobacco Control (ITC) Four Country Survey. Addiction, 2009. 104(12): p. 2088–99.19922574
33 Gilpin, E.A., J.P. Pierce, and A.J. Farkas, Duration of smoking abstinence and success in quitting. J Natl Cancer Inst, 1997. 89(8): p. 572–6.9106646
34 U.S. Department of Health and Human Services, The Health Benefits of Smoking Cessation. Vol. DHHS Publication No. (CDC) 90-8416. 1990, Rockville, MD: U.S. Department of Health and Human Services Public Health Service Centers for Disease Control Center for Chronic Disease Prevention and Health Promotion Office on Smoking and Health.
35 Siu, A.L., Screening for High Blood Pressure in Adults: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med, 2015. 163(10): p. 778–86.26458123
36 U. S. Preventive Services Task Force, K. Bibbins-Domingo, D.C. Grossman, S.J. Curry, K.W. Davidson, ., Statin Use for the Primary Prevention of Cardiovascular Disease in Adults: US Preventive Services Task Force Recommendation Statement. JAMA, 2016. 316(19): p. 1997–2007.27838723
37 Whelton, P.K., R.M. Carey, W.S. Aronow, D.E. Casey, Jr., K.J. Collins, ., 2017 ACC/AHA/AAPA/ABC/ACPM/AGS/APhA/ASH/ASPC/NMA/PCNA Guideline for the Prevention, Detection, Evaluation, and Management of High Blood Pressure in Adults: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. J Am Coll Cardiol, 2018. 71(19): p. e127–e248.29146535
38 Grundy, S.M., N.J. Stone, A.L. Bailey, C. Beam, K.K. Birtcher, ., 2018 AHA/ACC/AACVPR/AAPA/ABC/ACPM/ADA/AGS/APhA/ASPC/NLA/PCNA Guideline on the Management of Blood Cholesterol. Circulation, 2019. 139(25): p. e1082–e1143.30586774
39 Arnett, D.K., R.S. Blumenthal, M.A. Albert, A.B. Buroker, Z.D. Goldberger, ., 2019 ACC/AHA Guideline on the Primary Prevention of Cardiovascular Disease: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. J Am Coll Cardiol, 2019. 74(10): p. e177–e232.30894318
40 Centers for Disease Control and Prevention, National Health and Nutrition Examination Survey Data (2015-2016). 2017, Hyattsville, MD: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention.
41 Centers for Disease Control and Prevention, National Health and Nutrition Examination Survey Data (2017-2018). 2019, Hyattsville, MD: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention.
42 Selak, V., A. Kerr, K. Poppe, B. Wu, M. Harwood, ., Annual Risk of Major Bleeding Among Persons Without Cardiovascular Disease Not Receiving Antiplatelet Therapy. JAMA, 2018. 319(24): p. 2507–2520.29946729
43 National Cancer Institute. SEER*Stat Software. 2020 [Accessed Nov 15, 2020]; Available from: https://seer.cancer.gov/seerstat/.
44 U.S. Department of Health and Human Services, The Health Consequences of Smoking—50 Years of Progress: A Report of the Surgeon General, 2014. 2014, U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health: Atlanta, GA.
45 Goff, D.C., Jr., D.M. Lloyd-Jones, G. Bennett, S. Coady, R.B. D’Agostino, Sr., ., 2013 ACC/AHA guideline on the assessment of cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol, 2014. 63(25 Pt B): p. 2935–59.24239921
46 United States Census Bureau. American Community Survey 2018 [Accessed July 13, 2020]; Available from: https://www.census.gov/programs-surveys/acs/news/data-releases.2018.html.
47 National Center for Health Statistics, National Health Interview Survey, 2017-18. 2020, Hyattsville, Maryland: National Center for Health Statistics, Centers for Disease Control and Prevention.
48 De Berardis, G., G. Lucisano, A. D’Ettorre, F. Pellegrini, V. Lepore, ., Association of aspirin use with major bleeding in patients with and without diabetes. JAMA, 2012. 307(21): p. 2286–94.22706834
49 Rockall, T.A., R.F. Logan, H.B. Devlin, and T.C. Northfield, Incidence of and mortality from acute upper gastrointestinal haemorrhage in the United Kingdom. Steering Committee and members of the National Audit of Acute Upper Gastrointestinal Haemorrhage. BMJ, 1995. 311(6999): p. 222–6.7627034
50 Chobanian, A.V., G.L. Bakris, H.R. Black, W.C. Cushman, L.A. Green, ., Seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. Hypertension, 2003. 42(6): p. 1206–52.14656957
51 Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation, 2002. 106(25): p. 3143–421.12485966
52 Fowkes, F.G., J.F. Price, M.C. Stewart, I. Butcher, G.C. Leng, ., Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. JAMA, 2010. 303(9): p. 841–8.20197530
53 Hansson, L., A. Zanchetti, S.G. Carruthers, B. Dahlof, D. Elmfeldt, ., Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet, 1998. 351(9118): p. 1755–62.9635947
54 Ogawa, H., M. Nakayama, T. Morimoto, S. Uemura, M. Kanauchi, ., Low-dose aspirin for primary prevention of atherosclerotic events in patients with type 2 diabetes: a randomized controlled trial. JAMA, 2008. 300(18): p. 2134–41.18997198
55 Belch, J., A. MacCuish, I. Campbell, S. Cobbe, R. Taylor, ., The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ, 2008. 337: p. a1840.18927173
56 de Gaetano, G., Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet, 2001. 357(9250): p. 89–95.11197445
57 Thrombosis prevention trial: randomised trial of low-intensity oral anticoagulation with warfarin and low-dose aspirin in the primary prevention of ischaemic heart disease in men at increased risk. The Medical Research Council’s General Practice Research Framework. Lancet, 1998. 351(9098): p. 233–41.9457092
58 Ridker, P.M., N.R. Cook, I.M. Lee, D. Gordon, J.M. Gaziano, ., A randomized trial of low-dose aspirin in the primary prevention of cardiovascular disease in women, in N Engl J Med. 2005. p. 1293–304.15753114
59 Ikeda, Y., K. Shimada, T. Teramoto, S. Uchiyama, T. Yamazaki, ., Low-dose aspirin for primary prevention of cardiovascular events in Japanese patients 60 years or older with atherosclerotic risk factors: a randomized clinical trial. JAMA, 2014. 312(23): p. 2510–20.25401325
60 Flossmann, E. and P.M. Rothwell, Effect of aspirin on long-term risk of colorectal cancer: consistent evidence from randomised and observational studies. Lancet, 2007. 369(9573): p. 1603–13.17499602
61 Final report on the aspirin component of the ongoing Physicians’ Health Study. Steering Committee of the Physicians’ Health Study Research Group. N Engl J Med, 1989. 321(3): p. 129–35.2664509
62 Cook, N.R., I.M. Lee, S.M. Zhang, M.V. Moorthy, and J.E. Buring, Alternate-day, low-dose aspirin and cancer risk: long-term observational follow-up of a randomized trial. Ann Intern Med, 2013. 159(2): p. 77–85.23856681
63 Nyman, J.A., N.A. Barleen, B.E. Dowd, D.W. Russell, S.J. Coons, ., Quality-of-life weights for the US population: self-reported health status and priority health conditions, by demographic characteristics. Med Care, 2007. 45(7): p. 618–28.17571010
64 Sullivan, P.W., W.F. Lawrence, and V. Ghushchyan, A national catalog of preference-based scores for chronic conditions in the United States. Med Care, 2005. 43(7): p. 736–49.15970790
65 Mittmann, N., K. Trakas, N. Risebrough, and B.A. Liu, Utility scores for chronic conditions in a community-dwelling population. Pharmacoeconomics, 1999. 15(4): p. 369–76.10537955
66 Fryback, D.G., E.J. Dasbach, R. Klein, B.E. Klein, N. Dorn, ., The Beaver Dam Health Outcomes Study: initial catalog of health-state quality factors. Med Decis Making, 1993. 13(2): p. 89–102.8483408
67 Gold MR, Siegel JE, Russell LB, and Weinstein MC, eds. Cost-effectiveness in health and medicine. 1996, Oxford University Press: New York. xxiii, 425 p.
68 Sullivan, P.W. and V. Ghushchyan, Preference-Based EQ-5D index scores for chronic conditions in the United States. Med Decis Making, 2006. 26(4): p. 410–20.16855129
69 Djalalov, S., L. Rabeneck, G. Tomlinson, K.E. Bremner, R. Hilsden, ., A Review and Meta-analysis of Colorectal Cancer Utilities. Med Decis Making, 2014. 34(6): p. 809–818.24903121
70 Jeong, K. and J. Cairns, Systematic review of health state utility values for economic evaluation of colorectal cancer. Health Econ Rev, 2016. 6(1): p. 36.27541298
71 Lee, H.Y., J.S. Hwang, J.S. Jeng, and J.D. Wang, Quality-adjusted life expectancy (QALE) and loss of QALE for patients with ischemic stroke and intracerebral hemorrhage: a 13-year follow-up. Stroke, 2010. 41(4): p. 739–44.20150543
72 Salomon, J.A., Haagsma, J.A., Davis, A., de Noordhout, C.M., Polinder, S., Havelaar, A.H., Cassini, A., Devleesschauwer, B., Kretzschmar, M., Speybroeck, N., Murray, C.J., Vos, T. , Disability Weights for the Global Burden of Disease 2013 study. Lancet Glob Health. , 2015 3(11): p. e712–23.26475018
73 Briggs, A.H., M.C. Weinstein, E.A. Fenwick, J. Karnon, M.J. Sculpher, ., Model parameter estimation and uncertainty analysis: a report of the ISPOR-SMDM Modeling Good Research Practices Task Force Working Group-6. Med Decis Making, 2012. 32(5): p. 722–32.22990087
74 Ridker, P.M. and N.R. Cook, Statins: new American guidelines for prevention of cardiovascular disease. Lancet, 2013. 382(9907): p. 1762–5.24268611
75 Kavousi, M., M.J. Leening, D. Nanchen, P. Greenland, I.M. Graham, ., Comparison of application of the ACC/AHA guidelines, Adult Treatment Panel III guidelines, and European Society of Cardiology guidelines for cardiovascular disease prevention in a European cohort. JAMA, 2014. 311(14): p. 1416–23.24681960
76 Muntner, P., L.D. Colantonio, M. Cushman, D.C. Goff, Jr., G. Howard, ., Validation of the atherosclerotic cardiovascular disease Pooled Cohort risk equations. JAMA, 2014. 311(14): p. 1406–15.24682252
77 DeFilippis, A.P., R. Young, C.J. Carrubba, J.W. McEvoy, M.J. Budoff, ., An analysis of calibration and discrimination among multiple cardiovascular risk scores in a modern multiethnic cohort. Ann Intern Med, 2015. 162(4): p. 266–75.25686167
78 Elwood, P.C., G. Morgan, J. Galante, J.W. Chia, S. Dolwani, ., Systematic Review and Meta-Analysis of Randomised Trials to Ascertain Fatal Gastrointestinal Bleeding Events Attributable to Preventive Low-Dose Aspirin: No Evidence of Increased Risk. PLoS One, 2016. 11(11): p. e0166166.27846246
79 Lanas, A., P. Wu, J. Medin, and E.J. Mills, Low doses of acetylsalicylic acid increase risk of gastrointestinal bleeding in a meta-analysis. Clin Gastroenterol Hepatol, 2011. 9(9): p. 762–768 e6.21699808
80 Cuzick, J., M.A. Thorat, C. Bosetti, P.H. Brown, J. Burn, ., Estimates of benefits and harms of prophylactic use of aspirin in the general population. Ann Oncol, 2015. 26(1): p. 47–57.25096604
81 Qiao, Y., T. Yang, Y. Gan, W. Li, C. Wang, ., Associations between aspirin use and the risk of cancers: a meta-analysis of observational studies. BMC Cancer, 2018. 18(1): p. 288.29534696
82 Executive Summary of The Third Report of The National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, And Treatment of High Blood Cholesterol In Adults (Adult Treatment Panel III). JAMA, 2001. 285(19): p. 2486–97.11368702
83 Yeboah, J., R. Young, R.L. McClelland, J.C. Delaney, T.S. Polonsky, ., Utility of Nontraditional Risk Markers in Atherosclerotic Cardiovascular Disease Risk Assessment. J Am Coll Cardiol, 2016. 67(2): p. 139–147.26791059
84 Miedema, M.D., D.A. Duprez, J.R. Misialek, M.J. Blaha, K. Nasir, ., Use of coronary artery calcium testing to guide aspirin utilization for primary prevention: estimates from the multi-ethnic study of atherosclerosis. Circ Cardiovasc Qual Outcomes, 2014. 7(3): p. 453–60.24803472
85 American Diabetes, A., 10. Cardiovascular Disease and Risk Management: Standards of Medical Care in Diabetes-2021. Diabetes Care, 2021. 44(Suppl 1): p. S125–S150.33298421
86 U. S. Preventive Services Task Force, S.J. Curry, A.H. Krist, D.K. Owens, M.J. Barry, ., Risk Assessment for Cardiovascular Disease With Nontraditional Risk Factors: US Preventive Services Task Force Recommendation Statement. JAMA, 2018. 320(3): p. 272–280.29998297
87 Burn, J., A.M. Gerdes, F. Macrae, J.P. Mecklin, G. Moeslein, ., Long-term effect of aspirin on cancer risk in carriers of hereditary colorectal cancer: an analysis from the CAPP2 randomised controlled trial. Lancet, 2011. 378(9809): p. 2081–7.22036019
88 Centers for Disease Control and Prevention, National Health and Nutrition Examination Survey Data (2009-2010). 2011, Hyattsville, MD: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention.
89 Centers for Disease Control and Prevention, National Health and Nutrition Examination Survey Data (2007-2008). 2009, Hyattsville, MD: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention.
90 Centers for Disease Control and Prevention, National Health and Nutrition Examination Survey Data (2005-2006). 2007, Hyattsville, MD: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention.
91 Centers for Disease Control and Prevention, National Health and Nutrition Examination Survey Data (2003-2004). 2005, Hyattsville, MD: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention.
92 Centers for Disease Control and Prevention, National Health and Nutrition Examination Survey Data (2001-2002). 2004, Hyattsville, MD: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention.
93 National Center for Health Statistics, National Health Interview Survey, 2007. 2008: Hyattsville, Maryland: National Center for Health Statistics, Centers for Disease Control and Prevention.