# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Howard Tracer, MD, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Jack Cuzick, PhD, FRS, Vanessa Selak, PhD, and Steven M. Teutsch, MD, MPH, who provided expert review of the draft report; Holly G. Woodrow, MPH, from HealthPartners Institute for her project management support; and Janelle M. Guirguis-Blake, MD, Corinne V. Evans, MPP, Leslie A. Perdue, MPH, Sarah I. Bean, MPH, Caitlyn A. Senger, MPH, MS, and Jennifer Lin, MD, with the Kaiser Permanente Evidence-based Practice Center for their collaboration.