# Chapter 4 Discussion

The updated systematic evidence review conducted on behalf of the U.S. Preventive Services Taskforce produced new estimates of the effectiveness of low-dose aspirin in preventing non-fatal MI and ischemic stroke when using aspirin for primary prevention; however, these benefits must be weighed against the added risk of major GI bleeding and intracranial hemorrhage. This decision analysis used simulation modeling to combine findings from the updated systematic review with various data sources in order to quantify the potential balance of benefits and harms across clinically meaningful subgroups defined by age, sex, and 10-year ASCVD risk.

We found that the estimated net lifetime benefit of low dose aspirin varied by starting age, sex, and 10-year ASCVD risk level and that positive or negative assessments sometimes differed between the net QALY and net life year outcomes (KQ1). Overall, we found that men and women aged 40-59 years and with ≥10% 10-year ASCVD risk were most likely to see lifetime benefit from using aspirin for primary prevention and that adults aged 70-79 years with ≤ 20% 10-year ASCVD risk were most likely to experience net harm from starting aspirin. We found that stopping aspirin at 5-year intervals between ages 65-85 years generally showed consistent trends in net benefit that approached the net benefit with lifetime use, whether net beneficial or net harmful (KQ2). We also found that for most groups, aspirin may generate net harm during the first 10 years of use and for the groups that showed net benefit over this time horizon, it was small in magnitude (CQ1).

Importantly, our sensitivity analyses showed that our findings can be quite sensitive on certain assumptions for which evidence is insufficient to determine aspirin’s effect—especially, regarding aspirin’s effects on CRC incidence and fatal major GI bleeding. Various scenarios showed potential to predict widespread net benefit—or net harm—depending on assumptions made. Among these was moderate-to-large increase in net benefits when aspirin was assumed to reduce the risk of CVD mortality by 5%. Although this outcome was not statistically significant in the updated systematic evidence review (OR=0.95, 95% CI: 0.86-1.05), the point estimate of this effect is lower and has a narrower confidence interval compared to the corresponding finding in 2016 (relative risk=0.97, 95% CI: 0.85-1.10) [7]. If new aspirin study results reveal a clearer reduction in CVD mortality, the assessment of balance between benefits and harms could be meaningfully altered. Also notable was that net QALY assessments showed strong adverse influence from small disutility associated with aspirin use, suggesting that aspirin chemoprevention may not be well-suited to persons with no history of CVD who dislike routine use of medications.

## Comparison to 2016 Decision Analysis Findings

Table 34 compares the main findings of the 2016 and 2021 decision analyses. Although qualitatively similar in terms of assessment of positive or negative net benefit, the magnitudes of lifetime net QALYs and life years are substantially smaller with the 2021 update.

Table 34 Comparison of 2016 and 2021 Decision Analysis Main Findings, Lifetime Aspirin Use and Time Horizon

| Initiation Age 40-49y | | Initiation Age 50-59y | | Initiation Age 60-69y | | Initiation Age 70-79y
| 2016 | 2021 | 2016 | 2021 | 2016 | 2021 | 2016 | 2021
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 74.1 | 23.1 | 40.0 | 5.7 | 16.1 | −1.8 | N/A | N/A
7.5% 10y ASCVD Risk | N/A | 29.1 | N/A | 12.5 | N/A | 2.6 | N/A | −4.6
10% 10y ASCVD Risk | 97.2 | 48.0 | 58.8 | 18.0 | 18.0 | 7.0 | −1.0 | −1.1
15% 10y ASCVD Risk | 107.9 | 52.3 | 64.4 | 32.3 | 30.9 | 8.3 | −3.1 | −1.9
20% 10y ASCVD Risk | 105.7 | 66.2 | 83.4 | 48.4 | 31.8 | 16.3 | −6.2 | 0.9
Men, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 48.9 | 10.6 | 15.3 | −5.4 | −5.7 | −11.0 | N/A | N/A
7.5% 10y ASCVD Risk | N/A | 16.2 | N/A | 0.4 | N/A | −6.7 | N/A | −10.1
10% 10y ASCVD Risk | 71.0 | 36.1 | 33.3 | 4.2 | −2.0 | −3.0 | −15.0 | −6.9
15% 10y ASCVD Risk | 82.8 | 37.9 | 39.5 | 18.6 | 9.6 | −2.2 | −18.0 | −7.6
20% 10y ASCVD Risk | 80.1 | 52.4 | 60.5 | 33.9 | 11.6 | 4.9 | −22.5 | −5.5
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 78.4 | 11.1 | 45.0 | 1.9 | 16.4 | −9.5 | −4.4 | −11.7
7.5% 10y ASCVD Risk | N/A | 19.6 | N/A | 10.4 | N/A | −5.8 | N/A | −6.4
10% 10y ASCVD Risk | 96.9 | 35.1 | 62.1 | 17.1 | 28.4 | 2.3 | −4.4 | −6.1
15% 10y ASCVD Risk | 98.4 | 43.0 | 71.6 | 30.8 | 32.4 | 11.6 | −1.5 | −6.9
20% 10y ASCVD Risk | 106.5 | 50.4 | 83.3 | 41.6 | 36 | 19.1 | −2.7 | −4.4
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 41.7 | −10.6 | 10.0 | −18.7 | −12.0 | −23.5 | −23.4 | −20.6
7.5% 10y ASCVD Risk | N/A | −2.6 | N/A | −11.8 | N/A | −20.2 | N/A | −15.4
10% 10y ASCVD Risk | 59.0 | 11.4 | 21.9 | −6.5 | −1.2 | −13.5 | −25.1 | −16.6
15% 10y ASCVD Risk | 57.3 | 17.7 | 33.4 | 7.5 | 1.7 | −7.2 | −22.0 | −17.9
20% 10y ASCVD Risk | 67.7 | 24.2 | 46.3 | 16.9 | 4.8 | −1.6 | −26.1 | −14.8

Notes: ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. 2016 decision analysis findings are from Dehmer et al. [13].

The evidence informing this analysis diverged from the 2016 decision analysis in two important ways. First, while the underlying evidence and meta-analysis were similar, the updated systematic evidence review determined the available evidence was insufficient to have confidence in the effect of low-dose aspirin on CRC incidence when used for primary prevention. As noted in our sensitivity analysis findings, this difference makes a meaningful qualitative and quantitative difference in the assessment of net benefit favorable to aspirin nonuse. With this effect included in the 2016 decision analysis base case, but excluded from the 2021 decision analysis base case, the net benefits of aspirin estimated with the 2021 update are substantially lower.

The second major distinction was in the assessment of evidence regarding aspirin’s effect on fatal major GI bleeding events. Aspirin was assumed to have the same effect of increasing non-fatal and fatal major GI bleeds in the 2016 decision analysis. In the 2021 update, the assessment of evidence did not support this assumption. The updated systematic evidence review was not able to assess this outcome directly due to the very low number of fatal major GI bleeds observed in the aspirin primary prevention trials, but analyses by others have suggested there is no differential effect with aspirin use on fatal major GI bleeding [78, 79]. This change in methods generated higher estimated net benefits for aspirin and partially offset the reduction generated by the removal of the CRC incidence benefit.

## Limitations

The sensitivity analysis results highlight the practical significance of some of the remaining uncertainty about aspirin’s effects when used for primary prevention—particularly, whether aspirin reduces the risk for CRC incidence and affects fatal major GI bleeding risks. Risk of major GI bleeding has been shown to be correlated with some cardiometabolic risk factors, such as blood pressure, current smoking, and diabetes, but insufficient data were available to stratify risks in the model on these factors. Accounting for these factors in estimating major GI bleeding incidence may result in benefits and harms maintaining more consistent proportions across ASCVD risk strata. In addition, due to limited alternatives, we relied on estimates of major GI bleeding rates without aspirin use that were derived from a New Zealand population [42], and it is not known how these rates compare to the U.S. population. However, our sensitivity analyses (Tables 20–24, Scenarios 8-11) generally indicate that variation in major GI bleeding rates without aspirin do not substantially affect the lifetime net QALY and life year estimates when aspirin is assumed to only increase risk for non-fatal GI bleeds. Observational studies have found associations between aspirin use and lower rates of incidence and mortality in CRC and other cancers (including breast, esophageal, gastric, pancreatic, and prostate) [80, 81] which could substantially affect the assessment of using aspirin for primary prevention; however, the decision analysis follows the conclusions of the updated systematic evidence review which found the observational data subject to potential biases that complicate causal inference and evidence from randomized controlled trials insufficient to determine these relationships [17]. Although differences in cardiometabolic risk factors by race/ethnicity are accounted for within the model, lack of racial/ethnic-specific validated CVD event risk prediction and bleeding rates limits the ability to robustly assess these potentially important differences. The results from CQ1 best inform persons with a short planning horizon (such as persons with a life expectancy ≤10 years) because these analyses did not account for the additional benefits that may accrue after 10 years, regardless of whether continuing or stopping use of aspirin from that point in time. Men and women aged 40-49 years and 70-79 years are not as well-represented in the primary prevention aspirin trials, making it less clear how well the aspirin effects translate to these groups, but two new trials since 2016 did include these younger (A Study of Cardiovascular Events in Diabetes, ASCEND [14]) and older age (Aspirin in Reducing Events in the Elderly, ASPREE [16]) groups. The American College of Cardiology and American Heart Association have recognized that the Pooled Cohort Equations for 10-year CVD risk may systematically under- or over-estimate risks for certain patient subgroups [39]. Similarly, our findings depend in part on the natural history of cardiometabolic risk factors and event rates predicted by the model, which may inaccurately predict future outcomes for any given population group. Sensitivity analyses assuming systematically higher and lower baseline CVD event rates (Tables 20–24, Scenarios 5 and 6) are intended to inform how estimates would differ on this basis. While sensitivity analyses can help us understand the importance of limitations among model inputs and model validation provides assurance that the model structure is reasonable, replication in other models can further inform reliability of estimates.

Though our analysis considered pre-defined ages for stopping aspirin based on the age, sex, and 10-year ASCVD risk when starting aspirin (KQ2), our results do not directly address expected net benefits for current users of aspirin who may be considering a decision to continue or stop aspirin use. The analyses of pre-defined stopping ages accounted for the average predicted progression in CVD risk between starting and stopping aspirin based on each group’s characteristics when starting aspirin. However, individual risk progression will vary. The decision to stop or continue taking aspirin based on current clinical factors may be better informed by the results of analyses for KQ1. Based on the model assumptions, the estimated incremental net benefits of continuing versus stopping aspirin should be similar to the net benefits of starting or not starting. However, for many long-time users of aspirin for primary prevention, 10-year ASCVD risks may exceed 20% by their 60s or 70s, which is a risk range that was not considered in our analyses.

Our findings are not generalizable to all primary care patients. The simulation and systematic evidence review on which it is based does not address aspirin use for secondary prevention of CVD. We also did not assess net benefits in patients with more than a 20% 10-year risk of a CVD event due to the historical consideration of >20% 10-year ASCVD risk as a risk-equivalent for the presence of CVD [82] and the limited reporting by aspirin trials on the ASCVD risk levels of participants [17]. The simulation did not account for risk-enhancing factors for CVD, such as coronary artery calcium scores or family history of premature CVD [83]. Accounting for these factors may help to tailor aspirin advice [39, 84, 85], but paucity of trial data for patients with nontraditional CVD risks is a limiting factor [17]. In addition, it is important to note that the USPSTF has found insufficient evidence for adding nontraditional risk factors to the assessment of cardiovascular risk [86]. Furthermore, we did not assess net harms in individuals with recent use of non-aspirin nonsteroidal anti-inflammatory drugs, corticosteroids, or selective serotonin reuptake inhibitors, each of which may increase the risk of major GI bleeding or intracranial hemorrhage [48]. Finally, neither the systematic evidence review [17] nor this decision analysis assessed the potential effect of aspirin on patients with high risk for CRC due to Lynch Syndrome [87].

## Conclusions and Future Research Needs

These results indicate that several population groups may benefit from taking aspirin for the primary prevention of CVD, but magnitudes of net benefit were smaller in this update compared to the last USPSTF assessment of net benefits in 2016. Findings clearly suggest that the quality of life benefits from using aspirin may be considerably diminished among persons who dislike taking routine medications. The primary challenge for policymakers, clinicians, and patients making decisions about use of aspirin for primary prevention is the substantial variation in net benefit found when varying key assumptions lack certainty with the current evidence. Future research should focus on further investigating aspirin’s effect on CRC incidence and death, including the potential for delayed effects on these outcomes, and fatal major GI bleeding, as well as comprehensive risk assessment for major GI bleeding, similar to risk calculators for CVD risk. Additional evidence regarding whether aspirin effects differ by age, sex, 10-year CVD risk, diabetes status, and race/ethnicity may help identify patients who are more likely to benefit than be harmed by low-dose aspirin.