# Chapter 3 Results

## Population Characteristics

Cardiometabolic risk factors among the U.S. population aged 40-79 years have shifted modestly in the data underlying the 2021 decision model compared to the 2016 decision model (Table 6). The 2016 model was sourced by population data from 2001-2010, whereas the 2021 model is sourced by population data from 2015-2018. Notable changes include an overall increase in BMI (from 29.0 kg/m^2^ in the 2016 model to 30.1 kg/m^2^ in 2021 model) and diabetes (from 17% prevalence in the 2016 model to 20% prevalence in the 2021 model) and reductions in smoking prevalence in most population groups. The corresponding prevalence in 10-year ASCVD risk by age and sex is shown in Tables 7a and 7b.

Table 6 U.S. Population Cardiometabolic Risk Factors Used in 2021 and 2016 Aspirin Decision Models

| 2016 Model | 2021 Model
BMI (mean, kg/m^2^) | 29.0 | 30.1
% overweight | 73% | 77%
% obese | 37% | 44%
SBP (mean, mm Hg) | 126.0 | 127.0
% hypertension | 45% | 49%
% over goal (≥140 mm Hg) | 47% | 44%
% using medications | 30% | 33%
Total cholesterol (mean, mg/dL) | 206.0 | 197.4
LDL (mean, mg/dL) | 121.4 | 117.3
HDL (mean, mg/dL) | 53.9 | 55.2
% using medications | 20% | 25%
% with diabetes | 17% | 20%
% with previous CVD | 11% | 12%
% current smokers
Men, 40-49y | 26% | 18%
Men, 50-59y | 21% | 20%
Men, 60-69y | 19% | 15%
Men, 70-79y | 9% | 9%
Women, 40-49y | 21% | 13%
Women, 50-59y | 19% | 16%
Women, 60-69y | 15% | 12%
Women, 70-79y | 8% | 8%

Notes: BMI=body mass index; overweight=BMI ≥ 25 kg/m^2^; obese=BMI ≥ 25 kg/m^2^; SBP=systolic blood pressure; LDL=low-density lipoprotein; HDL=high-density lipoprotein; y=years. Data are presented for adults aged 40-79 years. For the 2016 model, all data but smoking were derived from 2001-2010 NHANES [88–92] data, and smoking status was derived from 2007 NHIS data [93]. For the 2021 model, all data but smoking were derived from 20015-2018 NHANES data [40, 41], and smoking status was derived from 2017-2018 NHIS data [47].

Table 7a Estimated Prevalence of 10-Year ASCVD Risk by Age Among Men

ACC/AHA 10-Year ASVD Risk % | Age 40-49y | Age 50-59y | Age 60-69y | Age 70-79y
0 | 0.7 | <0.1 | <0.1 | <0.1
1 | 20.7 | 0.1 | <0.1 | <0.1
2 | 21.8 | 4.9 | <0.1 | <0.1
3 | 20.1 | 5.8 | <0.1 | <0.1
4 | 10.9 | 8.0 | <0.1 | <0.1
5 | 7.9 | 13.0 | 0.3 | <0.1
6 | 3.9 | 11.0 | 1.0 | <0.1
7 | 4.6 | 12.4 | 3.7 | <0.1
7.5^*^ | 2.1 | 11.4 | 3.6 | <0.1
8 | 1.9 | 6.4 | 7.1 | 0.3
9 | 1.9 | 8.1 | 7.4 | <0.1
10 | 1.4 | 6.8 | 5.8 | <0.1
11 | 0.2 | 4.6 | 6.4 | 0.3
12 | 0.2 | 2.6 | 4.5 | 0.5
13 | 0.6 | 2.6 | 8.4 | 2.9
14 | 0.2 | 1.6 | 6.6 | 2.2
15 | <0.1 | 1.9 | 4.6 | 0.7
16 | 0.5 | 1.8 | 4.1 | 2.3
17 | <0.1 | 1.3 | 4.0 | 4.5
18 | 0.1 | 0.6 | 4.0 | 4.4
19 | 0.7 | 0.5 | 2.8 | 3.4
20 | 0.2 | 0.8 | 3.3 | 4.9
0-20 | 98.8 | 94.7 | 74.1 | 26.2
≥10, All race/ethnicities | 5.4 | 30.4 | 80.6 | 99.7
≥10, Non-Hispanic Black | 14.8 | 63.0 | 87.3 | 96.3
≥10, Not Non-Hispanic Black | 4.3 | 27.1 | 80.0 | 100.0

Notes: ACC/AHA=American College of Cardiology/American Heart Association; ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; y=years. Data derived by applying the AHA/ACC risk calculator to 2015-2018 NHANES data [40, 41]. The 0-20% totals do not sum to 100% because some CVD-free persons have a risk greater than 20%. Risk levels are rounded to the nearest integer.

* The 7.5% risk category is included among the decision analysis population groups and is calculated as 7-8% ACC/AHA 10-year risk.

Table 7b Estimated Prevalence of 10-Year ASCVD Risk by Age Among Women

ACC/AHA 10-Year ASVD Risk % | Age 40-49y | Age 50-59y | Age 60-69y | Age 70-79y
0 | 29.0 | 0.7 | <0.1 | <0.1
1 | 45.6 | 25.0 | <0.1 | <0.1
2 | 11.8 | 26.1 | 7.3 | <0.1
3 | 5.2 | 14.3 | 7.6 | <0.1
4 | 1.8 | 10.1 | 7.9 | <0.1
5 | 1.9 | 6.2 | 14.6 | <0.1
6 | 1.2 | 3.3 | 9.0 | 0.8
7 | 0.5 | 3.1 | 11.1 | 1.4
7.5^*^ | 0.7 | 2.3 | 9.3 | 0.8
8 | 1.0 | 1.8 | 8.4 | 1.0
9 | 0.4 | 2.7 | 4.7 | 3.8
10 | 0.3 | 1.1 | 4.8 | 1.7
11 | 0.2 | 0.9 | 5.3 | 2.2
12 | <0.1 | 1.0 | 4.2 | 2.3
13 | <0.1 | 0.1 | 1.9 | 2.2
14 | 0.4 | 0.8 | 1.6 | 6.7
15 | <0.1 | 1.0 | 1.3 | 3.9
16 | <0.1 | 0.1 | 1.3 | 3.5
17 | 0.1 | 0.2 | 2.7 | 3.3
18 | <0.1 | 0.1 | 0.6 | 5.5
19 | <0.1 | 0.4 | 1.0 | 4.8
20 | 0.3 | 0.2 | 0.6 | 7.7
0-20 | 99.8 | 99.2 | 96.0 | 50.8
≥10, All race/ethnicities | 1.5 | 6.7 | 29.4 | 93.0
≥10, Non-Hispanic Black | 4.9 | 29.8 | 64.9 | 97.2
≥10, Not Non-Hispanic Black | 1.0 | 4.1 | 25.8 | 92.7

Notes: ACC/AHA=American College of Cardiology/American Heart Association; ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; y=years. Data derived by applying the AHA/ACC risk calculator to 2015-2018 NHANES data [40, 41]. The 0-20% totals do not sum to 100% because some CVD-free persons have a risk greater than 20%. Risk levels are rounded to the nearest integer.

* The 7.5% risk category is included among the decision analysis population groups and is calculated as 7-8% ACC/AHA 10-year risk.

These population attributes define the characteristics of the age, sex, and 10-year ASCVD risk strata used by the decision model (Table 8). Among younger ages, the high 10-year ASCVD risk groups tend to have very high prevalence of current smoking and diabetes, which are key risk factors for reflecting above-average 10-year ASCVD risk at these ages. In contrast, among older ages, a low 10-year ASCVD risk is difficult to achieve among persons who currently smoke or have diabetes.

Table 8 Mean CVD Risk Characteristics by Age, Sex, and 10-Year ASCVD Risk Strata in Decision Model Population

| BMI (kg/m^2^) | SBP (mmHg) | LDL (mg/dL) | HDL (mg/dL) | Treated BP (%) | Diabetes (%) | Current Smoking (%)
Men, Age 40-49y
5% 10-year ASCVD risk | 30.9 | 127.1 | 140.2 | 42.4 | 17% | 18% | 29%
7.5% 10-year ASCVD risk | 31.5 | 128.8 | 142.5 | 41.2 | 25% | 30% | 51%
10% 10-year ASCVD risk | 31.9 | 130.9 | 147.1 | 39.3 | 27% | 37% | 63%
15% 10-year ASCVD risk | 32.7 | 133.6 | 151.3 | 37.6 | 39% | 58% | 78%
20% 10-year ASCVD risk | 33.2 | 136.9 | 155.2 | 35.6 | 43% | 76% | 86%
Women, Age 40-49y
5% 10-year ASCVD risk | 35.2 | 129.3 | 136.8 | 42.3 | 35% | 36% | 61%
7.5% 10-year ASCVD risk | 36.2 | 132.2 | 139.4 | 40.3 | 43% | 50% | 69%
10% 10-year ASCVD risk | 36.9 | 134.6 | 140.8 | 39.2 | 49% | 62% | 70%
15% 10-year ASCVD risk | 37.6 | 139.4 | 142.9 | 36.8 | 62% | 76% | 66%
20% 10-year ASCVD risk | 37.8 | 143.7 | 143.8 | 35.6 | 70% | 82% | 64%
Men, Age 50-59y
5% 10-year ASCVD risk | 29.3 | 123.9 | 118.4 | 53.6 | 17% | 3% | 5%
7.5% 10-year ASCVD risk | 30.0 | 128.8 | 127.9 | 48.6 | 24% | 10% | 15%
10% 10-year ASCVD risk | 30.6 | 131.2 | 132.2 | 45.7 | 31% | 19% | 25%
15% 10-year ASCVD risk | 31.7 | 135.7 | 137.1 | 41.3 | 40% | 44% | 38%
20% 10-year ASCVD risk | 32.5 | 138.1 | 139.1 | 38.6 | 48% | 64% | 47%
Women, Age 50-59y
5% 10-year ASCVD risk | 32.0 | 133.3 | 136.4 | 54.8 | 40% | 18% | 39%
7.5% 10-year ASCVD risk | 33.8 | 137.2 | 138.3 | 50.7 | 49% | 44% | 42%
10% 10-year ASCVD risk | 34.6 | 140.0 | 139.4 | 49.1 | 56% | 55% | 47%
15% 10-year ASCVD risk | 35.6 | 144.1 | 140.8 | 46.9 | 65% | 69% | 56%
20% 10-year ASCVD risk | 36.4 | 147.1 | 141.2 | 45.7 | 72% | 81% | 56%
Men, Age 60-69y
5% 10-year ASCVD risk | 27.3 | 108.9 | 87.2 | 66.3 | 10% | 0% | 0%
7.5% 10-year ASCVD risk | 28.0 | 118.7 | 101.6 | 58.8 | 17% | 0% | 3%
10% 10-year ASCVD risk | 28.5 | 123.8 | 109.4 | 55.0 | 25% | 2% | 6%
15% 10-year ASCVD risk | 29.3 | 130.8 | 118.9 | 50.2 | 41% | 10% | 16%
20% 10-year ASCVD risk | 30.1 | 136.0 | 123.7 | 46.6 | 50% | 28% | 23%
Women, Age 60-69y
5% 10-year ASCVD risk | 30.1 | 127.4 | 120.0 | 63.5 | 30% | 5% | 3%
7.5% 10-year ASCVD risk | 30.8 | 133.3 | 124.2 | 61.2 | 44% | 10% | 8%
10% 10-year ASCVD risk | 31.7 | 136.8 | 125.6 | 59.3 | 53% | 24% | 12%
15% 10-year ASCVD risk | 33.3 | 142.2 | 127.1 | 56.0 | 64% | 52% | 20%
20% 10-year ASCVD risk | 34.2 | 145.6 | 128.0 | 54.2 | 72% | 68% | 28%
Men, Age 70-79y
7.5% 10-year ASCVD risk | 25.6 | 101.7 | 92.0 | 67.5 | 0% | 0% | 0%
10% 10-year ASCVD risk | 26.1 | 107.8 | 91.8 | 66.7 | 3% | 0% | 0%
15% 10-year ASCVD risk | 27.1 | 116.3 | 98.1 | 61.9 | 21% | 1% | 5%
20% 10-year ASCVD risk | 27.8 | 124.8 | 106.0 | 57.5 | 35% | 3% | 8%
Women, Age 70-79y
5% 10-year ASCVD risk | 27.1 | 95.0 | 105.0 | 70.9 | 1% | 0% | 0%
7.5% 10-year ASCVD risk | 28.0 | 108.9 | 118.7 | 66.1 | 12% | 0% | 0%
10% 10-year ASCVD risk | 28.4 | 118.5 | 122.4 | 64.6 | 22% | 0% | 1%
15% 10-year ASCVD risk | 29.2 | 130.2 | 127.5 | 62.7 | 49% | 4% | 4%
20% 10-year ASCVD risk | 29.5 | 135.7 | 128.8 | 62.3 | 59% | 11% | 6%

Notes: BMI=body mass index; SBP=systolic blood pressure; LDL=low-density lipoprotein cholesterol; HDL=high-density lipoprotein cholesterol; BP=blood pressure; CVD=cardiovascular disease; ASCVD=atherosclerotic cardiovascular disease; y=years. All values are population means.

Figure 2 shows how the event rates over 10 years predicted by the model compare the event rates predicted by the 10-year ASCVD risk score. Perfect concordance in 10-year event rates is not necessarily expected. For example, this may be true for persons with higher ASCVD risk scores, for whom contemporary trends in prevention activities (such as hypertension management, statin use, smoking cessation) incorporated within the model may abate risks to a greater degree than observed in the cohort used to derive the 10-year risk scores. Similar patterns have been seen in other comparisons to event rates predicted by the ACC/AHA 10-year ASCVD Pooled Cohort risk scores [74–77].

Figure 2 Comparison of 10-Year Model Outcomes With ASCVD 10-Year Risk Among Men and Women Aged 40-79 years

Notes: ASCVD=atherosclerotic cardiovascular disease. The y-axis represents the percent of persons observed having their first hard ASCVD event (non-fatal MI, non-fatal stroke, or coronary death) in a ModelHealth: CVD simulated cohort with a 10-year ACC/AHA baseline risk [45] specified in x-axis. The 45-degree line indicates perfect concordance in 10-year outcomes predicted by the ACC/AHA risk calculator and those observed in a simulated population. Points above the 45-degree line indicate that 10-year event rates simulated in the model are above the rate indicated by 10-year ACC/AHA risk; points below the 45-degree line indicate that 10-year event rates simulated in the model are below the rate indicated by 10-year ACC/AHA risk. Similar patterns have been seen in other comparisons [74–77].

Figure 2 shows the predicted 10-year CVD event rates in the model (y-axis) compared to the initial calculated 10-year ASCVD risk level for each group (x-axis). A 45-degree line indicates perfect concordance in 10-year outcomes predicted by the ACC/AHA Pooled Cohort risk calculator and those observed in a simulated population. Points above the 45-degree line indicate that 10-year event rates simulated in the model are above the rate indicated by 10-year ACC/AHA risk; points below the 45-degree line indicate that 10-year event rates simulated in the model are below the rate indicated by 10-year ASCVD risk. The figure shows that the model general predicts slightly-to-moderately higher than expected event prevalence for 10-year ASCVD risk levels <10% and predicts moderately lower event prevalence than expected for 10-year ASCVD risk levels >15%.

## Effect of Model Updates on Baseline Event Rates

Shifts in cardiometabolic risk factors and other dynamic factors within the model, such as updates to reflect contemporary blood pressure and cholesterol treatment guidelines and medication use rates, can change the predicted event rates within a population strata even without changes to the event risk calculations within the model. Table 9 shows the proportional change in baseline event rates between the 2016 and 2021 decision models. For most CVD events, changes were within +/− 10 percent. Changes in event rates were greater for CRC and major GI bleeding outcomes due to the change in incidence and case-fatality rates for these outcomes. Changes in baseline event rates can affect the absolute magnitude of aspirin’s effects, even if the relative risk modification of taking aspirin remains the same.

Table 9 Proportional Change in Base Model Event Rates With 2021 Updates Compared to 2016 Decision Model

| Life Years | QALYs | Non-fatal Myocardial Infarction | Non-fatal Ischemic Stroke | CVD | CVD Death | Intracranial Hemorrhage | Intracranial Hemorrhage Death | Colorectal Cancer | Colorectal Cancer Deaths | Major GI Bleeds | Major GI Bleed Death
Men, Initiation age 40-49y
5% 10-yr ASCVD Risk | 3% | 3% | 8% | 6% | 9% | 11% | −7% | −7% | −8% | 57% | 16% | −7%
10% 10-yr ASCVD Risk | 2% | 2% | 4% | 3% | 4% | 8% | −12% | −11% | −9% | 59% | 13% | −4%
15% 10-yr ASCVD Risk | 0% | 0% | 9% | 8% | 10% | 13% | −6% | −5% | −6% | 62% | 8% | −20%
20% 10-yr ASCVD Risk | −1% | −1% | 11% | 8% | 10% | 13% | −13% | −11% | −9% | 58% | 15% | −6%
Women, Initiation age 40-49y
5% 10-yr ASCVD Risk | 3% | 3% | −1% | −5% | −1% | −1% | −10% | −10% | −19% | 22% | 44% | −19%
10% 10-yr ASCVD Risk | 3% | 3% | −1% | −2% | 0% | 1% | −17% | −15% | −17% | 33% | 47% | −20%
15% 10-yr ASCVD Risk | 2% | 2% | 1% | −3% | 3% | 1% | −21% | −21% | −16% | 47% | 40% | −28%
20% 10-yr ASCVD Risk | 2% | 2% | −3% | −3% | 0% | 1% | −17% | −17% | −16% | 35% | 43% | −21%
Men, Initiation age 50-59y
5% 10-yr ASCVD Risk | 4% | 4% | 3% | 5% | 6% | 9% | −6% | −5% | −20% | 30% | 9% | −15%
10% 10-yr ASCVD Risk | 4% | 4% | −2% | −1% | 1% | 6% | −16% | −16% | −18% | 45% | 8% | −24%
15% 10-yr ASCVD Risk | 3% | 3% | 1% | 3% | 3% | 6% | −13% | −15% | −19% | 46% | 4% | −8%
20% 10-yr ASCVD Risk | 3% | 3% | 1% | 4% | 4% | 7% | −11% | −11% | −13% | 61% | 8% | −14%
Women, Initiation age 50-59y
5% 10-yr ASCVD Risk | 2% | 2% | −9% | −11% | −8% | −9% | −11% | −12% | −21% | 25% | 28% | −36%
10% 10-yr ASCVD Risk | 3% | 3% | −8% | −8% | −3% | −2% | −17% | −17% | −26% | 17% | 33% | −34%
15% 10-yr ASCVD Risk | 4% | 5% | −9% | −8% | −5% | −4% | −20% | −20% | −23% | 24% | 36% | −24%
20% 10-yr ASCVD Risk | 3% | 3% | −5% | −4% | −2% | −3% | −21% | −20% | −23% | 22% | 38% | −12%
Men, Initiation age 60-69y
5% 10-yr ASCVD Risk | 7% | 7% | 5% | 6% | 7% | 8% | −2% | −3% | −24% | 36% | −1% | −33%
10% 10-yr ASCVD Risk | 6% | 6% | 3% | 4% | 5% | 5% | −10% | −10% | −24% | 28% | −1% | −34%
15% 10-yr ASCVD Risk | 4% | 4% | −6% | 0% | −2% | 1% | −8% | −8% | −22% | 34% | −1% | −27%
20% 10-yr ASCVD Risk | 2% | 3% | −2% | −2% | 0% | 2% | −12% | −13% | −20% | 42% | −3% | −34%
Women, Initiation age 60-69y
5% 10-yr ASCVD Risk | 1% | 2% | −10% | −8% | −9% | −7% | −14% | −17% | −25% | 14% | 23% | −43%
10% 10-yr ASCVD Risk | 1% | 1% | −12% | −11% | −8% | −8% | −16% | −17% | −25% | 21% | 25% | −36%
15% 10-yr ASCVD Risk | 0% | 0% | −7% | −9% | −4% | −4% | −21% | −20% | −21% | 20% | 22% | −39%
20% 10-yr ASCVD Risk | 0% | 0% | −6% | −4% | −2% | −3% | −24% | −24% | −21% | 25% | 19% | −45%
Men, Initiation age 70-79y
10% 10-yr ASCVD Risk | 4% | 4% | −1% | 2% | −1% | 2% | −9% | −12% | −29% | 27% | −8% | −54%
15% 10-yr ASCVD Risk | 5% | 6% | −1% | 2% | 0% | 2% | −3% | −4% | −27% | 23% | −8% | −48%
20% 10-yr ASCVD Risk | 6% | 6% | −1% | −3% | 0% | 2% | −3% | −3% | −29% | 20% | −10% | −56%
Women, Initiation age 70-79y
5% 10-yr ASCVD Risk | 0% | 0% | −5% | −7% | −7% | −5% | 5% | −1% | −27% | 4% | 20% | −48%
10% 10-yr ASCVD Risk | 2% | 3% | −10% | −10% | −10% | −10% | −7% | −7% | −25% | 11% | 20% | −44%
15% 10-yr ASCVD Risk | 0% | 1% | −12% | −12% | −11% | −11% | −7% | −9% | −28% | 5% | 13% | −50%
20% 10-yr ASCVD Risk | −2% | −2% | −12% | −13% | −12% | −12% | −13% | −18% | −29% | 6% | 11% | −52%

Notes: QALYs=quality-adjusted life years, CVD=cardiovascular disease, GI=gastrointestinal, ASCVD=atherosclerotic cardiovascular disease, y=years. The table shows the proportional change in event rates in the 2021 decision model compared to the 2016 decision model.

## KQ1 What Is the Lifetime Net Benefit of Aspirin?

In the base case analyses, the predicted lifetime net benefit from the routine use of aspirin for primary prevention of CVD was positive in terms of net QALYs for men and women aged 40-59 years (ranging from 1.9 net QALYs per 1000 women aged 50-59 years with 5% 10-year ASCVD risk to 66.2 net QALYs per 1000 men aged 40-49 years with 20% 10-year ASCVD risk, Table 10), but mixed for net life years, depending on 10-year ASCVD risk (ranging from −18.7 net life years per 1000 women aged 50-59 years with 5% 10-year ASCVD risk to 52.4 net life years per 1000 men aged 40-49 years with 20% 10-year ASCVD risk). For men and women aged 60-69 years, net QALYs were positive at and above the 10% 10-year ASCVD risk threshold (as high as 19.1 net QALYs per 1000 women with 20% 10-year ASCVD risk), but negative for nearly all groups in terms of net life years (as low as −23.5 net life years per 1000 women with 5% 10-year ASCVD risk). For men and women aged 70-79 years, lifetime net benefits were negative in terms of both net QALYs and life years for nearly all risk groups considered.

Table 10 Lifetime Net Benefit of Aspirin for Men and Women With Lifetime Use (KQ1)

| Initiation Age 40-49y | Initiation Age Age 50-59y | Initiation Age Age 60-69y | Initiation Age Age 70-79y
Men, Net QALYs per 1000 persons (95% Confidence Interval)
5% 10y ASCVD Risk | 23.1 (15.8 to 30.4) | 5.7 (−0.0 to 11.3) | −1.8 (−6.4 to 2.9) | N/A
7.5% 10y ASCVD Risk | 29.1 (22.3 to 36.0) | 12.5 (6.5 to 18.5) | 2.6 (−1.9 to 7.2) | −4.6 (−7.7 to −1.5)
10% 10y ASCVD Risk | 48.0 (40.6 to 55.5) | 18.0 (12.0 to 24.0) | 7.0 (2.2 to 11.8) | −1.1 (−4.4 to 2.2)
15% 10y ASCVD Risk | 52.3 (44.5 to 60.1) | 32.3 (26.2 to 38.5) | 8.3 (3.5 to 13.0) | −1.9 (−5.4 to 1.6)
20% 10y ASCVD Risk | 66.2 (58.2 to 74.1) | 48.4 (41.9 to 54.8) | 16.3 (11.4 to 21.1) | 0.9 (−2.2 to 3.9)
Men, Net Life Years per 1000 persons (95% Confidence Interval)
5% 10y ASCVD Risk | 10.6 (2.9 to 18.3) | −5.4 (−11.7 to 0.8) | −11.0 (−16.0 to −6.1) | N/A
7.5% 10y ASCVD Risk | 16.2 (9.0 to 23.5) | 0.4 (−6.1 to 6.9) | −6.7 (−11.5 to −1.9) | −10.1 (−13.4 to −6.8)
10% 10y ASCVD Risk | 36.1 (28.1 to 44.1) | 4.2 (−2.3 to 10.8) | −3.0 (−8.0 to 1.9) | −6.9 (−10.5 to −3.4)
15% 10y ASCVD Risk | 37.9 (29.6 to 46.2) | 18.6 (11.7 to 25.4) | −2.2 (−7.2 to 2.9) | −7.6 (−11.3 to −3.9)
20% 10y ASCVD Risk | 52.4 (43.9 to 60.9) | 33.9 (26.9 to 40.9) | 4.9 (−0.1 to 10.0) | −5.5 (−8.8 to −2.2)
Women, Net QALYs per 1000 persons (95% Confidence Interval)
5% 10y ASCVD Risk | 11.1 (3.5 to 18.6) | 1.9 (−5.1 to 8.8) | −9.5 (−14.4 to −4.6) | −11.7 (−15.2 to −8.1)
7.5% 10y ASCVD Risk | 19.6 (12.3 to 26.8) | 10.4 (3.9 to 16.9) | −5.8 (−10.9 to −0.7) | −6.4 (−10.0 to −2.8)
10% 10y ASCVD Risk | 35.1 (27.3 to 43.0) | 17.1 (10.2 to 24.0) | 2.3 (−2.7 to 7.4) | −6.1 (−9.4 to −2.7)
15% 10y ASCVD Risk | 43.0 (35.4 to 50.5) | 30.8 (24.5 to 37.2) | 11.6 (6.9 to 16.4) | −6.9 (−10.7 to −3.0)
20% 10y ASCVD Risk | 50.4 (42.3 to 58.5) | 41.6 (34.8 to 48.5) | 19.1 (14.2 to 24.1) | −4.4 (−8.1 to −0.7)
Women, Net Life Years per 1000 persons (95% Confidence Interval)
5% 10y ASCVD Risk | −10.6 (−18.5 to −2.7) | −18.7 (−26.0 to −11.5) | −23.5 (−28.4 to −18.5) | −20.6 (−24.3 to −16.9)
7.5% 10y ASCVD Risk | −2.6 (−10.0 to 4.7) | −11.8 (−18.7 to −5.0) | −20.2 (−25.6 to −14.9) | −15.4 (−19.0 to −11.8)
10% 10y ASCVD Risk | 11.4 (3.2 to 19.7) | −6.5 (−13.6 to 0.7) | −13.5 (−18.7 to −8.4) | −16.6 (−20.0 to −13.2)
15% 10y ASCVD Risk | 17.7 (9.8 to 25.5) | 7.5 (0.9 to 14.1) | −7.2 (−12.3 to −2.1) | −17.9 (−21.9 to −14.0)
20% 10y ASCVD Risk | 24.2 (15.7 to 32.7) | 16.9 (9.7 to 24.1) | −1.6 (−6.8 to 3.6) | −14.8 (−18.6 to −11.0)

Notes: ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Confidence intervals reflect stochastic heterogeneity and were calculated by bootstrap sampling with replacement 100,000 times from within the modeled population sample.

Tables 11 and 12 show the lifetime differences in net events that underlie the lifetime net QALY and life year estimates shown in Table 10. Prevented non-fatal MIs and ischemic strokes—along with downstream reductions in subsequent events and CVD deaths—balanced against non-fatal major GI bleeds and intracranial hemorrhage events. Due to differences in underlying event rates, more non-fatal MIs than non-fatal ischemic strokes were prevented for men; whereas, the reduction of these two types of events was more evenly balanced for women. Women also have a longer life expectancy, which corresponds to a longer average risk exposure during which aspirin can intervene.

Table 11 Lifetime Net Events of Aspirin for Men With Lifetime Use (KQ1)

| Benefits from aspirin; (Prevented events per 1,000 persons) | | | | | | Harms from aspirin; (Incurred events per 1,000 persons) | | | | Net Balance; (Benefits - harms)
10-yr ASCVD Risk (%) | Myocardial infarction | Ischemic stroke | Non-fatal CVD Events | CVD Deaths | CRC Cases | CRC Deaths | Major GI Bleeds | Major GI Bleed Deaths | Intracranial Hemorrhage | Intracranial Hemorrhage Deaths | Net QALYs | Net Life Years | Net Events Prevented
Men, Initiation Age 40-49 years
5 | 17.0 | 6.1 | 28.3 | 4.6 | - | - | 31.5 | 0.0 | 2.9 | 2.6 | 23.1 | 10.6 | −1.5
7.5 | 19.6 | 6.6 | 32.4 | 4.7 | - | - | 30.3 | 0.0 | 2.5 | 2.3 | 29.1 | 16.2 | 4.3
10 | 20.5 | 7.0 | 34.0 | 5.2 | - | - | 29.7 | 0.0 | 2.3 | 2.0 | 48.0 | 36.1 | 7.2
15 | 22.5 | 8.0 | 37.6 | 5.5 | - | - | 27.1 | 0.0 | 2.5 | 2.3 | 52.3 | 37.9 | 13.5
20 | 24.9 | 7.7 | 40.3 | 6.2 | - | - | 24.7 | 0.0 | 2.4 | 2.2 | 66.2 | 52.4 | 19.4
Men, Initiation Age 50-59 years
5 | 14.3 | 6.0 | 24.7 | 3.6 | - | - | 32.6 | 0.0 | 3.1 | 2.8 | 5.7 | −5.4 | −7.4
7.5 | 15.2 | 6.9 | 26.4 | 3.8 | - | - | 31.0 | 0.0 | 3.0 | 2.8 | 12.5 | 0.4 | −3.8
10 | 15.5 | 7.3 | 28.2 | 4.1 | - | - | 29.8 | 0.0 | 2.8 | 2.5 | 18.0 | 4.2 | −0.3
15 | 18.8 | 7.6 | 32.4 | 4.6 | - | - | 27.7 | 0.0 | 2.6 | 2.4 | 32.3 | 18.6 | 6.7
20 | 20.5 | 8.5 | 36.0 | 5.2 | - | - | 24.8 | 0.0 | 2.1 | 1.9 | 48.4 | 33.9 | 14.3
Men, Initiation Age 60-69 years
5 | 10.1 | 6.0 | 19.0 | 2.7 | - | - | 32.9 | 0.0 | 3.0 | 2.7 | −1.8 | −11.0 | −14.2
7.5 | 11.3 | 6.1 | 20.5 | 2.6 | - | - | 31.0 | 0.0 | 2.8 | 2.4 | 2.6 | −6.7 | −10.7
10 | 12.7 | 6.0 | 22.5 | 3.3 | - | - | 30.2 | 0.0 | 2.9 | 2.6 | 7.0 | −3.0 | −7.3
15 | 12.3 | 6.4 | 22.3 | 3.3 | - | - | 28.0 | 0.0 | 3.0 | 2.6 | 8.3 | −2.2 | −5.4
20 | 14.8 | 7.2 | 26.8 | 4.1 | - | - | 26.4 | 0.0 | 2.8 | 2.5 | 16.3 | 4.9 | 1.7
Men, Initiation Age 70-79 years
5 | - | - | - | - | - | - | - | - | - | - | - | -
7.5 | 8.0 | 4.6 | 14.9 | 1.8 | - | - | 27.9 | 0.0 | 2.6 | 2.3 | −4.6 | −10.1 | −13.8
10 | 8.9 | 5.1 | 16.4 | 2.2 | - | - | 28.2 | 0.0 | 2.6 | 2.2 | −1.1 | −6.9 | −12.2
15 | 8.9 | 5.1 | 16.2 | 2.1 | - | - | 27.4 | 0.0 | 2.6 | 2.1 | −1.9 | −7.6 | −11.7
20 | 9.7 | 5.5 | 17.6 | 2.0 | - | - | 25.7 | 0.0 | 2.6 | 2.1 | 0.9 | −5.5 | −8.7

Notes: ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; CRC=colorectal cancer; GI=gastrointestinal; QALY=quality-adjusted life year. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption; all else is held equal. MI and ischemic stroke events are non-fatal. The non-fatal CVD event column combines non-fatal MIs, ischemic strokes, and congestive heart failure (as a major sequela to MI). Net events prevented are defined by the net of benefit and harm events, or: (Non-fatal CVD events + CVD deaths + CRC cases) – (Major GI bleeds + intracranial hemorrhage). In the base case, there was no effect of aspirin use on CRC incidence.

Table 12 Lifetime Net Events of Aspirin for Women With Lifetime Use (KQ1)

| Benefits from aspirin; (Prevented events per 1,000 persons) | | | | | | Harms from aspirin; (Incurred events per 1,000 persons) | | | | Net Balance; (Benefits - harms)
10-yr ASCVD Risk (%) | Myocardial infarction | Ischemic stroke | Non-fatal CVD Events | CVD Deaths | CRC Cases | CRC Deaths | Major GI Bleeds | Major GI Bleed Deaths | Intracranial Hemorrhage | Intracranial Hemorrhage Deaths | Net QALYs | Net Life Years | Net Events Prevented
Women, Initiation Age 40-49 years
5 | 10.3 | 9.8 | 24.6 | 3.5 | - | - | 31.9 | 0.0 | 4.0 | 3.6 | 11.1 | −10.6 | −7.8
7.5 | 10.6 | 9.8 | 25.6 | 4.1 | - | - | 30.4 | 0.0 | 3.2 | 2.9 | 19.6 | −2.6 | −3.9
10 | 11.4 | 10.4 | 27.8 | 4.3 | - | - | 29.4 | 0.0 | 3.0 | 2.8 | 35.1 | 11.4 | −0.3
15 | 11.7 | 10.7 | 28.8 | 4.6 | - | - | 29.3 | 0.0 | 2.9 | 2.6 | 43.0 | 17.7 | 1.2
20 | 12.1 | 11.5 | 30.4 | 5.0 | - | - | 30.0 | 0.0 | 2.7 | 2.4 | 50.4 | 24.2 | 2.7
Women, Initiation Age 50-59 years
5 | 8.4 | 9.9 | 22.3 | 3.1 | - | - | 30.9 | 0.0 | 4.0 | 3.4 | 1.9 | −18.7 | −9.5
7.5 | 9.0 | 10.4 | 24.1 | 3.5 | - | - | 28.9 | 0.0 | 3.8 | 3.4 | 10.4 | −11.8 | −5.1
10 | 9.2 | 11.1 | 24.8 | 4.1 | - | - | 28.0 | 0.0 | 3.5 | 3.2 | 17.1 | −6.5 | −2.6
15 | 10.5 | 11.9 | 28.1 | 3.9 | - | - | 26.9 | 0.0 | 3.1 | 2.8 | 30.8 | 7.5 | 2.0
20 | 11.4 | 11.8 | 30.5 | 4.6 | - | - | 25.5 | 0.0 | 2.9 | 2.6 | 41.6 | 16.9 | 6.7
Women, Initiation Age 60-69 years
5 | 5.7 | 7.9 | 16.2 | 2.1 | - | - | 30.4 | 0.0 | 4.0 | 3.5 | −9.5 | −23.5 | −16.1
7.5 | 6.5 | 8.1 | 17.3 | 2.2 | - | - | 28.9 | 0.0 | 3.7 | 3.2 | −5.8 | −20.2 | −13.1
10 | 6.4 | 9.1 | 18.8 | 2.6 | - | - | 27.7 | 0.0 | 3.6 | 3.2 | 2.3 | −13.5 | −9.9
15 | 7.2 | 10.6 | 22.0 | 3.1 | - | - | 25.8 | 0.0 | 3.3 | 2.9 | 11.6 | −7.2 | −4.0
20 | 8.0 | 11.6 | 24.5 | 3.6 | - | - | 25.1 | 0.0 | 3.3 | 2.8 | 19.1 | −1.6 | −0.3
Women, Initiation Age 70-79 years
5 | 4.3 | 7.0 | 12.8 | 1.3 | - | - | 29.4 | 0.0 | 3.7 | 3.2 | −11.7 | −20.6 | −19.0
7.5 | 4.7 | 6.9 | 13.4 | 1.3 | - | - | 28.3 | 0.0 | 3.3 | 2.7 | −6.4 | −15.4 | −16.9
10 | 4.4 | 7.1 | 13.5 | 1.4 | - | - | 27.4 | 0.0 | 3.0 | 2.6 | −6.1 | −16.6 | −15.5
15 | 5.0 | 7.7 | 14.8 | 1.6 | - | - | 24.8 | 0.0 | 3.4 | 2.9 | −6.9 | −17.9 | −11.8
20 | 5.3 | 7.3 | 15.3 | 1.9 | - | - | 24.0 | 0.0 | 3.5 | 2.9 | −4.4 | −14.8 | −10.3

Notes: ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; CRC=colorectal cancer; GI=gastrointestinal; QALY=quality-adjusted life year. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption; all else is held equal. MI and ischemic stroke events are non-fatal. The non-fatal CVD event column combines non-fatal MIs, ischemic strokes, and congestive heart failure (as a major sequela to MI). Net events prevented are defined by the net of benefit and harm events, or: (Non-fatal CVD events + CVD deaths + CRC cases) – (Major GI bleeds + intracranial hemorrhage). In the base case, there was no effect of aspirin use on CRC incidence.

## KQ2 How Does Stopping Aspirin Use Between the Ages of 65 and 85 Years Modify Lifetime Net Benefit of Aspirin?

Tables 13 and 14 show lifetime net benefits of using aspirin for discrete intervals defined by stopping ages between 65-85 years. At older ages, net benefits of continued use of aspirin can be unclear. Although aspirin use can generate potential benefits as CVD event rates increase with age, these benefits can be partially or fully offset by higher rates of major GI bleeding and intracranial hemorrhage. For men (Table 13), the trends in net benefit across stopping ages were generally monotonic, typically increasing with later stopping ages for men aged 40-59 years and decreasing in terms of net life years for men aged 60-69 years. The trends for women (Table 14) were generally similar, but there were some exceptions, such as for net life years among women aged 50-59 years with 20% 10-year ASCVD risk where slightly higher net benefit (+1.5 net life years per 1000 women) was found when stopping aspirin at age 80 years compared to lifetime use.

Table 13 Lifetime Net Benefit of Aspirin for Men for Various Stopping Ages (KQ2)

% 10-yr ASCVD Risk | Stop Aspirin Age 65y | Stop Aspirin Age 70y | Stop Aspirin Age 75y | Stop Aspirin Age 80y | Stop Aspirin Age 85y
Men, Initiation Age 40-49 years, Net QALYs per 1000 persons (95% Confidence Interval)
5 | 13.1 (7.1 to 19.1) | 18.8 (12.1 to 25.5) | 20.9 (14.0 to 27.9) | 22.2 (15.1 to 29.3) | 23.6 (16.4 to 30.8)
7.5 | 17.4 (11.6 to 23.3) | 22.1 (15.7 to 28.5) | 25.0 (18.3 to 31.7) | 27.4 (20.6 to 34.3) | 28.7 (21.8 to 35.5)
10 | 35.1 (28.9 to 41.3) | 40.3 (33.5 to 47.1) | 43.6 (36.4 to 50.8) | 46.2 (38.8 to 53.6) | 47.1 (39.6 to 54.5)
15 | 40.8 (34.0 to 47.6) | 46.2 (39.1 to 53.4) | 49.8 (42.3 to 57.3) | 50.5 (42.7 to 58.2) | 52.1 (44.4 to 59.9)
20 | 50.2 (43.3 to 57.2) | 56.4 (48.8 to 63.9) | 61.3 (53.5 to 69.1) | 64.4 (56.5 to 72.2) | 65.5 (57.6 to 73.4)
Men, Initiation Age 40-49 years, Net Life Years per 1000 persons (95% Confidence Interval)
5 | 7.5 (1.2 to 13.8) | 11.7 (4.7 to 18.8) | 11.7 (4.3 to 19.0) | 11.3 (3.9 to 18.8) | 11.6 (4.0 to 19.2)
7.5 | 10.0 (3.8 to 16.2) | 13.3 (6.6 to 20.1) | 14.8 (7.8 to 21.9) | 15.9 (8.7 to 23.1) | 16.4 (9.2 to 23.6)
10 | 28.8 (22.2 to 35.4) | 32.2 (25.0 to 39.5) | 34.3 (26.7 to 42.0) | 35.7 (27.8 to 43.6) | 35.7 (27.7 to 43.6)
15 | 32.4 (25.2 to 39.6) | 36.2 (28.5 to 43.8) | 38.0 (30.0 to 46.0) | 37.2 (29.0 to 45.5) | 38.3 (30.1 to 46.6)
20 | 42.3 (34.8 to 49.8) | 45.8 (37.7 to 53.9) | 49.4 (41.1 to 57.8) | 51.8 (43.3 to 60.2) | 52.1 (43.6 to 60.6)
Men, Initiation Age 50-59 years, Net QALYs per 1000 persons (95% Confidence Interval)
5 | 2.0 (−2.2 to 6.2) | 2.9 (−1.8 to 7.5) | 4.0 (−1.2 to 9.3) | 4.7 (−0.7 to 10.2) | 5.7 (0.1 to 11.4)
7.5 | 5.5 (1.2 to 9.7) | 9.2 (4.2 to 14.2) | 10.7 (5.0 to 16.3) | 11.6 (5.7 to 17.5) | 12.1 (6.1 to 18.0)
10 | 9.1 (4.8 to 13.5) | 12.3 (7.2 to 17.5) | 15.2 (9.6 to 20.9) | 16.2 (10.4 to 22.0) | 17.6 (11.7 to 23.6)
15 | 17.2 (12.7 to 21.7) | 24.5 (19.0 to 29.9) | 28.7 (22.8 to 34.6) | 31.0 (24.9 to 37.2) | 31.7 (25.5 to 37.9)
20 | 26.1 (21.3 to 30.9) | 35.4 (30.0 to 40.9) | 41.5 (35.4 to 47.5) | 45.4 (39.0 to 51.7) | 47.2 (40.8 to 53.6)
Men, Initiation Age 50-59 years, Net Life Years per 1000 persons (95% Confidence Interval)
5 | −2.1 (−6.7 to 2.4) | −2.5 (−7.6 to 2.7) | −3.0 (−8.8 to 2.8) | −4.0 (−10.1 to 2.0) | −4.3 (−10.5 to 1.9)
7.5 | 2.4 (−2.3 to 7.0) | 3.5 (−1.9 to 8.9) | 2.7 (−3.4 to 8.9) | 1.7 (−4.7 to 8.2) | 0.6 (−5.9 to 7.1)
10 | 4.8 (0.1 to 9.6) | 5.8 (0.1 to 11.4) | 6.0 (−0.1 to 12.2) | 4.4 (−1.9 to 10.7) | 4.6 (−2.0 to 11.1)
15 | 11.8 (6.8 to 16.7) | 16.5 (10.5 to 22.4) | 18.2 (11.8 to 24.7) | 19.1 (12.3 to 25.9) | 18.5 (11.7 to 25.3)
20 | 20.2 (14.9 to 25.5) | 26.6 (20.7 to 32.6) | 30.2 (23.6 to 36.8) | 32.6 (25.7 to 39.4) | 33.4 (26.5 to 40.4)
Men, Initiation Age 60-69 years, Net QALYs per 1000 persons (95% Confidence Interval)
5 | N/A | N/A | −2.3 (−6.1 to 1.6) | −3.8 (−8.2 to 0.5) | −1.7 (−6.3 to 2.9)
7.5 | N/A | N/A | −0.4 (−4.4 to 3.5) | 1.6 (−2.6 to 5.8) | 2.0 (−2.4 to 6.5)
10 | N/A | N/A | 3.7 (−0.4 to 7.8) | 6.5 (1.9 to 11.1) | 7.2 (2.4 to 11.9)
15 | N/A | N/A | 5.5 (1.5 to 9.5) | 7.3 (2.9 to 11.7) | 8.3 (3.6 to 12.9)
20 | N/A | N/A | 12.5 (8.5 to 16.6) | 14.3 (9.6 to 18.9) | 15.2 (10.3 to 20.0)
Men, Initiation Age 60-69 years, Net Life Years per 1000 persons (95% Confidence Interval)
5 | N/A | N/A | −6.7 (−10.8 to −2.7) | −10.1 (−14.7 to −5.4) | −9.8 (−14.7 to −5.0)
7.5 | N/A | N/A | −5.5 (−9.7 to −1.3) | −5.3 (−9.7 to −0.8) | −6.4 (−11.2 to −1.7)
10 | N/A | N/A | −2.1 (−6.4 to 2.2) | −1.3 (−6.2 to 3.5) | −2.0 (−6.9 to 3.0)
15 | N/A | N/A | −0.6 (−4.8 to 3.7) | −0.9 (−5.6 to 3.8) | −1.3 (−6.3 to 3.7)
20 | N/A | N/A | 5.8 (1.6 to 10.0) | 5.3 (0.5 to 10.2) | 4.9 (−0.2 to 9.9)
Men, Initiation Age 70-79 years, Net QALYs per 1000 persons (95% Confidence Interval)
5 | N/A | N/A | N/A | N/A | N/A
7.5 | N/A | N/A | N/A | N/A | −5.7 (−8.6 to −2.7)
10 | N/A | N/A | N/A | N/A | −1.8 (−5.0 to 1.3)
15 | N/A | N/A | N/A | N/A | −1.8 (−5.1 to 1.4)
20 | N/A | N/A | N/A | N/A | 1.3 (−1.6 to 4.1)
Men, Initiation Age 70-79 years, Net Life Years per 1000 persons (95% Confidence Interval)
5 | N/A | N/A | N/A | N/A | N/A
7.5 | N/A | N/A | N/A | N/A | −9.5 (−12.6 to −6.3)
10 | N/A | N/A | N/A | N/A | −6.2 (−9.6 to −2.8)
15 | N/A | N/A | N/A | N/A | −6.3 (−9.8 to −2.8)
20 | N/A | N/A | N/A | N/A | −3.8 (−6.9 to −0.6)

Notes: ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. Confidence intervals reflect stochastic heterogeneity and were calculated by bootstrap sampling with replacement 100,000 times from within the modeled population sample.

Table 14 Lifetime Net Benefit of Aspirin for Women for Various Stopping Ages (KQ2)

% 10-yr ASCVD Risk | Stop Aspirin Age 65y | Stop Aspirin Age 70y | Stop Aspirin Age 75y | Stop Aspirin Age 80y | Stop Aspirin Age 85y
Women, Initiation Age 40-49 years, Net QALYs per 1000 persons (95% Confidence Interval)
5 | 8.5 (2.5 to 14.4) | 11.2 (4.5 to 17.9) | 10.4 (3.4 to 17.4) | 10.9 (3.5 to 18.4) | 11.1 (3.6 to 18.6)
7.5 | 12.2 (6.3 to 18.2) | 15.2 (8.8 to 21.6) | 17.8 (11.2 to 24.5) | 17.9 (10.9 to 24.9) | 18.8 (11.8 to 25.9)
10 | 20.4 (14.3 to 26.6) | 28.1 (21.2 to 35.0) | 31.2 (23.8 to 38.6) | 33.7 (26.0 to 41.3) | 34.4 (26.6 to 42.2)
15 | 28.9 (22.3 to 35.5) | 35.1 (28.2 to 42.0) | 39.6 (32.5 to 46.6) | 41.1 (33.7 to 48.4) | 42.3 (34.8 to 49.8)
20 | 34.5 (27.6 to 41.3) | 41.6 (34.2 to 49.0) | 44.4 (36.6 to 52.3) | 48.1 (40.1 to 56.1) | 49.2 (41.0 to 57.3)
Women, Initiation Age 40-49 years, Net Life Years per 1000 persons (95% Confidence Interval)
5 | −1.0 (−7.2 to 5.3) | −1.5 (−8.4 to 5.3) | −5.0 (−12.3 to 2.3) | −7.4 (−15.1 to 0.4) | −8.8 (−16.7 to −1.0)
7.5 | 2.0 (−4.1 to 8.1) | 1.6 (−5.0 to 8.2) | 1.2 (−5.7 to 8.0) | −0.7 (−7.9 to 6.4) | −1.7 (−9.0 to 5.5)
10 | 7.9 (1.4 to 14.4) | 12.6 (5.4 to 19.8) | 12.6 (4.8 to 20.4) | 12.9 (4.9 to 20.9) | 11.9 (3.7 to 20.1)
15 | 14.9 (8.0 to 21.9) | 17.2 (9.9 to 24.4) | 19.5 (12.1 to 26.9) | 18.4 (10.7 to 26.0) | 18.1 (10.3 to 25.9)
20 | 19.4 (12.2 to 26.6) | 23.2 (15.4 to 30.9) | 23.6 (15.4 to 31.9) | 24.9 (16.5 to 33.2) | 24.2 (15.7 to 32.8)
Women, Initiation Age 50-59 years, Net QALYs per 1000 persons (95% Confidence Interval)
5 | 1.0 (−3.5 to 5.6) | 0.8 (−4.8 to 6.5) | 1.3 (−4.9 to 7.5) | 2.8 (−3.8 to 9.4) | 2.2 (−4.7 to 9.1)
7.5 | 5.7 (1.3 to 10.2) | 8.3 (2.9 to 13.6) | 10.9 (5.2 to 16.7) | 10.0 (3.8 to 16.3) | 10.5 (4.0 to 17.0)
10 | 8.9 (4.0 to 13.9) | 13.7 (8.0 to 19.3) | 16.9 (10.6 to 23.2) | 17.0 (10.3 to 23.6) | 17.3 (10.4 to 24.1)
15 | 15.4 (10.8 to 20.0) | 21.3 (15.9 to 26.8) | 26.4 (20.4 to 32.4) | 28.6 (22.4 to 34.7) | 29.9 (23.6 to 36.3)
20 | 20.0 (15.0 to 25.0) | 30.6 (24.9 to 36.4) | 35.8 (29.6 to 42.1) | 39.8 (33.3 to 46.3) | 40.9 (34.1 to 47.6)
Women, Initiation Age 50-59 years, Net Life Years per 1000 persons (95% Confidence Interval)
5 | −4.9 (−9.7 to −0.1) | −8.5 (−14.5 to −2.5) | −11.9 (−18.5 to −5.3) | −14.2 (−21.2 to −7.2) | −16.6 (−23.8 to −9.5)
7.5 | −1.7 (−6.3 to 2.9) | −3.5 (−9.1 to 2.1) | −4.6 (−10.6 to 1.5) | −8.1 (−14.8 to −1.5) | −10.1 (−16.9 to −3.3)
10 | −0.3 (−5.5 to 4.9) | 1.1 (−4.8 to 7.1) | 0.6 (−6.0 to 7.2) | −2.7 (−9.6 to 4.2) | −4.9 (−12.0 to 2.2)
15 | 6.7 (1.9 to 11.5) | 7.8 (2.2 to 13.5) | 9.9 (3.7 to 16.1) | 9.2 (2.8 to 15.7) | 8.3 (1.7 to 14.9)
20 | 10.7 (5.4 to 16.0) | 16.8 (10.8 to 22.8) | 17.9 (11.4 to 24.4) | 18.4 (11.5 to 25.3) | 17.9 (10.7 to 25.0)
Women, Initiation Age 60-69 years, Net QALYs per 1000 persons (95% Confidence Interval)
5 | N/A | N/A | −4.6 (−8.3 to −0.9) | −6.1 (−10.4 to −1.8) | −8.5 (−13.2 to −3.8)
7.5 | N/A | N/A | −2.2 (−6.2 to 1.8) | −4.0 (−8.6 to 0.5) | −5.2 (−10.1 to −0.2)
10 | N/A | N/A | 1.6 (−2.4 to 5.6) | 4.8 (0.2 to 9.4) | 4.3 (−0.6 to 9.2)
15 | N/A | N/A | 6.5 (2.6 to 10.5) | 9.6 (5.3 to 13.9) | 10.9 (6.2 to 15.6)
20 | N/A | N/A | 13.7 (9.7 to 17.6) | 16.8 (12.3 to 21.3) | 18.3 (13.5 to 23.2)
Women, Initiation Age 60-69 years, Net Life Years per 1000 persons (95% Confidence Interval)
5 | N/A | N/A | −10.5 (−14.3 to −6.7) | −15.6 (−20.0 to −11.3) | −20.6 (−25.3 to −15.8)
7.5 | N/A | N/A | −9.2 (−13.5 to −5.0) | −14.7 (−19.4 to −9.9) | −17.7 (−22.9 to −12.4)
10 | N/A | N/A | −5.9 (−10.1 to −1.6) | −6.5 (−11.3 to −1.8) | −9.2 (−14.3 to −4.2)
15 | N/A | N/A | −3.0 (−7.3 to 1.2) | −4.0 (−8.6 to 0.7) | −5.7 (−10.7 to −0.7)
20 | N/A | N/A | 2.6 (−1.4 to 6.6) | 1.0 (−3.8 to 5.7) | −0.4 (−5.5 to 4.7)
Women, Initiation Age 70-79 years, Net QALYs per 1000 persons (95% Confidence Interval)
5 | N/A | N/A | N/A | N/A | −9.3 (−12.5 to −6.1)
7.5 | N/A | N/A | N/A | N/A | −3.1 (−6.4 to 0.2)
10 | N/A | N/A | N/A | N/A | −5.0 (−8.2 to −1.8)
15 | N/A | N/A | N/A | N/A | −4.8 (−8.3 to −1.3)
20 | N/A | N/A | N/A | N/A | −2.7 (−6.2 to 0.9)
Women, Initiation Age 70-79 years, Net Life Years per 1000 persons (95% Confidence Interval)
5 | N/A | N/A | N/A | N/A | −15.3 (−18.6 to −12.0)
7.5 | N/A | N/A | N/A | N/A | −9.3 (−12.6 to −6.0)
10 | N/A | N/A | N/A | N/A | −13.0 (−16.2 to −9.9)
15 | N/A | N/A | N/A | N/A | −13.2 (−16.9 to −9.6)
20 | N/A | N/A | N/A | N/A | −10.5 (−14.2 to −6.9)

Notes: ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. Confidence intervals reflect stochastic heterogeneity and were calculated by bootstrap sampling with replacement 100,000 times from within the modeled population sample.

## CQ1 What Is the 10-Year Net Benefit of Aspirin Use?

At the point of using aspirin for 10 years, the decision model predicted that aspirin will produce net harm for most population groups over this limited time horizon (Table 15). Net life years were negative for all groups considered over 10 years, and although net QALYs were positive for some groups, in no cases did net QALYs gained exceed 2 per 1,000 persons over this interval. Tables 16 and 17 show that over the first 10 years of aspirin use, although non-fatal MIs and ischemic strokes were prevented, the number of increased intracranial hemorrhage mortality exceeded that of the reduced CVD mortality and these led to the generally small or negative accumulation of net benefit over this period. It is important to note that these results describe the expected net benefits during the first 10 years of aspirin use and do not account for the full lifetime net benefits that could be expected with taking aspirin for 10 years and then stopping.

Table 15 Net Benefit of Aspirin for Men and Women After 10 Years of Use (CQ1)

| Initiation Age 40-49y | Initiation Age Age 50-59y | Initiation Age Age 60-69y | Initiation Age Age 70-79y
Men, Net QALYs per 1000 persons (95% Confidence Interval)
5% 10y ASCVD Risk | −0.6 (−1.1 to −0.0) | −1.3 (−1.9 to −0.7) | −2.1 (−2.9 to −1.4) | N/A
7.5% 10y ASCVD Risk | −0.5 (−1.1 to 0.0) | −0.6 (−1.2 to −0.0) | −1.8 (−2.6 to −1.1) | −3.4 (−4.3 to −2.6)
10% 10y ASCVD Risk | 0.5 (−0.0 to 1.0) | −0.5 (−1.2 to 0.1) | −1.6 (−2.4 to −0.8) | −2.7 (−3.6 to −1.8)
15% 10y ASCVD Risk | 0.7 (0.1 to 1.3) | 0.2 (−0.6 to 1.1) | −1.9 (−2.9 to −0.9) | −3.2 (−4.3 to −2.2)
20% 10y ASCVD Risk | 1.7 (1.0 to 2.5) | 0.9 (0.1 to 1.8) | −0.8 (−1.9 to 0.3) | −1.9 (−2.8 to −1.0)
Men, Net Life Years per 1000 persons (95% Confidence Interval)
5% 10y ASCVD Risk | −0.5 (−0.9 to −0.1) | −1.5 (−2.0 to −0.9) | −1.9 (−2.6 to −1.2) | N/A
7.5% 10y ASCVD Risk | −0.8 (−1.2 to −0.4) | −1.0 (−1.5 to −0.5) | −2.2 (−2.8 to −1.5) | −3.5 (−4.3 to −2.7)
10% 10y ASCVD Risk | −0.6 (−1.0 to −0.2) | −1.4 (−2.0 to −0.8) | −2.4 (−3.1 to −1.7) | −3.2 (−4.1 to −2.3)
15% 10y ASCVD Risk | −0.8 (−1.2 to −0.3) | −1.9 (−2.7 to −1.1) | −3.1 (−4.1 to −2.2) | −4.0 (−5.0 to −2.9)
20% 10y ASCVD Risk | −0.7 (−1.3 to −0.1) | −2.2 (−3.0 to −1.4) | −3.5 (−4.6 to −2.4) | −3.3 (−4.3 to −2.4)
Women, Net QALYs per 1000 persons (95% Confidence Interval)
5% 10y ASCVD Risk | −0.4 (−0.8 to 0.1) | −1.4 (−2.1 to −0.7) | −1.9 (−2.6 to −1.1) | −2.3 (−3.0 to −1.7)
7.5% 10y ASCVD Risk | −0.3 (−0.7 to 0.2) | −1.1 (−1.8 to −0.3) | −1.6 (−2.3 to −0.8) | −1.5 (−2.2 to −0.8)
10% 10y ASCVD Risk | 0.2 (−0.3 to 0.6) | 0.0 (−0.8 to 0.8) | −1.8 (−2.8 to −0.8) | −2.0 (−3.0 to −1.1)
15% 10y ASCVD Risk | 0.7 (0.1 to 1.2) | 1.3 (0.7 to 2.0) | −0.8 (−1.8 to 0.2) | −3.1 (−4.2 to −2.0)
20% 10y ASCVD Risk | 1.1 (0.5 to 1.6) | 1.6 (0.8 to 2.5) | 2.0 (1.0 to 2.9) | −3.1 (−4.3 to −2.0)
Women, Net Life Years per 1000 persons (95% Confidence Interval)
5% 10y ASCVD Risk | −0.6 (−0.9 to −0.2) | −1.6 (−2.2 to −1.0) | −1.7 (−2.3 to −1.1) | −2.0 (−2.6 to −1.4)
7.5% 10y ASCVD Risk | −0.5 (−0.8 to −0.2) | −2.1 (−2.8 to −1.4) | −2.3 (−3.0 to −1.6) | −1.8 (−2.3 to −1.2)
10% 10y ASCVD Risk | −0.6 (−0.9 to −0.3) | −1.8 (−2.4 to −1.1) | −3.1 (−4.0 to −2.2) | −3.0 (−3.8 to −2.2)
15% 10y ASCVD Risk | −0.5 (−0.9 to −0.2) | −0.9 (−1.5 to −0.4) | −3.8 (−4.8 to −2.9) | −4.5 (−5.6 to −3.5)
20% 10y ASCVD Risk | −0.5 (−0.9 to −0.1) | −1.3 (−2.0 to −0.6) | −2.3 (−3.1 to −1.6) | −5.0 (−6.1 to −4.0)

Notes: ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Confidence intervals reflect stochastic heterogeneity and were calculated by bootstrap sampling with replacement 100,000 times from within the modeled population sample.

Table 16 Net Events of Aspirin for Men After 10 Years of Use (CQ1)

| Benefits from aspirin; (Prevented events per 1,000 persons) | | | | | | Harms from aspirin; (Incurred events per 1,000 persons) | | | | Net Balance; (Benefits - harms)
10-yr ASCVD Risk (%) | Myocardial infarction | Ischemic stroke | Non-fatal CVD Events | CVD Deaths | CRC Cases | CRC Deaths | Major GI Bleeds | Major GI Bleed Deaths | Intracranial Hemorrhage | Intracranial Hemorrhage Deaths | Net QALYs | Net Life Years | Net Events Prevented
Men, Initiation Age 40-49 years
5 | 3.9 | 0.7 | 4.7 | 0.1 | - | - | 7.8 | 0.0 | 0.5 | 0.3 | −0.6 | −0.5 | −3.5
7.5 | 4.8 | 0.9 | 5.8 | 0.0 | - | - | 8.0 | 0.0 | 0.5 | 0.2 | −0.5 | −0.8 | −2.7
10 | 5.9 | 1.1 | 7.1 | 0.1 | - | - | 7.8 | 0.0 | 0.4 | 0.2 | 0.5 | −0.6 | −1.0
15 | 7.6 | 1.5 | 9.3 | 0.1 | - | - | 8.2 | 0.0 | 0.5 | 0.3 | 0.7 | −0.8 | 0.7
20 | 9.2 | 2.0 | 11.6 | 0.2 | - | - | 7.8 | 0.0 | 0.5 | 0.3 | 1.7 | −0.7 | 3.5
Men, Initiation Age 50-59 years
5 | 3.9 | 1.1 | 5.1 | 0.0 | - | - | 10.2 | 0.0 | 0.8 | 0.5 | −1.3 | −1.5 | −5.9
7.5 | 5.0 | 1.3 | 6.4 | 0.1 | - | - | 10.6 | 0.0 | 0.8 | 0.4 | −0.6 | −1.0 | −4.9
10 | 5.5 | 1.5 | 7.2 | 0.1 | - | - | 10.6 | 0.0 | 0.8 | 0.5 | −0.5 | −1.4 | −4.1
15 | 7.1 | 2.3 | 9.9 | 0.2 | - | - | 10.0 | 0.0 | 0.8 | 0.6 | 0.2 | −1.9 | −0.7
20 | 9.4 | 2.9 | 13.1 | 0.3 | - | - | 9.8 | 0.0 | 0.8 | 0.7 | 0.9 | −2.2 | 2.8
Men, Initiation Age 60-69 years
5 | 3.0 | 1.1 | 4.2 | 0.0 | - | - | 13.3 | 0.0 | 0.8 | 0.5 | −2.1 | −1.9 | −9.9
7.5 | 3.8 | 1.5 | 5.5 | 0.1 | - | - | 13.3 | 0.0 | 1.0 | 0.7 | −1.8 | −2.2 | −8.7
10 | 4.9 | 1.9 | 7.2 | 0.2 | - | - | 13.0 | 0.0 | 1.2 | 0.8 | −1.6 | −2.4 | −6.8
15 | 5.7 | 2.3 | 8.5 | 0.3 | - | - | 14.3 | 0.0 | 1.3 | 1.0 | −1.9 | −3.1 | −6.8
20 | 7.5 | 3.2 | 11.5 | 0.4 | - | - | 14.3 | 0.0 | 1.4 | 1.1 | −0.8 | −3.5 | −3.8
Men, Initiation Age 70-79 years
5 | - | - | - | - | - | - | - | - | - | - | - | -
7.5 | 3.8 | 1.7 | 5.7 | 0.2 | - | - | 17.9 | 0.0 | 1.5 | 1.1 | −3.4 | −3.5 | −13.5
10 | 4.1 | 2.2 | 6.6 | 0.2 | - | - | 17.5 | 0.0 | 1.3 | 1.1 | −2.7 | −3.2 | −12.0
15 | 4.8 | 2.5 | 7.7 | 0.3 | - | - | 17.2 | 0.0 | 1.6 | 1.2 | −3.2 | −4.0 | −10.8
20 | 5.7 | 2.8 | 9.1 | 0.3 | - | - | 17.0 | 0.0 | 1.6 | 1.2 | −1.9 | −3.3 | −9.2

Notes: ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; CRC=colorectal cancer; GI=gastrointestinal; QALY=quality-adjusted life year. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption; all else is held equal. MI and ischemic stroke events are non-fatal. The non-fatal CVD event column combines non-fatal MIs, ischemic strokes, and congestive heart failure (as a major sequela to MI). Net events prevented are defined by the net of benefit and harm events, or: (Non-fatal CVD events + CVD deaths + CRC cases) – (Major GI bleeds + intracranial hemorrhage). In the base case, there was no effect of aspirin use on CRC incidence.

Table 17 Net Events of Aspirin for Women After 10 Years of Use (CQ1)

| Benefits from aspirin; (Prevented events per 1,000 persons) | | | | | | Harms from aspirin; (Incurred events per 1,000 persons) | | | | Net Balance; (Benefits - harms)
10-yr ASCVD Risk (%) | Myocardial infarction | Ischemic stroke | Non-fatal CVD Events | CVD Deaths | CRC Cases | CRC Deaths | Major GI Bleeds | Major GI Bleed Deaths | Intracranial Hemorrhage | Intracranial Hemorrhage Deaths | Net QALYs | Net Life Years | Net Events Prevented
Women, Initiation Age 40-49 years
5 | 2.0 | 1.0 | 3.1 | 0.0 | - | - | 6.5 | 0.0 | 0.5 | 0.2 | −0.4 | −0.6 | −3.9
7.5 | 2.6 | 1.0 | 3.6 | 0.0 | - | - | 6.8 | 0.0 | 0.5 | 0.2 | −0.3 | −0.5 | −3.7
10 | 2.9 | 1.3 | 4.4 | 0.0 | - | - | 6.5 | 0.0 | 0.4 | 0.2 | 0.2 | −0.6 | −2.5
15 | 3.2 | 1.7 | 5.1 | 0.1 | - | - | 6.2 | 0.0 | 0.4 | 0.2 | 0.7 | −0.5 | −1.4
20 | 3.3 | 2.0 | 5.4 | 0.0 | - | - | 6.5 | 0.0 | 0.3 | 0.2 | 1.1 | −0.5 | −1.4
Women, Initiation Age 50-59 years
5 | 2.4 | 1.5 | 3.9 | 0.0 | - | - | 9.2 | 0.0 | 0.9 | 0.5 | −1.4 | −1.6 | −6.2
7.5 | 2.8 | 2.3 | 5.3 | 0.1 | - | - | 9.4 | 0.0 | 1.0 | 0.6 | −1.1 | −2.1 | −5.0
10 | 3.2 | 2.8 | 6.3 | 0.1 | - | - | 9.0 | 0.0 | 1.1 | 0.6 | 0.0 | −1.8 | −3.7
15 | 4.2 | 3.3 | 8.0 | 0.2 | - | - | 9.0 | 0.0 | 0.9 | 0.5 | 1.3 | −0.9 | −1.7
20 | 4.5 | 3.5 | 8.6 | 0.2 | - | - | 8.9 | 0.0 | 0.8 | 0.6 | 1.6 | −1.3 | −0.9
Women, Initiation Age 60-69 years
5 | 1.9 | 1.8 | 3.8 | 0.1 | - | - | 11.7 | 0.0 | 1.1 | 0.6 | −1.9 | −1.7 | −8.9
7.5 | 2.6 | 2.6 | 5.3 | 0.1 | - | - | 12.3 | 0.0 | 1.3 | 0.8 | −1.6 | −2.3 | −8.2
10 | 2.6 | 2.8 | 5.8 | 0.2 | - | - | 12.5 | 0.0 | 1.4 | 1.0 | −1.8 | −3.1 | −7.9
15 | 3.1 | 4.0 | 7.6 | 0.2 | - | - | 12.0 | 0.0 | 1.4 | 1.0 | −0.8 | −3.8 | −5.6
20 | 4.0 | 5.3 | 10.0 | 0.4 | - | - | 12.1 | 0.0 | 1.3 | 0.9 | 2.0 | −2.3 | −3.0
Women, Initiation Age 70-79 years
5 | 1.5 | 1.9 | 3.4 | 0.0 | - | - | 15.6 | 0.0 | 1.2 | 0.7 | −2.3 | −2.0 | −13.4
7.5 | 1.8 | 2.4 | 4.3 | 0.1 | - | - | 15.3 | 0.0 | 1.1 | 0.7 | −1.5 | −1.8 | −12.0
10 | 2.0 | 2.7 | 4.8 | 0.1 | - | - | 14.9 | 0.0 | 1.3 | 0.9 | −2.0 | −3.0 | −11.3
15 | 2.4 | 3.6 | 6.2 | 0.2 | - | - | 14.4 | 0.0 | 1.8 | 1.2 | −3.1 | −4.5 | −9.8
20 | 2.8 | 3.7 | 7.0 | 0.2 | - | - | 14.6 | 0.0 | 2.0 | 1.4 | −3.1 | −5.0 | −9.4

Notes: ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; CRC=colorectal cancer; GI=gastrointestinal; QALY=quality-adjusted life year. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption; all else is held equal. MI and ischemic stroke events are non-fatal. The non-fatal CVD event column combines non-fatal MIs, ischemic strokes, and congestive heart failure (as a major sequela to MI). Net events prevented are defined by the net of benefit and harm events, or: (Non-fatal CVD events + CVD deaths + CRC cases) – (Major GI bleeds + intracranial hemorrhage). In the base case, there was no effect of aspirin use on CRC incidence.

## Summary Findings

Tables 18a–18d combine the estimates of net QALYs and life years across both time horizons and stopping scenarios, reflecting the results for KQ1, KQ2, and CQ1 together. These side-by-side results show that for KQ2, stopping aspirin at some point compared to lifetime use generally results in lower net benefit in terms of lifetime net QALYs and life years. There are some exceptions, such as women aged 50-59 years with 20% 10-year ASCVD risk, where the lifetime net life years were 17.9 per 1,000 persons when stopping aspirin at age 85 years versus 16.9 per 1,000 persons with lifetime aspirin use. However, as in this case, the margins were typically small in both absolute and relative scales. Another exception is when net benefits were negative for lifetime use (such as −18.7 net life years per 1000 women aged 50-59 years with 5% 10-year ASCVD risk when starting aspirin), but less negative if stopped sooner (such as −4.9 net life years for the same group of women who instead stopped aspirin at age 65 years). In these cases, initiating aspirin was typically found to produce negative net benefit no matter the duration of use.

Table 18a Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (KQ1, KQ2, CQ1), Initiation Age 40-49y

| 10y use^*^ | Stop at age 65y | Stop at age 70y | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −0.6 | 13.1 | 18.8 | 20.9 | 22.2 | 23.6 | 23.1
7.5% 10y ASCVD Risk | −0.5 | 17.4 | 22.1 | 25.0 | 27.4 | 28.7 | 29.1
10% 10y ASCVD Risk | 0.5 | 35.1 | 40.3 | 43.6 | 46.2 | 47.1 | 48.0
15% 10y ASCVD Risk | 0.7 | 40.8 | 46.2 | 49.8 | 50.5 | 52.1 | 52.3
20% 10y ASCVD Risk | 1.7 | 50.2 | 56.4 | 61.3 | 64.4 | 65.5 | 66.2
Men, Net Life Years per 1000 persons
5% 10y ASCVD Risk | −0.5 | 7.5 | 11.7 | 11.7 | 11.3 | 11.6 | 10.6
7.5% 10y ASCVD Risk | −0.8 | 10.0 | 13.3 | 14.8 | 15.9 | 16.4 | 16.2
10% 10y ASCVD Risk | −0.6 | 28.8 | 32.2 | 34.3 | 35.7 | 35.7 | 36.1
15% 10y ASCVD Risk | −0.8 | 32.4 | 36.2 | 38.0 | 37.2 | 38.3 | 37.9
20% 10y ASCVD Risk | −0.7 | 42.3 | 45.8 | 49.4 | 51.8 | 52.1 | 52.4
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −0.4 | 8.5 | 11.2 | 10.4 | 10.9 | 11.1 | 11.1
7.5% 10y ASCVD Risk | −0.3 | 12.2 | 15.2 | 17.8 | 17.9 | 18.8 | 19.6
10% 10y ASCVD Risk | 0.2 | 20.4 | 28.1 | 31.2 | 33.7 | 34.4 | 35.1
15% 10y ASCVD Risk | 0.7 | 28.9 | 35.1 | 39.6 | 41.1 | 42.3 | 43.0
20% 10y ASCVD Risk | 1.1 | 34.5 | 41.6 | 44.4 | 48.1 | 49.2 | 50.4
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | −0.6 | −1.0 | −1.5 | −5.0 | −7.4 | −8.8 | −10.6
7.5% 10y ASCVD Risk | −0.5 | 2.0 | 1.6 | 1.2 | −0.7 | −1.7 | −2.6
10% 10y ASCVD Risk | −0.6 | 7.9 | 12.6 | 12.6 | 12.9 | 11.9 | 11.4
15% 10y ASCVD Risk | −0.5 | 14.9 | 17.2 | 19.5 | 18.4 | 18.1 | 17.7
20% 10y ASCVD Risk | −0.5 | 19.4 | 23.2 | 23.6 | 24.9 | 24.2 | 24.2

Notes: ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 18b Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (KQ1, KQ2, CQ1), Initiation Age 50-59y

| 10y use^*^ | Stop at age 65y | Stop at age 70y | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −1.3 | 2.0 | 2.9 | 4.0 | 4.7 | 5.7 | 5.7
7.5% 10y ASCVD Risk | −0.6 | 5.5 | 9.2 | 10.7 | 11.6 | 12.1 | 12.5
10% 10y ASCVD Risk | −0.5 | 9.1 | 12.3 | 15.2 | 16.2 | 17.6 | 18.0
15% 10y ASCVD Risk | 0.2 | 17.2 | 24.5 | 28.7 | 31.0 | 31.7 | 32.3
20% 10y ASCVD Risk | 0.9 | 26.1 | 35.4 | 41.5 | 45.4 | 47.2 | 48.4
Men, Net Life Years per 1000 persons
5% 10y ASCVD Risk | −1.5 | −2.1 | −2.5 | −3.0 | −4.0 | −4.3 | −5.4
7.5% 10y ASCVD Risk | −1.0 | 2.4 | 3.5 | 2.7 | 1.7 | 0.6 | 0.4
10% 10y ASCVD Risk | −1.4 | 4.8 | 5.8 | 6.0 | 4.4 | 4.6 | 4.2
15% 10y ASCVD Risk | −1.9 | 11.8 | 16.5 | 18.2 | 19.1 | 18.5 | 18.6
20% 10y ASCVD Risk | −2.2 | 20.2 | 26.6 | 30.2 | 32.6 | 33.4 | 33.9
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −1.4 | 1.0 | 0.8 | 1.3 | 2.8 | 2.2 | 1.9
7.5% 10y ASCVD Risk | −1.1 | 5.7 | 8.3 | 10.9 | 10.0 | 10.5 | 10.4
10% 10y ASCVD Risk | 0.0 | 8.9 | 13.7 | 16.9 | 17.0 | 17.3 | 17.1
15% 10y ASCVD Risk | 1.3 | 15.4 | 21.3 | 26.4 | 28.6 | 29.9 | 30.8
20% 10y ASCVD Risk | 1.6 | 20.0 | 30.6 | 35.8 | 39.8 | 40.9 | 41.6
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | −1.6 | −4.9 | −8.5 | −11.9 | −14.2 | −16.6 | −18.7
7.5% 10y ASCVD Risk | −2.1 | −1.7 | −3.5 | −4.6 | −8.1 | −10.1 | −11.8
10% 10y ASCVD Risk | −1.8 | −0.3 | 1.1 | 0.6 | −2.7 | −4.9 | −6.5
15% 10y ASCVD Risk | −0.9 | 6.7 | 7.8 | 9.9 | 9.2 | 8.3 | 7.5
20% 10y ASCVD Risk | −1.3 | 10.7 | 16.8 | 17.9 | 18.4 | 17.9 | 16.9

Notes: ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 18c Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (KQ1, KQ2, CQ1), Initiation Age 60-69y

| 10y use^*^ | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −2.1 | −2.3 | −3.8 | −1.7 | −1.8
7.5% 10y ASCVD Risk | −1.8 | −0.4 | 1.6 | 2.0 | 2.6
10% 10y ASCVD Risk | −1.6 | 3.7 | 6.5 | 7.2 | 7.0
15% 10y ASCVD Risk | −1.9 | 5.5 | 7.3 | 8.3 | 8.3
20% 10y ASCVD Risk | −0.8 | 12.5 | 14.3 | 15.2 | 16.3
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −1.9 | −6.7 | −10.1 | −9.8 | −11.0
7.5% 10y ASCVD Risk | −2.2 | −5.5 | −5.3 | −6.4 | −6.7
10% 10y ASCVD Risk | −2.4 | −2.1 | −1.3 | −2.0 | −3.0
15% 10y ASCVD Risk | −3.1 | −0.6 | −0.9 | −1.3 | −2.2
20% 10y ASCVD Risk | −3.5 | 5.8 | 5.3 | 4.9 | 4.9
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −1.9 | −4.6 | −6.1 | −8.5 | −9.5
7.5% 10y ASCVD Risk | −1.6 | −2.2 | −4.0 | −5.2 | −5.8
10% 10y ASCVD Risk | −1.8 | 1.6 | 4.8 | 4.3 | 2.3
15% 10y ASCVD Risk | −0.8 | 6.5 | 9.6 | 10.9 | 11.6
20% 10y ASCVD Risk | 2.0 | 13.7 | 16.8 | 18.3 | 19.1
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | −1.7 | −10.5 | −15.6 | −20.6 | −23.5
7.5% 10y ASCVD Risk | −2.3 | −9.2 | −14.7 | −17.7 | −20.2
10% 10y ASCVD Risk | −3.1 | −5.9 | −6.5 | −9.2 | −13.5
15% 10y ASCVD Risk | −3.8 | −3.0 | −4.0 | −5.7 | −7.2
20% 10y ASCVD Risk | −2.3 | 2.6 | 1.0 | −0.4 | −1.6

Notes: ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 18d Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (KQ1, KQ2, CQ1), Initiation Age 70-79y

| 10y use^*^ | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | N/A | N/A | N/A
7.5% 10y ASCVD Risk | −3.4 | −5.7 | −4.6
10% 10y ASCVD Risk | −2.7 | −1.8 | −1.1
15% 10y ASCVD Risk | −3.2 | −1.8 | −1.9
20% 10y ASCVD Risk | −1.9 | 1.3 | 0.9
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | N/A | N/A | N/A
7.5% 10y ASCVD Risk | −3.5 | −9.5 | −10.1
10% 10y ASCVD Risk | −3.2 | −6.2 | −6.9
15% 10y ASCVD Risk | −4.0 | −6.3 | −7.6
20% 10y ASCVD Risk | −3.3 | −3.8 | −5.5
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −2.3 | −9.3 | −11.7
7.5% 10y ASCVD Risk | −1.5 | −3.1 | −6.4
10% 10y ASCVD Risk | −2.0 | −5.0 | −6.1
15% 10y ASCVD Risk | −3.1 | −4.8 | −6.9
20% 10y ASCVD Risk | −3.1 | −2.7 | −4.4
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | −2.0 | −15.3 | −20.6
7.5% 10y ASCVD Risk | −1.8 | −9.3 | −15.4
10% 10y ASCVD Risk | −3.0 | −13.0 | −16.6
15% 10y ASCVD Risk | −4.5 | −13.2 | −17.9
20% 10y ASCVD Risk | −5.0 | −10.5 | −14.8

Notes: ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Tables 19a–19d present a qualitative summary of the decision analytic criteria. Ignoring the magnitude and uncertainty of the base case estimates, predicted lifetime net QALYs were positive for all risk groups considered among men and women initiating aspirin at ages 40-59 years and for all groups with ≥10% 10-year ASCVD risk among men and women aged 60-69 years. Lifetime net life years were likewise positive for most risk groups among men aged 40-59 years, but this was only the case at higher risk thresholds (≥7.5% to ≥15% 10-year ASCVD risk) for women at these ages. For men and women aged 60-69 years, lifetime net QALYs were positive for persons with ≥10% 10-year ASCVD risk, but lifetime net life years were negative for most risk groups at this age. For men and women initiating aspirin at ages 70-79 years, lifetime net QALYs and life years were negative for nearly all scenarios considered.

Table 19a Decision Analytic Summary of Aspirin Use Scenarios (KQ1, KQ2, CQ1), Initiation Age 40-49y

| 10y use^*^ | Stop at age 65y | Stop at age 70y | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | – | + | + | + | + | + | +
7.5% 10y ASCVD Risk | – | + | + | + | + | + | +
10% 10y ASCVD Risk | + | + | + | + | + | + | +
15% 10y ASCVD Risk | + | + | + | + | + | + | +
20% 10y ASCVD Risk | + | + | + | + | + | + | +
Men, Net Life Years per 1000 persons
5% 10y ASCVD Risk | – | + | + | + | + | + | +
7.5% 10y ASCVD Risk | – | + | + | + | + | + | +
10% 10y ASCVD Risk | – | + | + | + | + | + | +
15% 10y ASCVD Risk | – | + | + | + | + | + | +
20% 10y ASCVD Risk | – | + | + | + | + | + | +
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | – | + | + | + | + | + | +
7.5% 10y ASCVD Risk | – | + | + | + | + | + | +
10% 10y ASCVD Risk | + | + | + | + | + | + | +
15% 10y ASCVD Risk | + | + | + | + | + | + | +
20% 10y ASCVD Risk | + | + | + | + | + | + | +
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | – | – | – | – | – | – | –
7.5% 10y ASCVD Risk | – | + | + | + | – | – | –
10% 10y ASCVD Risk | – | + | + | + | + | + | +
15% 10y ASCVD Risk | – | + | + | + | + | + | +
20% 10y ASCVD Risk | – | + | + | + | + | + | +

Notes: ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Cells with a “+” sign indicate net benefit was found to be positive in Table 18a, favoring aspirin use. Cells with a “–” sign indicate net benefit was found to be negative in Table 18a, favoring aspirin nonuse.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 19b Decision Analytic Summary of Aspirin Use Scenarios (KQ1, KQ2, CQ1), Initiation Age 50-59y

| 10y use^*^ | Stop at age 65y | Stop at age 70y | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | − | + | + | + | + | + | +
7.5% 10y ASCVD Risk | − | + | + | + | + | + | +
10% 10y ASCVD Risk | − | + | + | + | + | + | +
15% 10y ASCVD Risk | + | + | + | + | + | + | +
20% 10y ASCVD Risk | + | + | + | + | + | + | +
Men, Net Life Years per 1000 persons
5% 10y ASCVD Risk | − | − | − | − | − | − | −
7.5% 10y ASCVD Risk | − | + | + | + | + | + | +
10% 10y ASCVD Risk | − | + | + | + | + | + | +
15% 10y ASCVD Risk | − | + | + | + | + | + | +
20% 10y ASCVD Risk | − | + | + | + | + | + | +
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | − | + | + | + | + | + | +
7.5% 10y ASCVD Risk | − | + | + | + | + | + | +
10% 10y ASCVD Risk | + | + | + | + | + | + | +
15% 10y ASCVD Risk | + | + | + | + | + | + | +
20% 10y ASCVD Risk | + | + | + | + | + | + | +
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | − | − | − | − | − | − | −
7.5% 10y ASCVD Risk | − | − | − | − | − | − | −
10% 10y ASCVD Risk | − | − | + | + | − | − | −
15% 10y ASCVD Risk | − | + | + | + | + | + | +
20% 10y ASCVD Risk | − | + | + | + | + | + | +

Notes: ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Cells with a “+” sign indicate net benefit was found to be positive in Table 18b, favoring aspirin use. Cells with a “–” sign indicate net benefit was found to be negative in Table 18b, favoring aspirin nonuse.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 19c Decision Analytic Summary of Aspirin Use Scenarios (KQ1, KQ2, CQ1), Initiation Age 60-69y

| 10y use^*^ | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | − | − | − | − | −
7.5% 10y ASCVD Risk | − | − | + | + | +
10% 10y ASCVD Risk | − | + | + | + | +
15% 10y ASCVD Risk | − | + | + | + | +
20% 10y ASCVD Risk | − | + | + | + | +
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | − | − | − | − | −
7.5% 10y ASCVD Risk | − | − | − | − | −
10% 10y ASCVD Risk | − | − | − | − | −
15% 10y ASCVD Risk | − | − | − | − | −
20% 10y ASCVD Risk | − | + | + | + | +
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | − | − | − | − | −
7.5% 10y ASCVD Risk | − | − | − | − | −
10% 10y ASCVD Risk | − | + | + | + | +
15% 10y ASCVD Risk | − | + | + | + | +
20% 10y ASCVD Risk | + | + | + | + | +
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | − | − | − | − | −
7.5% 10y ASCVD Risk | − | − | − | − | −
10% 10y ASCVD Risk | − | − | − | − | −
15% 10y ASCVD Risk | − | − | − | − | −
20% 10y ASCVD Risk | − | + | + | − | −

Notes: ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Cells with a “+” sign indicate net benefit was found to be positive in Table 18c, favoring aspirin use. Cells with a “–” sign indicate net benefit was found to be negative in Table 18c, favoring aspirin nonuse.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 19d Decision Analytic Summary of Aspirin Use Scenarios (KQ1, KQ2, CQ1), Initiation Age 70-79y

| 10y use^*^ | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | N/A | N/A | N/A
7.5% 10y ASCVD Risk | − | − | −
10% 10y ASCVD Risk | − | − | −
15% 10y ASCVD Risk | − | − | −
20% 10y ASCVD Risk | − | + | +
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | N/A | N/A | N/A
7.5% 10y ASCVD Risk | − | − | −
10% 10y ASCVD Risk | − | − | −
15% 10y ASCVD Risk | − | − | −
20% 10y ASCVD Risk | − | − | −
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | − | − | −
7.5% 10y ASCVD Risk | − | − | −
10% 10y ASCVD Risk | − | − | −
15% 10y ASCVD Risk | − | − | −
20% 10y ASCVD Risk | − | − | −
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | − | − | −
7.5% 10y ASCVD Risk | − | − | −
10% 10y ASCVD Risk | − | − | −
15% 10y ASCVD Risk | − | − | −
20% 10y ASCVD Risk | − | − | −

Notes: ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Cells with a “+” sign indicate net benefit was found to be positive in Table 18d, favoring aspirin use. Cells with a “–” sign indicate net benefit was found to be negative in Table 18d, favoring aspirin nonuse.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

## Sensitivity Analyses

Tables 20–24 show sensitivity analysis findings for lifetime use of aspirin across 19 scenarios for each age, sex, and 10-year ASCVD risk group in terms of lifetime net QALYs and life years. Although magnitudes vary, the proportional differences across sensitivity scenarios were generally similar across the 10-year ASCVD risk groups shown separately in each table. The largest and most notable impact on net benefit resulted from assumptions on whether aspirin when used for primary prevention reduces risk of CRC incidence (Scenario 3), reduces risk of CVD mortality (Scenario 4), or increases the risk of fatal major GI bleeds (Scenario 7). For example, for persons with 10% 10-year ASCVD risk, the inclusion of a 34% reduction in CRC incidence risk increased lifetime net QALYs and life years by as much as 67.6 and 68.1 per 1000 persons (among women aged 40-49 years), respectively. The inclusion of a 5 percent reduction in CVD mortality risk increased lifetime net QALYs and life years by as much as 77.6 and 92.7 per 1,000 persons, respectively (again, with the largest change among women aged 40-49 years). Conversely, when it was assumed that aspirin increases fatal major GI bleeding at the same rate as non-fatal major GI bleeds, lifetime net QALYs and life years decreased by as much as 23.4 and 27.3, respectively, per 1,000 persons (among men aged 50-59 years). Also notable is that assuming even a very small (about 0.1%) reduction in health utility as a result of taking aspirin daily lifetime can reduce lifetime net QALYs by as much as 24.1 per 1,000 persons (among women aged 40-49 years with 5% 10-year ASCVD risk).

Table 20 Sensitivity Analysis Results for Persons With 5% ASCVD Baseline Risk (Lifetime Aspirin Use, Lifetime Follow-Up)

| Age 40-49y | | | | Age 50-59y | | | | Age 60-69y | | | | Age 70-79y
| Men | | Women | | Men | | Women | | Men | | Women | | Men | | Women
Scenario | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY
(0) Base Case | 23.1 | 10.6 | 11.1 | −10.6 | 5.7 | −5.4 | 1.9 | −18.7 | −1.8 | −11.0 | −9.5 | −23.5 | - | - | −11.7 | −20.6
(1) ASA Disutility = 0.001 | 2.3 | 10.6 | −13.0 | −10.6 | −11.9 | −5.4 | −17.0 | −18.7 | −16.7 | −11.0 | −25.5 | −23.5 | - | - | −24.8 | −20.6
(2) ASA Disutility = 0.005 | −80.9 | 10.6 | −109.4 | −10.6 | −82.2 | −5.4 | −92.5 | −18.7 | −76.7 | −11.0 | −89.5 | −23.5 | - | - | −77.2 | −20.6
(3) CRC RR = 0.64 | 82.9 | 69.7 | 69.8 | 47.5 | 58.8 | 45.9 | 53.1 | 31.0 | 50.0 | 38.8 | 33.8 | 18.0 | - | - | 21.1 | 9.2
(4) CVD Death RR = 0.95 | 100.4 | 101.9 | 79.5 | 70.9 | 77.1 | 78.8 | 67.0 | 59.1 | 51.3 | 51.6 | 40.2 | 35.5 | - | - | 23.1 | 20.4
(5) CVD Incidence Rates ↑10% | 24.9 | 11.4 | 14.2 | −9.0 | 11.1 | −1.2 | 2.4 | −17.5 | −1.0 | −10.8 | −7.4 | −22.0 | - | - | −9.4 | −18.7
(6) CVD Incidence Rates ↓10% | 18.8 | 5.4 | 11.9 | −9.5 | 3.1 | −7.5 | −1.4 | −19.4 | −2.1 | −9.7 | −10.4 | −23.0 | - | - | −13.6 | −20.0
(7) Fatal GIB RR = 1.58 | 2.1 | −13.9 | −10.4 | −35.6 | −16.3 | −30.9 | −19.4 | −43.5 | −26.7 | −39.9 | −28.3 | −45.4 | - | - | −26.8 | −38.2
(8) Fatal GIB Incidence Rate - High | 22.7 | 10.2 | 10.9 | −10.7 | 5.6 | −5.4 | 1.8 | −18.7 | −1.8 | −11.1 | −9.6 | −23.6 | - | - | −11.5 | −20.4
(9) Fatal GIB Incidence Rate - Low | 23.2 | 10.6 | 11.3 | −10.5 | 5.8 | −5.3 | 2.0 | −18.6 | −1.7 | −11.0 | −9.5 | −23.6 | - | - | −11.7 | −20.7
(10) Non-fatal GIB Incidence Rate - High | 22.7 | 11.1 | 9.9 | −10.8 | 4.6 | −5.6 | 0.9 | −18.5 | −3.1 | −11.1 | −10.5 | −23.3 | - | - | −12.6 | −19.9
(11) Non-fatal GIB Incidence Rate - Low | 23.2 | 10.0 | 11.8 | −10.7 | 6.6 | −5.4 | 2.3 | −19.1 | −1.0 | −11.0 | −8.7 | −23.8 | - | - | −10.7 | −20.7
(12) Non-fatal GIB RR = 1.38 | 24.0 | 10.5 | 12.2 | −10.6 | 6.8 | −5.3 | 2.9 | −18.6 | −0.8 | −11.0 | −8.6 | −23.6 | - | - | −10.8 | −20.7
(13) Non-fatal GIB RR = 1.80 | 22.0 | 10.7 | 9.8 | −10.7 | 4.3 | −5.7 | 0.7 | −18.8 | −3.0 | −11.2 | −10.2 | −23.3 | - | - | −12.4 | −20.3
(14) ICH RR = 1.11 | 45.5 | 34.7 | 40.2 | 20.3 | 29.5 | 10.6 | 29.5 | 10.6 | 17.8 | 10.1 | 12.4 | −0.6 | - | - | 4.4 | −4.0
(15) ICH RR = 1.54 | −0.7 | −15.0 | −22.5 | −45.3 | −21.7 | −35.0 | −29.9 | −52.7 | −20.8 | −31.5 | −35.7 | −50.8 | - | - | −28.2 | −37.7
(16) IS RR = 0.78 | 44.1 | 20.4 | 44.2 | 2.6 | 22.2 | 1.5 | 26.8 | −9.5 | 9.3 | −6.9 | 8.4 | −17.2 | - | - | −2.0 | −18.0
(17) IS RR = 1.00 | −0.2 | 0.4 | −24.1 | −23.9 | −13.2 | −13.7 | −29.4 | −30.4 | −16.6 | −16.7 | −29.9 | −29.6 | - | - | −24.2 | −23.5
(18) MI RR = 0.80 | 49.1 | 36.8 | 28.1 | 6.3 | 21.5 | 10.2 | 12.3 | −8.6 | 7.5 | −2.3 | −4.0 | −18.5 | - | - | −9.5 | −18.9
(19) MI RR = 0.96 | −4.6 | −17.9 | −5.4 | −26.8 | −9.1 | −19.9 | −7.6 | −27.6 | −11.3 | −20.2 | −14.5 | −28.0 | - | - | −14.2 | −22.7
(20) QOL Weight for Benefits ↑10% | 16.1 | 10.6 | 1.6 | −10.6 | 5.7 | −5.4 | −6.6 | −18.7 | −1.8 | −11.0 | −15.4 | −23.5 | - | - | −15.6 | −20.6
(21) QOL Weight for Benefits ↓10% | 47.5 | 10.6 | 31.9 | −10.6 | −11.9 | −5.4 | 18.1 | −18.7 | −16.7 | −11.0 | 0.9 | −23.5 | - | - | −5.1 | −20.6
(22) QOL Weight for Harms ↑10% | 26.1 | 10.6 | 14.3 | −10.6 | −82.2 | −5.4 | 5.0 | −18.7 | −76.7 | −11.0 | −6.4 | −23.5 | - | - | −8.9 | −20.6
(23) QOL Weight for Harms ↓10% | 20.3 | 10.6 | 8.0 | −10.6 | 58.8 | 45.9 | −1.0 | −18.7 | 50.0 | 38.8 | −12.4 | −23.5 | - | - | −14.3 | −20.6

Notes: y=years; ASCVD=atherosclerotic cardiovascular disease; ASA=acetylsalicylic acid (aspirin); CRC=colorectal cancer; RR=relative risk; CVD=cardiovascular disease; GIB=major gastrointestinal bleeding; ICH=intracranial hemorrhage; IS=ischemic stroke; MI=myocardial infarction; QALY=net quality-adjusted life years; LY=net life years; QOL=quality-of-life (health utility). Each numbered item represents a one-way sensitivity analysis with the parameter changed as described. Sensitivity ranges are described in Tables 2, 3, and 4.

Table 21 Sensitivity Analysis Results for Persons With 7.5% ASCVD Baseline Risk (Lifetime Aspirin Use, Lifetime Follow-Up)

| Age 40-49y | | | | Age 50-59y | | | | Age 60-69y | | | | Age 70-79y
| Men | | Women | | Men | | Women | | Men | | Women | | Men | | Women
Scenario | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY
(0) Base Case | 29.1 | 16.2 | 19.6 | −2.6 | 12.5 | 0.4 | 10.4 | −11.8 | 2.6 | −6.7 | −5.8 | −20.2 | −4.6 | −10.1 | −6.4 | −15.4
(1) ASA Disutility = 0.001 | 9.4 | 16.2 | −3.9 | −2.6 | −3.9 | 0.4 | −7.6 | −11.8 | −11.5 | −6.7 | −20.7 | −20.2 | −14.9 | −10.1 | −19.0 | −15.4
(2) ASA Disutility = 0.005 | −69.5 | 16.2 | −97.8 | −2.6 | −69.4 | 0.4 | −79.4 | −11.8 | −67.8 | −6.7 | −80.2 | −20.2 | −55.9 | −10.1 | −69.5 | −15.4
(3) CRC RR = 0.64 | 95.4 | 82.3 | 84.7 | 61.9 | 68.7 | 55.6 | 67.9 | 45.3 | 51.0 | 38.9 | 34.1 | 17.3 | 47.6 | 41.2 | 28.4 | 16.9
(4) CVD Death RR = 0.95 | 108.1 | 109.8 | 91.3 | 83.2 | 82.6 | 83.3 | 73.4 | 63.7 | 60.6 | 61.8 | 41.9 | 36.7 | 34.0 | 35.8 | 33.0 | 31.3
(5) CVD Incidence Rates ↑10% | 38.6 | 26.9 | 31.4 | 9.3 | 15.1 | 2.4 | 18.7 | −4.3 | 6.9 | −3.6 | −4.7 | −20.8 | −2.6 | −8.9 | −9.2 | −19.1
(6) CVD Incidence Rates ↓10% | 29.5 | 16.9 | 18.8 | −4.4 | 12.2 | 0.0 | 3.7 | −15.7 | −0.9 | −9.3 | −4.7 | −19.1 | −4.1 | −9.4 | −8.3 | −16.0
(7) Fatal GIB RR = 1.58 | 9.8 | −6.2 | 1.5 | −24.1 | −10.2 | −26.2 | −6.2 | −31.1 | −19.2 | −32.1 | −21.8 | −38.9 | −18.3 | −25.9 | −23.5 | −35.4
(8) Fatal GIB Incidence Rate - High | 29.0 | 16.1 | 19.7 | −2.5 | 12.5 | 0.4 | 10.1 | −12.1 | 2.6 | −6.7 | −5.9 | −20.3 | −4.6 | −10.0 | −6.5 | −15.4
(9) Fatal GIB Incidence Rate - Low | 29.2 | 16.2 | 19.7 | −2.6 | 12.4 | 0.3 | 10.6 | −11.7 | 2.6 | −6.7 | −5.7 | −20.2 | −4.5 | −10.0 | −6.4 | −15.5
(10) Non-fatal GIB Incidence Rate - High | 28.5 | 16.3 | 18.8 | −2.5 | 11.6 | 0.6 | 9.6 | −11.3 | 1.5 | −6.7 | −6.4 | −19.6 | −5.9 | −9.9 | −7.1 | −14.8
(11) Non-fatal GIB Incidence Rate - Low | 29.6 | 15.9 | 21.0 | −2.2 | 13.2 | 0.4 | 11.4 | −11.6 | 3.3 | −6.8 | −5.1 | −20.4 | −3.4 | −9.8 | −5.6 | −15.6
(12) Non-fatal GIB RR = 1.38 | 30.0 | 16.0 | 21.2 | −2.1 | 13.7 | 0.7 | 11.7 | −11.4 | 3.5 | −6.8 | −5.0 | −20.3 | −3.5 | −9.8 | −5.5 | −15.3
(13) Non-fatal GIB RR = 1.80 | 28.2 | 16.2 | 18.6 | −2.7 | 11.4 | 0.4 | 9.4 | −11.7 | 1.7 | −6.6 | −6.6 | −20.1 | −5.6 | −10.2 | −7.3 | −15.4
(14) ICH RR = 1.11 | 50.8 | 39.8 | 45.7 | 24.7 | 35.5 | 15.4 | 35.5 | 15.4 | 19.2 | 11.3 | 18.0 | 4.8 | 6.2 | 1.4 | 8.9 | 0.3
(15) ICH RR = 1.54 | 3.9 | −10.8 | −11.8 | −36.2 | −10.1 | −24.3 | −15.3 | −39.1 | −16.6 | −27.4 | −28.2 | −43.5 | −15.8 | −22.2 | −26.5 | −36.5
(16) IS RR = 0.78 | 49.9 | 26.2 | 50.8 | 8.4 | 30.6 | 7.9 | 38.2 | −1.1 | 14.9 | −2.5 | 14.6 | −12.8 | 3.9 | −6.9 | 3.6 | −13.2
(17) IS RR = 1.00 | 6.7 | 7.1 | −16.0 | −16.2 | −7.7 | −8.0 | −24.6 | −26.1 | −12.6 | −12.8 | −27.0 | −27.2 | −12.4 | −12.2 | −20.1 | −19.2
(18) MI RR = 0.80 | 58.2 | 45.7 | 40.4 | 17.8 | 32.6 | 20.4 | 22.3 | −0.4 | 12.0 | 1.9 | 0.4 | −14.7 | 0.6 | −5.5 | −3.5 | −12.8
(19) MI RR = 0.96 | 1.3 | −11.8 | 3.3 | −18.4 | −6.5 | −18.7 | −2.4 | −24.6 | −7.0 | −16.0 | −12.1 | −26.0 | −10.7 | −15.6 | −9.8 | −18.4
(20) QOL Weight for Benefits ↑10% | 21.9 | 16.2 | 9.8 | −2.6 | 6.4 | 0.4 | 1.3 | −11.8 | −2.0 | −6.7 | −11.8 | −20.2 | −7.5 | −10.1 | −10.5 | −15.4
(21) QOL Weight for Benefits ↓10% | 55.8 | 16.2 | 41.3 | −2.6 | 31.8 | 0.4 | 27.8 | −11.8 | 15.0 | −6.7 | 5.4 | −20.2 | 2.4 | −10.1 | 0.4 | −15.4
(22) QOL Weight for Harms ↑10% | 31.9 | 16.2 | 22.6 | −2.6 | 15.3 | 0.4 | 13.2 | −11.8 | 5.4 | −6.7 | −3.0 | −20.2 | −2.2 | −10.1 | −3.7 | −15.4
(23) QOL Weight for Harms ↓10% | 26.5 | 16.2 | 16.7 | −2.6 | 9.9 | 0.4 | 7.7 | −11.8 | 0.0 | −6.7 | −8.5 | −20.2 | −6.9 | −10.1 | −8.9 | −15.4

Notes: y=years; ASCVD=atherosclerotic cardiovascular disease; ASA=acetylsalicylic acid (aspirin); CRC=colorectal cancer; RR=relative risk; CVD=cardiovascular disease; GIB=major gastrointestinal bleeding; ICH=intracranial hemorrhage; IS=ischemic stroke; MI=myocardial infarction; QALY=net quality-adjusted life years; LY=net life years; QOL=quality-of-life (health utility). Each numbered item represents a one-way sensitivity analysis with the parameter changed as described. Sensitivity ranges are described in Tables 2, 3, and 4.

Table 22 Sensitivity Analysis Results for Persons With 10% ASCVD Baseline Risk (Lifetime Aspirin Use, Lifetime Follow-Up)

| Age 40-49y | | | | Age 50-59y | | | | Age 60-69y | | | | Age 70-79y
| Men | | Women | | Men | | Women | | Men | | Women | | Men | | Women
Scenario | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY
(0) Base Case | 48.0 | 36.1 | 35.1 | 11.4 | 18.0 | 4.2 | 17.1 | −6.5 | 7.0 | −3.0 | 2.3 | −13.5 | −1.1 | −6.9 | −6.1 | −16.6
(1) ASA Disutility = 0.001 | 29.0 | 36.1 | 12.2 | 11.4 | 2.3 | 4.2 | −0.3 | −6.5 | −6.4 | −3.0 | −11.9 | −13.5 | −11.4 | −6.9 | −18.3 | −16.6
(2) ASA Disutility = 0.005 | −47.3 | 36.1 | −79.4 | 11.4 | −60.7 | 4.2 | −70.0 | −6.5 | −60.0 | −3.0 | −68.8 | −13.5 | −52.4 | −6.9 | −67.2 | −16.6
(3) CRC RR = 0.64 | 109.9 | 96.6 | 102.6 | 79.5 | 72.3 | 57.3 | 74.5 | 50.4 | 55.7 | 43.4 | 41.6 | 23.2 | 45.3 | 37.0 | 25.1 | 12.1
(4) CVD Death RR = 0.95 | 126.3 | 128.4 | 112.8 | 104.1 | 89.4 | 88.4 | 80.9 | 69.8 | 68.0 | 69.2 | 48.7 | 41.8 | 43.0 | 45.0 | 29.1 | 25.1
(5) CVD Incidence Rates ↑10% | 53.1 | 40.9 | 46.0 | 20.2 | 21.8 | 9.2 | 24.3 | 1.6 | 7.1 | −3.9 | −0.7 | −17.4 | 0.1 | −6.7 | −6.3 | −16.8
(6) CVD Incidence Rates ↓10% | 34.5 | 22.7 | 24.0 | 0.1 | 15.9 | 2.6 | 11.0 | −9.4 | 1.6 | −6.6 | −2.3 | −17.2 | −0.7 | −6.1 | −7.0 | −16.3
(7) Fatal GIB RR = 1.58 | 29.3 | 14.3 | 19.4 | −7.1 | −5.3 | −23.0 | −0.5 | −26.8 | −13.7 | −27.2 | −12.9 | −31.4 | −18.2 | −26.7 | −24.3 | −38.0
(8) Fatal GIB Incidence Rate - High | 47.7 | 35.8 | 35.1 | 11.3 | 17.8 | 4.1 | 16.9 | −6.6 | 6.9 | −3.1 | 2.3 | −13.5 | −1.0 | −6.8 | −6.0 | −16.5
(9) Fatal GIB Incidence Rate - Low | 48.2 | 36.2 | 35.3 | 11.5 | 17.7 | 4.0 | 17.0 | −6.5 | 7.0 | −3.0 | 2.3 | −13.5 | −1.2 | −7.1 | −6.3 | −17.0
(10) Non-fatal GIB Incidence Rate - High | 47.2 | 35.7 | 34.0 | 11.3 | 17.2 | 4.5 | 16.6 | −5.9 | 5.5 | −3.4 | 1.4 | −13.3 | −2.3 | −6.6 | −7.3 | −16.4
(11) Non-fatal GIB Incidence Rate - Low | 48.5 | 35.7 | 35.8 | 11.3 | 18.5 | 4.0 | 17.6 | −7.0 | 7.7 | −3.0 | 3.0 | −13.7 | −0.3 | −7.0 | −5.6 | −17.2
(12) Non-fatal GIB RR = 1.38 | 49.1 | 36.2 | 36.4 | 11.7 | 18.8 | 4.1 | 17.8 | −6.8 | 8.0 | −2.8 | 3.3 | −13.4 | −0.3 | −6.9 | −5.6 | −17.1
(13) Non-fatal GIB RR = 1.80 | 47.1 | 36.0 | 34.1 | 11.4 | 17.2 | 4.6 | 16.0 | −6.5 | 5.6 | −3.4 | 1.5 | −13.6 | −1.9 | −6.8 | −6.9 | −16.6
(14) ICH RR = 1.11 | 66.4 | 56.1 | 58.3 | 36.7 | 41.4 | 19.9 | 41.4 | 19.9 | 22.5 | 13.7 | 21.8 | 6.9 | 9.9 | 4.9 | 8.4 | −1.4
(15) ICH RR = 1.54 | 26.3 | 12.6 | 9.3 | −16.4 | −2.4 | −18.1 | −10.7 | −37.0 | −14.8 | −26.7 | −22.0 | −39.7 | −14.0 | −20.9 | −24.6 | −35.8
(16) IS RR = 0.78 | 68.1 | 45.4 | 71.9 | 28.2 | 37.8 | 13.3 | 48.3 | 7.8 | 19.5 | 2.2 | 22.7 | −7.0 | 7.4 | −3.8 | 5.5 | −13.5
(17) IS RR = 1.00 | 21.1 | 23.0 | −7.9 | −8.8 | −3.9 | −4.7 | −22.5 | −23.7 | −9.6 | −9.6 | −22.8 | −23.1 | −10.5 | −10.2 | −20.5 | −20.0
(18) MI RR = 0.80 | 80.6 | 69.3 | 57.9 | 34.4 | 38.1 | 24.2 | 31.4 | 7.7 | 18.9 | 8.6 | 8.4 | −8.2 | 4.4 | −1.9 | −2.5 | −13.4
(19) MI RR = 0.96 | 12.7 | −0.6 | 14.2 | −9.3 | −1.4 | −14.7 | 4.6 | −18.5 | −6.0 | −15.8 | −4.6 | −20.1 | −7.2 | −12.7 | −8.6 | −18.6
(20) QOL Weight for Benefits ↑10% | 40.4 | 36.1 | 24.5 | 11.4 | 11.2 | 4.2 | 7.3 | −6.5 | 1.9 | −3.0 | −4.3 | −13.5 | −4.2 | −6.9 | −10.5 | −16.6
(21) QOL Weight for Benefits ↓10% | 75.3 | 36.1 | 58.8 | 11.4 | 37.5 | 4.2 | 35.2 | −6.5 | 21.2 | −3.0 | 13.5 | −13.5 | 6.3 | −6.9 | 1.4 | −16.6
(22) QOL Weight for Harms ↑10% | 50.7 | 36.1 | 38.0 | 11.4 | 20.7 | 4.2 | 19.9 | −6.5 | 9.7 | −3.0 | 5.0 | −13.5 | 1.3 | −6.9 | −3.5 | −16.6
(23) QOL Weight for Harms ↓10% | 45.5 | 36.1 | 32.5 | 11.4 | 15.5 | 4.2 | 14.5 | −6.5 | 4.4 | −3.0 | −0.2 | −13.5 | −3.4 | −6.9 | −8.4 | −16.6

Notes: y=years; ASCVD=atherosclerotic cardiovascular disease; ASA=acetylsalicylic acid (aspirin); CRC=colorectal cancer; RR=relative risk; CVD=cardiovascular disease; GIB=major gastrointestinal bleeding; ICH=intracranial hemorrhage; IS=ischemic stroke; MI=myocardial infarction; QALY=net quality-adjusted life years; LY=net life years; QOL=quality-of-life (health utility). Each numbered item represents a one-way sensitivity analysis with the parameter changed as described. Sensitivity ranges are described in Tables 2, 3, and 4.

Table 23 Sensitivity Analysis Results for Persons With 15% ASCVD Baseline Risk (Lifetime Aspirin Use, Lifetime Follow-Up)

| Age 40-49y | | | | Age 50-59y | | | | Age 60-69y | | | | Age 70-79y
| Men | | Women | | Men | | Women | | Men | | Women | | Men | | Women
Scenario | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY
(0) Base Case | 52.3 | 37.9 | 43.0 | 17.7 | 32.3 | 18.6 | 30.8 | 7.5 | 8.3 | −2.2 | 11.6 | −7.2 | −1.9 | −7.6 | −6.9 | −17.9
(1) ASA Disutility = 0.001 | 34.5 | 37.9 | 20.7 | 17.7 | 17.8 | 18.6 | 14.2 | 7.5 | −3.8 | −2.2 | −1.6 | −7.2 | −11.9 | −7.6 | −18.2 | −17.9
(2) ASA Disutility = 0.005 | −36.4 | 37.9 | −68.5 | 17.7 | −40.2 | 18.6 | −52.5 | 7.5 | −52.3 | −2.2 | −54.6 | −7.2 | −52.1 | −7.6 | −63.4 | −17.9
(3) CRC RR = 0.64 | 109.6 | 94.3 | 103.3 | 77.6 | 85.1 | 70.0 | 87.0 | 62.3 | 51.5 | 38.1 | 53.4 | 33.2 | 36.3 | 27.3 | 26.8 | 13.7
(4) CVD Death RR = 0.95 | 128.6 | 128.6 | 115.8 | 104.8 | 104.8 | 104.5 | 100.2 | 90.6 | 69.2 | 69.8 | 67.2 | 59.4 | 45.4 | 48.3 | 31.4 | 28.0
(5) CVD Incidence Rates ↑10% | 55.3 | 42.0 | 52.9 | 28.2 | 40.7 | 25.6 | 37.3 | 13.6 | 10.8 | 1.3 | 13.4 | −5.8 | −1.0 | −7.9 | −3.6 | −16.4
(6) CVD Incidence Rates ↓10% | 44.2 | 29.9 | 42.9 | 17.7 | 25.6 | 13.4 | 23.2 | −0.4 | 6.6 | −4.5 | 10.1 | −6.7 | −3.4 | −9.6 | −7.5 | −16.2
(7) Fatal GIB RR = 1.58 | 33.4 | 15.8 | 27.8 | −0.3 | 15.1 | −1.6 | 16.0 | −9.8 | −9.8 | −23.3 | −2.1 | −23.1 | −15.5 | −23.4 | −17.6 | −30.4
(8) Fatal GIB Incidence Rate - High | 51.9 | 37.7 | 42.7 | 17.4 | 31.9 | 18.2 | 30.9 | 7.6 | 8.1 | −2.3 | 11.4 | −7.3 | −1.9 | −7.6 | −6.9 | −17.9
(9) Fatal GIB Incidence Rate - Low | 52.4 | 38.0 | 43.0 | 17.7 | 32.6 | 18.9 | 31.1 | 7.7 | 8.2 | −2.3 | 11.7 | −7.1 | −1.9 | −7.6 | −6.8 | −17.9
(10) Non-fatal GIB Incidence Rate - High | 51.8 | 38.2 | 42.3 | 17.9 | 31.4 | 18.5 | 29.6 | 7.3 | 7.1 | −2.2 | 10.4 | −7.3 | −3.5 | −7.8 | −7.9 | −17.6
(11) Non-fatal GIB Incidence Rate - Low | 53.6 | 38.8 | 43.9 | 17.9 | 33.3 | 18.8 | 32.0 | 8.1 | 9.0 | −2.1 | 12.2 | −7.4 | −1.4 | −7.9 | −6.3 | −18.2
(12) Non-fatal GIB RR = 1.38 | 54.0 | 38.8 | 44.2 | 18.0 | 33.5 | 18.9 | 32.1 | 8.0 | 9.0 | −2.2 | 12.4 | −7.3 | −1.2 | −7.6 | −6.3 | −18.1
(13) Non-fatal GIB RR = 1.80 | 51.0 | 37.7 | 41.9 | 17.7 | 31.2 | 18.3 | 29.9 | 7.5 | 7.4 | −2.1 | 10.3 | −7.6 | −2.7 | −7.6 | −7.5 | −17.8
(14) ICH RR = 1.11 | 72.5 | 60.3 | 66.6 | 43.1 | 54.9 | 33.7 | 54.9 | 33.7 | 24.3 | 15.0 | 30.1 | 13.1 | 8.7 | 3.8 | 9.4 | −1.0
(15) ICH RR = 1.54 | 32.6 | 16.3 | 15.0 | −12.5 | 12.4 | −3.6 | 6.4 | −18.8 | −8.0 | −19.5 | −10.5 | −30.9 | −16.4 | −23.2 | −23.5 | −35.5
(16) IS RR = 0.78 | 76.1 | 49.6 | 84.5 | 37.7 | 51.1 | 27.0 | 65.4 | 22.6 | 23.3 | 3.6 | 35.6 | 2.3 | 6.8 | −4.9 | 5.6 | −13.6
(17) IS RR = 1.00 | 21.7 | 21.9 | −3.5 | −3.5 | 4.5 | 3.6 | −9.7 | −11.2 | −8.9 | −9.4 | −16.1 | −17.0 | −11.2 | −11.0 | −22.1 | −21.8
(18) MI RR = 0.80 | 85.3 | 71.5 | 70.0 | 44.9 | 60.1 | 47.3 | 47.5 | 23.8 | 20.3 | 9.6 | 20.0 | 0.4 | 4.1 | −1.9 | −2.7 | −14.0
(19) MI RR = 0.96 | 14.2 | −0.6 | 20.0 | −5.8 | 9.3 | −4.4 | 13.7 | −9.1 | −2.9 | −12.6 | 1.7 | −16.9 | −8.1 | −13.3 | −10.6 | −21.3
(20) QOL Weight for Benefits ↑10% | 43.7 | 37.9 | 31.5 | 17.7 | 25.0 | 18.6 | 20.7 | 7.5 | 3.1 | −2.2 | 4.0 | −7.2 | −4.9 | −7.6 | −11.5 | −17.9
(21) QOL Weight for Benefits ↓10% | 81.7 | 37.9 | 67.3 | 17.7 | 53.5 | 18.6 | 50.2 | 7.5 | 21.4 | −2.2 | 23.8 | −7.2 | 5.8 | −7.6 | 0.7 | −17.9
(22) QOL Weight for Harms ↑10% | 54.7 | 37.9 | 45.8 | 17.7 | 34.8 | 18.6 | 33.4 | 7.5 | 10.8 | −2.2 | 14.0 | −7.2 | 0.5 | −7.6 | −4.5 | −17.9
(23) QOL Weight for Harms ↓10% | 50.0 | 37.9 | 40.3 | 17.7 | 30.0 | 18.6 | 28.4 | 7.5 | 5.9 | −2.2 | 9.4 | −7.2 | −4.2 | −7.6 | −9.1 | −17.9

Notes: y=years; ASCVD=atherosclerotic cardiovascular disease; ASA=acetylsalicylic acid (aspirin); CRC=colorectal cancer; RR=relative risk; CVD=cardiovascular disease; GIB=major gastrointestinal bleeding; ICH=intracranial hemorrhage; IS=ischemic stroke; MI=myocardial infarction; QALY=net quality-adjusted life years; LY=net life years; QOL=quality-of-life (health utility). Each numbered item represents a one-way sensitivity analysis with the parameter changed as described. Sensitivity ranges are described in Tables 2, 3, and 4.

Table 24 Sensitivity Analysis Results for Persons With 20% ASCVD Baseline Risk (Lifetime Aspirin Use, Lifetime Follow-Up)

| Age 40-49y | | | | Age 50-59y | | | | Age 60-69y | | | | Age 70-79y
| Men | | Women | | Men | | Women | | Men | | Women | | Men | | Women
Scenario | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY | QALY | LY
(0) Base Case | 66.2 | 52.4 | 50.4 | 24.2 | 48.4 | 33.9 | 41.6 | 16.9 | 16.3 | 4.9 | 19.1 | −1.6 | 0.9 | −5.5 | −4.4 | −14.8
(1) ASA Disutility = 0.001 | 49.4 | 52.4 | 28.3 | 24.2 | 34.8 | 33.9 | 25.4 | 16.9 | 5.0 | 4.9 | 6.6 | −1.6 | −8.5 | −5.5 | −14.9 | −14.8
(2) ASA Disutility = 0.005 | −17.5 | 52.4 | −59.9 | 24.2 | −19.5 | 33.9 | −39.5 | 16.9 | −39.9 | 4.9 | −43.5 | −1.6 | −45.9 | −5.5 | −57.2 | −14.8
(3) CRC RR = 0.64 | 120.0 | 105.2 | 118.9 | 94.0 | 104.7 | 89.8 | 99.2 | 74.3 | 60.3 | 46.4 | 55.3 | 32.5 | 35.0 | 25.4 | 23.1 | 9.6
(4) CVD Death RR = 0.95 | 149.2 | 151.2 | 125.4 | 114.1 | 119.6 | 119.0 | 110.9 | 100.0 | 72.0 | 71.5 | 70.8 | 60.5 | 42.7 | 44.1 | 32.4 | 28.9
(5) CVD Incidence Rates ↑10% | 72.7 | 59.8 | 48.0 | 23.7 | 53.0 | 39.0 | 40.0 | 15.9 | 17.1 | 4.5 | 20.6 | 1.1 | 1.1 | −6.5 | −3.7 | −15.0
(6) CVD Incidence Rates ↓10% | 51.9 | 37.1 | 39.8 | 15.4 | 36.7 | 23.8 | 40.9 | 17.0 | 10.3 | −0.5 | 18.7 | 1.1 | −0.1 | −7.4 | −4.4 | −15.7
(7) Fatal GIB RR = 1.58 | 50.9 | 34.6 | 35.1 | 6.2 | 33.7 | 16.9 | 25.2 | −2.3 | −1.7 | −16.1 | 7.5 | −15.5 | −12.4 | −20.8 | −16.9 | −29.3
(8) Fatal GIB Incidence Rate - High | 65.7 | 51.9 | 50.2 | 24.0 | 48.3 | 33.9 | 41.0 | 16.2 | 16.3 | 5.0 | 18.8 | −1.9 | 0.7 | −5.7 | −4.4 | −14.8
(9) Fatal GIB Incidence Rate - Low | 66.2 | 52.3 | 50.5 | 24.3 | 48.7 | 34.3 | 41.7 | 16.8 | 16.4 | 5.1 | 19.1 | −1.7 | 0.9 | −5.4 | −4.4 | −14.8
(10) Non-fatal GIB Incidence Rate - High | 65.5 | 52.4 | 49.3 | 24.0 | 47.7 | 34.0 | 40.2 | 16.4 | 14.9 | 4.6 | 18.1 | −1.4 | −0.7 | −5.9 | −5.5 | −14.5
(11) Non-fatal GIB Incidence Rate - Low | 66.6 | 52.4 | 51.9 | 24.9 | 49.3 | 34.4 | 42.2 | 16.6 | 17.0 | 5.0 | 19.7 | −1.8 | 1.7 | −5.5 | −3.6 | −14.9
(12) Non-fatal GIB RR = 1.38 | 67.1 | 52.6 | 51.8 | 24.6 | 49.3 | 34.1 | 42.3 | 16.6 | 17.2 | 5.1 | 19.7 | −1.8 | 1.8 | −5.3 | −3.7 | −14.7
(13) Non-fatal GIB RR = 1.80 | 65.2 | 52.3 | 49.1 | 23.9 | 47.5 | 34.0 | 40.3 | 16.4 | 15.4 | 5.0 | 18.2 | −1.7 | −0.1 | −5.7 | −5.0 | −14.5
(14) ICH RR = 1.11 | 83.3 | 71.3 | 73.4 | 49.3 | 64.4 | 41.7 | 64.4 | 41.7 | 31.8 | 22.0 | 36.3 | 17.0 | 11.4 | 5.8 | 10.4 | 0.6
(15) ICH RR = 1.54 | 46.5 | 30.6 | 24.8 | −3.0 | 29.0 | 12.3 | 16.0 | −11.3 | −3.7 | −17.2 | 1.3 | −20.7 | −12.3 | −19.7 | −21.6 | −32.6
(16) IS RR = 0.78 | 92.5 | 66.6 | 86.6 | 40.4 | 69.8 | 44.5 | 77.7 | 33.5 | 33.5 | 13.8 | 45.4 | 9.1 | 10.5 | −2.3 | 9.9 | −11.3
(17) IS RR = 1.00 | 31.7 | 32.8 | 0.2 | 0.3 | 19.5 | 19.9 | −3.9 | −4.5 | −2.2 | −2.7 | −12.6 | −13.3 | −9.1 | −8.9 | −20.4 | −20.4
(18) MI RR = 0.80 | 108.1 | 95.6 | 80.0 | 54.3 | 77.8 | 64.2 | 64.0 | 39.7 | 31.2 | 19.3 | 30.5 | 9.4 | 7.6 | 0.7 | −0.8 | −11.9
(19) MI RR = 0.96 | 24.4 | 9.2 | 25.9 | −0.8 | 17.7 | 2.6 | 20.4 | −4.3 | −0.1 | −11.2 | 9.9 | −10.3 | −5.4 | −11.3 | −8.4 | −18.0
(20) QOL Weight for Benefits ↑10% | 57.2 | 52.4 | 38.5 | 24.2 | 40.3 | 33.9 | 30.8 | 16.9 | 10.6 | 4.9 | 10.6 | −1.6 | −2.4 | −5.5 | −8.9 | −14.8
(21) QOL Weight for Benefits ↓10% | 96.8 | 52.4 | 75.4 | 24.2 | 71.3 | 33.9 | 62.3 | 16.9 | 30.9 | 4.9 | 33.0 | −1.6 | 9.1 | −5.5 | 3.3 | −14.8
(22) QOL Weight for Harms ↑10% | 68.4 | 52.4 | 53.2 | 24.2 | 50.5 | 33.9 | 44.0 | 16.9 | 18.6 | 4.9 | 21.5 | −1.6 | 3.1 | −5.5 | −2.1 | −14.8
(23) QOL Weight for Harms ↓10% | 64.0 | 52.4 | 47.7 | 24.2 | 46.3 | 33.9 | 39.4 | 16.9 | 14.1 | 4.9 | 16.9 | −1.6 | −1.2 | −5.5 | −6.6 | −14.8

Notes: y=years; ASCVD=atherosclerotic cardiovascular disease; ASA=acetylsalicylic acid (aspirin); CRC=colorectal cancer; RR=relative risk; CVD=cardiovascular disease; GIB=major gastrointestinal bleeding; ICH=intracranial hemorrhage; IS=ischemic stroke; MI=myocardial infarction; QALY=net quality-adjusted life years; LY=net life years; QOL=quality-of-life (health utility). Each numbered item represents a one-way sensitivity analysis with the parameter changed as described. Sensitivity ranges are described in Tables 2, 3, and 4.

Tables 25a–25d show the effect of assuming aspirin reduces CRC incidence by 34% across both time horizons and all stopping scenarios. Lifetime net QALYs and life years were positive for all scenarios. Over 10 years, net QALYs and life years were positive for all groups but one: net life years for women aged 60-69 years with 10% 10-year ASCVD risk. Tables 26 and 27 show how the addition of prevented CRC cases and deaths contributed to additional net QALYs and life years.

Table 25a Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (CRC RR = 0.64), Initiation Age 40-49y

| 10y use^*^ | Stop at age 65y | Stop at age 70y | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 2.4 | 60.9 | 72.9 | 79.2 | 81.6 | 83.3 | 82.9
7.5% 10y ASCVD Risk | 2.8 | 73.2 | 82.9 | 89.3 | 93.2 | 94.9 | 95.4
10% 10y ASCVD Risk | 3.8 | 85.9 | 96.8 | 103.3 | 107.7 | 108.9 | 109.9
15% 10y ASCVD Risk | 4.1 | 87.7 | 98.1 | 104.9 | 107.3 | 109.4 | 109.6
20% 10y ASCVD Risk | 5.6 | 97.0 | 107.1 | 114.0 | 117.9 | 119.3 | 120.0
Men, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 1.4 | 55.5 | 65.9 | 69.7 | 70.2 | 70.7 | 69.7
7.5% 10y ASCVD Risk | 1.1 | 66.4 | 74.5 | 79.2 | 81.5 | 82.4 | 82.3
10% 10y ASCVD Risk | 1.3 | 79.2 | 88.1 | 93.0 | 95.9 | 96.2 | 96.6
15% 10y ASCVD Risk | 1.3 | 78.9 | 87.5 | 92.5 | 93.3 | 94.7 | 94.3
20% 10y ASCVD Risk | 1.8 | 88.7 | 96.1 | 101.3 | 104.4 | 104.8 | 105.2
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 2.2 | 52.4 | 61.1 | 65.3 | 68.6 | 69.8 | 69.8
7.5% 10y ASCVD Risk | 2.9 | 61.8 | 71.1 | 79.5 | 82.3 | 83.8 | 84.7
10% 10y ASCVD Risk | 3.1 | 72.6 | 88.0 | 95.5 | 100.0 | 101.8 | 102.6
15% 10y ASCVD Risk | 4.1 | 75.7 | 88.2 | 96.6 | 100.4 | 102.4 | 103.3
20% 10y ASCVD Risk | 4.7 | 90.2 | 103.1 | 110.3 | 116.1 | 117.6 | 118.9
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 0.9 | 43.3 | 48.4 | 49.8 | 49.9 | 49.2 | 47.5
7.5% 10y ASCVD Risk | 1.3 | 52.1 | 57.6 | 62.8 | 63.3 | 62.8 | 61.9
10% 10y ASCVD Risk | 1.2 | 61.3 | 73.8 | 77.9 | 80.1 | 79.9 | 79.5
15% 10y ASCVD Risk | 1.3 | 62.1 | 70.5 | 76.6 | 77.5 | 77.9 | 77.6
20% 10y ASCVD Risk | 1.4 | 77.0 | 86.5 | 91.1 | 94.4 | 94.0 | 94.0

Notes: CRC=colorectal cancer; RR=relative risk; ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. This table presents results for a sensitivity analysis in which the risk for CRC incidence was 36% lower (RR = 0.64) with use of aspirin for at least 10 years.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 25b Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (CRC RR = 0.64), Initiation Age 50-59y

| 10y use^*^ | Stop at age 65y | Stop at age 70y | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 3.6 | 33.9 | 49.9 | 54.8 | 57.2 | 58.7 | 58.8
7.5% 10y ASCVD Risk | 4.1 | 36.5 | 58.4 | 65.1 | 67.7 | 68.3 | 68.7
10% 10y ASCVD Risk | 5.4 | 35.8 | 59.5 | 67.0 | 69.9 | 71.9 | 72.3
15% 10y ASCVD Risk | 6.1 | 45.3 | 71.9 | 79.6 | 83.2 | 84.4 | 85.1
20% 10y ASCVD Risk | 8.5 | 56.2 | 86.3 | 95.9 | 101.5 | 103.5 | 104.7
Men, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 1.5 | 29.7 | 43.8 | 46.6 | 46.9 | 47.0 | 45.9
7.5% 10y ASCVD Risk | 1.8 | 34.0 | 52.6 | 56.6 | 57.0 | 55.9 | 55.6
10% 10y ASCVD Risk | 2.3 | 31.2 | 52.5 | 57.0 | 57.0 | 57.6 | 57.3
15% 10y ASCVD Risk | 1.8 | 40.0 | 63.3 | 68.3 | 70.1 | 69.9 | 70.0
20% 10y ASCVD Risk | 3.1 | 50.8 | 77.6 | 84.4 | 88.3 | 89.3 | 89.8
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 2.4 | 23.1 | 39.9 | 47.7 | 52.7 | 53.3 | 53.1
7.5% 10y ASCVD Risk | 4.2 | 31.3 | 56.1 | 64.0 | 66.3 | 67.7 | 67.9
10% 10y ASCVD Risk | 5.4 | 37.2 | 61.4 | 69.9 | 73.0 | 74.5 | 74.5
15% 10y ASCVD Risk | 6.5 | 40.7 | 69.0 | 79.0 | 83.7 | 86.0 | 87.0
20% 10y ASCVD Risk | 7.1 | 43.7 | 78.6 | 90.0 | 96.6 | 98.4 | 99.2
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 0.4 | 16.8 | 29.8 | 33.6 | 34.6 | 33.0 | 31.0
7.5% 10y ASCVD Risk | 1.3 | 24.7 | 45.0 | 48.6 | 48.1 | 46.8 | 45.3
10% 10y ASCVD Risk | 1.6 | 29.3 | 49.4 | 53.5 | 53.1 | 51.9 | 50.4
15% 10y ASCVD Risk | 2.2 | 32.3 | 55.1 | 61.5 | 63.3 | 63.1 | 62.3
20% 10y ASCVD Risk | 2.1 | 34.8 | 65.3 | 72.3 | 75.2 | 75.2 | 74.3

Notes: CRC=colorectal cancer; RR=relative risk; ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. This table presents results for a sensitivity analysis in which the risk for CRC incidence was 36% lower (RR = 0.64) with use of aspirin for at least 10 years.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 25c Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (CRC RR = 0.64), Initiation Age 60-69y

| 10y use^*^ | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 5.1 | 45.5 | 46.9 | 50.1 | 50.0
7.5% 10y ASCVD Risk | 5.1 | 41.9 | 48.8 | 50.2 | 51.0
10% 10y ASCVD Risk | 6.1 | 44.9 | 54.7 | 55.9 | 55.7
15% 10y ASCVD Risk | 6.7 | 38.0 | 49.8 | 51.4 | 51.5
20% 10y ASCVD Risk | 8.0 | 43.1 | 57.6 | 59.1 | 60.3
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 3.0 | 39.9 | 39.0 | 40.0 | 38.8
7.5% 10y ASCVD Risk | 2.1 | 35.0 | 39.5 | 39.0 | 38.9
10% 10y ASCVD Risk | 2.6 | 37.8 | 44.8 | 44.5 | 43.4
15% 10y ASCVD Risk | 2.4 | 30.8 | 39.0 | 38.9 | 38.1
20% 10y ASCVD Risk | 2.1 | 35.2 | 46.3 | 46.2 | 46.4
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 2.7 | 28.4 | 35.3 | 34.5 | 33.8
7.5% 10y ASCVD Risk | 4.3 | 25.1 | 34.1 | 34.5 | 34.1
10% 10y ASCVD Risk | 3.7 | 24.3 | 42.5 | 43.4 | 41.6
15% 10y ASCVD Risk | 6.5 | 31.4 | 50.0 | 52.5 | 53.4
20% 10y ASCVD Risk | 8.5 | 35.4 | 51.6 | 54.3 | 55.3
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 1.0 | 22.0 | 24.4 | 20.8 | 18.0
7.5% 10y ASCVD Risk | 1.4 | 17.2 | 21.6 | 19.7 | 17.3
10% 10y ASCVD Risk | −0.1 | 15.6 | 29.1 | 27.4 | 23.2
15% 10y ASCVD Risk | 1.0 | 21.6 | 35.4 | 34.7 | 33.2
20% 10y ASCVD Risk | 1.7 | 23.9 | 34.1 | 33.7 | 32.5

Notes: CRC=colorectal cancer; RR=relative risk; ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. This table presents results for a sensitivity analysis in which the risk for CRC incidence was 36% lower (RR = 0.64) with use of aspirin for at least 10 years.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 25d Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (CRC RR = 0.64), Initiation Age 70-79y

| 10y use^*^ | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | N/A | N/A | N/A
7.5% 10y ASCVD Risk | 10.7 | 45.6 | 47.6
10% 10y ASCVD Risk | 9.8 | 43.5 | 45.3
15% 10y ASCVD Risk | 7.9 | 35.6 | 36.3
20% 10y ASCVD Risk | 9.5 | 33.3 | 35.0
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | N/A | N/A | N/A
7.5% 10y ASCVD Risk | 7.2 | 41.1 | 41.2
10% 10y ASCVD Risk | 5.5 | 37.0 | 37.0
15% 10y ASCVD Risk | 3.5 | 28.0 | 27.3
20% 10y ASCVD Risk | 4.7 | 25.5 | 25.4
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 3.8 | 23.0 | 21.1
7.5% 10y ASCVD Risk | 5.1 | 31.4 | 28.4
10% 10y ASCVD Risk | 4.9 | 25.6 | 25.1
15% 10y ASCVD Risk | 5.0 | 26.4 | 26.8
20% 10y ASCVD Risk | 4.8 | 21.3 | 23.1
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 1.7 | 14.4 | 9.2
7.5% 10y ASCVD Risk | 2.2 | 22.8 | 16.9
10% 10y ASCVD Risk | 1.4 | 15.3 | 12.1
15% 10y ASCVD Risk | 0.8 | 16.2 | 13.7
20% 10y ASCVD Risk | 0.1 | 11.1 | 9.6

Notes: CRC=colorectal cancer; RR=relative risk; ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. This table presents results for a sensitivity analysis in which the risk for CRC incidence was 36% lower (RR = 0.64) with use of aspirin for at least 10 years.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 26 Lifetime Net Events of Aspirin for Men With Lifetime Use (CRC RR = 0.64)

| Benefits from aspirin; (Prevented events per 1,000 persons) | | | | | | Harms from aspirin; (Incurred events per 1,000 persons) | | | | Net Balance; (Benefits - harms)
10-yr ASCVD Risk (%) | Myocardial infarction | Ischemic stroke | Non-fatal CVD Events | CVD Deaths | CRC Cases | CRC Deaths | Major GI Bleeds | Major GI Bleed Deaths | Intracranial Hemorrhage | Intracranial Hemorrhage Deaths | Net QALYs | Net Life Years | Net Events Prevented
Men, Initiation Age 40-49 years
5 | 16.3 | 5.8 | 26.6 | 3.4 | 10.4 | 4.3 | 31.8 | 0.0 | 3.0 | 2.7 | 82.9 | 69.7 | 5.6
7.5 | 18.9 | 6.2 | 30.4 | 3.2 | 11.3 | 4.7 | 30.6 | 0.0 | 2.6 | 2.4 | 95.4 | 82.3 | 11.7
10 | 19.8 | 6.7 | 32.0 | 3.7 | 11.4 | 4.6 | 30.0 | 0.0 | 2.3 | 2.1 | 109.9 | 96.6 | 14.8
15 | 21.8 | 7.6 | 35.8 | 3.9 | 10.5 | 4.3 | 27.4 | 0.0 | 2.6 | 2.3 | 109.6 | 94.3 | 20.2
20 | 24.1 | 7.3 | 37.9 | 4.5 | 10.2 | 4.1 | 25.1 | 0.0 | 2.5 | 2.3 | 120.0 | 105.2 | 25
Men, Initiation Age 50-59 years
5 | 13.8 | 5.7 | 23.2 | 2.5 | 10.6 | 4.1 | 33.0 | 0.0 | 3.2 | 2.8 | 58.8 | 45.9 | 0.1
7.5 | 14.6 | 6.5 | 24.7 | 2.5 | 10.9 | 4.7 | 31.3 | 0.0 | 3.1 | 2.8 | 68.7 | 55.6 | 3.7
10 | 15.1 | 7.0 | 26.5 | 2.7 | 10.7 | 4.5 | 30.2 | 0.0 | 2.9 | 2.6 | 72.3 | 57.3 | 6.8
15 | 18.2 | 7.3 | 30.8 | 3.2 | 10.4 | 4.3 | 28.1 | 0.0 | 2.7 | 2.5 | 85.1 | 70.0 | 13.6
20 | 19.7 | 8.0 | 33.5 | 3.5 | 10.6 | 4.5 | 25.2 | 0.0 | 2.2 | 1.9 | 104.7 | 89.8 | 20.2
Men, Initiation Age 60-69 years
5 | 9.7 | 5.7 | 17.4 | 1.5 | 11.0 | 4.6 | 33.2 | 0.0 | 3.1 | 2.7 | 50.0 | 38.8 | −6.4
7.5 | 10.9 | 5.9 | 19.3 | 1.5 | 10.9 | 4.7 | 31.4 | 0.0 | 2.8 | 2.5 | 51.0 | 38.9 | −2.5
10 | 12.2 | 5.7 | 21.1 | 2.2 | 11.1 | 4.7 | 30.6 | 0.0 | 3.1 | 2.7 | 55.7 | 43.4 | 0.7
15 | 11.8 | 6.1 | 20.9 | 2.2 | 10.7 | 4.0 | 28.3 | 0.1 | 3.0 | 2.6 | 51.5 | 38.1 | 2.5
20 | 14.3 | 7.0 | 25.3 | 3.0 | 10.5 | 4.2 | 26.7 | 0.0 | 2.9 | 2.6 | 60.3 | 46.4 | 9.2
Men, Initiation Age 70-79 years
5 | - | - | - | - | - | - | - | - | - | - | - | -
7.5 | 7.5 | 4.4 | 13.4 | 0.5 | 11.4 | 6.1 | 28.3 | 0.0 | 2.6 | 2.4 | 47.6 | 41.2 | −5.6
10 | 8.5 | 4.7 | 14.9 | 1.0 | 11.7 | 5.4 | 28.5 | 0.0 | 2.7 | 2.3 | 45.3 | 37.0 | −3.6
15 | 8.5 | 5.0 | 15.2 | 1.2 | 10.5 | 4.6 | 27.6 | 0.0 | 2.6 | 2.2 | 36.3 | 27.3 | −3.3
20 | 9.3 | 5.3 | 16.7 | 1.3 | 10.0 | 4.0 | 25.9 | 0.0 | 2.6 | 2.2 | 35.0 | 25.4 | −0.5

Notes: ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; CRC=colorectal cancer; RR=relative risk; GI=gastrointestinal; QALY=quality-adjusted life year. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption; all else is held equal. MI and ischemic stroke events are non-fatal. The non-fatal CVD event column combines non-fatal MIs, ischemic strokes, and congestive heart failure (as a major sequela to MI). Net events prevented are defined by the net of benefit and harm events, or: (Non-fatal CVD events + CVD deaths + CRC cases) – (Major GI bleeds + intracranial hemorrhage). This table presents results for a sensitivity analysis in which the risk for CRC incidence was 36% lower (RR = 0.64) with use of aspirin for at least 10 years.

Table 27 Lifetime Net Events of Aspirin for Women With Lifetime Use (CRC RR = 0.64)

| Benefits from aspirin; (Prevented events per 1,000 persons) | | | | | | Harms from aspirin; (Incurred events per 1,000 persons) | | | | Net Balance; (Benefits - harms)
10-yr ASCVD Risk (%) | Myocardial infarction | Ischemic stroke | Non-fatal CVD Events | CVD Deaths | CRC Cases | CRC Deaths | Major GI Bleeds | Major GI Bleed Deaths | Intracranial Hemorrhage | Intracranial Hemorrhage Deaths | Net QALYs | Net Life Years | Net Events Prevented
Women, Initiation Age 40-49 years
5 | 10.0 | 9.4 | 23.2 | 2.6 | 10.4 | 3.9 | 32.1 | 0.0 | 4.0 | 3.6 | 69.8 | 47.5 | 0.1
7.5 | 10.2 | 9.5 | 24.1 | 3.0 | 11.0 | 4.3 | 30.6 | 0.0 | 3.2 | 2.9 | 84.7 | 61.9 | 4.3
10 | 11.0 | 9.9 | 25.6 | 2.9 | 11.3 | 4.8 | 29.6 | 0.0 | 3.1 | 2.9 | 102.6 | 79.5 | 7.1
15 | 11.3 | 10.2 | 27.0 | 3.6 | 10.6 | 4.1 | 29.6 | 0.0 | 2.9 | 2.6 | 103.3 | 77.6 | 8.7
20 | 11.8 | 10.8 | 28.3 | 3.6 | 10.6 | 4.3 | 30.3 | 0.0 | 2.8 | 2.5 | 118.9 | 94.0 | 9.4
Women, Initiation Age 50-59 years
5 | 8.2 | 9.5 | 21.2 | 2.4 | 10.3 | 4.1 | 31.1 | 0.0 | 4.1 | 3.5 | 53.1 | 31.0 | −1.3
7.5 | 8.8 | 10.0 | 22.9 | 2.5 | 10.4 | 4.3 | 29.1 | 0.0 | 3.8 | 3.4 | 67.9 | 45.3 | 2.9
10 | 8.9 | 10.5 | 23.0 | 3.0 | 11.1 | 4.3 | 28.3 | 0.0 | 3.6 | 3.3 | 74.5 | 50.4 | 5.2
15 | 10.1 | 11.4 | 26.3 | 2.5 | 10.8 | 4.3 | 27.3 | 0.0 | 3.2 | 2.9 | 87.0 | 62.3 | 9.1
20 | 11.1 | 11.2 | 28.3 | 3.0 | 10.8 | 4.4 | 25.8 | 0.0 | 2.9 | 2.7 | 99.2 | 74.3 | 13.4
Women, Initiation Age 60-69 years
5 | 5.5 | 7.6 | 15.2 | 1.4 | 9.5 | 4.0 | 30.7 | 0.0 | 4.1 | 3.5 | 33.8 | 18.0 | −8.7
7.5 | 6.4 | 7.9 | 16.5 | 1.6 | 9.2 | 3.6 | 29.2 | 0.0 | 3.8 | 3.2 | 34.1 | 17.3 | −5.7
10 | 6.3 | 8.9 | 17.9 | 2.0 | 9.4 | 3.7 | 27.8 | 0.0 | 3.7 | 3.2 | 41.6 | 23.2 | −2.2
15 | 7.0 | 10.2 | 20.6 | 2.2 | 9.4 | 3.9 | 26.1 | 0.0 | 3.3 | 2.9 | 53.4 | 33.2 | 2.8
20 | 7.8 | 11.3 | 23.5 | 2.7 | 8.6 | 3.5 | 25.4 | 0.0 | 3.3 | 2.8 | 55.3 | 32.5 | 6.1
Women, Initiation Age 70-79 years
5 | 4.2 | 6.8 | 12.1 | 0.9 | 8.7 | 3.4 | 29.6 | 0.0 | 3.8 | 3.2 | 21.1 | 9.2 | −11.7
7.5 | 4.6 | 6.7 | 12.6 | 0.7 | 8.8 | 3.7 | 28.5 | 0.0 | 3.3 | 2.7 | 28.4 | 16.9 | −9.7
10 | 4.2 | 6.9 | 12.8 | 1.0 | 8.2 | 3.3 | 27.5 | 0.0 | 3.0 | 2.7 | 25.1 | 12.1 | −8.5
15 | 4.9 | 7.5 | 13.9 | 1.1 | 8.5 | 3.7 | 24.9 | 0.0 | 3.5 | 2.9 | 26.8 | 13.7 | −4.9
20 | 5.2 | 7.2 | 14.8 | 1.6 | 8.0 | 3.0 | 24.2 | 0.0 | 3.5 | 3.0 | 23.1 | 9.6 | −3.3

Notes: ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; CRC=colorectal cancer; RR=relative risk; GI=gastrointestinal; QALY=quality-adjusted life year. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption; all else is held equal. MI and ischemic stroke events are non-fatal. The non-fatal CVD event column combines non-fatal MIs, ischemic strokes, and congestive heart failure (as a major sequela to MI). Net events prevented are defined by the net of benefit and harm events, or: (Non-fatal CVD events + CVD deaths + CRC cases) – (Major GI bleeds + intracranial hemorrhage). This table presents results for a sensitivity analysis in which the risk for CRC incidence was 36% lower (RR = 0.64) with use of aspirin for at least 10 years.

Tables 28a–28d show the effect of assuming aspirin reduces CVD mortality incidence by 5% (including death associated with MI and ischemic stroke but excluding intracranial hemorrhage) across both time horizons and all stopping scenarios. Net QALYs and life years over a lifetime and 10-year horizon were positive for all scenarios under this assumption. Tables 29 and 30 show how the addition of aspirin prevented CVD deaths contributed to additional net QALYs and life years.

Table 28a Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (CVD Death RR = 0.95), Initiation Age 40-49y

| 10y use^*^ | Stop at age 65y | Stop at age 70y | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 2.5 | 54.5 | 69.1 | 81.6 | 91.8 | 97.5 | 100.4
7.5% 10y ASCVD Risk | 3.6 | 63.0 | 77.7 | 89.9 | 100.1 | 105.5 | 108.1
10% 10y ASCVD Risk | 5.5 | 84.1 | 98.7 | 109.6 | 117.0 | 123.2 | 126.3
15% 10y ASCVD Risk | 6.4 | 90.4 | 106.0 | 116.7 | 121.7 | 127.1 | 128.6
20% 10y ASCVD Risk | 8.1 | 102.9 | 120.4 | 134.3 | 142.4 | 146.0 | 149.2
Men, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 3.1 | 56.0 | 71.0 | 83.1 | 93.4 | 98.9 | 101.9
7.5% 10y ASCVD Risk | 3.9 | 63.8 | 79.2 | 91.7 | 102.0 | 107.4 | 109.8
10% 10y ASCVD Risk | 5.1 | 86.4 | 100.9 | 112.0 | 119.1 | 125.5 | 128.4
15% 10y ASCVD Risk | 5.8 | 91.1 | 106.9 | 117.3 | 121.7 | 127.3 | 128.6
20% 10y ASCVD Risk | 6.7 | 104.8 | 121.8 | 136.1 | 144.5 | 147.8 | 151.2
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 1.3 | 39.6 | 52.0 | 61.1 | 70.3 | 75.5 | 79.5
7.5% 10y ASCVD Risk | 2.1 | 47.6 | 61.6 | 73.7 | 80.2 | 86.5 | 91.3
10% 10y ASCVD Risk | 3.4 | 62.0 | 80.9 | 92.6 | 103.0 | 108.1 | 112.8
15% 10y ASCVD Risk | 3.5 | 65.4 | 82.3 | 95.8 | 104.4 | 110.8 | 115.8
20% 10y ASCVD Risk | 4.3 | 74.0 | 92.1 | 104.0 | 114.4 | 119.9 | 125.4
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 1.4 | 35.8 | 46.7 | 55.1 | 63.0 | 67.8 | 70.9
7.5% 10y ASCVD Risk | 2.2 | 44.2 | 57.1 | 67.8 | 73.7 | 79.2 | 83.2
10% 10y ASCVD Risk | 3.1 | 57.3 | 75.2 | 85.7 | 95.8 | 99.9 | 104.1
15% 10y ASCVD Risk | 2.8 | 58.4 | 73.6 | 86.7 | 94.1 | 100.1 | 104.8
20% 10y ASCVD Risk | 3.2 | 66.5 | 83.5 | 94.8 | 104.3 | 109.0 | 114.1

Notes: CVD=cardiovascular disease; RR=relative risk; ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. This table presents results for a sensitivity analysis in which the risk for CVD mortality was 5% lower (RR = 0.95) with aspirin use.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 28b Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (CVD Death RR = 0.95), Initiation Age 50-59y

| 10y use^*^ | Stop at age 65y | Stop at age 70y | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 3.7 | 29.1 | 43.8 | 56.5 | 66.5 | 72.6 | 77.1
7.5% 10y ASCVD Risk | 5.2 | 29.0 | 45.8 | 59.2 | 71.0 | 78.0 | 82.6
10% 10y ASCVD Risk | 6.3 | 36.6 | 52.2 | 67.2 | 77.3 | 85.6 | 89.4
15% 10y ASCVD Risk | 8.9 | 46.9 | 69.3 | 84.2 | 94.8 | 100.7 | 104.8
20% 10y ASCVD Risk | 10.4 | 57.0 | 80.4 | 96.0 | 109.0 | 115.3 | 119.6
Men, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 4.3 | 29.6 | 45.5 | 58.6 | 68.6 | 74.4 | 78.8
7.5% 10y ASCVD Risk | 5.7 | 30.1 | 46.6 | 60.0 | 71.8 | 78.5 | 83.3
10% 10y ASCVD Risk | 6.6 | 36.9 | 52.5 | 67.3 | 76.4 | 84.7 | 88.4
15% 10y ASCVD Risk | 8.3 | 46.7 | 69.5 | 83.9 | 94.6 | 100.3 | 104.5
20% 10y ASCVD Risk | 8.9 | 56.8 | 80.1 | 95.2 | 108.4 | 114.8 | 119.0
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 3.1 | 21.9 | 32.2 | 45.1 | 55.0 | 61.9 | 67.0
7.5% 10y ASCVD Risk | 3.4 | 25.5 | 39.1 | 51.3 | 60.2 | 67.5 | 73.4
10% 10y ASCVD Risk | 5.8 | 30.8 | 48.3 | 61.0 | 69.3 | 75.1 | 80.9
15% 10y ASCVD Risk | 8.0 | 41.2 | 61.7 | 76.7 | 88.3 | 94.8 | 100.2
20% 10y ASCVD Risk | 9.1 | 47.1 | 69.4 | 85.4 | 96.8 | 104.1 | 110.9
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 3.6 | 19.8 | 28.8 | 40.3 | 48.0 | 54.5 | 59.1
7.5% 10y ASCVD Risk | 3.0 | 21.8 | 33.3 | 43.8 | 51.9 | 58.1 | 63.7
10% 10y ASCVD Risk | 4.9 | 25.7 | 42.4 | 53.2 | 59.8 | 64.1 | 69.8
15% 10y ASCVD Risk | 6.9 | 37.7 | 56.2 | 70.2 | 80.9 | 86.0 | 90.6
20% 10y ASCVD Risk | 7.5 | 43.2 | 63.2 | 77.4 | 86.8 | 93.8 | 100.0

Notes: CVD=cardiovascular disease; RR=relative risk; ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. This table presents results for a sensitivity analysis in which the risk for CVD mortality was 5% lower (RR = 0.95) with aspirin use.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 28c Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (CVD Death RR = 0.95), Initiation Age 60-69y

| 10y use^*^ | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 3.2 | 26.7 | 35.5 | 45.3 | 51.3
7.5% 10y ASCVD Risk | 5.7 | 34.9 | 47.0 | 54.1 | 60.6
10% 10y ASCVD Risk | 7.6 | 40.8 | 54.3 | 62.5 | 68.0
15% 10y ASCVD Risk | 9.4 | 42.2 | 54.2 | 63.3 | 69.2
20% 10y ASCVD Risk | 11.3 | 45.4 | 60.1 | 66.8 | 72.0
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 4.3 | 27.4 | 36.3 | 45.6 | 51.6
7.5% 10y ASCVD Risk | 6.6 | 36.1 | 48.3 | 55.1 | 61.8
10% 10y ASCVD Risk | 8.4 | 41.6 | 55.2 | 63.4 | 69.2
15% 10y ASCVD Risk | 10.0 | 42.6 | 54.4 | 63.6 | 69.8
20% 10y ASCVD Risk | 10.7 | 45.0 | 60.0 | 66.5 | 71.5
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 3.8 | 22.3 | 29.5 | 34.2 | 40.2
7.5% 10y ASCVD Risk | 4.2 | 20.9 | 29.4 | 36.2 | 41.9
10% 10y ASCVD Risk | 4.9 | 23.7 | 36.1 | 43.1 | 48.7
15% 10y ASCVD Risk | 9.0 | 36.3 | 49.8 | 59.2 | 67.2
20% 10y ASCVD Risk | 10.6 | 38.9 | 54.0 | 63.7 | 70.8
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 5.0 | 21.4 | 26.5 | 30.1 | 35.5
7.5% 10y ASCVD Risk | 4.4 | 18.2 | 25.2 | 31.6 | 36.7
10% 10y ASCVD Risk | 4.8 | 20.5 | 30.9 | 37.1 | 41.8
15% 10y ASCVD Risk | 7.7 | 32.5 | 44.2 | 52.2 | 59.4
20% 10y ASCVD Risk | 7.8 | 33.1 | 45.8 | 54.1 | 60.5

Notes: CVD=cardiovascular disease; RR=relative risk; ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. This table presents results for a sensitivity analysis in which the risk for CVD mortality was 5% lower (RR = 0.95) with aspirin use.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 28d Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (CVD Death RR = 0.95), Initiation Age 70-79y

| 10y use^*^ | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | N/A | N/A | N/A
7.5% 10y ASCVD Risk | 6.4 | 24.2 | 34.0
10% 10y ASCVD Risk | 7.1 | 32.6 | 43.0
15% 10y ASCVD Risk | 9.4 | 37.1 | 45.4
20% 10y ASCVD Risk | 11.0 | 34.2 | 42.7
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | N/A | N/A | N/A
7.5% 10y ASCVD Risk | 8.0 | 25.9 | 35.8
10% 10y ASCVD Risk | 8.2 | 34.3 | 45.0
15% 10y ASCVD Risk | 10.9 | 39.7 | 48.3
20% 10y ASCVD Risk | 11.8 | 35.3 | 44.1
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | 2.6 | 16.4 | 23.1
7.5% 10y ASCVD Risk | 5.5 | 26.0 | 33.0
10% 10y ASCVD Risk | 5.0 | 21.6 | 29.1
15% 10y ASCVD Risk | 5.9 | 23.4 | 31.4
20% 10y ASCVD Risk | 6.4 | 23.1 | 32.4
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | 3.8 | 14.8 | 20.4
7.5% 10y ASCVD Risk | 6.4 | 25.2 | 31.3
10% 10y ASCVD Risk | 5.3 | 18.4 | 25.1
15% 10y ASCVD Risk | 6.2 | 20.7 | 28.0
20% 10y ASCVD Risk | 6.3 | 20.1 | 28.9

Notes: CVD=cardiovascular disease; RR=relative risk; ASCVD=atherosclerotic cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. This table presents results for a sensitivity analysis in which the risk for CVD mortality was 5% lower (RR = 0.95) with aspirin use.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 29 Lifetime Net Events of Aspirin for Men With Lifetime Use (CVD Death RR = 0.95)

| Benefits from aspirin; (Prevented events per 1,000 persons) | | | | | | Harms from aspirin; (Incurred events per 1,000 persons) | | | | Net Balance; (Benefits - harms)
10-yr ASCVD Risk (%) | Myocardial infarction | Ischemic stroke | Non-fatal CVD Events | CVD Deaths | CRC Cases | CRC Deaths | Major GI Bleeds | Major GI Bleed Deaths | Intracranial Hemorrhage | Intracranial Hemorrhage Deaths | Net QALYs | Net Life Years | Net Events Prevented
Men, Initiation Age 40-49 years
5 | 16.0 | 5.5 | 25.6 | 9.1 | −0.3 | 0.2 | 32.0 | 0.0 | 3.0 | 2.6 | 100.4 | 101.9 | −0.6
7.5 | 18.6 | 5.9 | 29.3 | 9.3 | −0.4 | 0.2 | 30.8 | 0.0 | 2.7 | 2.4 | 108.1 | 109.8 | 4.7
10 | 19.3 | 6.5 | 30.9 | 9.5 | −0.2 | 0.1 | 30.2 | 0.0 | 2.4 | 2.1 | 126.3 | 128.4 | 7.6
15 | 21.3 | 7.3 | 34.2 | 9.4 | −0.4 | 0.2 | 27.6 | 0.1 | 2.6 | 2.3 | 128.6 | 128.6 | 13.0
20 | 23.3 | 7.0 | 36.1 | 10.3 | −0.4 | 0.2 | 25.2 | 0.0 | 2.6 | 2.3 | 149.2 | 151.2 | 18.2
Men, Initiation Age 50-59 years
5 | 13.6 | 5.5 | 22.5 | 8.3 | −0.2 | 0.1 | 33.1 | 0.0 | 3.2 | 2.9 | 77.1 | 78.8 | −5.7
7.5 | 14.3 | 6.5 | 23.9 | 8.5 | −0.2 | 0.1 | 31.5 | 0.0 | 3.2 | 2.9 | 82.6 | 83.3 | −2.5
10 | 14.6 | 6.8 | 25.3 | 8.8 | −0.2 | 0.1 | 30.2 | 0.0 | 2.9 | 2.6 | 89.4 | 88.4 | 0.8
15 | 17.8 | 7.0 | 29.4 | 9.0 | −0.2 | 0.1 | 28.2 | 0.0 | 2.8 | 2.5 | 104.8 | 104.5 | 7.2
20 | 19.1 | 7.9 | 32.2 | 9.5 | −0.3 | 0.2 | 25.3 | 0.1 | 2.2 | 1.9 | 119.6 | 119.0 | 13.9
Men, Initiation Age 60-69 years
5 | 9.7 | 5.6 | 17.4 | 7.5 | −0.2 | 0.1 | 33.3 | 0.0 | 3.2 | 2.8 | 51.3 | 51.6 | −11.8
7.5 | 10.7 | 5.6 | 18.5 | 7.2 | −0.1 | 0.0 | 31.6 | 0.0 | 2.8 | 2.5 | 60.6 | 61.8 | −8.8
10 | 12.1 | 5.6 | 20.5 | 8.4 | −0.2 | 0.1 | 30.7 | 0.0 | 3.1 | 2.7 | 68.0 | 69.2 | −5.1
15 | 11.5 | 6.0 | 20.1 | 8.5 | −0.2 | 0.1 | 28.5 | 0.1 | 3.1 | 2.7 | 69.2 | 69.8 | −3.2
20 | 13.8 | 6.7 | 24.2 | 8.9 | −0.2 | 0.2 | 26.9 | 0.0 | 2.9 | 2.6 | 72.0 | 71.5 | 3.1
Men, Initiation Age 70-79 years
5 | - | - | - | - | - | - | - | - | - | - | - | - | -
7.5 | 7.7 | 4.3 | 13.5 | 6.5 | −0.2 | 0.1 | 28.2 | 0.1 | 2.6 | 2.3 | 34.0 | 35.8 | −11.0
10 | 8.4 | 4.7 | 14.9 | 7.2 | −0.1 | 0.1 | 28.6 | 0.0 | 2.7 | 2.3 | 43.0 | 45.0 | −9.3
15 | 8.3 | 4.7 | 14.5 | 7.3 | −0.1 | 0.0 | 27.8 | 0.0 | 2.7 | 2.1 | 45.4 | 48.3 | −8.8
20 | 9.2 | 5.2 | 16.0 | 6.9 | −0.2 | 0.1 | 26.1 | 0.0 | 2.7 | 2.2 | 42.7 | 44.1 | −6.1

Notes: ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; RR=relative risk; CRC=colorectal cancer; GI=gastrointestinal; QALY=quality-adjusted life year. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption; all else is held equal. MI and ischemic stroke events are non-fatal. The non-fatal CVD event column combines non-fatal MIs, ischemic strokes, and congestive heart failure (as a major sequela to MI). Net events prevented are defined by the net of benefit and harm events, or: (Non-fatal CVD events + CVD deaths + CRC cases) – (Major GI bleeds + intracranial hemorrhage). This table presents results for a sensitivity analysis in which the risk for CVD mortality was 5% lower (RR = 0.95) with aspirin use.

Table 30 Lifetime Net Events of Aspirin for Women With Lifetime Use (CVD Death RR = 0.95)

| Benefits from aspirin; (Prevented events per 1,000 persons) | | | | | | Harms from aspirin; (Incurred events per 1,000 persons) | | | | Net Balance; (Benefits - harms)
10-yr ASCVD Risk (%) | Myocardial infarction | Ischemic stroke | Non-fatal CVD Events | CVD Deaths | CRC Cases | CRC Deaths | Major GI Bleeds | Major GI Bleed Deaths | Intracranial Hemorrhage | Intracranial Hemorrhage Deaths | Net QALYs | Net Life Years | Net Events Prevented
Women, Initiation Age 40-49 years
5 | 9.9 | 9.3 | 22.5 | 7.5 | −0.2 | 0.1 | 32.3 | 0.0 | 4.1 | 3.6 | 79.5 | 70.9 | −6.6
7.5 | 10.1 | 9.2 | 23.0 | 8.2 | −0.2 | 0.1 | 30.8 | 0.0 | 3.3 | 3.0 | 91.3 | 83.2 | −3.1
10 | 10.9 | 9.8 | 25.1 | 8.4 | −0.2 | 0.1 | 29.7 | 0.0 | 3.0 | 2.8 | 112.8 | 104.1 | 0.6
15 | 11.2 | 10.1 | 26.0 | 8.8 | −0.2 | 0.1 | 29.7 | 0.0 | 3.0 | 2.7 | 115.8 | 104.8 | 1.9
20 | 11.6 | 10.7 | 27.6 | 9.0 | −0.2 | 0.1 | 30.3 | 0.0 | 2.8 | 2.5 | 125.4 | 114.1 | 3.3
Women, Initiation Age 50-59 years
5 | 8.0 | 9.4 | 20.4 | 7.5 | −0.2 | 0.1 | 31.4 | 0.0 | 4.1 | 3.4 | 67.0 | 59.1 | −7.8
7.5 | 8.6 | 9.9 | 21.9 | 7.9 | −0.2 | 0.1 | 29.2 | 0.0 | 3.8 | 3.4 | 73.4 | 63.7 | −3.4
10 | 8.8 | 10.5 | 22.5 | 8.4 | −0.1 | 0.1 | 28.3 | 0.0 | 3.6 | 3.3 | 80.9 | 69.8 | −1.1
15 | 10.0 | 11.2 | 25.5 | 8.2 | −0.2 | 0.1 | 27.2 | 0.0 | 3.2 | 2.9 | 100.2 | 90.6 | 3.1
20 | 10.8 | 11.2 | 27.9 | 9.1 | −0.2 | 0.2 | 25.9 | 0.0 | 3.0 | 2.7 | 110.9 | 100.0 | 7.9
Women, Initiation Age 60-69 years
5 | 5.5 | 7.7 | 15.1 | 6.4 | −0.1 | 0.0 | 30.8 | 0.0 | 4.1 | 3.5 | 40.2 | 35.5 | −13.5
7.5 | 6.2 | 7.6 | 15.5 | 6.3 | −0.1 | 0.0 | 29.1 | 0.0 | 3.8 | 3.2 | 41.9 | 36.7 | −11.2
10 | 6.2 | 8.6 | 17.3 | 6.8 | −0.1 | 0.1 | 27.9 | 0.0 | 3.7 | 3.2 | 48.7 | 41.8 | −7.6
15 | 6.9 | 10.0 | 19.6 | 7.5 | −0.2 | 0.1 | 26.2 | 0.0 | 3.3 | 2.9 | 67.2 | 59.4 | −2.6
20 | 7.6 | 11.0 | 22.1 | 7.9 | −0.1 | 0.1 | 25.5 | 0.0 | 3.4 | 2.8 | 70.8 | 60.5 | 1.0
Women, Initiation Age 70-79 years
5 | 4.1 | 6.7 | 11.9 | 5.0 | 0.0 | 0.0 | 29.6 | 0.0 | 3.8 | 3.2 | 23.1 | 20.4 | −16.5
7.5 | 4.4 | 6.6 | 12.2 | 5.7 | −0.1 | 0.0 | 28.5 | 0.0 | 3.3 | 2.7 | 33.0 | 31.3 | −14.0
10 | 4.2 | 6.9 | 12.6 | 5.3 | −0.1 | 0.1 | 27.5 | 0.0 | 3.1 | 2.6 | 29.1 | 25.1 | −12.8
15 | 4.8 | 7.4 | 13.6 | 5.6 | 0.0 | 0.0 | 24.9 | 0.0 | 3.5 | 2.9 | 31.4 | 28.0 | −9.2
20 | 5.1 | 7.0 | 14.2 | 6.1 | −0.1 | 0.0 | 24.3 | 0.0 | 3.6 | 2.9 | 32.4 | 28.9 | −7.7

Notes: ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; RR=relative risk; CRC=colorectal cancer; GI=gastrointestinal; QALY=quality-adjusted life year. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption; all else is held equal. MI and ischemic stroke events are non-fatal. The non-fatal CVD event column combines non-fatal MIs, ischemic strokes, and congestive heart failure (as a major sequela to MI). Net events prevented are defined by the net of benefit and harm events, or: (Non-fatal CVD events + CVD deaths + CRC cases) – (Major GI bleeds + intracranial hemorrhage). This table presents results for a sensitivity analysis in which the risk for CVD mortality was 5% lower (RR = 0.95) with aspirin use.

Tables 31a–31d show the effect of assuming aspirin increases the risk of fatal major GI bleeds by the same amount (OR=1.58) as non-fatal bleeds. While not as dramatic as the two prior examples, this assumption reduced estimated lifetime net QALYs and life years across the board, resulting in many more population groups predicted to experience net harm. Tables 32 and 33 show how the addition of aspirin-caused major GI bleeding deaths reduced net QALYs and life years.

Table 31a Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (GIB Death RR = 1.58), Initiation Age 40-49y

| 10y use^*^ | Stop at age 65y | Stop at age 70y | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −1.2 | 2.0 | 3.6 | 3.7 | 3.9 | 3.5 | 2.1
7.5% 10y ASCVD Risk | −1.5 | 5.8 | 8.1 | 9.6 | 10.4 | 10.0 | 9.8
10% 10y ASCVD Risk | −0.4 | 22.5 | 25.3 | 27.6 | 29.6 | 28.9 | 29.3
15% 10y ASCVD Risk | −0.1 | 29.9 | 32.3 | 33.9 | 33.2 | 34.0 | 33.4
20% 10y ASCVD Risk | 0.7 | 40.7 | 44.7 | 48.2 | 50.8 | 50.9 | 50.9
Men, Net Life Years per 1000 persons
5% 10y ASCVD Risk | −1.2 | −5.5 | −5.9 | −8.4 | −10.0 | −11.8 | −13.9
7.5% 10y ASCVD Risk | −1.9 | −3.5 | −2.8 | −3.0 | −3.8 | −5.3 | −6.2
10% 10y ASCVD Risk | −1.6 | 14.1 | 14.7 | 15.7 | 16.4 | 14.5 | 14.3
15% 10y ASCVD Risk | −1.8 | 19.7 | 20.0 | 19.5 | 17.1 | 17.2 | 15.8
20% 10y ASCVD Risk | −1.8 | 31.1 | 32.2 | 34.1 | 36.0 | 35.1 | 34.6
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −0.9 | −2.9 | −2.4 | −7.2 | −7.4 | −9.1 | −10.4
7.5% 10y ASCVD Risk | −0.7 | 3.6 | 4.1 | 4.0 | 2.7 | 2.0 | 1.5
10% 10y ASCVD Risk | −0.3 | 13.8 | 19.9 | 20.0 | 21.1 | 19.9 | 19.4
15% 10y ASCVD Risk | 0.1 | 21.5 | 26.0 | 28.3 | 28.1 | 28.2 | 27.8
20% 10y ASCVD Risk | 0.6 | 27.6 | 32.2 | 32.7 | 34.8 | 34.6 | 35.1
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | −1.2 | −14.2 | −17.4 | −25.6 | −28.8 | −32.5 | −35.6
7.5% 10y ASCVD Risk | −1.0 | −8.3 | −11.8 | −15.4 | −18.9 | −21.8 | −24.1
10% 10y ASCVD Risk | −1.1 | 0.2 | 2.9 | −0.5 | −1.8 | −5.1 | −7.1
15% 10y ASCVD Risk | −1.2 | 6.1 | 6.4 | 6.1 | 3.0 | 1.3 | −0.3
20% 10y ASCVD Risk | −1.2 | 11.3 | 12.1 | 9.8 | 9.1 | 7.0 | 6.2

Notes: GIB=major gastrointestinal bleeding; RR=relative risk; ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. This table presents results for a sensitivity analysis in which the risk for major GI mortality was 58% higher (RR = 1.58) with aspirin use.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 31b Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (GIB Death RR = 1.58), Initiation Age 50-59y

| 10y use^*^ | Stop at age 65y | Stop at age 70y | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −3.0 | −8.3 | −10.6 | −12.3 | −14.3 | −14.9 | −16.3
7.5% 10y ASCVD Risk | −3.3 | −5.5 | −5.5 | −9.1 | −8.8 | −9.5 | −10.2
10% 10y ASCVD Risk | −3.0 | −0.4 | −2.5 | −3.4 | −4.2 | −4.6 | −5.3
15% 10y ASCVD Risk | −1.9 | 9.0 | 13.7 | 15.3 | 16.1 | 15.1 | 15.1
20% 10y ASCVD Risk | −1.0 | 20.0 | 26.2 | 29.8 | 33.0 | 33.2 | 33.7
Men, Net Life Years per 1000 persons
5% 10y ASCVD Risk | −3.4 | −14.1 | −18.0 | −21.9 | −26.0 | −28.1 | −30.9
7.5% 10y ASCVD Risk | −4.1 | −10.5 | −13.7 | −20.4 | −22.2 | −24.6 | −26.2
10% 10y ASCVD Risk | −4.2 | −6.3 | −11.6 | −15.7 | −19.4 | −21.4 | −23.0
15% 10y ASCVD Risk | −4.4 | 2.2 | 3.9 | 2.6 | 1.7 | −0.9 | −1.6
20% 10y ASCVD Risk | −4.4 | 13.1 | 15.9 | 16.6 | 18.1 | 17.1 | 16.9
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −3.2 | −6.3 | −10.5 | −14.1 | −14.6 | −17.5 | −19.4
7.5% 10y ASCVD Risk | −2.5 | −0.4 | 0.1 | 0.1 | −3.2 | −4.6 | −6.2
10% 10y ASCVD Risk | −1.6 | 2.3 | 4.4 | 4.9 | 2.8 | 1.1 | −0.5
15% 10y ASCVD Risk | −0.1 | 9.1 | 13.6 | 16.4 | 16.7 | 16.0 | 16.0
20% 10y ASCVD Risk | 0.4 | 15.3 | 23.3 | 24.8 | 26.9 | 25.7 | 25.2
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | −3.7 | −13.4 | −21.7 | −29.8 | −34.5 | −39.5 | −43.5
7.5% 10y ASCVD Risk | −3.8 | −8.8 | −12.9 | −17.2 | −23.5 | −27.6 | −31.1
10% 10y ASCVD Risk | −3.7 | −7.9 | −9.6 | −13.4 | −19.2 | −23.6 | −26.8
15% 10y ASCVD Risk | −2.7 | −0.6 | −1.2 | −1.8 | −4.6 | −7.9 | −9.8
20% 10y ASCVD Risk | −2.8 | 5.1 | 8.2 | 5.0 | 3.3 | 0.1 | −2.3

Notes: GIB=major gastrointestinal bleeding; RR=relative risk; ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. This table presents results for a sensitivity analysis in which the risk for major GI mortality was 58% higher (RR = 1.58) with aspirin use.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 31c Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (GIB Death RR = 1.58), Initiation Age 60-69y

| 10y use^*^ | Stop at age 75y | Stop at age 80y | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −6.1 | −19.5 | −24.4 | −24.3 | −26.7
7.5% 10y ASCVD Risk | −5.3 | −14.4 | −15.4 | −18.8 | −19.2
10% 10y ASCVD Risk | −4.7 | −8.1 | −9.2 | −12.0 | −13.7
15% 10y ASCVD Risk | −5.5 | −5.3 | −6.2 | −8.1 | −9.8
20% 10y ASCVD Risk | −5.1 | 0.0 | 0.0 | −1.5 | −1.7
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −6.3 | −26.8 | −33.9 | −36.1 | −39.9
7.5% 10y ASCVD Risk | −6.2 | −21.7 | −25.1 | −30.7 | −32.1
10% 10y ASCVD Risk | −6.0 | −15.9 | −19.6 | −24.3 | −27.2
15% 10y ASCVD Risk | −7.3 | −13.2 | −16.7 | −20.5 | −23.3
20% 10y ASCVD Risk | −8.4 | −8.9 | −11.5 | −14.8 | −16.1
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −4.0 | −14.2 | −19.7 | −24.8 | −28.3
7.5% 10y ASCVD Risk | −3.8 | −9.7 | −14.8 | −18.8 | −21.8
10% 10y ASCVD Risk | −3.7 | −4.3 | −3.8 | −7.8 | −12.9
15% 10y ASCVD Risk | −2.7 | 0.1 | 0.4 | −1.3 | −2.1
20% 10y ASCVD Risk | −0.0 | 8.0 | 9.0 | 8.6 | 7.5
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | −4.1 | −21.7 | −31.5 | −39.5 | −45.4
7.5% 10y ASCVD Risk | −4.9 | −18.0 | −27.4 | −33.6 | −38.9
10% 10y ASCVD Risk | −5.3 | −13.0 | −16.6 | −23.5 | −31.4
15% 10y ASCVD Risk | −6.0 | −10.5 | −14.7 | −19.7 | −23.1
20% 10y ASCVD Risk | −4.6 | −4.0 | −8.3 | −11.9 | −15.5

Notes: GIB=major gastrointestinal bleeding; RR=relative risk; ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. This table presents results for a sensitivity analysis in which the risk for major GI mortality was 58% higher (RR = 1.58) with aspirin use.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 31d Net Benefit of Aspirin After 10 Years and Lifetime Net Benefit at Stopping Intervals and With Lifetime Use (GIB Death RR = 1.58), Initiation Age 70-79y

| 10y use^*^ | Stop at age 85y | Lifetime use
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | N/A | N/A | N/A
7.5% 10y ASCVD Risk | −7.5 | −17.4 | −18.3
10% 10y ASCVD Risk | −7.4 | −16.4 | −18.2
15% 10y ASCVD Risk | −6.7 | −13.7 | −15.5
20% 10y ASCVD Risk | −5.9 | −9.3 | −12.4
Men, Net QALYs per 1000 persons
5% 10y ASCVD Risk | N/A | N/A | N/A
7.5% 10y ASCVD Risk | −8.1 | −23.0 | −25.9
10% 10y ASCVD Risk | −8.6 | −23.0 | −26.7
15% 10y ASCVD Risk | −8.0 | −20.1 | −23.4
20% 10y ASCVD Risk | −8.0 | −16.0 | −20.8
Women, Net QALYs per 1000 persons
5% 10y ASCVD Risk | −5.1 | −21.3 | −26.8
7.5% 10y ASCVD Risk | −5.6 | −17.9 | −23.5
10% 10y ASCVD Risk | −6.1 | −20.0 | −24.3
15% 10y ASCVD Risk | −5.5 | −13.0 | −17.6
20% 10y ASCVD Risk | −6.6 | −12.6 | −16.9
Women, Net Life Years per 1000 persons
5% 10y ASCVD Risk | −5.1 | −29.2 | −38.2
7.5% 10y ASCVD Risk | −6.5 | −26.7 | −35.4
10% 10y ASCVD Risk | −7.7 | −30.6 | −38.0
15% 10y ASCVD Risk | −7.3 | −22.7 | −30.4
20% 10y ASCVD Risk | −9.0 | −22.1 | −29.3

Notes: GIB=major gastrointestinal bleeding; RR=relative risk; ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; QALY=quality-adjusted life year; N/A=not applicable; y=years. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption. All else is held equal. Stopping age indicates the age at which persons in the aspirin for primary prevention arm stop aspirin. This table presents results for a sensitivity analysis in which the risk for major GI mortality was 58% higher (RR = 1.58) with aspirin use.

* The “10y use” column indicates net benefit over 10 years of aspirin use. All other columns indicate net benefits over a lifetime horizon.

Table 32 Lifetime Net Events of Aspirin for Men With Lifetime Use (Major GI Bleeding Death RR = 1.58)

| Benefits from aspirin; (Prevented events per 1,000 persons) | | | | | | Harms from aspirin; (Incurred events per 1,000 persons) | | | | Net Balance; (Benefits - harms)
10-yr ASCVD Risk (%) | Myocardial infarction | Ischemic stroke | Non-fatal CVD Events | CVD Deaths | CRC Cases | CRC Deaths | Major GI Bleeds | Major GI Bleed Deaths | Intracranial Hemorrhage | Intracranial Hemorrhage Deaths | Net QALYs | Net Life Years | Net Events Prevented
Men, Initiation Age 40-49 years
5 | 17.2 | 6.2 | 28.9 | 5.1 | - | - | 33.3 | 1.7 | 2.9 | 2.6 | 2.1 | −13.9 | −2.2
7.5 | 19.9 | 6.7 | 32.9 | 5.1 | - | - | 31.8 | 1.6 | 2.5 | 2.3 | 9.8 | −6.2 | 3.7
10 | 20.8 | 7.2 | 34.6 | 5.7 | - | - | 31.3 | 1.5 | 2.3 | 2.0 | 29.3 | 14.3 | 6.7
15 | 22.7 | 8.0 | 38.3 | 6.0 | - | - | 28.5 | 1.6 | 2.5 | 2.2 | 33.4 | 15.8 | 13.3
20 | 25.2 | 7.8 | 40.9 | 6.5 | - | - | 26.1 | 1.2 | 2.4 | 2.2 | 50.9 | 34.6 | 18.9
Men, Initiation Age 50-59 years
5 | 14.4 | 6.1 | 25.2 | 4.1 | - | - | 34.4 | 1.9 | 3.1 | 2.8 | −16.3 | −30.9 | −8.2
7.5 | 15.4 | 7.0 | 27.0 | 4.3 | - | - | 32.8 | 1.8 | 3.0 | 2.7 | −10.2 | −26.2 | −4.5
10 | 15.9 | 7.5 | 29.0 | 4.6 | - | - | 31.7 | 1.9 | 2.8 | 2.5 | −5.3 | −23.0 | −0.9
15 | 19.0 | 7.8 | 33.1 | 5.0 | - | - | 29.4 | 1.5 | 2.6 | 2.4 | 15.1 | −1.6 | 6.1
20 | 20.6 | 8.6 | 36.4 | 5.6 | - | - | 26.3 | 1.4 | 2.1 | 1.9 | 33.7 | 16.9 | 13.6
Men, Initiation Age 60-69 years
5 | 10.2 | 6.0 | 19.4 | 3.2 | - | - | 34.9 | 2.2 | 3.0 | 2.6 | −26.7 | −39.9 | −15.3
7.5 | 11.5 | 6.2 | 21.1 | 3.0 | - | - | 32.7 | 2.1 | 2.7 | 2.4 | −19.2 | −32.1 | −11.3
10 | 12.9 | 6.1 | 23.1 | 3.7 | - | - | 32.4 | 2.1 | 2.9 | 2.6 | −13.7 | −27.2 | −8.5
15 | 12.4 | 6.6 | 22.9 | 3.7 | - | - | 29.7 | 1.9 | 3.0 | 2.6 | −9.8 | −23.3 | −6.1
20 | 15.0 | 7.4 | 27.7 | 4.7 | - | - | 28.2 | 1.8 | 2.7 | 2.4 | −1.7 | −16.1 | 1.5
Men, Initiation Age 70-79 years
5 | - | - | - | - | - | - | - | - | - | - | - | - | -
7.5 | 8.1 | 4.7 | 15.1 | 2.1 | - | - | 30.0 | 1.8 | 2.5 | 2.3 | −18.3 | −25.9 | −15.3
10 | 9.0 | 5.2 | 17.0 | 2.7 | - | - | 30.2 | 2.1 | 2.6 | 2.2 | −18.2 | −26.7 | −13.1
15 | 9.1 | 5.2 | 16.7 | 2.5 | - | - | 29.3 | 1.7 | 2.5 | 2.1 | −15.5 | −23.4 | −12.6
20 | 9.9 | 5.6 | 18.0 | 2.3 | - | - | 27.7 | 1.8 | 2.6 | 2.1 | −12.4 | −20.8 | −10.0

Notes: ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; CRC=colorectal cancer; GI=gastrointestinal; QALY=quality-adjusted life year. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption; all else is held equal. MI and ischemic stroke events are non-fatal. The non-fatal CVD event column combines non-fatal MIs, ischemic strokes, and congestive heart failure (as a major sequela to MI). Net events prevented are defined by the net of benefit and harm events, or: (Non-fatal CVD events + CVD deaths + CRC cases) – (Major GI bleeds + intracranial hemorrhage). This table presents results for a sensitivity analysis in which the risk for major GI mortality was 58% higher (RR = 1.58) with aspirin use.

Table 33 Lifetime Net Events of Aspirin for Women With Lifetime Use (Major GI Bleeding Death RR = 1.58)

| Benefits from aspirin; (Prevented events per 1,000 persons) | | | | | | Harms from aspirin; (Incurred events per 1,000 persons) | | | | Net Balance; (Benefits - harms)
10-yr ASCVD Risk (%) | Myocardial infarction | Ischemic stroke | Non-fatal CVD Events | CVD Deaths | CRC Cases | CRC Deaths | Major GI Bleeds | Major GI Bleed Deaths | Intracranial Hemorrhage | Intracranial Hemorrhage Deaths | Net QALYs | Net Life Years | Net Events Prevented
Women, Initiation Age 40-49 years
5 | 10.4 | 9.9 | 25.1 | 3.8 | - | - | 33.2 | 1.5 | 4.0 | 3.5 | −10.4 | −35.6 | −8.3
7.5 | 10.7 | 10.1 | 26.3 | 4.5 | - | - | 31.7 | 1.5 | 3.1 | 2.8 | 1.5 | −24.1 | −4.0
10 | 11.4 | 10.6 | 28.2 | 4.6 | - | - | 30.5 | 1.2 | 3.0 | 2.8 | 19.4 | −7.1 | −0.7
15 | 11.7 | 10.8 | 29.3 | 5.0 | - | - | 30.3 | 1.2 | 2.9 | 2.6 | 27.8 | −0.3 | 1.1
20 | 12.2 | 11.6 | 30.9 | 5.3 | - | - | 31.5 | 1.2 | 2.7 | 2.4 | 35.1 | 6.2 | 2.0
Women, Initiation Age 50-59 years
5 | 8.4 | 10.0 | 22.7 | 3.4 | - | - | 32.3 | 1.7 | 4.0 | 3.4 | −19.4 | −43.5 | −10.2
7.5 | 9.0 | 10.5 | 24.6 | 3.9 | - | - | 30.4 | 1.4 | 3.8 | 3.4 | −6.2 | −31.1 | −5.7
10 | 9.2 | 11.1 | 25.0 | 4.4 | - | - | 29.6 | 1.4 | 3.5 | 3.2 | −0.5 | −26.8 | −3.7
15 | 10.5 | 12.0 | 28.4 | 4.2 | - | - | 28.1 | 1.3 | 3.1 | 2.8 | 16.0 | −9.8 | 1.4
20 | 11.5 | 12.0 | 31.0 | 4.9 | - | - | 26.7 | 1.3 | 2.9 | 2.6 | 25.2 | −2.3 | 6.3
Women, Initiation Age 60-69 years
5 | 5.8 | 8.0 | 16.7 | 2.5 | - | - | 32.0 | 1.8 | 4.0 | 3.5 | −28.3 | −45.4 | −16.8
7.5 | 6.5 | 8.3 | 17.7 | 2.4 | - | - | 30.4 | 1.7 | 3.7 | 3.2 | −21.8 | −38.9 | −14.0
10 | 6.5 | 9.3 | 19.3 | 2.9 | - | - | 29.4 | 1.6 | 3.5 | 3.1 | −12.9 | −31.4 | −10.7
15 | 7.2 | 10.7 | 22.2 | 3.4 | - | - | 27.4 | 1.5 | 3.2 | 2.8 | −2.1 | −23.1 | −5.0
20 | 8.1 | 11.7 | 25.1 | 4.0 | - | - | 26.6 | 1.2 | 3.3 | 2.8 | 7.5 | −15.5 | −0.8
Women, Initiation Age 70-79 years
5 | 4.3 | 7.0 | 13.1 | 1.5 | - | - | 31.1 | 1.7 | 3.7 | 3.2 | −26.8 | −38.2 | −20.2
7.5 | 4.8 | 7.0 | 13.8 | 1.6 | - | - | 30.2 | 1.9 | 3.3 | 2.7 | −23.5 | −35.4 | −18.1
10 | 4.5 | 7.2 | 14.0 | 1.7 | - | - | 29.0 | 2.1 | 3.0 | 2.5 | −24.3 | −38.0 | −16.3
15 | 5.1 | 7.8 | 15.1 | 1.7 | - | - | 26.4 | 1.3 | 3.4 | 2.9 | −17.6 | −30.4 | −13.0
20 | 5.4 | 7.4 | 15.6 | 2.1 | - | - | 25.7 | 1.6 | 3.5 | 2.9 | −16.9 | −29.3 | −11.5

Notes: ASCVD=atherosclerotic cardiovascular disease; CVD=cardiovascular disease; CRC=colorectal cancer; GI=gastrointestinal; QALY=quality-adjusted life year. The 10-year ASCVD risk levels are based on the ACC/AHA risk calculator and refer to a person’s risk at model baseline/initiation. Risk levels are rounded to the nearest threshold (+/− 0.5%). Results reflect the difference between universal adoption of aspirin for primary prevention versus zero adoption; all else is held equal. MI and ischemic stroke events are non-fatal. The non-fatal CVD event column combines non-fatal MIs, ischemic strokes, and congestive heart failure (as a major sequela to MI). Net events prevented are defined by the net of benefit and harm events, or: (Non-fatal CVD events + CVD deaths + CRC cases) – (Major GI bleeds + intracranial hemorrhage). This table presents results for a sensitivity analysis in which the risk for major GI mortality was 58% higher (RR = 1.58) with aspirin use.