# Chapter 2 Methods

This decision analysis uses microsimulation modeling to assess the net balance of harms and benefits from routine use of aspirin for the primary prevention of CVD for individuals with up to 20% risk of having a CVD event in the next ten years. The simulation uses evidence from the corresponding updated systematic evidence review conducted for the USPSTF [17]. Net benefits are assessed across three dimensions (sex, age, and baseline 10-year ASCVD risk) and two time horizons (lifetime and 10 years). Our decision analytic criterion was whether expected net benefit was positive (i.e., favoring aspirin use) or negative (i.e., indicating net harm and favoring aspirin non-use). Clinicians and patients may weigh the size of expected net benefit against uncertainty of the estimates to determine appropriateness of aspirin use.

## Key Questions

The decision model addressed two key questions (KQ) and one contextual question (CQ) described below and summarized in Table 1.

KQ1 For clinically meaningful subgroups defined by age, sex, and 10-year ASCVD risk, what is the lifetime net benefit of starting aspirin for the primary prevention of CVD—assuming lifetime continuation or until adverse event or death—in terms of net quality-adjusted life years (primary outcome), life years, and events?
KQ2 For clinically meaningful subgroups defined by age, sex, and 10-year ASCVD risk, how does assuming aspirin will be discontinued prior to an adverse event or death (expressed as 5-year age intervals for discontinuation) affect the lifetime benefit of starting aspirin for the primary prevention of CVD, in terms of quality-adjusted life years (primary outcome), net life years, and events?
CQ1 For clinically meaningful subgroups defined by age, sex, and 10-year ASCVD risk, what is the 10-year net benefit of starting aspirin—assuming continuation until adverse event or death—for the primary prevention of CVD in terms of net quality-adjusted life years (primary outcome), life years, and events?

Table 1 Summary of Key and Contextual Questions

Question | Example Clinical Scenario | Population | Outcomes | Outcome Time Horizon | Duration of Therapy or Stopping Age
KQ1 | [underlined: Patient]: 55 year old female without prior CVD or elevated bleeding risk and a 10% risk of a hard atherosclerotic event in the next 10 years; [underlined: Question]: If starting aspirin now, with a plan for continued lifetime use unless contraindicated, will the expected lifelong benefits exceed the harms? | [underlined: Age]: 40-49, 50-59, 60-69, and 70-79 years old; [underlined: Sex]: female or male; [underlined: 10-year ASCVD risk]: 5%, 7.5%, 10%, 15%, and 20% | QALYs^§^; Net life years; Events^†^ | Lifetime | Lifetime therapy or until adverse event or death
KQ2 | [underlined: Patient]: 55 year old female without prior CVD or elevated bleeding risk and a 10% risk of a hard atherosclerotic event in the next 10 years; [underlined: Question]: If starting aspirin now, would the expected lifelong net benefit of using aspirin be higher or lower, compared to lifetime use, if planning to stop therapy at age 75? | [underlined: Age]: 40-49, 50-59, 60-69, and 70-79 years old; [underlined: Sex]: female or male; [underlined: 10-year ASCVD risk]: 5%, 7.5%, 10%, 15%, and 20% | QALYs^§^; Net life years; Events^†^ | Lifetime | 5-year future stopping age intervals from 65 to 85 years vs. lifetime therapy (or until adverse event or death)
CQ1 | [underlined: Patient]: 55 year old female without prior CVD or elevated bleeding risk and a 10% risk of a hard atherosclerotic event in the next 10 years; [underlined: Question]: If starting aspirin now, with a plan for continued lifetime use unless contraindicated, will the benefits exceed the harms within 10 years? | [underlined: Age]: 40-49, 50-59, 60-69, and 70-79 years old; [underlined: Sex]: female or male; [underlined: 10-year ASCVD risk]: 5%, 7.5%, 10%, 15%, and 20% | QALYs^§^; Net life years; Events^†^ | 10 years | First 10 years of lifetime therapy or until adverse event or death

§ Quality-adjusted life years (primary outcome)

† Non-fatal myocardial infarction, non-fatal ischemic stroke, hospitalization for congestive heart failure (as a major sequelae to MI), cardiovascular disease-related death (excluding due to intracranial hemorrhage), colorectal cancer cases, colorectal cancer death, gastrointestinal bleeding, gastrointestinal bleeding death, intracranial hemorrhage, intracranial hemorrhage death

## Model Design

Analyses in this study were conducted using the HealthPartners Institute ModelHealth^TM^: Cardiovascular disease (ModelHealth: CVD) microsimulation model. ModelHealth: CVD also was used to conduct the 2016 decision analysis on aspirin for the USPSTF [12, 13]. This model was originally designed to assess the population health benefits and value of the USPSTF aspirin chemoprevention and CVD screening recommendations for the National Commission on Prevention Priorities [18, 19], but it has been broadly used for assessing disease prevention strategies in the U.S. population [20–23]. The model includes a CRC module capable of assessing primary prevention of either CRC cases or deaths directly. The model also includes detailed tobacco use microsimulation functions from the HealthPartners Institute ModelHealth^TM^: Tobacco model [24, 25] to capture correlation of smoking risk between CVD and CRC at the level of individual patients. The Technical Appendix provides a detailed description of the microsimulation model used for this study. ModelHealth: CVD is a discrete-event, annual-cycle microsimulation model parameterized to estimate the lifetime incidence of CVD events in a cross-section of individuals representative of the U.S. population. Modeled outcomes included incidence of myocardial infarction, ischemic stroke, intracranial hemorrhage, angina pectoris, congestive heart failure, intermittent claudication, diabetes, and CVD-related death. Variations in age, sex, and race/ethnicity were accounted for in the baseline prevalence of disease and in the distribution and progression of CVD risk factors. These risk factors included an individual’s body mass index (BMI), systolic blood pressure (SBP), total cholesterol, high- and low-density lipoprotein cholesterol (HDL-C/LDL-C), diabetes status, and cigarette smoking status.

CVD incidence was modeled annually. CVD events were predicted by one-year risk equations estimated specifically for the model from long-term epidemiological data sourced from the Framingham Heart Study [26, 27]. Event risk was estimated based on a person’s age, sex, BMI, blood pressure, cholesterol levels, smoking status, diabetes status, and previous history of CVD. CVD risk was not adjusted by race/ethnicity, but differences in cardiometabolic risk factors by race/ethnicity were accounted for in the model. Technical Appendix Table 7 summarizes the risk equations for CVD outcomes and diabetes in ModelHealth: CVD.

The annual progression of continuous CVD risk factors was modeled in a two-step process (Technical Appendix, Section 3.2). First, the probability of an increase, decrease, or maintenance of a risk factor was determined given individual characteristics and the previous year’s value. Second, if a risk factor changes, the amount of change was determined by a second set of equations using the same covariates. We estimated the equations that determine these probabilities using data from the Behavioral Risk Factor Surveillance System [28] and Framingham Heart Study [26, 27]. Tobacco cessation depended on a person’s current smoking status, time in that state, and their demographic characteristics using probabilities derived from the National Health Interview Survey data [29] and published estimates from longitudinal studies of smoking relapse [30–34].

Screening and treatment for hypertension and dyslipidemia in the model were consistent with national clinical guidelines [35–39], and identification and adherence patterns were consistent with the rates observed within the National Health and Nutrition Examination Survey (NHANES) [40, 41] (Technical Appendix, Sections 4.2 and 4.3). The use of antihypertensive drugs and lipid-acting agents was modeled as an exogenous treatment effect that modifies these respective risk factors and alters disease risk accordingly. The use of aspirin may affect the relative risk of non-fatal myocardial infarction and ischemic stroke, CVD-related mortality, CRC incidence, major GI bleeding, and intracranial hemorrhage.

Rates of fatal and non-fatal major GI bleeding for persons not using aspirin and without elevated bleeding risks were obtained from a large New Zealand cohort study [42] (Tables 2a and 2b). Major GI bleeding in these data was defined as gastrointestinal bleeds leading to hospitalization or death. The population without elevated bleeding risks was: aged 30-80 years; had no history of CVD, chronic kidney disease, and prior intracranial hemorrhage; had no history of aspirin, antiplatelet or anticoagulant use in the prior 6 months; and was not at high risk for bleeding based on comorbidities or co-treatments (non-aspirin nonsteroidal anti-inflammatory drugs, corticosteroids, or selective serotonin reuptake inhibitors in the prior 6 months). CRC was modeled using an incidence and case-fatality rate approach, which tracks cancer incidence and mortality for each agent (Technical Appendix, Section 3.6). Baseline incidence and case-fatality rates by age, sex, and race/ethnicity were estimated from National Cancer Institute’s Surveillance, Epidemiology, and End Results (SEER) data using SEER*Stat software version 8.3.8 [43]. Baseline incidence rates were adjusted according to smoking status using relative risks provided by the Smoking-Attributable Mortality, Morbidity, and Economic Costs (SAMMEC) as reported in the 2014 Surgeon General’s Report on the Health Consequences of Smoking [44]. Baseline CRC incidence rates used in the model reflect contemporary use of screening technologies, such as colonoscopy, which can prevent CRC by the identification and removal of precursor adenomatous polyps or adenoma.

Table 2a Annual Fatal Major GI Bleeding Incidence Rates in Non-Aspirin Users

| Base Case^a^ | Low Bound^b^ | High Bound^c^
Men
Age 40-49y | 0.002% | 0.000% | 0.004%
Age 50-59y | 0.007% | 0.003% | 0.011%
Age 60-69y | 0.016% | 0.007% | 0.025%
Age 70-79y | 0.021% | 0.000% | 0.041%
Age 80+y | 0.041%^d^ | 0.021%^e^ | 0.082%^f^
Women
Age 40-49y | 0.001% | 0.000% | 0.003%
Age 50-59y | 0.004% | 0.001% | 0.007%
Age 60-69y | 0.008% | 0.003% | 0.014%
Age 70-79y | 0.015% | 0.000% | 0.029%
Age 80+y | 0.029%^d^ | 0.015%^e^ | 0.058%^f^

Notes: y=years. Baseline major GI bleeding risks are the probabilities of developing a major GI bleed, without aspirin, by age and sex.

a) for ages 40-70 years, major GI bleeding incidence rates in the “nonmedication cohort” from Selak et al. [42];

b) for ages 40-79 years, lower threshold of 95% confidence interval;

c) for ages 40-79 years, lower threshold of 95% confidence interval;

d) based on the upper threshold of the 95% confidence interval for ages 70-79 years;

e) assumes half the base case;

f) assumes double the base rate; low and high bounds are for sensitivity analyses.

Table 2b Annual Non-Fatal Major GI Bleeding Incidence Rates in Non-Aspirin Users

| Base Case^a^ | Low Bound^b^ | High Bound^c^
Men
Age 40-49y | 0.14% | 0.12% | 0.15%
Age 50-59y | 0.16% | 0.14% | 0.18%
Age 60-69y | 0.24% | 0.21% | 0.28%
Age70-79y | 0.37% | 0.28% | 0.45%
Age 80+y | 0.45%^d^ | 0.23%^e^ | 0.90%^f^
Women
Age 40-49y | 0.10% | 0.08% | 0.12%
Age 50-59y | 0.13% | 0.12% | 0.15%
Age 60-69y | 0.20% | 0.17% | 0.22%
Age 70-79y | 0.29% | 0.23% | 0.36%
Age 80+y | 0.36%^d^ | 0.18%^e^ | 0.72%^f^

Notes: y=years. Baseline major GI bleeding risks are the probabilities of developing a major GI bleed, without aspirin, by age and sex.

a) for ages 40-70 years, major GI bleeding incidence rates in the “nonmedication cohort” from Selak et al. [42];

b) for ages 40-79 years, lower threshold of 95% confidence interval;

c) for ages 40-79 years, lower threshold of 95% confidence interval;

d) based on the upper threshold of the 95% confidence interval for ages 70-79 years;

e) assumes half the base case;

f) assumes double the base rate; low and high bounds are for sensitivity analyses.

## Patient Population

The key questions were assessed independently for men and women across four 10-year age bands (40-49, 50-59, 60-69, and 70-79 years old) and across baseline 10-year ASCVD risk bands that included 5%, 7.5%, 10%, 15%, and 20%, with each risk band defined by +/− 0.5% (1% bands). Baseline 10-year CVD risk was estimated using the American College of Cardiology/American Heart Association (ACC/AHA) Pooled Cohort risk equation for the first hard ASCVD event (non-fatal MI, non-fatal stroke, or coronary death) [45]. The calculation of ASCVD risk at baseline is independent from the event rates predicted by the model. Therefore, the model mirrors use of ASCVD risk identification in clinical practice where an individual’s 10-year risk prediction does not necessarily correspond with future events. For each age, sex, and 1% baseline ASCVD risk band, simulated persons were randomly oversampled from population characteristics representative of the U.S. population to obtain a sample of 100,000 for each combination of age group, sex and 1% CVD risk band. For men aged 70-79 years, the 5% ASCVD 10-year risk band was excluded due to being rarely observed. To define the representative U.S. population from which the samples are drawn, initial demographic characteristics—including age, sex, and race/ethnicity—were obtained from the 2018 American Community Survey [46]. Initial CVD risk factors, including BMI, SBP, total cholesterol, LDL-C, HDL-C, BP treatment status, and diabetes status, were derived from the combined 2015-2018 NHANES surveys [40, 41]. Initial smoking status was derived from the combined 2017-2018 National Health Interview Surveys [47]. All persons for the decision analysis were free of CVD and CRC at baseline.

## Summary of Model Updates From 2016 to 2021

A number of elements to the model design have been updated from the 2016 decision model [12, 13] for use in the current analysis. Population demographics by age, sex, and race/ethnicity have been updated from the 2010 U.S. Census to estimates from the 2018 American Community Survey. Cardiometabolic risks have been updated from 2001-2010 to 2015-2018 data from NHANES. Smoking prevalence and transitions have been updated from 2007 to 2017-2018 data from the National Health Interview Survey. CRC incidence and case-fatality rates have been updated from data from SEER registry years 2001-2010 to years 2005-2017. Major GI bleeding incidence and fatality rates have been updated from an Italian cohort [48] and U.K. hospital data [49] with data from a large and more contemporary New Zealand cohort [42]. Death rates from causes other than CVD, CRC, and other smoking-attributable cancers have been updated from 2009-based life tables and mortality data to rates from 2017. Management of hypertension and high blood pressure in the model has been updated from following the Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure [50] and Adult Treatment Panel III [51] recommendations to be consistent with current USPSTF and ACC/AHA Task Force clinical practice guidelines [35–39]. The results will show that none of these model updates were a major factor in any key changes between findings of the 2021 and 2016 decision models.

## Integration of Systematic Evidence Review Results Into the Model

Findings from an updated systematic evidence review on aspirin conducted on behalf of the USPSTF [17] were integral to the parameter assumptions and model design in this study. This review incorporated the latest evidence on aspirin’s potential benefits and harms in the primary prevention of CVD and CRC. With an assessment of high confidence, the review found evidence that daily low dose (≤100 mg) aspirin use reduces the risk of non-fatal myocardial infarction (Odds Ratio [OR]=0.88, 95% confidence interval [CI]: 0.78-1.00) and non-fatal stroke (OR=0.88, 95% CI: 0.80-0.96) and increases the risk of major GI bleeding (OR=1.58, 95% CI: 1.38-1.80) and intracerebral hemorrhage (OR=1.31, 95% CI: 1.11-1.54). With an assessment of moderate confidence, the review found no to very small potential benefit for aspirin reducing risk of CVD mortality (OR=0.95, 95% CI: 0.86-1.05). With an assessment of insufficient evidence, the review found that aspirin may, after 10 years of use, reduce CRC incidence (OR=0.64, 95% CI: 0.52-0.79). The best balance of cardiovascular benefits to harms was reflected in daily aspirin doses of 100mg or less. There was not clear or compelling evidence that aspirin changes risk for fatal major GI bleeds. Nor was there evidence that aspirin effects differ for specific populations defined by age, sex, race/ethnicity, diabetes status, or ASCVD risk. Evidence review findings also were used to inform the data source for baseline levels of major GI bleeding risk, the selection of the ACC/AHA Pooled Cohort risk equation [45] to determine baseline ASCVD risk in the model, and a lack of evidence to inform patient preferences regarding use of aspirin or the effect on quality of life. The systematic evidence review did not assess the evidence for aspirin use in secondary prevention of CVD.

## Aspirin Benefits and Harms

All aspirin effects were modeled as relative risk modifications to the annual probability of an event. Model parameters for aspirin’s effects when used for primary prevention are summarized in Table 3. CVD and bleeding odds ratios from the updated systematic evidence review [17] were derived from primary prevention trials with aspirin dosing of 100mg of aspirin per day or less [14–16, 52–59]. Due to the updated systematic evidence review finding very low strength of evidence to support a reduction in CRC incidence from any dose of aspirin [17], this effect was not included in the base case analysis. The odds ratios for non-fatal myocardial infarction, non-fatal stroke, non-fatal major GI bleeding, and intracranial hemorrhage were used to approximate relative risks in the simulation base case analysis. The odds ratio confidence intervals informed the low and high bounds of the sensitivity analyses. The updated systematic evidence review also informed effects on reducing CVD mortality and increasing fatal major GI bleed risk in sensitivity analyses. All CVD benefits and harms were assumed to take effect immediately and relative risks were assumed to return to 1.00 with discontinuation of aspirin. Indirect effects of aspirin on CVD incidence and mortality may arise when the prevention or occurrence of an initial event alters the disease progression probabilities for subsequent events, as determined by the Framingham-derived risk equations internal to the model (Technical Appendix Table 7). Effects of aspirin after experiencing a non-fatal CVD event were derived from secondary prevention trials (Technical Appendix Table 18). In sensitivity analysis, the effect of aspirin on the risk of developing colorectal cancer was estimated from 4 randomized clinical trials [60–62] identified by the systematic evidence review [17]. Based on the systematic evidence review, the potential reduction in CRC incidence risk in sensitivity analysis was applied only after 10 years of continuous use and was assumed to persist for up to 10 years after stopping aspirin.

Table 3 Effects of Using Low-Dose (≤100 mg/d) Aspirin for Primary Prevention

Parameter | Base case | Worst Case | Best Case | Other values | Source
Benefits
CRC incidence (>10 years), relative risk | 1.00 | | | 0.64 | [17]
CVD death, relative risk | 1.00 | | | 0.95 | [17]
Non-fatal ischemic stroke, relative risk | 0.88 | 1.00 | 0.78 | | [17]
Non-fatal myocardial infarction, relative risk | 0.88 | 0.96 | 0.80 | | [17]
Harms
Intracranial hemorrhage, relative risk | 1.31 | 1.54 | 1.11 | | [17]
Fatal major GI bleeding, relative risk | 1.00 | | | 1.58 | Assumed, [17]
Non-fatal major GI bleeding, relative risk | 1.58 | 1.80 | 1.38 | | [17]

Notes: CRC=colorectal cancer; CVD=cardiovascular disease; GI=gastrointestinal. The odds ratios from the systematic evidence review [17] were used to approximate relative risks in the simulation analysis. The odds ratio confidence intervals informed the low and high bounds of the sensitivity analyses.

## Quality-of-Life Weights

Health utilities for the major outcomes affected by aspirin use were estimated using literature sources [63–72] and are summarized in Table 4. Living without a CVD condition or CRC was given a health utility of 0.87. All other health utility weights were applied multiplicatively to that baseline. Disutilities from myocardial infarction and major GI bleeding events were applied only during the year an event occurred. Quality-of-life reductions for congestive heart failure were included because, as a major sequela to myocardial infarction, incidence may be indirectly affected by aspirin use in the model. In the base case analysis, no disutility was applied to taking aspirin daily, but two alternative scenarios with aspirin disutilities were simulated in sensitivity analysis.

Table 4 Health Utility Weights

| First year/new event | Ongoing quality-of-life | Source
Baseline health utility weight
No CVD conditions | | 0.87 | [63, 65–68]
Relative health utility weight
Congestive heart failure | 0.79 | 0.79 | [64, 66–68, 72]
GI bleeding (major) | 0.91 | 1.00 | [72]
Intracranial hemorrhage | 0.60 | 0.60 | [63–67, 71, 72]
Ischemic stroke | 0.77 | 0.77 | [63–67, 72]
Myocardial Infarction | 0.86 | 1.00 | [63, 64, 66, 68, 72]
Taking aspirin daily, base case | | 1.00 | Assumption
Relative health utility weights for sensitivity analysis scenarios
Colorectal cancer | 0.70 | 0.70 | [69, 70]
Taking aspirin, sensitivity #1 | | 0.999 | Assumption
Taking aspirin, sensitivity #2 | | 0.995 | Assumption

Notes: CVD=cardiovascular disease; GI=gastrointestinal. All health utility weights are applied multiplicatively to the baseline health utility weight. The quality-of-life reduction for colorectal cancer is applied for up to five years in the case of non-fatal episodes. First year/new event health utility weights are applied during the year of an incidence event or first year of disease onset; ongoing health utilities are applied in subsequent years.

## Outcomes

Quality-adjusted life years (QALYs) and life years were the primary outcomes of the simulations, with QALYs selected as the leading measure because aspirin benefits and harms can affect both fatal and non-fatal outcomes. Simulated events included (benefits) non-fatal ischemic stroke, non-fatal myocardial infarction, combined non-fatal CVD events (non-fatal myocardial infarction, ischemic stroke, and congestive heart failure), CVD deaths (excluding those due to intracranial hemorrhage), CRC incidence, and CRC deaths and (harms) fatal and non-fatal major GI bleeding and intracranial hemorrhage. Net event totals were calculated as: (non-fatal CVD events + CVD deaths + CRC cases) – (major GI bleeding and intracranial hemorrhage events), with CRC cases included only in sensitivity analysis.

## Time Horizon

To account for measurement of all relevant benefits and harms related to the decision to use aspirin for primary prevention, the primary time horizon was a person’s lifetime (KQ1 and KQ2). A 10-year time horizon was included to address CQ1.

## Decision Analysis Base Case

All analyses assessed outcomes of a simulated population initially without a history of CVD routinely using aspirin for the primary prevention compared to the same simulated population, all else held equal, not using aspirin for primary prevention (Figure 1). For secondary prevention (e.g., after a major CVD event), aspirin was initiated at contemporary rates of adherence in both simulation arms. To align with common clinical practice, aspirin use was discontinued permanently in both arms after any major GI bleeding or an intracranial hemorrhage event. Positive net QALYs and life years were deemed to favor aspirin use; negative net QALYs and life years were deemed to favor aspirin nonuse. Model simulations were independently conducted with a sample population of 100,000 persons for each age, sex, and baseline ASCVD risk group.

Figure 1 Decision Analysis Design

Notes: Figure adapted from Dehmer et al. [13]. BMI=body mass index; SBP=systolic blood pressure; HDL=high-density lipoprotein; LDL=low-density lipoprotein; BP=blood pressure; CVD=cardiovascular disease; CRC=colorectal cancer.

Figure 1 shows the design of the decision analysis model workflow. At the initialization of the model, person-level attributes are assigned. If the modeled agent is assigned to the intervention group (aspirin for primary prevention), low-dose aspirin is initiated. If the agent is assigned to the counterfactual group (no aspirin for primary prevention), low-dose aspirin is not initiated. Following that decision point in the model, both groups follow the same path. Next is the assessment for screening and treatment for hypertension and lipid disorders. Next is a determination of whether the agent experiences any non-fatal events. If an agent experiences a non-fatal bleeding event, aspirin use is stopped. Next is a determination of whether the agent experiences a fatal event. If yes, the life cycle for that agent is complete. If no, person-level attributes are updated for the next annual cycle, which repeats this sequence.

## Uncertainty and Sensitivity Analysis

Two sources of uncertainty were considered in this study: stochastic heterogeneity resulting from the variability in outcomes experienced by a randomly selected sample population and parameter uncertainty resulting from the imprecision of model parameter estimates [73]. Confidence intervals reflecting stochastic heterogeneity were estimated by bootstrap resampling the simulated population for each stratified outcome 100,000 times with replacement. Deterministic (one-way) sensitivity analyses addressing uncertainty in key parameters were conducted by replicating simulations with all other parameters, probabilities, and population characteristics held equal.

## Model Validation

Baseline rates of CVD events were generated by the combination of population characteristics at model initiation, the model’s estimation of the natural progression of CVD risk factors as individuals age, and the model’s risk equations for disease. Tables 5a and 5b presents prevalence rates of myocardial infarction and ischemic stroke generated by the model for a birth cohort starting at age 40 and compares these values to corresponding rates observed in NHANES data [40, 41] as a benchmark for the external validity of the ModelHealth: CVD natural history engine.

Table 5a Comparison of ModelHealth: CVD Myocardial Infarction Event Rates With National Prevalence Estimates

| NHANES (2015-2018) | ModelHealth: CVD
Men
Age 40-49y | 1.2% | 2.2%
Age 50-59y | 5.0% | 5.3%
Age 60-69y | 10.3% | 10.3%
Age 70-79y | 16.8% | 16.0%
Women
Age 40-49y | 0.8% | 1.0%
Age 50-59y | 2.9% | 2.0%
Age 60-69y | 4.3% | 3.9%
Age 70-79y | 4.8% | 6.2%

Notes: y=years. NHANES=National Health and Nutrition Examination Survey; CVD=cardiovascular disease. This table compares myocardial infarction prevalence at various ages between NHANES 2015-2018 [40, 41] combined data and results from the ModelHealth: CVD model. Event rates indicate the percentage of the respective population with a history of event. The model run represented here is based on a birth cohort, starting at age 40 years, with hypertension screening and treatment, cholesterol screening and treatment, and aspirin for primary and secondary prevention all implemented and adopted at contemporary rates. For comparison purposes of the cross-sectional and longitudinal datasets, outcomes are calculated for the age range from NHANES and the mid-point of the age range from the ModelHealth: CVD output; this methodological difference can explain some small discrepancies.

Table 5b Comparison of ModelHealth: CVD Stroke Event Rates With National Prevalence Estimates

| NHANES (2015-2018) | ModelHealth: CVD
Men
Age 40-49y | 1.7% | 1.4%
Age 50-59y | 2.6% | 2.0%
Age 60-69y | 6.2% | 3.6%
Age 70-79y | 7.0% | 6.5%
Women
Age 40-49y | 1.4% | 0.9%
Age 50-59y | 3.8% | 1.5%
Age 60-69y | 3.7% | 2.9%
Age 70-79y | 8.3% | 5.6%

Notes: y=years. NHANES=National Health and Nutrition Examination Survey; CVD=cardiovascular disease. This table compares myocardial infarction prevalence at various ages between NHANES 2015-2018 [40, 41] combined data and results from the ModelHealth: CVD model. Event rates indicate the percentage of the respective population with a history of event. The model run represented here is based on a birth cohort, starting at age 40 years, with hypertension screening and treatment, cholesterol screening and treatment, and aspirin for primary and secondary prevention all implemented and adopted at contemporary rates. For comparison purposes of the cross-sectional and longitudinal datasets, outcomes are calculated for the age range from NHANES and the mid-point of the age range from the ModelHealth: CVD output; this methodological difference can explain some small discrepancies.