# Chapter 1 Introduction

In any given year, approximately 720,000 Americans will suffer their first coronary attack, and 610,000 will suffer their first stroke [1]. African Americans are at higher risk for heart attacks than their female and male counterparts of other race or ethnicity groups and are more likely to die following a heart attack [1]. Among cancers, colorectal cancer (CRC) is the third most common and deadly, accounting for about 8 percent of all new cases and deaths [2]. In economic terms, cardiovascular disease (CVD) and CRC account for more than $230 billion in direct medical costs annually, and the indirect costs from lost productivity and premature mortality are estimated to exceed $100 billion [1, 3, 4].

In 2016, the U.S. Preventive Services Task Force (USPSTF) recommended the initiation of low-dose aspirin use to prevent cardiovascular disease (CVD) and colorectal cancer (CRC) in adults aged 50-59 years (Grade: B) and 60-69 years (Grade: C) with ≥10% 10-year risk for first hard atherosclerotic CVD (ASCVD) event (i.e., for “primary prevention”) [5]. There was insufficient evidence to assess the initiation of aspirin use in adults aged <50 years or ≥70 years (Grade: I) [5]. The 2016 USPSTF aspirin recommendation for the prevention of CVD and CRC was supported by three separate systematic reviews [6–11] and a decision analysis [12, 13], with the systematic reviews informing key inputs to the decision analysis.

Since the release of the 2016 recommendation statement, findings from several large aspirin primary prevention trials have been published [14–16]. New evidence from these trials and other sources may alter the assessment of benefits and harms associated with using aspirin to prevent CVD and CRC. This decision analysis, informed by the systematic evidence review that has been conducted by the Kaiser Permanente Evidence Based Practice Center (EPC) [17], is designed to update estimates of the magnitude of the expected benefits and harms of using aspirin for primary prevention and support the USPSTF in updating their aspirin recommendation.