# References

1 Bibbins-Domingo K, U. S. Preventive Services Task Force. Aspirin Use for the Primary Prevention of Cardiovascular Disease and Colorectal Cancer: U.S. Preventive Services Task Force Recommendation Statement. Annals of internal medicine. 2016;164(12):836–45. PMID: 27064677. 10.7326/M16-0577 27064677
2 Guirguis-Blake JM, Evans CV, Senger CA, . Aspirin for the Primary Prevention of Cardiovascular Events: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2015. PMID: 2649176026491760.
3 Whitlock EP, Williams SB, Burda BU, . Aspirin Use in Adults: Cancer, All-Cause Mortality, and Harms: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2015. PMID: 2649175626491756.
4 Chubak J, Kamineni A, Buist DSM, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews (Evidence Syntheses, No. 133). Aspirin Use for the Prevention of Colorectal Cancer: An Updated Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2015.
5 Dehmer SP, Maciosek MV, Flottemesch TJ. Aspirin Use to Prevent Cardiovascular Disease and Colorectal Cancer: A Decision Analysis: Technical Report [Internet]. Rockville, MD: Agency for Healthcare Research and Quality (US); 2016. PMID: 2649175526491755.
6 American Heart Association. What is Cardiovascular Disease? https://www.heart.org/en/health-topics/consumer-healthcare/what-is-cardiovascular-disease. Accessed 10/8/2019. PMID: None.
7 Virani SS, Alonso A, Aparicio HJ, . Heart Disease and Stroke Statistics-2021 Update: A Report From the American Heart Association. Circulation. 2021;143(8):e254–e743. PMID: 33501848. 10.1161/CIR.0000000000000950 33501848
8 Murphy SL, Xu J, Kochanek KD, . Deaths: Final Data for 2018. Natl Vital Stat Rep. 2021;69(13):1–83. PMID: 33541516.33541516
9 Mensah GA, Wei GS, Sorlie PD, . Decline in Cardiovascular Mortality: Possible Causes and Implications. Circ Res. 2017;120(2):366–80. PMID: 28104770. 10.1161/CIRCRESAHA.116.309115 28104770
10 Vaughan AS, Ritchey MD, Hannan J, . Widespread recent increases in county-level heart disease mortality across age groups. Ann Epidemiol. 2017;27(12):796–800. PMID: 29122432. 10.1016/j.annepidem.2017.10.012 29122432
11 Nelson S, Whitsel L, Khavjou O, . Projections of cardiovascular disease prevalence and costs. RTI International; 2016. PMID: None.
12 Berry JD, Dyer A, Cai X, . Lifetime Risks of Cardiovascular Disease. New England Journal of Medicine. 2012;366(4):321–9. PMID: 22276822. 10.1056/NEJMoa1012848 22276822
13 Kressin NR, Orner MB, Manze M, . Understanding contributors to racial disparities in blood pressure control. Circ Cardiovasc Qual Outcomes. 2010;3(2):173–80. PMID: 20233981. 10.1161/CIRCOUTCOMES.109.860841 20233981
14 Rao S, Segar MW, Bress AP, . Association of Genetic West African Ancestry, Blood Pressure Response to Therapy, and Cardiovascular Risk Among Self-Reported Black Individuals in the Systolic Blood Pressure Reduction Intervention Trial (SPRINT). JAMA Cardiol. 2020. PMID: 33185651. 10.1001/jamacardio.2020.6566 33185651
15 American Cancer Society. Cancer Facts & Figures 2020. Atlanta, GA: 2020. PMID: None.
16 National Cancer Institute Surveillance Epidemiology and End Results (SEER) Program. Cancer Stat Facts: Colorectal Cancer. https://seer.cancer.gov/statfacts/html/colorect.html. Accessed Nov. 23, 2020. PMID: None.
17 Siegel RL, Miller KD, Goding Sauer A, . Colorectal cancer statistics, 2020. CA: a cancer journal for clinicians. 2020;70(3):145–64. PMID: None. 10.3322/caac.21601 32133645
18 Loomans-Kropp HA, Umar A. Increasing Incidence of Colorectal Cancer in Young Adults. J Cancer Epidemiol. 2019;2019:9841295. PMID: 31827515. 10.1155/2019/9841295 31827515
19 Joseph DA, King JB, Dowling NF, . Vital Signs: Colorectal Cancer Screening Test Use - United States, 2018. MMWR Morbidity and mortality weekly report. 2020;69(10):253–9. PMID: 32163384. 10.15585/mmwr.mm6910a1 32163384
20 Centers for Disease Control and Prevention. Know your risk for heart disease. https://www.cdc.gov/heartdisease/risk_factors.htm. Accessed 11/20/20. PMID: None.
21 Goff DC, Jr., Lloyd-Jones DM, Bennett G, . 2013 ACC/AHA guideline on the assessment of cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. Circulation. 2014;129(25 Suppl 2):S49–73. PMID: 24222018. 10.1161/01.cir.0000437741.48606.98 24222018
22 Anonymous. Aspirin Use for the Primary Prevention of Cardiovascular Disease and Colorectal Cancer: Recommendations From the U.S. Preventive Services Task Force. Annals of internal medicine. 2016;164(12). PMID: 27064765. 10.7326/P16-9015 27064765
23 Bibbins-Domingo K, Grossman DC, Curry SJ, . Statin use for the primary prevention of cardiovascular disease in adults: US Preventive Services Task Force recommendation statement. Jama. 2016;316(19):1997–2007. PMID: 27838723. 10.1001/jama.2016.15450 27838723
24 Arnett DK, Blumenthal RS, Albert MA, . 2019 ACC/AHA Guideline on the Primary Prevention of Cardiovascular Disease. Circulation. 2019:Cir0000000000000678. PMID: 30879355. 10.1161/cir.0000000000000678 30879355
25 Dehmer SP, Maciosek MV, Grossman ES. Aspirin Use to Prevent Cardiovascular Disease and Colorectal Cancer: A Decision Analysis: Technical Report. 2021. PMID: None.
26 PDQ® Screening and Prevention Editorial Board. Colorectal Cancer Prevention (PDQ(R)): Health Professional Version. PDQ Cancer Information Summaries. Bethesda (MD) 2002.
27 American Cancer Society. About Colorectal Cancer. https://www.cancer.org/cancer/colon-rectal-cancer/about/key-statistics.html. Accessed 9/26/2019. PMID: None.
28 Usher-Smith JA, Walter FM, Emery JD, . Risk Prediction Models for Colorectal Cancer: A Systematic Review. Cancer Prev Res (Phila Pa). 2016;9(1):13–26. PMID: 26464100. 10.1158/1940-6207.CAPR-15-0274 26464100
29 Virani SS, Alonso A, Benjamin EJ, . Heart Disease and Stroke Statistics-2020 Update: A Report From the American Heart Association. Circulation. 2020;141(9):e139–e596. PMID: 31992061. 10.1161/CIR.0000000000000757 31992061
30 Garcia-Albeniz X, Chan AT. Aspirin for the prevention of colorectal cancer. Best Pract Res Clin Gastroenterol. 2011;25(4–5):461–72. PMID: 22122763. 10.1016/j.bpg.2011.10.015 22122763
31 Wallace JL. Prostaglandins, NSAIDs, and gastric mucosal protection: why doesn’t the stomach digest itself? Physiological reviews. 2008;88(4):1547–65. PMID: 18923189. 10.1152/physrev.00004.2008 18923189
32 Nemerovski CW, Salinitri FD, Morbitzer KA, . Aspirin for primary prevention of cardiovascular disease events. Pharmacotherapy. 2012;32(11):1020–35. PMID: 23019080. 10.1002/phar.1127 23019080
33 Abramson S, Howard R. Aspirin: Mechanisms of action, major toxicities, and use in rheumatic diseases. 2014. PMID: None.
34 Golden BD, Abramson SB. Selective cyclooxygenase-2 inhibitors. Rheumatic diseases clinics of North America. 1999;25(2):359–78. PMID: 10356423.10356423
35 Pignone M, Alberts MJ, Colwell JA, . Aspirin for primary prevention of cardiovascular events in people with diabetes: a position statement of the American Diabetes Association, a scientific statement of the American Heart Association, and an expert consensus document of the American College of Cardiology Foundation. Diabetes care. 2010;33(6):1395–402. PMID: 20508233. 10.2337/dc10-0555 20508233
36 National Institute for Health and Care Excellence Clinical Knowledge Summaries. Antiplatelet treatment: Primary prevention of CVD Last revised September 2018. https://www.aspirin-foundation.com/scientific-information/guidelines/uk-guidelines-aspirin/#:~:text=NICE%20CKS%20Antiplatelet%20treatment%3A%20Primary,stroke%20or%20myocardial%20infarction.%E2%80%9D%20The (https://www.aspirin-foundation.com/scientific-information/guidelines/uk-guidelines-aspirin/#:~:text=NICE%20CKS%20Antiplatelet%20treatment%3A%20Primarystroke%20or%20myocardial%20infarction.%E2%80%9D%20The). Accessed. PMID: None.
37 Piepoli MF, Hoes AW, Agewall S, . 2016 European Guidelines on cardiovascular disease prevention in clinical practice: The Sixth Joint Task Force of the European Society of Cardiology and Other Societies on Cardiovascular Disease Prevention in Clinical Practice (constituted by representatives of 10 societies and by invited experts)Developed with the special contribution of the European Association for Cardiovascular Prevention & Rehabilitation (EACPR). European heart journal. 2016;37(29):2315–81. PMID: 27222591. 10.1093/eurheartj/ehw106 27222591
38 Scottish Intercollegiate Guidelines Network (SIGN). Risk estimation and the prevention of cardiovascular disease. SIGN Publication No. 149. https://www.sign.ac.uk/assets/sign149.pdf. Accessed Nov 7, 2019. PMID: None.
39 O’Brien CW, Juraschek SP, Wee CC. Prevalence of Aspirin Use for Primary Prevention of Cardiovascular Disease in the United States: Results From the 2017 National Health Interview Survey. Annals of internal medicine. 2019. PMID: 31330542. 10.7326/M19-0953 31330542
40 Macrae F, Chetcuti A, Julie Clarke, . PPR1: What is the risk-benefit ratio for use of aspirin for prevention of colorectal cancer stratified by risk of colorectal cancer itself? (What is the optimal dose and frequency of administration?) [Version URL: https://wiki.cancer.org.au/australiawiki/index.php?oldid=196954. Accessed Nov 7, 2019. PMID: None.
41 Shaukat A, Kahi CJ, Burke CA, . ACG Clinical Guidelines: Colorectal Cancer Screening 2021. Official journal of the American College of Gastroenterology| ACG. 2021;116(3):458–79. PMID: None. 10.14309/ajg.0000000000001122
42 Liang PS, Shaukat A, Crockett SD. AGA Clinical Practice Update on Chemoprevention for Colorectal Neoplasia: Expert Review. Clin Gastroenterol Hepatol. 2021. PMID: 33581359. 10.1016/j.cgh.2021.02.014 33581359
43 Dehmer SP, Maciosek MV, Flottemesch TJ, . Aspirin for the Primary Prevention of Cardiovascular Disease and Colorectal Cancer: A Decision Analysis for the U.S. Preventive Services Task Force. Annals of internal medicine. 2016;164(12):777–86. PMID: 27064573. 10.7326/M15-2129 27064573
44 United Nations Development Programme. Human Development Indices and Indicators: 2018 Statistical Update. New York, NY: 2018. PMID: None.
45 The Medical Research Council’s General Practice Research Framework. Thrombosis prevention trial: randomised trial of low-intensity oral anticoagulation with warfarin and low-dose aspirin in the primary prevention of ischaemic heart disease in men at increased risk. Lancet (London, England). 1998;351(9098):233–41. PMID: 9457092.9457092
46 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. PMID: None.
47 Sacco RL, Kasner SE, Broderick JP, . An updated definition of stroke for the 21st century: a statement for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. 2013;44(7):2064–89. PMID: 23652265. 10.1161/STR.0b013e318296aeca 23652265
48 Morton SC MM, O’Connor E, Lee CS, Booth M, Vandermeer BW, Snowden JM, D’Anci KE, Fu R, Gartlehner G, Wang Z, Steele DW. Quantitative Synthesis—An Update. Methods Guide for Comparative Effectiveness Reviews.(Prepared by the Scientific Resource Center under Contract No. 290-2012-0004-C). AHRQ Publication No. 18-EHC007-EF. Rockville, MD: Agency for Healthcare Research and Quality: 2018. PMID: None.
49 Buring JE, I-Min L. Personal communication. Updated WHS data ed2020. PMID: None.
50 Baigent C, Blackwell L, Collins R, . Aspirin in the primary and secondary prevention of vascular disease: collaborative meta-analysis of individual participant data from randomised trials. Lancet (London, England). 2009;373(9678):1849–60. PMID: 19482214. 10.1016/s0140-6736(09)60503-1 19482214
51 Baigent C. Personal communication. 2020. PMID: None.
52 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: 2440462724404627.
53 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
54 McNeil JJ, Nelson MR, Woods RL, . Effect of Aspirin on All-Cause Mortality in the Healthy Elderly. N Engl J Med. 2018;379(16):1519–28. PMID: 30221595. 10.1056/NEJMoa1803955 30221595
55 Ascend Study Collaborative Group, Bowman L, Mafham M, . Effects of Aspirin for Primary Prevention in Persons with Diabetes Mellitus. N Engl J Med. 2018;379(16):1529–39. PMID: 30146931. 10.1056/NEJMoa1804988 30146931
56 Gaziano JM, Brotons C, Coppolecchia R, . Use of aspirin to reduce risk of initial vascular events in patients at moderate risk of cardiovascular disease (ARRIVE): a randomised, double-blind, placebo-controlled trial. Lancet (London, England). 2018;392(10152):1036–46. PMID: 30158069. 10.1016/S0140-6736(18)31924-X 30158069
57 Saito Y, Okada S, Ogawa H, . Low-Dose Aspirin for Primary Prevention of Cardiovascular Events in Patients With Type 2 Diabetes Mellitus: 10-Year Follow-Up of a Randomized Controlled Trial. Circulation. 2017;135(7):659–70. PMID: 27881565. 10.1161/CIRCULATIONAHA.116.025760 27881565
58 Uchiyama S, Ishizuka N, Shimada K, . Aspirin for Stroke Prevention in Elderly Patients With Vascular Risk Factors: Japanese Primary Prevention Project. Stroke. 2016;47(6):1605–11. PMID: 27165949. 10.1161/STROKEAHA.115.012461 27165949
59 Anonymous. Final report on the aspirin component of the ongoing Physicians’ Health Study. Steering Committee of the Physicians’ Health Study Research Group. N Engl J Med. 1989;321(3):129–35. PMID: 2664509. 10.1056/NEJM198907203210301 2664509
60 Physicians’ Health Study Research Group. Preliminary Report: Findings From the Aspirin Component of The Ongoing Physicians’ Health Study. New England Journal of Medicine. 1988;318:262–4. PMID: 3275899. 10.1056/NEJM198801283180431 3275899
61 Cook NR, Hebert PR, Manson JE, . Self-selected posttrial aspirin use and subsequent cardiovascular disease and mortality in the physicians’s health study. Archives of Internal Medicine. 2000;160(7):921–8. PMID: 10761956. 10.1001/archinte.160.7.921 10761956
62 Cook NR, Cole SR, Hennekens CH. Use of a Marginal Structural Model to Determine the Effect of Aspirin on Cardiovascular Mortality in the Physicians’ Health Study. American Journal of Epidemiology. 2002;155(11):1045–53. PMID: 12034583. 10.1093/aje/155.11.1045 12034583
63 Kurth T, Glynn RJ, Walker AM, . Inhibition of Clinical Benefits of Aspirin on First Myocardial Infarction by Nonsteroidal Antiinflammatory Drugs. Circulation. 2003;108(10):1191–5. PMID: 12939216. 10.1161/01.CIR.0000087593.07533.9B 12939216
64 Roncaglioni M, Collaborative Group of the Primary Prevention Project (PPP). Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general Practice. The Lancet. 2001;357(9250):89–95. PMID: 11197445. 10.1016/s0140-6736(00)03539-x 11197445
65 Meade TW, Brennan PJ. Determination of who may derive most benefit from aspirin in primary prevention: subgroup results from a randomised controlled trial. BMJ (Clinical research ed). 2000;321(7252):13–7. PMID: 10875825. 10.1136/bmj.321.7252.13 10875825
66 Belch J, MacCuish A, Campbell I, . The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ (Clinical research ed). 2008;337:1–10. PMID: 18927173. 10.1136/bmj.a1840 18927173
67 Sacco M, Pellegrini F, Roncaglioni MC, . Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general Practice. Diabetes care. 2003;26(12):3264–72. PMID: None.14633812
68 Berger JS, Roncaglioni MC, Avanzini F, . Aspirin for the primary prevention of cardiovascular events in women and men: a sex-specific meta-analysis of randomized controlled trials. Jama. 2006;295(3):306–13. PMID: 16418466. 10.1001/jama.295.3.306 16418466
69 Fowkes FG, Price JF, Stewart MC, . Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. Jama. 2010;303(9):841–8. PMID: 20197530. 10.1001/jama.2010.221 20197530
70 Hansson L, Zanchetti A, Carruthers SG, . Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet (London, England). 1998;351(9118):1755–62. PMID: 9635947. 10.1016/s0140-6736(98)04311-6 9635947
71 Anonymous. The Hypertension Optimal Treatment Study (the HOT Study). Blood Press. 1993;2(1):62–8. PMID: 8193735. 10.3109/08037059309077529 8193735
72 Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study--patient characteristics: randomization, risk profiles, and early blood pressure results. Blood Press. 1994;3(5):322–7. PMID: 7866597. 10.3109/08037059409102281 7866597
73 Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study: 12-month data on blood pressure and tolerability. With special reference to age and gender. Blood Press. 1995;4(5):313–9. PMID: 8535554. 10.3109/08037059509077613 8535554
74 Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study: 24-month data on blood pressure and tolerability. Blood Press. 1997;6(5):313–7. PMID: 9360003. 10.3109/08037059709062088 9360003
75 Zanchetti A, Hansson L, Dahlof B, . Effects of individual risk factors on the incidence of cardiovascular events in the treated hypertensive patients of the Hypertension Optimal Treatment Study. HOT Study Group. J Hypertens. 2001;19(6):1149–59. PMID: 11403365.11403365
76 Zanchetti A, Hansson L, Menard J, . Risk assessment and treatment benefit in intensively treated hypertensive patients of the hypertension Optimal Treatment (HOT) study. J Hypertens. 2001;19(4):819–25. PMID: 11330886.11330886
77 Zanchetti A, Hansson L, Dahlof B, . Benefit and harm of low-dose aspirin in well-treated hypertensives at different baseline cardiovascular risk. J Hypertens. 2002;20(11):2301–7. PMID: 12409970.12409970
78 Jardine MJ, Ninomiya T, Perkovic V, . Aspirin is beneficial in hypertensive patients with chronic kidney disease: a post-hoc subgroup analysis of a randomized controlled trial. Journal of the American College of Cardiology. 2010;56(12):956–65. PMID: 20828648. 10.1016/j.jacc.2010.02.068 20828648
79 Kjeldsen SE, Kolloch RE, Leonetti G, . Influence of gender and age on preventing cardiovascular disease by antihypertensive treatment and acetylsalicylic acid. The HOT study. Hypertension Optimal Treatment. J Hypertens. 2000;18(5):629–42. PMID: 10826567. 10.1097/00004872-200018050-00017 10826567
80 Zanchetti A. Aspirin and Antiplatet Drugs in the Prevention of Cardiovascular Complications of Diabetes. Pharmacotherapy of diabetes: new developments: improving life and prognosis for diabetic patients. New York, New York: Springer Science and Business Media; 2007. p. 211–8.
81 Ogawa H, Nakayama M, Morimoto T, . Low-dose aspirin for primary prevention of atherosclerotic events in patients with type 2 diabetes: a randomized controlled trial.[Erratum appears in JAMA. 2009 May 13;301(18):1882]. Jama. 2008;300(18):2134–41. PMID: 18997198.18997198
82 Peto R, Gray R, Collins R, . Randomised trial of prophylactic daily aspirin in British male doctors. Br Med J (Clin Res Ed). 1988;296(6618):313–6. PMID: 3125882. 10.1136/bmj.296.6618.313 3125882
83 Ridker PM, Cook NR, Lee IM, . A randomized trial of low-dose aspirin in the primary prevention of cardiovascular disease in women. N Engl J Med. 2005;352(13):1293–304. PMID: 15753114. 10.1056/NEJMoa050613 15753114
84 Rexrode KM, Lee IM, Cook NR, . Baseline characteristics of participants in the Women’s Health Study. J Womens Health Gend Based Med. 2000;9(1):19–27. PMID: 10718501. 10.1089/152460900318911 10718501
85 Christen WG, Glynn RJ, Chew EY, . Low-dose aspirin and medical record-confirmed age-related macular degeneration in a randomized trial of women. Ophthalmology. 2009;116(12):2386–92. PMID: 19815293. 10.1016/j.ophtha.2009.05.031 19815293
86 Rist PM, Buring JE, Kase CS, . Effect of low-dose aspirin on functional outcome from cerebral vascular events in women. Stroke. 2013;44(2):432–6. PMID: 23306328. 10.1161/STROKEAHA.112.672451 23306328
87 Dorresteijn JA, Visseren FL, Ridker PM, . Aspirin for primary prevention of vascular events in women: individualized prediction of treatment effects. European heart journal. 2011;32(23):2962–9. PMID: 22090661. 10.1093/eurheartj/ehr423 22090661
88 Okada S, Morimoto T, Ogawa H, . Differential effect of low-dose aspirin for primary prevention of atherosclerotic events in diabetes management: a subanalysis of the JPAD trial. Diabetes care. 2011;34(6):1277–83. PMID: 21515838. 10.2337/dc10-2451 21515838
89 Saito Y, Morimoto T, Ogawa H, . Low-dose aspirin therapy in patients with type 2 diabetes and reduced glomerular filtration rate: subanalysis from the JPAD trial. Diabetes care. 2011;34(2):280–5. PMID: 21270185. 10.2337/dc10-1615 21270185
90 Soejima H, Ogawa H, Morimoto T, . Aspirin reduces cerebrovascular events in type 2 diabetic patients with poorly controlled blood pressure. Subanalysis from the JPAD trial. Circ J. 2012;76(6):1526–32. PMID: 22447019. 10.1253/circj.cj-11-1033 22447019
91 Ikeda Y, Shimada K, Teramoto T, . Low-dose aspirin for primary prevention of cardiovascular events in Japanese patients 60 years or older with atherosclerotic risk factors: a randomized clinical trial. Jama. 2014;312(23):2510–20. PMID: 25401325. 10.1001/jama.2014.15690 25401325
92 Flossmann E, Rothwell PM, British Doctors Aspirin T, . Effect of aspirin on long-term risk of colorectal cancer: consistent evidence from randomised and observational studies. Lancet (London, England). 2007;369(9573):1603–13. PMID: 17499602. 10.1016/S0140-6736(07)60747-8 17499602
93 Rothwell PM, Wilson M, Elwin CE, . Long-term effect of aspirin on colorectal cancer incidence and mortality: 20-year follow-up of five randomised trials. Lancet (London, England). 2010;376(9754):1741–50. PMID: 20970847. 10.1016/S0140-6736(10)61543-7 20970847
94 The SALT Collaborative Group. Swedish Aspirin Low-Dose Trial (SALT) of 75 mg aspirin as secondary prophylaxis after cerebrovascular ischaemic events. The SALT Collaborative Group. Lancet (London, England). 1991;338(8779):1345–9. PMID: 1682734.1682734
95 Okada S, Morimoto T, Ogawa H, . Effect of low-dose aspirin on primary prevention of cardiovascular events in Japanese diabetic patients at high risk. Circ J. 2013;77(12):3023–8. PMID: 24042256. 10.1253/circj.cj-13-0307 24042256
96 Soejima H, Ogawa H, Morimoto T, . Aspirin possibly reduces cerebrovascular events in type 2 diabetic patients with higher C-reactive protein level: subanalysis from the JPAD trial. Journal of Cardiology. 2013;62(3):165–70. PMID: 23778008.23778008
97 Sugawara M, Goto Y, Yamazaki T, . Low-Dose Aspirin for Primary Prevention of Cardiovascular Events in Elderly Japanese Patients with Atherosclerotic Risk Factors: Subanalysis of a Randomized Clinical Trial (JPPP-70). American Journal of Cardiovascular Drugs. 2019;19(3):299–311. PMID: 30565155. 10.1007/s40256-018-0313-0 30565155
98 Luo PJ, Lin XH, Lin CC, . Risk factors for upper gastrointestinal bleeding among aspirin users: An old issue with new findings from a population-based cohort study. J Formos Med Assoc. 2019;118(5):939–44. PMID: 30366771. 10.1016/j.jfma.2018.10.007 30366771
99 Wolfe R, Murray AM, Woods RL, . The aspirin in reducing events in the elderly trial: Statistical analysis plan. International Journal of Stroke. 2018;13(3):335–8. PMID: 29111960. 10.1177/1747493017741383 29111960
100 Bowman L, Mafham M, Stevens W, . ASCEND: A Study of Cardiovascular Events iN Diabetes: Characteristics of a randomized trial of aspirin and of omega-3 fatty acid supplementation in 15,480 people with diabetes. American Heart Journal. 2018;198:135–44. PMID: 29653635. 10.1016/j.ahj.2017.12.006 29653635
101 McNeil JJ, Wolfe R, Woods RL, . Effect of Aspirin on Cardiovascular Events and Bleeding in the Healthy Elderly. New England Journal of Medicine. 2018;379(16):1509–18. PMID: 30221597. 10.1056/NEJMoa1805819 30221597
102 McNeil JJ, Woods RL, Nelson MR, . Effect of Aspirin on Disability-free Survival in the Healthy Elderly. New England Journal of Medicine. 2018;379(16):1499–508. PMID: 30221596. 10.1056/NEJMoa1800722 30221596
103 Okada S, Morimoto T, Ogawa H, . Effect of Aspirin on Cancer Chemoprevention in Japanese Patients With Type 2 Diabetes: 10-Year Observational Follow-up of a Randomized Controlled Trial. Diabetes care. 2018;41(8):1757–64. PMID: 29909377. 10.2337/dc18-0368 29909377
104 Aung T, Haynes R, Barton J, . Cost-effective recruitment methods for a large randomised trial in people with diabetes: A Study of Cardiovascular Events iN Diabetes (ASCEND). Trials [Electronic Resource]. 2016;17(1):286. PMID: 27296091. 10.1186/s13063-016-1354-9 27296091
105 McNeil JJ, Woods RL, Nelson MR, . Baseline Characteristics of Participants in the ASPREE (ASPirin in Reducing Events in the Elderly) Study. J Gerontol A Biol Sci Med Sci. 2017;72(11):1586–93. PMID: 28329340. 10.1093/gerona/glw342 28329340
106 Chen WC, Lin KH, Huang YT, . The risk of lower gastrointestinal bleeding in low-dose aspirin users. Alimentary Pharmacology & Therapeutics. 2017;45(12):1542–50. PMID: 28449186. 10.1111/apt.14079 28449186
107 Jung M, Lee S. Efficacy of Aspirin in the Primary Prevention of Cardiovascular Diseases and Cancer in the Elderly: A Population-Based Cohort Study in Korea. Drugs Aging. 2020;37(1):43–55. PMID: 31755069. 10.1007/s40266-019-00723-3 31755069
108 Yokoyama K, Ishizuka N, Uemura N, . Effects of daily aspirin on cancer incidence and mortality in the elderly Japanese. Research And Practice In Thrombosis And Haemostasis. 2018;2(2):274–81. PMID: 30046729. 10.1002/rth2.12097 30046729
109 Margolis KL, Mahady SE, Nelson MR, . Development of a standardized definition for clinically significant bleeding in the ASPirin in Reducing Events in the Elderly (ASPREE) trial. Contemporary Clinical Trials Communications. 2018;11:30–6. PMID: 30023457. 10.1016/j.conctc.2018.05.015 30023457
110 Cook NR, Lee IM, Gaziano JM, . Low-dose aspirin in the primary prevention of cancer: the Women’s Health Study: a randomized controlled trial. Jama. 2005;294(1):47–55. PMID: 15998890. 10.1001/jama.294.1.47 15998890
111 Farrell B, Godwin J, Richards S, . The United Kingdom transient ischaemic attack (UK-TIA) aspirin trial: final results. J Neurol Neurosurg Psychiatry. 1991;54(12):1044–54. PMID: 1783914. 10.1136/jnnp.54.12.1044 1783914
112 Cook NR, Lee IM, Zhang SM, . Alternate-day, low-dose aspirin and cancer risk: long-term observational follow-up of a randomized trial. Annals of internal medicine. 2013;159(2):77–85. PMID: 23856681. 10.7326/0003-4819-159-2-201307160-00002 23856681
113 Sturmer T, Glynn RJ, Lee IM, . Aspirin use and colorectal cancer: post-trial follow-up data from the Physicians’ Health Study. Annals of internal medicine. 1998;128(9):713–20. PMID: 9556464. 10.7326/0003-4819-128-9-199805010-00003 9556464
114 Gann PH, Manson JE, Glynn RJ, . Low-dose aspirin and incidence of colorectal tumors in a randomized trial. Journal of the National Cancer Institute. 1993;85(15):1220–4. PMID: 8331682. 10.1093/jnci/85.15.1220 8331682
115 Christen WG, Glynn RJ, Ajani UA, . Age-related maculopathy in a randomized trial of low-dose aspirin among US physicians. Arch Ophthalmol. 2001;119(8):1143–9. PMID: 11483080. 10.1001/archopht.119.8.1143 11483080
116 Buring JE, Hennekens CH. The Women’s Health Study: summary of the study design. J Myocardial Ischemia. 1992;4(3):27–9. PMID: None.
117 de Berardis G, Lucisano G, D’Ettorre A, . Association of aspirin use with major bleeding in patients with and without diabetes. Jama. 2012;307(21):2286–94. PMID: 22706834. 10.1001/jama.2012.5034 22706834
118 Ekstrom N, Cederholm J, Zethelius B, . Aspirin treatment and risk of first incident cardiovascular diseases in patients with type 2 diabetes: an observational study from the Swedish National Diabetes Register. BMJ Open. 2013;3(4):1–9. PMID: 23604419. 10.1136/bmjopen-2013-002688 23604419
119 Glynn RJ, Ridker PM, Goldhaber SZ, . Effect of low-dose aspirin on the occurrence of venous thromboembolism: a randomized trial. Annals of internal medicine. 2007;147(8):525–33. PMID: 17938390. 10.7326/0003-4819-147-8-200710160-00004 17938390
120 Huang ES, Strate LL, Ho WW, . A prospective study of aspirin use and the risk of gastrointestinal bleeding in men. PLoS ONE. 2010;5(12):e15721. PMID: 21209949. 10.1371/journal.pone.0015721 21209949
121 Huang ES, Strate LL, Ho WW, . Long-term use of aspirin and the risk of gastrointestinal bleeding. American Journal of Medicine. 2011;124(5):426–33. PMID: 21531232. 10.1016/j.amjmed.2010.12.022 21531232
122 Iso H, Hennekens CH, Stampfer MJ, . Prospective study of aspirin use and risk of stroke in women. Stroke. 1999;30(9):1764–71. PMID: 10471421. 10.1161/01.str.30.9.1764 10471421
123 Manson JE, Stampfer MJ, Colditz GA, . A prospective study of aspirin use and primary prevention of cardiovascular disease in women. Jama. 1991;266(4):521–7. PMID: 2061978.2061978
124 Meade TW, Roderick PJ, Brennan PJ, . Extra-cranial bleeding and other symptoms due to low dose aspirin and low intensity oral anticoagulation. Thromb Haemost. 1992;68(1):1–6. PMID: 1514166.1514166
125 Nelson MR, Reid CM, Ames DA, . Feasibility of conducting a primary prevention trial of low-dose aspirin for major adverse cardiovascular events in older people in Australia: results from the ASPirin in Reducing Events in the Elderly (ASPREE) pilot study. Med J Aust. 2008;189(2):105–9. PMID: 18637782. 10.5694/j.1326-5377.2008.tb01932.x 18637782
126 Sacco M, Pellegrini F, Roncaglioni MC, . Primary prevention of cardiovascular events with low-dose aspirin and vitamin E in type 2 diabetic patients: results of the Primary Prevention Project (PPP) trial. Diabetes care. 2003;26(12):3264–72. PMID: 14633812. 10.2337/diacare.26.12.3264 14633812
127 Silagy CA, McNeil JJ, Donnan GA, . Adverse effects of low-dose aspirin in a healthy elderly population. Clin Pharmacol Ther. 1993;54(1):84–9. PMID: 8330469. 10.1038/clpt.1993.115 8330469
128 Strate LL, Liu YL, Huang ES, . Use of aspirin or nonsteroidal anti-inflammatory drugs increases risk for diverticulitis and diverticular bleeding. Gastroenterology. 2011;140(5):1427–33. PMID: 21320500. 10.1053/j.gastro.2011.02.004 21320500
129 ASPREE. ASPrin in Reducing Events in the Elderly Protocol Version 9. https://aspree.org/usa/wp-content/uploads/sites/3/2014/04/ASPREE-Protocol-Version-9_-Nov2014_FINAL.pdf. Accessed June 3, 2020. PMID: None.
130 Mahady SE, Margolis KL, Chan A, . Major GI bleeding in older persons using aspirin: incidence and risk factors in the ASPREE randomised controlled trial. Gut. 2020. PMID: 32747412. 10.1136/gutjnl-2020-321585 32747412
131 McNeil JJ, Gibbs P, Orchard SG, . Effect of aspirin on cancer incidence and mortality in older adults. Journal of the National Cancer Institute. 2020. PMID: 32778876. 10.1093/jnci/djaa114 32778876
132 Expert Panel on Detection Evaluation Treatment of High Blood Cholesterol in Adults. Executive Summary of The Third Report of The National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, And Treatment of High Blood Cholesterol In Adults (Adult Treatment Panel III). Jama. 2001;285(19):2486–97. PMID: 11368702. 10.1001/jama.285.19.2486 11368702
133 Zheng SL, Roddick AJ. Association of Aspirin Use for Primary Prevention With Cardiovascular Events and Bleeding Events: A Systematic Review and Meta-analysis. Jama. 2019;321(3):277–87. PMID: 30667501. 10.1001/jama.2018.20578 30667501
134 Haykal T, Barbarawi M, Zayed Y, . Safety and efficacy of aspirin for primary prevention of cancer: a meta-analysis of randomized controlled trials. J Cancer Res Clin Oncol. 2019;145(7):1795–809. PMID: 31098750. 10.1007/s00432-019-02932-0 31098750
135 Christiansen M, Grove EL, Hvas AM. Primary Prevention of Cardiovascular Events with Aspirin: Toward More Harm than Benefit-A Systematic Review and Meta-Analysis. Semin Thromb Hemost. 2019;45(5):478–89. PMID: 31096304. 10.1055/s-0039-1687905 31096304
136 Abdelaziz HK, Saad M, Pothineni NVK, . Aspirin for Primary Prevention of Cardiovascular Events. Journal of the American College of Cardiology. 2019;73(23):2915–29. PMID: 31196447. 10.1016/j.jacc.2019.03.501 31196447
137 Mahmoud AN, Gad MM, Elgendy AY, . Efficacy and safety of aspirin for primary prevention of cardiovascular events: a meta-analysis and trial sequential analysis of randomized controlled trials. European heart journal. 2019;40(7):607–17. PMID: 30561620. 10.1093/eurheartj/ehy813 30561620
138 Lin JS, Evans CV, Johnson E, . Nontraditional Risk Factors in Cardiovascular Disease Risk Assessment: A Systematic Evidence Report for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2018. PMID: 3023493330234933.
139 Muntner P, Colantonio LD, Cushman M, . Validation of the atherosclerotic cardiovascular disease Pooled Cohort risk equations. Jama. 2014;311(14):1406–15. PMID: 24682252. 10.1001/jama.2014.2630 24682252
140 DeFilippis AP, Young R, Carrubba CJ, . An analysis of calibration and discrimination among multiple cardiovascular risk scores in a modern multiethnic cohort. Annals of internal medicine. 2015;162(4):266–75. PMID: 25686167. 10.7326/M14-1281 25686167
141 Cook NR, Ridker PM. Calibration of the Pooled Cohort Equations for Atherosclerotic Cardiovascular Disease: An Update. Annals of internal medicine. 2016;165(11):786–94. PMID: 27723890. 10.7326/M16-1739 27723890
142 Dalton JE, Perzynski AT, Zidar DA, . Accuracy of Cardiovascular Risk Prediction Varies by Neighborhood Socioeconomic Position: A Retrospective Cohort Study. Annals of internal medicine. 2017;167(7):456–64. PMID: 28847012. 10.7326/M16-2543 28847012
143 Kavousi M, Leening MJ, Nanchen D, . Comparison of application of the ACC/AHA guidelines, Adult Treatment Panel III guidelines, and European Society of Cardiology guidelines for cardiovascular disease prevention in a European cohort. Jama. 2014;311(14):1416–23. PMID: 24681960. 10.1001/jama.2014.2632 24681960
144 Rana JS, Tabada GH, Solomon MD, . Accuracy of the Atherosclerotic Cardiovascular Risk Equation in a Large Contemporary, Multiethnic Population. Journal of the American College of Cardiology. 2016;67(18):2118–30. PMID: 27151343. 10.1016/j.jacc.2016.02.055 27151343
145 Ko DT, Sivaswamy A, Sud M, . Calibration and discrimination of the Framingham Risk Score and the Pooled Cohort Equations. CMAJ. 2020;192(17):E442–E9. PMID: 32392491. 10.1503/cmaj.190848 32392491
146 De Filippis AP, Young R, McEvoy JW, . Risk score overestimation: The impact of individual cardiovascular risk factors and preventive therapies on the performance of the American Heart Association-American College of Cardiology-Atherosclerotic Cardiovascular Disease risk score in a modern multi-ethnic cohort. European heart journal. 2017;38(8):598–608. PMID: 27436865. 10.1093/eurheartj/ehw301 27436865
147 Mora S, Wenger NK, Cook NR, . Evaluation of the Pooled Cohort Risk Equations for Cardiovascular Risk Prediction in a Multiethnic Cohort From the Women’s Health Initiative. JAMA Internal Medicine. 2018;178(9):1231–40. PMID: 30039172. 10.1001/jamainternmed.2018.2875 30039172
148 Colantonio LD, Richman JS, Carson AP, . Performance of the Atherosclerotic Cardiovascular Disease Pooled Cohort Risk Equations by Social Deprivation Status. J Am Heart Assoc. 2017;6(3). PMID: 28314800. 10.1161/JAHA.117.005676 28314800
149 Pylypchuk R, Wells S, Kerr A, . Cardiovascular disease risk prediction equations in 400 000 primary care patients in New Zealand: a derivation and validation study. Lancet (London, England). 2018;391(10133):1897–907. PMID: 29735391. 10.1016/s0140-6736(18)30664-0 29735391
150 Moons KG, Altman DG, Reitsma JB, . Transparent Reporting of a multivariable prediction model for Individual Prognosis or Diagnosis (TRIPOD): explanation and elaboration. Annals of internal medicine. 2015;162(1):W1–73. PMID: 25560730. 10.7326/M14-0698 25560730
151 Andersson C, Enserro D, Larson MG, . Implications of the US cholesterol guidelines on eligibility for statin therapy in the community: comparison of observed and predicted risks in the Framingham Heart Study Offspring Cohort. J Am Heart Assoc. 2015;4(4). PMID: 25888372. 10.1161/JAHA.115.001888 25888372
152 Yadlowsky S, Hayward RA, Sussman JB, . Clinical Implications of Revised Pooled Cohort Equations for Estimating Atherosclerotic Cardiovascular Disease Risk. Annals of internal medicine. 2018;169(1):20–9. PMID: 29868850. 10.7326/M17-3011 29868850
153 Cainzos-Achirica M, Miedema MD, McEvoy JW, . Coronary Artery Calcium for Personalized Allocation of Aspirin in Primary Prevention of Cardiovascular Disease in 2019: The MESA Study (Multi-Ethnic Study of Atherosclerosis). Circulation. 2020;141(19):1541–53. PMID: 32233663. 10.1161/CIRCULATIONAHA.119.045010 32233663
154 Gage BF, Yan Y, Milligan PE, . Clinical classification schemes for predicting hemorrhage: results from the National Registry of Atrial Fibrillation (NRAF). Am Heart J. 2006;151(3):713–9. PMID: 16504638. 10.1016/j.ahj.2005.04.017 16504638
155 Go AS, Hylek EM, Borowsky LH, . Warfarin use among ambulatory patients with nonvalvular atrial fibrillation: the anticoagulation and risk factors in atrial fibrillation (ATRIA) study. Annals of internal medicine. 1999;131(12):927–34. PMID: 10610643. 10.7326/0003-4819-131-12-199912210-00004 10610643
156 Donze J, Rodondi N, Waeber G, . Scores to predict major bleeding risk during oral anticoagulation therapy: a prospective validation study. Am J Med. 2012;125(11):1095–102. PMID: 22939362. 10.1016/j.amjmed.2012.04.005 22939362
157 Pisters R, Lane DA, Nieuwlaat R, . A novel user-friendly score (HAS-BLED) to assess 1-year risk of major bleeding in patients with atrial fibrillation: the Euro Heart Survey. Chest. 2010;138(5):1093–100. PMID: 20299623. 10.1378/chest.10-0134 20299623
158 Hippisley-Cox J, Coupland C. Predicting risk of upper gastrointestinal bleed and intracranial bleed with anticoagulants: cohort study to derive and validate the QBleed scores. BMJ (Clinical research ed). 2014;349:g4606. PMID: 25069704. 10.1136/bmj.g4606 25069704
159 Selak V, Jackson R, Poppe K, . Predicting Bleeding Risk to Guide Aspirin Use for the Primary Prevention of Cardiovascular Disease: A Cohort Study. Annals of internal medicine. 2019;170(6):357–68. PMID: 30802900. 10.7326/M18-2808 30802900
160 de Groot NL, Hagenaars MP, Smeets HM, . Primary non-variceal upper gastrointestinal bleeding in NSAID and low-dose aspirin users: development and validation of risk scores for either medication in two large Dutch cohorts. J Gastroenterol. 2014;49(2):245–53. PMID: 23609946. 10.1007/s00535-013-0817-y 23609946
161 Whitlock EP, Johnson ES. Are We There Yet? Another Milepost in the Journey to Identify Appropriate Candidates for Aspirin Primary Prevention. Annals of internal medicine. 2019;170(6):411–3. PMID: 30802898. 10.7326/M19-0416 30802898
162 Dugani S, Ames JM, Manson JE, . Weighing the Anti-Ischemic Benefits and Bleeding Risks from Aspirin Therapy: a Rational Approach. Curr Atheroscler Rep. 2018;20(3):15. PMID: 29464356. 10.1007/s11883-018-0717-y 29464356
163 Coon SA, Brooks AD, Wolff SE. Primary prevention aspirin use in high-risk patients: A pharmacist intervention and comparison of risk stratification tools. J Am Pharm Assoc (2003). 2017;57(5):585–90. PMID: 28811088. 10.1016/j.japh.2017.07.003 28811088
164 Selak V, Jackson R, Poppe K, . Personalized Prediction of Cardiovascular Benefits and Bleeding Harms From Aspirin for Primary Prevention: A Benefit-Harm Analysis. Annals of internal medicine. 2019. PMID: 31525775. 10.7326/M19-1132 31525775
165 Yu EW, Bauer SR, Bain PA, . Proton pump inhibitors and risk of fractures: a meta-analysis of 11 international studies. Am J Med. 2011;124(6):519–26. PMID: 21605729. 10.1016/j.amjmed.2011.01.007 21605729
166 Jung SB, Nagaraja V, Kapur A, . Association between vitamin B12 deficiency and long-term use of acid-lowering agents: a systematic review and meta-analysis. Intern Med J. 2015;45(4):409–16. PMID: 25583062. 10.1111/imj.12697 25583062
167 Moayyedi P, Eikelboom JW, Bosch J, . Safety of Proton Pump Inhibitors Based on a Large, Multi-Year, Randomized Trial of Patients Receiving Rivaroxaban or Aspirin. Gastroenterology. 2019;157(3):682–91.e2. PMID: 31152740. 10.1053/j.gastro.2019.05.056 31152740
168 Singh G, Sharma S, Kaur J, . Efficacy and tolerability of proton pump inhibitors in the long-term aspirin users: meta-analysis of randomized controlled trials. American journal of gastroenterology. 2016;111:S444. PMID: None. 10.1038/ajg.2016.360
169 Garcia Rodriguez LA, Lanas A, Soriano-Gabarro M, . Effect of Proton Pump Inhibitors on Risks of Upper and Lower Gastrointestinal Bleeding among Users of Low-Dose Aspirin: A Population-Based Observational Study. J Clin Med. 2020;9(4). PMID: 32231106. 10.3390/jcm9040928 32231106
170 Chan FK, Chung SC, Suen BY, . Preventing recurrent upper gastrointestinal bleeding in patients with Helicobacter pylori infection who are taking low-dose aspirin or naproxen. N Engl J Med. 2001;344(13):967–73. PMID: 11274623. 10.1056/NEJM200103293441304 11274623
171 Sundstrom J, Hedberg J, Thuresson M, . Low-Dose Aspirin Discontinuation and Risk of Cardiovascular Events: A Swedish Nationwide, Population-Based Cohort Study. Circulation. 2017;136(13):1183–92. PMID: 28947478. 10.1161/CIRCULATIONAHA.117.028321 28947478
172 Gerstein NS, Albrechtsen CL, Mercado N, . A Comprehensive Update on Aspirin Management during Noncardiac Surgery. Anesthesia and Analgesia. 2020:1111–23. PMID: 32675638. 10.1213/ANE.0000000000005064
173 Rodriguez LA, Cea-Soriano L, Martin-Merino E, . Discontinuation of low dose aspirin and risk of myocardial infarction: case-control study in UK primary care. BMJ (Clinical research ed). 2011;343:d4094. PMID: 21771831. 10.1136/bmj.d4094 21771831
174 ClinicalTrials.gov [Internet]. Aspirin Withdrawal and Clinical Outcome in Patients With Moderate to High Cardiovascular Risk But Without Cardiovascular Disease. https://clinicaltrialsgov/show/NCT03757156 [serial on the Internet]. 2018 [cited Search 1 - CENTRALRegistries: Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01795153/full.
175 Shah R, Khan B, Latham SB, . A Meta-Analysis of Aspirin for the Primary Prevention of Cardiovascular Diseases in the Context of Contemporary Preventive Strategies. American Journal of Medicine. 2019;132(11):1295–304.e3. PMID: 31153866. 10.1016/j.amjmed.2019.05.015 31153866
176 Ebell MH. Clopidogrel plus 21 days of aspirin is superior to aspirin alone within first 24 hours of TIA or minor stroke. American Family Physician. 2014;89(1):55. PMID: None.
177 Taylor F, Huffman MD, Macedo AF, . Statins for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev. 2013(1):CD004816. PMID: 23440795. 10.1002/14651858.CD004816.pub5 23440795
178 Yusuf S, Joseph P, Dans A, . Polypill with or without Aspirin in Persons without Cardiovascular Disease. The New England journal of medicine. 2020;384:216–28. PMID: 33186492. 10.1056/NEJMoa2028220 33186492
179 Qiao Y, Yang T, Gan Y, . Associations between aspirin use and the risk of cancers: a meta-analysis of observational studies. BMC Cancer. 2018;18(1):288. PMID: 29534696. 10.1186/s12885-018-4156-5 29534696
180 Loomans-Kropp HA, Pinsky P, Cao Y, . Association of Aspirin Use With Mortality Risk Among Older Adult Participants in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. JAMA network open. 2019;2(12):e1916729. PMID: 31800071. 10.1001/jamanetworkopen.2019.16729 31800071
181 Guo CG, Ma W, Drew DA, . Aspirin Use and Risk of Colorectal Cancer Among Older Adults. JAMA Oncol. 2021. PMID: 33475710. 10.1001/jamaoncol.2020.7338 33475710
182 Hull MA, Sprange K, Hepburn T, . Eicosapentaenoic acid and aspirin, alone and in combination, for the prevention of colorectal adenomas (seAFOod Polyp Prevention trial): a multicentre, randomised, double-blind, placebo-controlled, 2 × 2 factorial trial. Lancet (London, England). 2018;392(10164):2583–94. PMID: 30466866. 10.1016/S0140-6736(18)31775-6 30466866
183 Pommergaard HC, Burcharth J, Rosenberg J, . Aspirin, Calcitriol, and Calcium Do Not Prevent Adenoma Recurrence in a Randomized Controlled Trial. Gastroenterology. 2016;150(1):114–22.e4. PMID: 26404953. 10.1053/j.gastro.2015.09.010 26404953
184 Hull M, Sprange K, Hepburn T, . Randomised trial of EPA and aspirin for colorectal cancer chemoprevention: The seafood polyp prevention trial. Gut. 2018;67:A183. PMID: None. 10.1136/gutjnl-2018-BSGAbstracts.363
185 Ma K, Sarrafi S, Chan YM, . Aspirin Effect on Polyp Recurrence Depends on Polyp Subtype. Gastroenterology. 2018;154(6):S-871–S-2. PMID: None. 10.1016/S0016-5085(18)32945-7
186 Dulai PS, Singh S, Marquez E, . Chemoprevention of colorectal cancer in individuals with previous colorectal neoplasia: systematic review and network meta-analysis. BMJ (Clinical research ed). 2016;355:i6188. PMID: 27919915. 10.1136/bmj.i6188 27919915
187 Ye XF, Wang J, Shi WT, . Relationship between aspirin use after diagnosis of colorectal cancer and patient survival: a meta-analysis of observational studies. British Journal of Cancer. 2014;111(11):2172–9. PMID: 25180765. 10.1038/bjc.2014.481 25180765
188 Burn J, Gerdes AM, Macrae F, . Long-term effect of aspirin on cancer risk in carriers of hereditary colorectal cancer: an analysis from the CAPP2 randomised controlled trial. Lancet (London, England). 2011;378(9809):2081–7. PMID: 22036019. 10.1016/S0140-6736(11)61049-0 22036019
189 Burn J, Sheth H, Elliott F, . Cancer prevention with aspirin in hereditary colorectal cancer (Lynch syndrome), 10-year follow-up and registry-based 20-year data in the CAPP2 study: a double-blind, randomised, placebo-controlled trial. The Lancet. 2020;395(10240):1855–63. PMID: 32534647. 10.1016/S0140-6736(20)30366-4 32534647
190 Rothwell PM, Fowkes FG, Belch JF, . Effect of daily aspirin on long-term risk of death due to cancer: analysis of individual patient data from randomised trials. Lancet (London, England). 2011;377(9759):31–41. PMID: 21144578. 10.1016/S0140-6736(10)62110-1 21144578
191 Rothwell PM, Price JF, Fowkes FG, . Short-term effects of daily aspirin on cancer incidence, mortality, and non-vascular death: analysis of the time course of risks and benefits in 51 randomised controlled trials. Lancet (London, England). 2012;379(9826):1602–12. PMID: 22440946. 10.1016/S0140-6736(11)61720-0 22440946
192 Elwood PC, Morgan G, Galante J, . Systematic Review and Meta-Analysis of Randomised Trials to Ascertain Fatal Gastrointestinal Bleeding Events Attributable to Preventive Low-Dose Aspirin: No Evidence of Increased Risk. PLoS ONE [Electronic Resource]. 2016;11(11):e0166166. PMID: 27846246. 10.1371/journal.pone.0166166 27846246
193 Lanas A, Wu P, Medin J, . Low doses of acetylsalicylic acid increase risk of gastrointestinal bleeding in a meta-analysis. Clin Gastroenterol Hepatol. 2011;9(9):762–8 e6. PMID: 21699808. 10.1016/j.cgh.2011.05.020 21699808
194 Lanas A, Aabakken L, Fonseca J, . Clinical predictors of poor outcomes among patients with nonvariceal upper gastrointestinal bleeding in Europe. Aliment Pharmacol Ther. 2011;33(11):1225–33. PMID: 21480935. 10.1111/j.1365-2036.2011.04651.x 21480935
195 Centers for Disease Control and Prevention. United States Cancer Statistics: 1999-2014, WONDER Online Database. https://wonder.cdc.gov/wonder/help/cancer-v2014.html. Accessed. PMID: None.
196 American Diabetes Association. 10. Cardiovascular Disease and Risk Management: Standards of Medical Care in Diabetes—2020. Diabetes care. 2020;43(Suppl 1):S111–S34. PMID: 31862753. https://care.diabetesjournals.org/content/43/Supplement_1/S111 31862753
197 American Academy of Family Physicians. Clinical Preventive Service Recommendations: Aspirin Use to Prevent CVD and Colorectal Cancer. https://www.aafp.org/patient-care/clinical-recommendations/all/aspirin-use-prevention.html. Accessed 9/27/2019. PMID: None.
198 American Cancer Society. Can Colorectal Cancer Be Prevented? https://www.cancer.org/cancer/colon-rectal-cancer/causes-risks-prevention/prevention.html. Accessed 9/26/2019. PMID: None.
199 American Cancer Society. Aspirin and Cancer Prevention: What the Research Really Shows. https://www.cancer.org/latest-news/aspirin-and-cancer-prevention-what-the-research-really-shows.html. Accessed 9/26/2019. PMID: None.
200 National Institute for Health and Care Excellence. Prevention of colorectal cancer in people with Lynch syndrome. https://www.nice.org.uk/guidance/ng151. Accessed 2/23/2021. PMID: None.
201 Wells GA, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Online. 2013.
202 Anonymous. 1999 World Health Organization-International Society of Hypertension Guidelines for the Management of Hypertension. Guidelines Subcommittee. J Hypertens. 1999;17(2):151–83.10067786