# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Howard Tracer, MD, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; the Centers for Disease Control and Prevention, the National Heart, Lung, and Blood Institute, the National Cancer Institute, and the National Institute on Aging for providing federal partner review of the draft report; Nancy Cook, ScD, Colin Baigent, FFPH, FRCP, Asad Umar, DVM, PhD, John McNeil, PhD, and Diana Petitti, MD, MPH, who provided expert review of the draft report; Steven P. Dehmer, PhD, Michael Maciosek, PhD, Lauren Erickson, MS, and Elizabeth Grossman, MPH, from the decision analysis team for their collaboration; Jennifer Lin, MD, for mentoring and project oversight; and Melinda Davies, MA, and Jill Pope, BA, for technical and editorial assistance at the Center for Health Research.