# Chapter 4 Discussion

## Summary of Evidence

We conducted this review to support the USPSTF in updating its recommendation on aspirin to prevent CVD and CRC. We have included three new trials and three new cohort studies published since the previous review. Our meta-analyses of 11 low-dose primary CVD prevention trials show that aspirin reduces the risk of major CVD events by 10 percent, total MI by 11 percent and ischemic stroke by 18 percent, with no difference in CVD mortality or all-cause mortality (Table 21). CVD benefits were of similar magnitude when 13 primary prevention trials of all doses of aspirin were analyzed (Table 22). On the other hand, even with low-dose aspirin, we found a 31 percent increase in intracranial hemorrhage, and 53 percent in extracranial hemorrhage. These findings are remarkably similar to our previous CVD review^2^ despite the addition of 47,170 participants from three new trials. Our findings are also consistent with those of several other recent meta-analyses.^133–137^

Table 21 Summary of Evidence for Low-Dose Aspirin (≤100 mg/d)

Outcome | Studies (K); Study design Observations (N) | Summary of findings^*^ | Consistency and precision | Overall SOE | Body of evidence limitations | Applicability
KQ1
Major CVD events (total MI, total stroke, CVD death) | K=11 RCTs; N=134,470 | Peto OR (95% CI): 0.90 (0.85, 0.95); Range of absolute effects, %: −2.5 to −0.1 | Consistent, precise | HIGH for benefit | CVD outcomes:; Substantial clinical heterogeneity in populations, recency as a proxy for optimal CVD risk factor management, and trial duration. Trials mostly 4-6 years with one trial as long as 10 years. Trials may have insufficient followup for potential long-term CVD mortality benefit.; Trials powered for composite CVD outcomes of varying severity (fatal and nonfatal outcomes with some trials including angina, revascularization in composite CVD outcome).; Low event rates for stroke (1 to 2% for total stroke in control groups; <1% to 2% ischemic stroke events in control groups) limit precision for these outcomes.; Studies infrequently adjusted for confounders. | Broadly appliable to primary prevention populations, including those with comorbidities.
Total MI | K=11 RCTs; N=134,470 | Peto OR (95% CI): 0.89 (0.82, 0.96); Range of absolute effects, %: −1.9 to 1.2 | Consistent, precise | HIGH for benefit | | Broadly appliable to primary prevention populations, including those with comorbidities.
Total stroke | K=11 RCTs; N=134,470 | Peto OR (95% CI): 0.91 (0.84, 0.99); Range of absolute effects, %: −2.0 to 0.1 | Reasonably consistent, precise | MODERATE for benefit | | Broadly appliable to primary prevention populations, including those with comorbidities.
Total ischemic stroke | K=5 RCTs; N=79,334 | Peto OR (95% CI): 0.82 (0.72, 0.92); Range of absolute effects, %: −0.6 to −0.2 | Consistent, precise | MODERATE for benefit | | Broadly appliable to primary prevention populations, including those with comorbidities.
CVD mortality | K=11 RCTs; N=134,470 | Peto OR (95% CI): 0.95 (0.86, 1.05) | Reasonably consistent, imprecise | MODERATE for no benefit | | Broadly appliable to primary prevention populations, including those with comorbidities.
All-cause mortality | K=11 RCTs; N=134,470 | Peto OR (95% CI): 0.98 (0.93, 1.03) | Reasonably consistent, reasonably precise | MODERATE for no benefit | | Broadly appliable to primary prevention populations, including those with comorbidities.
CRC incidence (based on trial evidence only) | K=4; N=86,137 | Peto OR (95% CI): 1.07 (0.92, 1.24) | Inconsistent, imprecise | INSUFFICIENT | CRC outcomes:; Most trials have inadequate RCT followup period of ~5 years for cancer outcomes; only WHS has a randomized period of 10 years. Very few cases and wide confidence intervals.; Long-term followup collected in an observational design where allocation to aspirin or control was no longer randomized. Adherence and cross-over increased over time. Observational data for some trials collected by outside investigators. | Broadly applicable to primary prevention populations, but for longest-term F/U some analyses available for females only (WHS) or males only (TPT). TPT is an older trial where 41% were current smokers.
CRC incidence (based on long-term observational evidence only in primary prevention populations) | K=1 (WHS); N=39,876 | WHS 17.5 years: Peto OR 0.82 (0.69 to 0.98); WHS 26 years: Peto OR 0.87 (0.74, 1.02) | NA (1 study: WHS), imprecise | INSUFFICIENT | | Broadly applicable to primary prevention populations, but for longest-term F/U some analyses available for females only (WHS) or males only (TPT). TPT is an older trial where 41% were current smokers.
CRC mortality (based on trial only evidence) | K=2; N=59,020 | 2 trials: Peto ORs 1.74 (1.02, 2.95) and 1.14 (0.73, 1.78) | Reasonably consistent, imprecise | INSUFFICIENT | | Broadly applicable to primary prevention populations, but for longest-term F/U some analyses available for females only (WHS) or males only (TPT). TPT is an older trial where 41% were current smokers.
CRC mortality (based on long-term observational evidence only in primary prevention populations) | K=2; N=44,961 | 17-18 years F/U: 2 trials, not pooled: Peto ORs 0.86 (0.64, 1.16) and 0.62 (0.41, 0.94) | Consistent, imprecise | INSUFFICIENT | | Broadly applicable to primary prevention populations, but for longest-term F/U some analyses available for females only (WHS) or males only (TPT). TPT is an older trial where 41% were current smokers.
KQ2
Total major bleed | K=10 RCTs; N=133,194 | Peto OR (95% CI): 1.44 (1.32, 1.57); Range of absolute effects, %: 0.1 to 1.0 | Consistent, precise | HIGH for harm | Harms outcomes:; Rare event rates for bleeding harms limit precision, particularly for hemorrhagic stroke. Substantial clinical heterogeneity in populations, recency, and trial duration. Ascertainment methods of GI bleeding events rarely reported in trials.; Dose analyses very limited in cohorts because many cohorts reported a wide range of doses. | Broadly appliable to primary prevention populations, including those with comorbidities.
Extracranial hemorrhage | K=10 RCTs; N=133,194 | Peto OR (95% CI): 1.53 (1.39, 1.70); Range of absolute effects, %: 0.2 to 0.9 | Consistent, reasonably precise | MODERATE to HIGH for harm | | Broadly appliable to primary prevention populations, including those with comorbidities.
Major gastrointestinal bleeding | K=10 RCTs; N=119,130; Cohort; K=1 (HPFS); N=32,989 | Peto OR (95% CI): 1.58 (1.38, 1.80); Range of absolute effects, %: 0.06 to 0.6; Cohort: Within-study comparisons from 1 cohort suggest that higher dose is associated with higher rates of major GI bleeding (81 mg/d: adjusted RR 1.17 [95% CI, 0.89 to 1.53]; 325 mg/d: adjusted RR 1.67 [95% CI, 1.20 to 2.33]). | Consistent, reasonably precise | MODERATE for harm | | Broadly appliable to primary prevention populations, including those with comorbidities.
Intracranial hemorrhage | K=11 RCTs; N=134,470 | Peto OR (95% CI): 1.31 (1.11, 1.54); Range of absolute effects, %: −0.2 to 0.4 | Consistent, imprecise | MODERATE for harm | | Broadly appliable to primary prevention populations, including those with comorbidities.
Total hemorrhagic stroke | K=10 RCTs; N=133,194; Cohort; K=1 (NHS); N=87,680 | Peto OR (95% CI): 1.18 (0.97, 1.45); Cohort: within-study comparisons from 1 cohort suggest that increased days of aspirin/ week are associated with a statistically significant trend for increased risk (p=0.02) (1-6 doses/week: IRR 0.84 [95% CI, 0.58 to1.21]; 7-14 doses/week adjusted RR 1.25 [95% CI, 0.76 to 2.05]; ≥15 doses/week adjusted RR 1.63 [95% CI, 0.93 to 2.86]. | Inconsistent, imprecise | LOW for harm | | Broadly appliable to primary prevention populations, including those with comorbidities.

* Pooled estimates presented where quantitative pooling was conducted; absolute effects calculated only when relative effects were statistically significant

Abbreviations: ACM = all-cause mortality; CI=confidence interval; CRC = colorectal cancer; CVD=cardiovascular disease; d = day; F/U = followup; GI = gastrointestinal; HPFS = Health Professionals’ Followup Study; IPD = individual patient data; K=number of studies; KQ = Key Question; MA = meta-analysis; mg = milligram; N=number of participants; NA = not applicable; NHS = Nurses’ Health Study; OR=odds ratio; PHS = Physicians’ Health Study; RCT=randomized controlled trial; SOE = strength of evidence; TPT = Thrombosis Prevention Trial; US = United States; WHS = Women’s Health Study

Table 22 Summary of Evidence for All Aspirin Doses and Sub-Key Questions (KQ1a/b, KQ2 a/b)

Outcome | Studies (K); Study design Observations (N) | Summary of findings^*^ | Consistency and precision | Overall SOE | Body of evidence limitations | Applicability
KQ1
Major CVD events | K=13; N=161,680 | Peto OR (95% CI): 0.89 (0.85, 0.94); Range of absolute effects, %: −2.5 to −0.08 | Consistent, precise | HIGH for benefit | CVD outcomes:; Substantial clinical heterogeneity in populations, recency as a proxy for optimal CVD risk factor management, and trial duration. Trials mostly 4-6 years with one trial as long as 10 years.; Trials powered for composite CVD outcomes of varying severity (fatal and nonfatal outcomes with some trials including angina, revascularization in composite CVD outcome).; Low event rates for stroke (1 to 2% for total stroke in control groups; <1% to 2% ischemic stroke events in control groups) limit precision for these outcomes.; Studies infrequently adjusted for confounders. | Broadly appliable to primary prevention populations, including those with comorbidities.; Most trials (11 of 13) used low-dose aspirin which is the most clinically relevant in current practice.
Total MI | K=13; N=161,680 | Peto OR (95% CI): 0.86 (0.80, 0.92); Range of absolute effects, %: −1.9 to 1.2 | Consistent, precise | HIGH for benefit | | Broadly appliable to primary prevention populations, including those with comorbidities.; Most trials (11 of 13) used low-dose aspirin which is the most clinically relevant in current practice.
Total stroke | K=13; N=161,680 | Peto OR (95% CI): 0.94 (0.87, 1.01); Range of absolute effects, %: −2.0 to 0.4 | Reasonably consistent, reasonably precise | LOW for no benefit | | Broadly appliable to primary prevention populations, including those with comorbidities.; Most trials (11 of 13) used low-dose aspirin which is the most clinically relevant in current practice.
Total ischemic stroke | K=7; N=106,554 | Peto OR (95% CI): 0.86 (0.77, 0.97); Range of absolute effects, %: −0.6 to 0.2 | Consistent, precise | MODERATE for benefit | | Broadly appliable to primary prevention populations, including those with comorbidities.; Most trials (11 of 13) used low-dose aspirin which is the most clinically relevant in current practice.
CVD mortality | K=13; N=161,680 | Peto OR (95% CI): 0.95 (0.87, 1.04) | Reasonably consistent, imprecise | MODERATE for no benefit | | Broadly appliable to primary prevention populations, including those with comorbidities.; Most trials (11 of 13) used low-dose aspirin which is the most clinically relevant in current practice.
All-cause mortality | K=13; N=161,680 | Peto OR (95% CI): 0.97 (0.93, 1.02) | Reasonably consistent, reasonably precise | MODERATE for no benefit | | Broadly appliable to primary prevention populations, including those with comorbidities.; Most trials (11 of 13) used low-dose aspirin which is the most clinically relevant in current practice.
CRC incidence (based on trial only evidence) | K= 5; N=108,208 | Peto OR (95% CI): 1.08 (0.94, 1.24) | Inconsistent, imprecise | INSUFFICIENT | CRC outcomes:; Most trials have inadequate RCT followup period of ~5 years for cancer outcomes; only WHS has a randomized period of 10 years. Very few cases and wide confidence intervals.; Long-term followup collected in an observational design where allocation to aspirin or control was no longer randomized. Adherence and cross-over increased over time. Observational data for some trials collected by outside investigators. | Broadly applicable to primary prevention populations, but for longest-term F/U some analyses available for females only (WHS) or males only (TPT). TPT is an older trial where 41% were current smokers.
CRC incidence (based on long-term observational evidence only in primary prevention populations) | K= 2; N=45,015 | 2 trials, up to 20 years F/U: Peto ORs 0.70 (0.50 to 0.98) and 0.82 (0.69, 0.98); Range of absolute effects, %: −1.1 to −0.2 | Consistent, imprecise | VERY LOW for benefit | | Broadly applicable to primary prevention populations, but for longest-term F/U some analyses available for females only (WHS) or males only (TPT). TPT is an older trial where 41% were current smokers.
CRC mortality (based on trial only evidence) | K=2; N=59,020 | 2 trials: Peto ORs 1.74 (1.02, 2.95) and 1.14 (0.73, 1.78) | Reasonably consistent, imprecise | INSUFFICIENT | | Broadly applicable to primary prevention populations, but for longest-term F/U some analyses available for females only (WHS) or males only (TPT). TPT is an older trial where 41% were current smokers.
CRC mortality (based on long-term observational evidence only in primary prevention populations) | K=3; N=50,100 | Up to 18 years F/U: Peto OR 0.76 (0.62, 0.94); Range of absolute effects, %: −0.8 to −0.06 | Consistent, imprecise | INSUFFICIENT | | Broadly applicable to primary prevention populations, but for longest-term F/U some analyses available for females only (WHS) or males only (TPT). TPT is an older trial where 41% were current smokers.
KQ2
Total major bleed | K=12; N=160,404; Cohort; K=1; N=372,850 | Peto OR (95% CI): 1.45 (1.33, 1.58); Range of absolute effects from trials, %: −0.1 to 1.0; Cohort: IRR 1.55 (1.48 to 1.63) | Consistent, precise | HIGH for harm | Harms outcomes:; Rare event rates for bleeding harms limit precision. Substantial clinical heterogeneity in populations, recency, and trial duration. Ascertainment methods of GI bleeding events rarely reported in trials.; Dose analyses very limited in cohorts because many cohorts reported a wide range of doses. | Broadly appliable to primary prevention populations, including those with comorbidities.; Most trials (11 of 13) used low-dose aspirin which is the most clinically relevant in current practice.
Extracranial hemorrhage | K=12; N=160,404 | Peto OR (95% CI): 1.53 (1.39, 1.69); Range of absolute effects from trials, %: −0.1 to 0.9 | Consistent, reasonably precise | MODERATE for harm | | Broadly appliable to primary prevention populations, including those with comorbidities.; Most trials (11 of 13) used low-dose aspirin which is the most clinically relevant in current practice.
Major gastrointestinal bleeding | K=12; N=146,340; Cohort; K=5; N=852,014 | Peto OR (95% CI): 1.57 (1.37, 1.78); Range of absolute effects from trials, %: −0.1 to 0.6; Cohorts: Relative comparisons ranged from 0.97 (0.77, 1.16) to 1.67 (1.20, 2.33) | Consistent, reasonably precise | MODERATE for harm | | Broadly appliable to primary prevention populations, including those with comorbidities.; Most trials (11 of 13) used low-dose aspirin which is the most clinically relevant in current practice.
Intracranial hemorrhage | K=13; N=161,680; Cohort; K=1; N=372,850 | Peto OR (95% CI): 1.33 (1.13, 1.56); Range of absolute effects from trials, %: −0.2 to 0.4; Cohort: IRR 1.54 (1.43, 1.67) in 1 cohort | Consistent, imprecise | MODERATE for harm | | Broadly appliable to primary prevention populations, including those with comorbidities.; Most trials (11 of 13) used low-dose aspirin which is the most clinically relevant in current practice.
Total hemorrhagic stroke | K=12; N=160,404; Cohort; K=3; N=119,781 | Peto OR (95% CI): 1.23 (1.01, 1.48); Range of absolute effects from trials, %: −0.07 to 0.2; Cohorts: Relative comparisons ranged from 0.85 (0.53, 1.10) to 1.26 (0.70, 2.25) | Inconsistent, imprecise | LOW for harm | | Broadly appliable to primary prevention populations, including those with comorbidities.; Most trials (11 of 13) used low-dose aspirin which is the most clinically relevant in current practice.
Subquestions for differences in treatment effect in specific a priori populations and analyses by duration
KQ1/2a. Differences in treatment effect for CVD outcomes, CRC, and harms in a priori identified subpopulations defined by age, sex, race and ethnicity, diabetes, and CVD risk | See specific population credibility table (Appendix D, Table 23) for details | In the body of evidence for aspirin for the primary prevention of CVD, there is robust and credible reporting for CVD outcomes for subpopulations as defined by age and sex. Reporting is less robust, but still credible, for CVD outcomes by diabetes status and baseline CVD risk strata. Analyses by race and ethnicity are extremely sparse. For all subpopulation analyses examined, ACM, CRC and harms were reported less frequently than CVD outcomes.; Findings consistently showed no difference in treatment effect across all subpopulations evaluated and CVD outcomes, all-cause mortality, CRC, and harms, with one notable exception. There was an inconsistent signal in analyses by age where WHS and PHS reported statistically significant interaction testing with greater benefit in older age groups for MI. This finding was not consistent with findings in other trials for CVD composite outcomes and such suggestion of treatment effect modification was not confirmed in a prior 2009 IPD MA. | See specific population credibility table (Appendix D, Table 23) for details | INSUFFICIENT to LOW | No updated IPD MA that includes 3 trials published since previous review. IPD MA is more appropriate for evaluation of potential heterogeneity of treatment effect than trial-level analyses.; For analyses by baseline CVD risk, each trial used a different CVD risk calculator and different risk thresholds; Adjustments for confounders were generally not performed in subgroup analyses and in a few cases it was unclear if they were performed; Limited reporting for ACM, CRC, harms. | For analyses by age, sex, and diabetes status, broad applicability across primary prevention populations; In the 1 reporting trial for race and ethnicity, only 13% of participants were from the US.; No trials reported CVD risk subgroups defined by the Pooled Cohort Equations; others were study-derived scores not available or validated for use in clinical practice.
KQ1/2b. Differences in treatment effect for CVD outcomes, CRC, and harms by treatment duration | CVD outcomes; K=11; N=137,653; CRC; K=1; N=39,876; Harms; K=4; N=86,224 | In cases where time-to-event analyses suggest benefit for individual CVD outcomes, benefit generally accrues within the first 1-2 years.; For CRC incidence, followup rather than duration of use appeared to show a trend towards effects appearing after 10 years and continuing through approximately 17 to 20 years, however the results are driven by the large WHS trial.; Only 4 of 14 trials report time-to-event analyses for any bleeding harms. Using Kaplan-Meier curves, it appears that the bleeding harms occur immediately or at about 1 year. However, results are statistically significant in only 2 of 4 trials reporting time-to-event analyses. | CVD: consistent and reasonably precise; CRC: consistency NA and precise; HARMS: consistent and reasonably precise | MODERATE that CVD benefit accrues in 1-2 years and continues for at least 4-6 years; INSUFFICIENT for CRC outcomes; MODERATE that bleeding harm accrues soon after aspirin initiation | In most trials, aspirin administration continued for only the 4-6 year trial duration so it is difficult to make any conclusions about effect of aspirin on CVD outcomes for longer term use.; Most trials reported time-to-event analyses for study-defined CVD composite outcomes and there was variation in the definition for these composites.; Analyses limited by very rare harms events. | Broadly appliable to primary prevention populations, including those with comorbidities.; CRC duration analyses limited 1 study in females only

* Pooled estimates presented where quantitative pooling was conducted; absolute effects calculated only when relative effects were statistically significant

Abbreviations: ACM = all-cause mortality; CI=confidence interval; CRC = colorectal cancer; CVD=cardiovascular disease; F/U = followup; GI = gastrointestinal; HPFS = Health Professionals’ Followup Study; IPD = individual patient data; K=number of studies; KQ = Key Question; MA = meta-analysis; MOD = moderate; N=number of participants; NA = not applicable; NHS = Nurses’ Health Study; OR=odds ratio; PHS = Physicians’ Health Study; RCT=randomized controlled trial; SOE = strength of evidence; TPT = Thrombosis Prevention Trial; US = United States; WHS = Women’s Health Study

Thus, the small absolute CVD event reductions associated with aspirin use are closely matched by increases in major bleeding. Additional CRC benefit could potentially change the net benefit of aspirin. However, our systematic review found the evidence for CRC outcomes to be insufficient to very low strength because of limitations in the number of reporting trials, adequacy of followup duration, power, and reliance on observational followup (Tables 21 and 22). New CRC data published since the previous review^4^ is available from two new trials^56,^ ^101^ and additional reporting from two older trials.^49,^ ^103^ With approximately 5 years of followup, the two new trials are too short in duration to expect a CRC incidence or mortality benefit to accrue, so the nonstatistically significant findings for CRC incidence in both trials are not surprising. However, in this same approximate 5-year period, ASPREE’s findings of a statistically significant increase in CRC mortality—apparently due to a shift in greater late-stage cancers^131^—is concerning. The 10.7-year followup newly available from JPAD does not materially change prior CRC incidence estimates at 10-year followup because of the small and nearly equal number of incident CRC cases in the aspirin and control groups (27 and 31 cases, respectively). Longer-term results from WHS confirm that no CRC benefit is seen until 10 years after initiation, which may be plausible as the progression of an adenoma to CRC can take up to 10 years or longer. The CRC incidence benefit appears to be mitigated over time without continued aspirin use as unpublished results show that during the time period from years 17-26 years, the CRC incidence benefit is no longer seen^49^

## Risk-Based Approach

The net benefit of aspirin for primary prevention is directly related to the risk of CVD events balanced by the risk of bleeding events. Baseline risk of both CVD and bleeding determine if the relative benefits and harms from aspirin translate into meaningful absolute differences. Limiting aspirin use to those populations more likely to see a greater relative benefit or lesser relative harms would be desirable. In our analyses of specific populations, there was no compelling evidence to suggest that the relative benefits or harms of aspirin differ in any of our a priori identified populations defined by age, sex, race and ethnicity, diabetes status, and estimated CVD risk (Appendix D, Table 23). However, the strength of evidence for analyses in specific populations is insufficient to low in the absence of an updated IPD meta-analysis, which is the most appropriate source from which to conduct these analyses. Our conclusions are consistent with findings from a previous IPD meta-analysis,^50^ which will likely be updated in 2021 and will include the most recent trials.^51^ The one specific population previously understudied with newly available information was the older adult population. The new ASPREE trial^54,^ ^101^ suggests an overall harm of aspirin in the older population with an increase in all-cause mortality driven by higher cancer-related deaths. In the absence of evidence for differential treatment harms and benefits, aspirin’s net benefit then hinges on the target population’s baseline risk of CVD and bleeding.

## Baseline CVD Risk Models

Given results from recent trials suggesting at most modest benefits from aspirin and harm in the ASPREE trial, many international guideline panels have recommended against routine aspirin use for primary prevention and instead have guidance to limit aspirin use to those with higher CVD risk and low GI bleeding risk (Table 3). The previous USPSTF recommendation^1^ recommended low-dose aspirin for those 50-59 years with a 10 percent or greater CVD risk without an increased risk of bleeding (B recommendation) and for those 60-69 years with 10 percent or greater risk and no increased risk of bleeding as a shared decision (C recommendation). Because absolute benefit hinges on CVD risk, the selection of a specific CVD risk estimation tool has a substantive influence on for whom aspirin would be recommended. Inaccuracies in risk prediction could lead to over- or under-use of aspirin if a risk calculator systematically over or under predicts absolute CVD risk. The previous USPSTF aspirin recommendation uses the specific estimated 10-year CVD risk threshold of 10 percent from the PCE to guide decision-making.^22^

Concerns have been raised about potential inaccuracies with the PCE. These concerns have centered around model calibration, which is the agreement between observed and predicted outcomes.^138^ While selected analyses have shown good calibration of the PCE in some external validation cohorts,^139^ others have shown under- and overprediction in the PCE.^140–142^ Reports of under- and overprediction are not unique to the PCE and have been observed in other risk tools that have been used in practice.^140,^ ^143^ Most commonly, external validation analyses show overprediction of the PCE in broad populations of men and women, in Black and White adults, and in older adults.^140,^ ^141,^ ^143,^ ^144^ One potential source of inaccuracy in the PCE is that risk equations are available for White and Black populations, but not for other racial and ethnic groups, who are recommended to use the equations for White participants.^21,^ ^145^ An analysis of a large and diverse primary care dataset (N=307,591), showed that overprediction also occurs in Asian, Pacific Islander, and Hispanic populations when the PCE equations for White men and women are used as recommended.^144^ However, differences in outcome ascertainment and surveillance between the routine care database used for this validation cohort and prospectively collected outcomes for the derivation cohort limit the conclusions of this analysis. Analyses from the Multi-Ethnic Study of Atherosclerosis (MESA) cohort and Women’s Health Initiative (WHI) similarly show overprediction in these racial and ethnic groups.^146,^ ^147^ Overestimation was dramatically reduced when events from additional surveillance were included in sensitivity analyses in one^147^ cohort but was not reduced in similar sensitivity analyses in the other cohort.^9^ Another source of inaccuracy may be the use of dated cohorts in the development of the PCE.

Limited evidence suggests that there may be important differences in PCE performance by socioeconomic characteristics, where underprediction occurs in economically disadvantaged communities.^142,^ ^148^ If confirmed, such a finding would imply systematic under-initiation of aspirin as a preventive measure in disadvantaged communities which also experience higher event rates. However, another analysis of a large primary care dataset reported similar risk overestimation across socioeconomic status subgroups.^144^ An external validation of the PCE conducted in a large New Zealand cohort found that socioeconomic deprivation was an independent and statistically significant predictor of CVD when added to the risk prediction equation.^149^ Taken together, these findings suggest that the addition of socioeconomic status to CVD risk prediction tools may improve the identification of populations at high risk of adverse outcomes.

Despite the aforementioned shortcomings, the PCE is, to date, the only U.S.-based global CVD calculator that has published its external validations in other U.S.-based populations. Addition of nontraditional risk factors,^24,^ ^150^ recalibration, and other model revisions have been suggested to improve model fit, and such updates to the PCE may mitigate over- and underestimation concerns.^150–152^ Some have specifically suggested the addition of coronary artery calcium (CAC) scoring to guide aspirin use.^153^ However, this approach has not been evaluated in trials.

## Bleeding Risk

### Prognostic Models

Risk estimation models for major bleeding are far more limited compared to those for CVD. We identified no U.S.-based externally validated risk prediction tools for bleeding risks associated with low-dose aspirin for the primary prevention of CVD. Several well-known bleeding risk models have been developed to inform clinical decision-making, however most have been developed in patients with atrial fibrillation or venous thromboembolic events for anticoagulation candidacy (HAS-BLED, QBLEED, ATRIA, RIETE, OBRI).^154–158^ In addition to population applicability concerns, these bleeding models either lack external validation or have shown poor predictive value.^156^ Likewise, models differ in the type and severity of bleeding events predicted.

Two risk models^159,^ ^160^ may represent the most promising risk models that could be used for aspirin decision-making for primary CVD prevention, but both have limitations which preclude application to U.S.-based clinical practice. Selak et al. developed a prognostic major bleeding model among persons in whom aspirin might be considered for the primary prevention of CVD.^159^ This group analyzed the New Zealand primary care PREDICT cohort (2007-2016) for model derivation (N=234,825) and a split-sample internal validation (N=143,675) in individuals ages 30-79 years not using aspirin. The multivariate model included a large number of predictors, including: demographic characteristics (age, ethnicity, and socioeconomic deprivation), clinical measurements (systolic blood pressure and ratio of total-high-density lipoprotein cholesterol), family history of premature CVD, medical history (smoking, diabetes, bleeding, peptic ulcer, cancer, alcohol related condition, chronic liver disease or pancreatitis), and medication use (nonsteroidal anti-inflammatory agents, corticosteroids, and selective serotonin reuptake inhibitors). The non-parsimonious nature of the model has been criticized as presenting a barrier to routine use, with particular note that the social deprivation predictor is not transportable to other populations.^161^ This risk prediction model has not been externally validated outside of New Zealand.

In an older paper with the aim of developing an easy-to-use score, DeGroot et al. developed a simple upper GI bleeding risk score for low-dose aspirin users without a history of prior GI bleed using a large Dutch health insurance database (2006-2010; N=235,531 aspirin users age ≥18 year).^160^ External validation was conducted in a separate but similar Dutch insurance database of aspirin users identified via a nested case control approach (2005-2010; N=32,613 aspirin users, mean age 69 years). A limited set of candidate risk factors was considered based on plausibility, reliability, and distribution in the cohort and then the risk score was simplified to only 5 of the most important risk factors with backward stepwise elimination using likelihood ratio statistics. Risk factors were then assigned a point score based on the beta coefficient of the risk factor. Age >60 years, anemia, diabetes, other antiplatelet use, and anticoagulant use were the risk factors included in the final risk score. The authors reported modest accuracy in the validation cohort (C-statistic=0.63). While the tool was designed for easy implementation, other investigators have not externally validated the score and because of brief reporting, there is some uncertainty regarding the selection of risk factors.

### Multivariate Analyses

In the absence of externally validated risk prediction models in clinically relevant populations, multivariate analyses identifying risk factors independently associated with increased bleeding risk could inform whether there are specific populations for whom bleeding risk is high enough to preclude aspirin use in the context of modest CVD benefit. We have compared risk factors identified in four multivariate analyses^50,^ ^117,^ ^159,^ ^160^ (Appendix D, Table 24). Risk factors consistently and independently associated with bleeding risk in these four analyses are older age, male sex, and diabetes. The three cohort analyses consistently showed that a history of GI issues, such as prior GI hospitalization, liver disease, alcohol disease, or peptic ulcer disease can increase the risk of bleeding. Further, concomitant medications including antiplatelets, NSAIDs, steroids, and anticoagulants can additionally increase the risk of bleeding. Only the New Zealand analysis by Selak et al^159^ evaluated race, ethnicity, and socioeconomic status as predictors of bleeding risk. Both self-reported Maori and Pacific ethnicity were associated with a statistically significant elevated risk of major bleeding compared to those of European background. Socioeconomic deprivation was also statistically significantly associated with an increased risk of major bleeding in this analysis.^159^

The approach of limiting aspirin use in primary prevention to those patients without selected baseline bleeding risk factors including concomitant medications (NSAIDs, systemic steroids, anticoagulants, other antiplatelet agents) and medical conditions (history of GI bleeding, coagulopathy, peptic ulcer disease, liver disease, alcohol related diseases) has been used in trials and suggested in guidelines.^1,^ ^24^

### Net Benefit Risk Calculators

Much attention has been given to net benefit assessment tools for aspirin use in primary prevention.^87,^ ^162,^ ^163^ One model is currently being developed to inform the USPSTF deliberations.^25^ A benefit to an integrated net benefit model—as opposed to use of separate CVD and bleeding risk calculators—is that several risk factors increase both CVD risk and bleeding risk.^50^ Because the literature base on CVD risk prediction is more developed than that for GI bleeding risk, net benefit calculators emphasizing CVD risk may not fully account for bleeding risk factors. For example, certain risk factors which contribute to increased CVD risk also appear to elevate bleeding risk (age, sex, smoking, diabetes) while other CVD risk factors may not alter baseline bleeding risk (hyperlipidemia, family history of premature CVD). A calculator that includes risk factors such as smoking and diabetes (which increase CVD risk) for CVD estimation, but does not include these factors (which also increase GI bleeding risk) for GI bleeding risk estimation, may bias a calculator in favor of aspirin for persons at above average CVD risk levels by underestimating potential harms. However, critical limitations in the reporting of baseline GI bleeding estimates accounting for the presence of multiple risk factors, particularly in United States populations, presents limitations for the development of net benefit calculators. Because of the availability of a New Zealand-specific bleeding risk tool, Selak and colleagues were able to bring together their bleeding risk calculator along with updated pooled estimates of the effectiveness of aspirin to prevent CVD from a 2019 meta-analysis,^133^ to develop individualized benefit-harm analyses available as an online net benefit calculator for clinical application (https://aspirinbenefitharmcalculator.shinyapps.io/calculator/).^164^ Cancer outcomes are not incorporated into this model. This model calculates net benefit using two methods: assuming one CVD event was equivalent to one major bleed, and then assuming one CVD event was equivalent to two major bleeds. Assuming one CVD event is equivalent to one major bleed, 2.5 percent of females and 12.1 percent of males age 30-79 years without known CVD in this New Zealand cohort would achieve a net benefit from aspirin, with results highly dependent on baseline CVD and bleeding risk.

Ideally, shared decision-making related to aspirin initiation or discontinuation would be informed by user-friendly decision support tools including publicly available online net benefit risk calculators. In addition to the Selak calculator mentioned above, there are a few other such calculators available: https://asarisk.doctime.es/, http://www.aspiringuide.com/nav/3, and https://www.benefit-harm-balance.com/. The latter of these also offers estimates that include patient preferences. For application in the United States, these calculators do require updated CVD risk estimation with the PCE, updated meta-analysis estimates for the relative benefit and harm of aspirin in primary prevention populations, and contemporary estimates of absolute baseline bleeding risk rates.

### Bleeding Risk Mitigation

Strategies to mitigate bleeding risk in those identified to be aspirin candidates may be to limit aspirin dose, use an aspirin formulation with enteric coating, or coadminister aspirin with a proton pump inhibitor (PPI). Our review of primary CVD prevention trials did not provide sufficient evidence to make any conclusions about whether enteric coating mitigates bleeding risk, however, observational evidence does show that higher doses are associated with higher bleeding risk,^121^ despite the similar bleeding risk for low-dose and all dose aspirin seen in our meta-analysis of only primary CVD prevention trials. There is evidence supporting the use of PPIs to reduce upper GI bleeding in low-dose aspirin users, although some concerns remain about osteoporosis,^165^ B12 deficiency,^166^ and enteric infections including clostridium difficile resulting from long term PPI use.^167^ One meta-analysis of randomized trials (k=9, N=6,382) demonstrated that PPIs in primary and secondary CVD prevention populations are associated with a substantially decreased risk of peptic ulcers, bleeding ulcers, and erosive esophagitis.^168^ One analysis from the United Kingdom primary care the Health Improvement Network (THIN) database analysis (N=199,049) found that aspirin users with concurrent PPI use had a 31 percent reduced risk of upper GI bleeding when the PPI was used for more than 1 month (OR 0.69 [95% CI, 0.54 to 0.88]) compared to aspirin users with past use of PPI.^169^ Additionally, h pylori eradication has been proposed to mitigate aspirin-associated bleeding risk.^170^

## Aspirin Discontinuation

Our analyses of primary CVD prevention trials suggest that CVD benefits accrue within the first 1-2 years and bleeding risks begin soon after initiation of aspirin. Unfortunately, limited specificity of the time points reported in trials’ time-to-event analyses and Kaplan-Meier curves preclude more precise estimations of onset of these effects. These benefits and harms appear to persist while the participants continued to take aspirin during the trial duration, with cessation of CVD benefits and harms after aspirin has been discontinued. For example, in the long-term observational followup of WHS, CVD outcomes became null over long observational time points.^112^ These primary trials do not provide precise estimates of temporal variations in bleeding risk over the duration of aspirin administration. It is unclear whether the risk of bleeding associated with aspirin use is especially high in the earliest period of administration. Nonetheless, assuming lifelong aspirin administration is likely unreasonable. Periodic re-assessment of net benefit is essential with decisions to discontinue aspirin use at some future time point after initiation.

Very little is known about any rebound thrombotic risks associated with aspirin discontinuation, although one cohort study has been published since the last review. A Swedish cohort study of over 600,000 adults evaluated the risk of cardiovascular events (hospitalization for MI, stroke, or CVD death) associated with discontinuation of long-term, low-dose aspirin therapy.^171^ In the population taking aspirin for CVD primary prevention, discontinuation of aspirin was associated with a 28 percent increase (95% CI, 1.22 to 1.34) in cardiovascular events over a median of 3 years’ followup. Until this study has been confirmed in another large primary prevention cohort, these findings should be considered with caution. This increase in risk associated with discontinuation is roughly similar to our pooled estimates of CVD risk reduction associated with aspirin initiation, so this limited evidence suggests that CVD risk returns to baseline after discontinuation without an excess rebound harm. Other research with intermediate platelet markers in animal models or in the secondary prevention literature is likewise scant.^172,^ ^173^ More evidence is needed on this point, and an ongoing trial testing outcomes in aspirin withdrawal was also identified, but the estimated completion date is not until 2024.^174^

## Statin Use

We examined how contemporary CVD risk factor management, especially widespread statin use, may impact aspirin’s effectiveness on CVD outcomes with our sensitivity analyses examining trials conducted before and after the ATP III guideline release in 2001. Results were conflicting across outcomes. Consistent with other analyses^175,^ ^176^ comparing the effect of aspirin in the context of older versus contemporary CVD management,^175^ we report that the major CVD event and MI benefits as well as most bleeding harms were diminished while ischemic stroke emerged as a statistically significant benefit in the post-ATP III pooled analysis. We believe these findings likely to be influenced by dose as contemporary trials solely use low-dose aspirin. The two higher dose trials—BMD (500 mg/day) and PHS (162.5 mg/day)—were published in the 1980s, prior to widespread statin use. Other sources of heterogeneity such as trial populations and duration may have further influenced aspirin’s effect in these analyses. Three contemporary trials, ASCEND, ARRIVE, and ASPREE performed subgroup analyses by statin use finding no statistically significant interaction between aspirin and statins.^55,^ ^56,^ ^101^ Nonetheless, statins have taken priority in the primary prevention clinical landscape due to recent aspirin trials generally showing null effects on CVD outcomes along with statins’ well-established statistically significant relative risk reductions for cardiovascular disease events (25%), stroke events (22%), and mortality (14%) and favorable side effect profile.^177^

The recently published TIPS-3 trial (N=5,713) with a 2x2 factorial design evaluating a polypill and aspirin and recruiting patients with elevated CVD risk was not included in our results.^178^ Nearly all countries represented were not high Human Development Index countries which we required for generalizability to the United States population by our inclusion criteria. However, inclusion of this trial would not have changed our overall conclusions. In this trial, aspirin reduced stroke (RR 0.58 [95% CI, 0.35 to 0.98]) but there was no statistically significant difference in CVD composite outcomes, CVD death, or MI between the aspirin and control groups.

## CRC

Because this review was an update of prior reviews,^2–4^ our scope included potential benefits from CVD as well as CRC. Our conclusions about the CRC benefits of aspirin are somewhat different than the previous review.^4^ We conclude that there is insufficient evidence on the influence of low-dose aspirin on CRC incidence and CRC mortality in the primary CVD prevention trial evidence due to methodological limitations associated with the observational periods of trials. We have assessed that there is a very low strength of evidence supporting a reduction in CRC incidence from any dose of aspirin, including high doses above what would be considered appropriate in the context of primary CVD prevention. Our insufficient strength of evidence for CRC outcomes is supported by few included trials, many of which were small and reliant on post-trial observational results that are subject to biases (Table 21). Even ASPREE, which showed a CRC mortality harm occurring within the first 5 years of randomized aspirin use, is limited by the short duration and large quantity of outcomes.

Our sensitivity analyses included trials of secondary CVD prevention^94,^ ^111^ and all doses of aspirin, as was done in the prior review (Figures 20–22, 24). These sensitivity analyses include broader post-trial observational data with consistent patterns of CRC incidence and mortality benefits, however there are still few overall studies with concerns about applicability and the biases associated with observational designs. Additionally, we recognize that there is a larger evidence base of observational studies addressing the association between aspirin use and CRC incidence or mortality. For example, a 2018 meta-analysis of 39 observational studies^179^ reported an association between aspirin use and decreased colorectal cancer incidence (RR 0.79 [95% CI, 0.74 to 0.85]). In addition, a recent cohort study using the PLCO trial participants (n~146k) also reported a reduction in CRC incidence associated with aspirin use.^180^ However, some of the surprising and substantial benefits reported bring into question the validity of observational data; for example, aspirin used only 1-3 times per month was associated with a large all-cause mortality benefit. Further, a pooled analysis^181^ of two cohort studies indicated initiation of aspirin at 70 years or older was not associated with a lower risk of CRC, but did lower the risk of CRC for adults who initiated aspirin prior to age 70. The observational literature is further limited by heterogeneity of aspirin dosages, duration, indications, and populations. Observational data is also subject to numerous biases: selection bias (aspirin users may be healthier), misclassification bias (post-hoc CRC outcome measurement and aspirin exposures may not be accurate), recall bias (about reporting of true aspirin exposure), and confounding (particularly when indication and duration/dose vary or are unreported).

While not included in this update, the previous version of this systematic review^4^ included evidence of the effect of aspirin on adenoma prevention. The previous review identified three RCTs among people with a history of adenomas, but the association of aspirin use with adenoma risk was inconsistent. Research conducted since the previous review also reported conflicting conclusions—with some suggesting aspirin had no effect on adenomas,^182,^ ^183^ or an effect only on adenomas in certain locations^184^ (e.g., right-sided) or types of adenomas^185^ (e.g., tubular adenomas).

Aspirin may also be useful in the prevention of CRC in people who are at higher risk of developing CRC, such as those with previous CRC, a history of adenomas, or genetic risk factors for CRC. One systematic review of RCTs recruiting people with previous colorectal neoplasia (CRC or advanced adenomas) found that low-dose aspirin was associated with a nonstatistically significant reduction in advanced neoplasia (k=3).^186^ Another systematic review of five cohorts and one nested case-control study suggests that aspirin use after CRC diagnosis is associated with a lower risk of all-cause mortality, but the decreased risk in CRC-specific mortality was not statistically significant.^187^ Many randomized controlled trials designed to assess the impact of aspirin on colorectal cancer are in progress. One trial—Add-Aspirin—is designed to determine if aspirin use after the diagnosis of an early-stage cancer (including colon/rectum, breast, gastrointestinal, and prostate cancers) can prevent the cancer from coming back (http://www.addaspirintrial.org/). Further studies have reported that among Lynch syndrome gene carriers, high-dose aspirin for 2 years was associated with a decreased risk of colorectal cancer.^188,^ ^189^

While others have been interested in a possible benefit for other types of cancer,^190,^ ^191^ two recent study level meta-analyses did not find an association between aspirin and cancer. Overall cancer incidence and mortality outcomes were reported as exploratory outcomes in one review by Zheng (cancer incidence: 10 RCTs, N=124,523; cancer mortality: 12 RCTs, N=149,134), and no cancer outcome was statistically significant.^133^ Similarly, the 2019 review by Haykal and colleagues focused on aspirin for the primary prevention of cancer (16 RCTs, N=104,018) found no statistically significant differences for any cancer outcome.^134^

## Ongoing Trials

We identified a few ongoing primary prevention aspirin trials and related cohorts (Appendix E). A cohort study in Hong Kong (N=NR) will study the effectiveness of low-dose aspirin for the primary prevention of GI cancers (NCT04081831). A Korean trial of 4,118 participants is examining the effects of aspirin discontinuation on CVD events and is expected to publish in 2024 (NCT03757156 (https://clinicaltrials.gov/ct2/show/NCT03757156)). Finally, one in-progress cross sectional study (N=1,028) in Italy aims to examine patient preferences around benefit and harm trade-offs associated with of low-dose aspirin for primary and secondary prevention (NCT03603366). Further, ASCEND (NCT00135226) and ASPREE (ASPREE-XT) are following participants for long-term cancer outcomes.

## Limitations of the Literature

There are several limitations to this literature. As mentioned previously, the 13 primary prevention studies are clinically heterogeneous in terms of aspirin dose, duration, populations, and baseline CVD risk. Additionally, most trials were powered for variably-defined composite CVD outcomes rather than any individual CVD outcomes. In these primary prevention populations, individual CVD outcomes were rare enough that findings of nonstatistical significance could potentially be due to lack of power. While some of this lack of power can be overcome with meta-analysis, the trials are further limited by short trial durations and lack of comparable time-to-event data reporting, so we could not precisely determine the minimum time-to-benefit for CVD outcomes. We could also not determine if CVD benefits persist at a constant rate beyond 5 to 10 years of use.

Overall, there were few trials reporting CRC outcomes and they were of too short duration to expect CRC incidence or mortality benefits to accrue. Thus, we included observational periods after trial completion, recognizing that the data collection after the randomized stage is similar to an observational study and is potentially subject to bias or confounding. We also included trials recruiting secondary CVD prevention populations; since CRC and CVD share many risk factors, these populations may have increased CRC risk when compared to a general population. The timing of the CRC outcomes were inconsistent among studies, and some were captured post-hoc by a separate research group conducting an IPD MA. With the exception of WHS, trials did not collect CRC screening rates. For most studies, we also do not know the proportion of participants who continued their assigned allocation at daily or every other day dosing beyond the 5-10 year randomized phase.

Because of rare event rates for bleeding harms, estimates in this meta-analysis are imprecise for some bleeding outcomes. We therefore expanded our study design to include observational studies for harms but little detail about specific dosing and indication were available, thus little could be concluded about the harms specific to daily low-dose aspirin. We acknowledge that these cohort studies themselves have limitations, such as self-reporting of aspirin exposure,^120,^ ^121^ and incomplete reporting of dose and indication for use.^98,^ ^106,^ ^107^ In some studies, regular use was defined as >2 tablets per week, which is less use than would be seen in every other day dosing trials and may reflect indication for analgesia.^120,^ ^121^ Other cohorts reported use in excess of what would be typically used for primary prevention of CVD, also suggesting the indication was not for CVD prevention.

One additional unanswered clinical question is whether GI bleeds associated with aspirin use are more fatal, less fatal, or have similar case fatality compared to GI bleeds occurring in nonaspirin users. We did not pool fatal GI bleeding events in our meta-analysis of included trials because of an exceedingly small number of fatal bleeding events in reporting trials, and inconsistent reporting among trials. Other systematic reviews have chosen to combine primary and secondary CVD prevention trials and present data using these very small event rates, showing conflicting results.^192–194^

Little has been published about quality of life (QOL) outcomes with aspirin for primary prevention or patient preferences with aspirin use. While ASPREE’s primary outcome was disability-free survival with results showing no difference in this QOL-related outcome in the aspirin group,^102,^ ^105^ there were no other trials reporting QOL outcomes. Shared decision-making tools would ideally incorporate any QOL effects along with patient preferences; one in-progress cross sectional study (N=1,028) in Italy aims to examine patient preferences around the risks and benefits and harms of low-dose aspirin for primary and secondary prevention (NCT03603366).

## Limitations of Our Review

Our primary analyses focused on primary CVD prevention literature for all outcomes including CVD benefits, bleeding harms, and CRC effects. We did not include secondary prevention populations for the bleeding outcomes because those with CVD often have higher bleeding risk either due to risk factors (smoking, uncontrolled hypertension) or co-medication with anticoagulants. In contrast, we did pool primary and secondary CVD prevention trials for our CRC outcome analyses because there were very few primary prevention trials reporting CRC outcomes; we reported results from the post-trial observational period but did not include a wider literature of observational studies examining aspirin use and CRC outcomes. In order to maximize the number of trials pooled for CVD and bleeding outcomes, we accepted narrower or broader outcome definitions as reported by trials. For some trials we calculated our primary composite outcomes of major CVD events from individual outcomes. This approach may overestimate events if the reporting of separate outcomes included individuals with nonfatal events followed by a fatal event.

## Future Research Needs

The literature related to CVD risk estimation is far more developed than for GI bleeding risk. The next generation of aspirin net benefit calculators will require more precise estimates of GI bleeding, including fatal bleeding, that account for additional risk factors beyond age, sex, and history of aspirin use (e.g., race/ethnicity, socioeconomic status, comorbidities). Ideally, these data would be available in a large US-based cohort and could serve as the underlying data for an externally validated GI bleeding risk calculator.

For both CVD and bleeding outcomes, the forthcoming ATT IPD meta-analysis update is likely to provide the more definitive analyses on whether there is differential benefit or harm for CVD and bleeding outcomes in specific populations.

Finally, a large, long-term, low-dose aspirin trial examining CRC effects at 20 years would be ideal to examine the marginal effects of aspirin in the context of contemporary screening practices. It could also be useful to conduct a shorter trial among the general population to assess the impact of aspirin on adenomas, although that could be resource intensive and require a large number of colonoscopies. At minimum, the CVD prevention trials already conducted could link their trial participants to registries that track CRC diagnoses or deaths. However, this type of observational design would have the same limitations as those in the extended followup studies previously described. Any future trials should account for all modalities of CRC screening as well as CRC risk factors, as most of the CVD prevention trials do not address these potential confounders. Further, there are exceedingly scant data available to date to inform the role of aspirin used for primary prevention in Black, Hispanic, Asian and Native populations.

## Conclusions

This updated systematic review included three new trials (N=47,170) and three new cohort studies (N=358,495). Despite this accrual of new evidence, findings for CVD outcomes and bleeding harms were remarkably similar to our prior review.^2^ In both low-dose and all-dose analyses, aspirin was associated with statistically significant relative risk reductions and small absolute risk reductions of up to 2.5 percent for major CVD events in primary prevention populations. These benefits were offset by statistically significant relative risk increases and small absolute increases of up to 1.0 percent for major bleeding harm. While there was little new evidence about CRC effects, ASPREE’s findings of potentially increased rates of later stage cancers in older adults puts into question potential CRC benefits. Moreover, aspirin’s potential role in CRC prevention could be diminished by increases in CRC screening in recommended ages. The role of aspirin in primary prevention for CVD will continue to evolve based on the closely matched magnitude of CVD benefit and bleeding risks in the context of declining smoking rates, increasing statin use, and more aggressive hypertension management.