# Chapter 3 Results

## Literature Search

We reviewed 12,710 abstracts and assessed 225 full-text articles for inclusion (Appendix A Figure 1). For all KQs, we included 23 studies (reported in 79 articles).^45,^ ^54–131^ For KQ 1, we included 15 trials (66 articles)^45,^ ^49,^ ^54–97,^ ^99–105,^ ^108–116,^ ^125,^ ^126,^ ^129,^ ^131^ representing 165,492 people. For KQ 2, we included 21 studies (72 articles)^45,^ ^54–91,^ ^95–102,^ ^104–109,^ ^112–130^; these comprised 14 RCTs of 162,080 people and seven cohorts of 870,660 people. Three trials^55,^ ^56,^ ^101^ and three cohorts^98,^ ^106,^ ^107^ were newly identified in this update. In addition, two trials that were previously included published new data since the previous review: longer-term CVD followup from one trial,^57^ new subpopulation analyses in one trial,^97^ and CRC outcomes in two trials.^103,^ ^108^

A list of included studies and a list of excluded studies with reasons for exclusion are available in Appendix B and Appendix C, respectively. We determined all included studies were of fair or good quality (Appendix A, Table 2).

## KQ1 Does Regular Aspirin Use in Patients Without Known CVD Reduce CVD and CRC Incidence and Mortality, or All-Cause Mortality?

KQ1a Does the Effect Vary in Specific a Priori Populations Defined by Age, Sex, 10-Year Cardiovascular Risk, Diagnosis of Diabetes Mellitus, or Race/Ethnicity?
KQ1b Does the Effect Vary by Dose or Duration of Aspirin Use?

### Summary of Results

There are three new trials^55,^ ^56,^ ^101^ published since the previous reviews on this topic.^2–4^

Based on a meta-analysis of 13 primary prevention trials, aspirin at doses of 50 to 500 mg/day is associated with an11 percent reduction in major CVD events (k=13; N=161,680; Peto OR 0.89 [0.85 to 0.94]; I^2^=0%) as well as a 14 percent reduction in MIs (k=13; N=161,680; Peto OR, 0.86 [95% CI, 0.80 to 0.92]; I^2^=45.7%) and ischemic strokes (k=7; N=106,554; Peto OR, 0.86 [95% CI, 0.77 to 0.97]; I^2^=16.0%) (Table 5, Figure 3). Aspirin does not appear to have a statistically significant effect on all-cause mortality or CVD mortality. In this group of trials with relatively healthy populations, the absolute major CVD event reductions ranged from 0.08 to 2.5 percent (Table 6). All 13 primary prevention trials were powered for composite outcomes, making it difficult to determine if the nonstatistically significant findings with some individual outcomes were attributable to lack of power. Each of the trials recruited participants from specific patient populations using a wide variety of aspirin doses, thereby making pooled estimates potentially less precise for specific clinical application.

Table 5 Pooled Estimates for KQ1 and KQ2 Outcomes for Primary and Sensitivity Analyses

Outcome | Analysis | k | n | Peto Fixed Effects OR (95% CI) | I^2^ | Mantel-Haenszel Fixed Effects RR (95% CI) | I^2^ | Restricted Maximum Likelihood Random Effects (95% CI) | I^2^
Major CVD events (nonfatal MI, nonfatal stroke, CVD mortality) | All | 13 | 161,680 | 0.89 (0.85, 0.94) | 0 | 0.90 (0.86, 0.94) | 0 | 0.90 (0.86, 0.95) | 0
Major CVD events (nonfatal MI, nonfatal stroke, CVD mortality) | ≤100 mg | 11 | 134,470 | 0.90 (0.85, 0.95) | 0 | 0.90 (0.86, 0.95) | 0 | 0.90 (0.86,0.95) | 0
Major CVD events (nonfatal MI, nonfatal stroke, CVD mortality) | Prior statins | 5 | 55,574 | 0.84 (0.77, 0.92) | 0 | 0.85 (0.78, 0.93) | 1.9 | 0.85 (0.78, 0.93) | 0
Major CVD events (nonfatal MI, nonfatal stroke, CVD mortality) | Statin use | 8 | 106,106 | 0.92 (0.87, 0.98) | 0 | 0.93 (0.87, 0.98) | 0 | 0.93 (0.87, 0.98) | 0
Total MI Events | All | 13 | 161,680 | 0.86 (0.80, 0.92) | 45.7 | 0.86 (0.81, 0.92) | 47.0 | 0.86 (0.78, 0.95) | 47.8
Total MI Events | ≤100 mg | 11 | 134,470 | 0.89 (0.82, 0.96) | 26.8 | 0.89 (0.83, 0.96) | 28.0 | 0.89 (0.81, 0.97) | 26.1
Total MI Events | Prior statins | 5 | 53,035 | 0.75 (0.67, 0.83) | 16.6 | 0.75 (0.67, 0.84) | 23.6 | 0.76 (0.66, 0.87) | 31.8
Total MI Events | Statin use | 8 | 108,645 | 0.94 (0.86, 1.02) | 6.0 | 0.94 (0.86, 1.02) | 6.8 | 0.94 (0.86, 1.02) | 0
Fatal MI Events | All | 13 | 161,680 | 0.91 (0.80, 1.03) | 18.0 | 0.91 (0.81, 1.03) | 3.7 | 0.92 (0.81, 1.04) | 0
Fatal MI Events | ≤100 mg | 11 | 134,470 | 0.91 (0.79, 1.06) | 31.0 | 0.92 (0.79, 1.06) | 18.8 | 0.92 (0.80, 1.07) | 0
Fatal MI Events | Prior statins | 5 | 53,035 | 0.92 (0.77, 1.09) | 0 | 0.92 (0.77, 1.09) | 0 | 0.92 (0.77, 1.09) | 0
Fatal MI Events | Statin use | 8 | 108,645 | 0.90 (0.75, 1.08) | 49.5 | 0.91 (0.76, 1.08) | 40.2 | 0.93 (0.72, 1.21) | 33.8
Nonfatal MI Events | All | 13 | 161,680 | 0.83 (0.76, 0.90) | 62.1 | 0.83 (0.77, 0.90) | 62.3 | 0.82 (0.72, 0.94) | 60.5
Nonfatal MI Events | ≤100 mg | 11 | 134,470 | 0.88 (0.80, 0.96) | 44.2 | 0.88 (0.81, 0.96) | 43.9 | 0.86 (0.75, 0.98) | 44.4
Nonfatal MI Events | Prior statins | 5 | 53,035 | 0.64 (0.56, 0.74) | 28.4 | 0.64 (0.56, 0.74) | 32.4 | 0.66 (0.55, 0.80) | 36.4
Nonfatal MI Events | Statin use | 8 | 108,645 | 0.95 (0.86, 1.05) | 0 | 0.95 (0.86, 1.05) | 0 | 0.95 (0.86, 1.05) | 0
Total Stroke (all types) | All | 13 | 161,680 | 0.94 (0.87, 1.01) | 0 | 0.94 (0.87, 1.01) | 0 | 0.94 (0.87, 1.01) | 0
Total Stroke (all types) | ≤100 mg | 11 | 134,470 | 0.91 (0.84, 0.99) | 0 | 0.91 (0.84, 0.99) | 0 | 0.91 (0.84, 0.99) | 0
Total Stroke (all types) | Prior statins | 5 | 53,035 | 1.03 (0.89, 1.20) | 26.3 | 1.03 (0.89, 1.20) | 25.6 | 1.03 (0.88, 1.21) | 7.4
Total Stroke (all types) | Statin use | 8 | 108,645 | 0.91 (0.83, 0.99) | 0 | 0.91 (0.84, 0.99) | 0 | 0.91 (0.84, 0.99) | 0
Fatal Stroke (all types) | All | 11 | 130,344 | 0.98 (0.78, 1.22) | 12.4 | 0.98 (0.78, 1.22) | 1.1 | 1.00 (0.80, 1.25) | 0
Fatal Stroke (all types) | ≤100 mg | 9 | 103,134 | 0.92 (0.72, 1.18) | 20.0 | 0.92 (0.72, 1.18) | 10.2 | 0.95 (0.74, 1.21) | 0
Fatal Stroke (all types) | Prior statins | 4 | 34,245 | 1.10 (0.67, 1.81) | 36.1 | 1.10 (0.67, 1.83) | 19.1 | 1.18 (0.70, 2.01) | 0
Fatal Stroke (all types) | Statin use | 7 | 96,099 | 0.95 (0.74, 1.22) | 6.9 | 0.95 (0.74, 1.22) | 0 | 0.96 (0.75, 1.24) | 0
Nonfatal Stroke (all types) | All | 11 | 130,344 | 0.92 (0.84, 1.00) | 0 | 0.92 (0.84, 1.00) | 0 | 0.92 (0.84, 1.01) | 8.2
Nonfatal Stroke (all types) | ≤100 mg | 9 | 103,134 | 0.88 (0.80, 0.97) | 0 | 0.88 (0.80, 0.97) | 0 | 0.88 (0.80, 0.97) | 0
Nonfatal Stroke (all types) | Prior statins | 4 | 34,245 | 1.06 (0.86, 1.31) | 19.8 | 1.06 (0.86, 1.31) | 18.8 | 1.04 (0.81, 1.33) | 17.6
Nonfatal Stroke (all types) | Statin use | 7 | 96,099 | 0.89 (0.81, 0.98) | 0 | 0.89 (0.81, 0.98) | 0 | 0.89 (0.81, 0.98) | 0
Total Ischemic Stroke | All | 7 | 106,554 | 0.86 (0.77, 0.97) | 16.0 | 0.86 (0.77, 0.97) | 14.7 | 0.87 (0.77, 0.98) | 10.1
Total Ischemic Stroke | ≤100 mg | 5 | 79,334 | 0.82 (0.72, 0.92) | 0 | 0.82 (0.72, 0.93) | 0 | 0.82 (0.72, 0.93) | 0
Total Ischemic Stroke | Prior statins | 3 | 29,750 | 1.05 (0.81, 1.37) | 42.5 | 1.05 (0.81, 1.37) | 41.1 | 1.01 (0.67, 1.53) | 34.0
Total Ischemic Stroke | Statin use | 4 | 76,804 | 0.82 (0.73, 0.94) | 0 | 0.83 (0.73, 0.94) | 0 | 0.83 (0.73, 0.94) | 0
Fatal Ischemic Stroke | All | 6 | 65,414 | 0.80 (0.50, 1.29) | 13.0 | 0.80 (0.50, 1.29) | 8.4 | 0.80 (0.45, 1.40) | 14.5
Fatal Ischemic Stroke | ≤100 mg | 4 | 38,204 | 0.71 (0.42, 1.22) | 38.9 | 0.71 (0.41, 1.23) | 37.6 | 0.61 (0.27, 1.39) | 40.6
Fatal Ischemic Stroke | Prior statins | 2 | 27,210 | 1.18 (0.44, 3.18) | 0 | 1.19 (0.43, 3.29) | 0 | 1.18 (0.43, 3.29) | 0
Fatal Ischemic Stroke | Statin use | 4 | 38,204 | 0.71 (0.42, 1.22) | 38.9 | 0.71 (0.41, 1.23) | 37.6 | 0.61 (0.27, 1.39) | 40.6
Nonfatal Ischemic Stroke | All | 7 | 82,157 | 0.92 (0.82, 1.03) | 0 | 0.92 (0.82, 1.03) | 0 | 0.92 (0.82, 1.03) | 0
Nonfatal Ischemic Stroke | ≤100 mg | 5 | 54,947 | 0.88 (0.78, 1.00) [Note: p<0.05] | 0 | 0.88 (0.78, 1.00) [Note: p<0.05] | 0 | 0.88 (0.78, 1.00) | 0
Nonfatal Ischemic Stroke | Prior statins | 2 | 27,210 | 1.15 (0.86, 1.53) | 0 | 1.15 (0.86, 1.53) | 0 | 1.14 (0.85, 1.53) | 0
Nonfatal Ischemic Stroke | Statin use | 5 | 54,947 | 0.88 (0.78, 1.00) [Note: p<0.05] | 0 | 0.88 (0.78, 1.00) [Note: p<0.05] | 0 | 0.88 (0.78, 1.0) | 0
CVD Mortality | All | 13 | 161,680 | 0.95 (0.87, 1.04)^*^ | 4.3 | 0.95 (0.87, 1.04) | 0 | 0.96 (0.88, 1.05) | 0
CVD Mortality | ≤100 mg | 11 | 134,470 | 0.95 (0.86, 1.05) | 20.1 | 0.95 (0.87, 1.04) | 0 | 0.96 (0.87, 1.06) | 0
CVD Mortality | Prior statins | 5 | 53,035 | 0.93 (0.81, 1.08) | 0 | 0.94 (0.81, 1.08) | 0 | 0.94 (0.81, 1.8) | 0
CVD Mortality | Statin use | 8 | 108,645 | 0.97 (0.86, 1.08) | 22.4 | 0.97 (0.86, 1.08) | 0 | 0.97 (0.87, 1.09) | 0
All-cause Mortality | All | 13 | 161,680 | 0.97 (0.93, 1.02)^†^ | 0 | 0.97 (0.93, 1.02) | 0 | 0.97 (0.92, 1.02) | 14.2
All-cause Mortality | ≤100 mg | 11 | 134,470 | 0.98 (0.93, 1.03) | 0 | 0.98 (0.93,1.03) | 0 | 0.98 (0.92, 1.03) | 18.6
All-cause Mortality | Prior statins | 5 | 53,035 | 0.93 (0.84, 1.02) | 0 | 0.93 (0.85, 1.02) | 0 | 0.93 (0.85, 1.02) | 0
All-cause Mortality | Statin use | 8 | 108,645 | 0.99 (0.93, 1.04) | 6.0 | 0.99 (0.94, 1.04) | 5.5 | 0.99 (0.92, 1.05) | 26.9
CRC incidence (RCT only, 5 or 10 years f/u) | 1° prevention, all doses | 5 | 108,208 | 1.08 (0.94, 1.24) | 16.7 | 1.08 (0.94, 1.24) | 14.7 | 1.08 (0.94, 1.24) | 0
CRC incidence (RCT only, 5 or 10 years f/u) | 1° prevention, ≤100 mg | 4 | 86,137 | 1.07 (0.92, 1.24) | 36.0 | 1.07 (0.92, 1.24) | 34.2 | 1.07 (0.92, 1.24) | 0
CRC incidence (RCT only, 5 or 10 years f/u) | 1° and 2° prevention, all doses | NA | NA | NA | NA | NA | NA | NA | NA
CRC incidence (RCT+obs, 10-year f/u) | 1° prevention, all doses | 4 | 69,622 | 0.98 (0.85, 1.14) | 0 | 0.98 (0.85, 1.14) | 0 | 0.98 (0.85, 1.14) | 0
CRC incidence (RCT+obs, 10-year f/u) | 1° prevention, ≤100 mg | 2 | 42,412 | 0.96 (0.78, 1.19) | 0 | 0.96 (0.78, 1.19) | 0 | 0.96 (0.78, 1.19) | 0
CRC incidence (RCT+obs, 10-year f/u) | 1° and 2° prevention, all doses | 5 | 72,071 | 0.99 (0.86, 1.14) | 0 | 0.99 (0.85, 1.14) | 0 | 0.99 (0.86, 1.14) | 0
CRC incidence (RCT+obs, 20-year f/u) | 1° prevention | 2 | 45,015 | 0.79 (0.68, 0.93) | 0 | 0.80 (0.68, 0.93) | 0 | 0.80 (0.68, 0.93) | 0
CRC incidence (RCT+obs, 20-year f/u) | 1° prevention, ≤100 mg | 1 | 39,876 | 0.82 (0.69, 0.98) | NA | 0.82 (0.69, 0.98) | NA | 0.82 (0.69, 0.98) | NA
CRC incidence (RCT+obs, 20-year f/u) | 1° and 2° prevention, all doses | 3 | 47,464 | 0.79 (0.68, 0.92) | 0 | 0.80 (0.69, 0.92) | 0 | 0.80 (0.69, 0.92) | 0
CRC incidence (obs, 10+ years only) | 1° prevention, all doses | 3 | 67,086 | 0.66 (0.53, 0.82) | 0 | 0.66 (0.54, 0.82) | 0 | 0.66 (0.54, 0.82) | 0
CRC incidence (obs, 10+ years only) | 1° prevention, ≤100 mg | 1 | 39,876 | 0.63 (0.47, 0.83) | NA | 0.63 (0.54, 0.82) | NA | 0.63 (0.54, 0.82) | NA
CRC incidence (obs, 10+ years only) | 1° and 2° prevention, all doses | 4 | 69,535 | 0.64 (0.52, 0.79) | 0 | 0.65 (0.53, 0.80) | 0 | 0.65 (0.53, 0.79) | 0
CRC mortality (RCT only, 5 or 10 years f/u) | 1° prevention, all doses | 2 | 58,990 | 1.36 (0.97, 1.91) | 30.2 | 1.36 (0.96, 1.92) | 31.4 | 1.37 (0.90, 2.10) | 31.3
CRC mortality (RCT only, 5 or 10 years f/u) | 1° prevention, ≤100 mg | 2 | 58,990 | 1.36 (0.97, 1.91) | 30.2 | 1.36 (0.96, 1.92) | 31.4 | 1.37 (0.90, 2.10) | 31.3
CRC mortality (RCT only, 5 or 10 years f/u) | 1° and 2° prevention, all doses | NA | NA | NA | NA | NA | NA | NA | NA
CRC mortality (RCT+obs, 18-year f/u) | 1° prevention, all doses | 3 | 50,100 | 0.76 (0.62 to 0.94) | 0 | 0.76 (0.62 to 0.94) | 0 | 0.76 (0.62, 0.94) | 0
CRC mortality (RCT+obs, 18-year f/u) | 1° prevention, ≤100 mg | 2 | 44,961 | 0.77 (0.61, 0.98) | 39.9 | 0.77 (0.61, 0.98) | 39.4 | 0.76 (0.55, 1.05) | 39.4
CRC mortality (RCT+obs, 18-year f/u) | 1° and 2° prevention, all doses | 5 | 53,909 | 0.74 (0.61 to 0.90) | 0 | 0.75 (0.62 to 0.90) | 0 | 0.75 (0.62, 0.90) | 0
Total Major Bleeding | All | 12 | 160,404 | 1.45 (1.33, 1.58) | 12.1 | 1.44 (1.32, 1.57) | 16.7 | 1.47 (1.32, 1.63) | 17.9
Total Major Bleeding | ≤100 mg | 10 | 133,194 | 1.44 (1.32, 1.57) | 4.7 | 1.43 (1.31, 1.56) | 9.6 | 1.46 (1.31, 1.62) | 18.2
Total Major Bleeding | Prior statins | 5 | 53,035 | 1.74 (1.42, 2.11) | 22.1 | 1.75 (1.43, 2.14) | 27.0 | 1.74 (1.42, 2.13) | 0
Total Major Bleeding | Statin use | 7 | 107,369 | 1.39 (1.26, 1.53) | 0 | 1.38 (1.26, 1.52) | 0 | 1.38 (1.26, 1.51) | 0
Extracranial Bleeding | All | 12 | 160,404 | 1.53 (1.39, 1.69) | 66.2 | 1.53 (1.39, 1.69) | 64.9 | 1.73 (1.39, 2.16) | 66.6
Extracranial Bleeding | ≤100 mg | 10 | 133,194 | 1.53 (1.39, 1.70) | 67.4 | 1.53 (1.38, 1.69) | 67.2 | 1.80 (1.40, 2.31) | 73.1
Extracranial Bleeding | Prior statins | 5 | 53,035 | 2.30 (1.82, 2.90) | 61.8 | 2.40 (1.87, 3.09) | 59.9 | 2.22 (1.47, 3.36) | 42.9
Extracranial Bleeding | Statin use | 7 | 107,369 | 1.40 (1.26, 1.56) | 23.2 | 1.40 (1.25, 1.56) | 12.0 | 1.39 (1.25, 1.55) | 0
Major GI Bleeding | All | 12 | 146,340 | 1.57 (1.37, 1.78) | 37.2 | 1.57 (1.37, 1.79) | 25.8 | 1.57 (1.35, 1.84) | 9.5
Major GI Bleeding | ≤100 mg | 10 | 119,130 | 1.58 (1.38, 1.80) | 25.5 | 1.58 (1.38, 1.80) | 17.5 | 1.59 (1.36, 1.87) | 14.1
Major GI Bleeding | Prior statins | 6 | 53,435 | 2.09 (1.52, 2.88) | 36.2 | 2.12 (1.51, 2.97) | 17.8 | 2.14 (1.51, 3.03) | 0
Major GI Bleeding | Statin use | 6 | 92,905 | 1.48 (1.28, 1.71) | 15.9 | 1.48 (1.28, 1.71) | 0 | 1.47 (1.27, 1.70) | 0
Intracranial Bleeding | All | 13 | 161,680 | 1.33 (1.13, 1.56) | 0 | 1.33 (1.13, 1.56) | 0 | 1.33 (1.13, 1.56) | 0
Intracranial Bleeding | ≤100 mg | 11 | 134,470 | 1.31 (1.11, 1.54) | 0 | 1.31 (1.11, 1.54) | 0 | 1.31 (1.10, 1.54) | 0
Intracranial Bleeding | Prior statins | 5 | 53,035 | 1.32 (0.88, 1.98) | 0 | 1.32 (0.87, 1.99) | 0 | 1.31 (0.86, 1.98) | 0
Intracranial Bleeding | Statin use | 8 | 108,645 | 1.33 (1.12, 1.58) | 0 | 1.33 (1.13, 1.56) | 0 | 1.33 (1.12, 1.58) | 0
Total Hemorrhagic Stroke | All | 12 | 160,404 | 1.23 (1.01, 1.48) | 0 | 1.23 (1.01, 1.49) | 0 | 1.22 (1.01, 1.48) | 0
Total Hemorrhagic Stroke | ≤100 mg | 10 | 133,194 | 1.18 (0.97, 1.45) | 0 | 1.18 (0.97, 1.45) | 0 | 1.18 (0.96, 1.45) | 0
Total Hemorrhagic Stroke | Prior statins | 5 | 53,035 | 1.27 (0.84, 1.91) | 0 | 1.27 (0.84, 1.92) | 0 | 1.25 (0.81, 1.93) | 0
Total Hemorrhagic Stroke | Statin use | 7 | 107,369 | 1.21 (0.98, 1.50) | 0 | 1.21 (0.98, 1.50) | 0 | 1.21 (0.98, 1.50) | 0
Fatal Hemorrhagic Stroke | All | 9 | 102,223 | 1.06 (0.73, 1.54) | 0 | 1.06 (0.73, 1.54) | 0 | 1.06 (0.73, 1.55) | 0
Fatal Hemorrhagic Stroke | ≤100 mg | 7 | 75,013 | 0.94 (0.62, 1.42) | 0 | 0.94 (0.62, 1.42) | 0 | 0.96 (0.63, 1.45) | 0
Fatal Hemorrhagic Stroke | Prior statins | 3 | 46,000 | 1.50 (0.70, 3.21) | 2.4 | 1.51 (0.69, 3.34) | 0.5 | 1.45 (0.63, 3.32) | 0
Fatal Hemorrhagic Stroke | Statin use | 6 | 56,223 | 0.96 (0.63, 1.46) | 0 | 0.96 (0.63, 1.46) | 0 | 0.98 (0.61, 1.50) | 0
Nonfatal Hemorrhagic Stroke | All | 8 | 100,947 | 1.38 (1.04, 1.82) | 0 | 1.38 (1.04, 1.83) | 0 | 1.36 (1.01, 1.84) | 6.8
Nonfatal Hemorrhagic Stroke | ≤100 mg | 6 | 73,737 | 1.37 (1.01, 1.85) | 0.1 | 1.37 (1.01, 1.86) | 0.6 | 1.35 (0.93, 1.95) | 20.5
Nonfatal Hemorrhagic Stroke | Prior statins | 3 | 46,000 | 1.22 (0.71, 2.07) | 0 | 1.22 (0.71, 2.07) | 0 | 1.21 (0.71, 2.07) | 0
Nonfatal Hemorrhagic Stroke | Statin use | 5 | 54,947 | 1.44 (1.04, 2.00) | 7.3 | 1.38 (1.04, 1.83) | 8.3 | 1.43 (0.93, 2.21) | 27.8

* REML model: RR, 0.96 (95% CI, 0.88 to 1.05)

† REML model: RR, 0.97 (95% CI, 0.92 to 1.02)

Abbreviations: 1° = primary; 2° = secondary; CI = confidence interval; CRC = colorectal cancer; CVD = cardiovascular disease; ECH = extracranial hemorrhage; F/U = followup; GI = gastrointestinal; ICH = intracranial hemorrhage; k = number of studies; mg = milligrams; MI = myocardial infarction; n = number of participants; obs = observational; OR = odds ratio; RCT = randomized controlled trial

Figure 3 Pooled Analyses for KQ 1 and KQ 2 Outcomes

* Pooled results for outcomes with only 2 trials are shown only for illustrative purposes. Individual trial results are consistent with the pooled results.

Abbreviations: CI = confidence interval; CRC = colorectal cancer; CVD = cardiovascular disease; GI = gastrointestinal; K = number of studies; N = number of participants; Obs = observational; OR = odds ratio; RCT = randomized controlled trial

Figure 3 displays a pooled analysis for KQ1 and KQ2 outcomes for all aspirin doses.

Table 6 Range in Absolute Estimates for Statistically Significant Relative Effects

Outcome | Analysis | k | n | Peto Fixed Effects OR (95% CI) | Range in absolute effects, %
Major CVD events (nonfatal MI, nonfatal stroke, CVD mortality) | All | 13 | 161,680 | 0.89 (0.85, 0.94) | −2.5 to −0.08
Major CVD events (nonfatal MI, nonfatal stroke, CVD mortality) | ≤100 mg | 11 | 134,470 | 0.90 (0.85, 0.95) | −2.5 to −0.1
Total MI Events | All | 13 | 161,680 | 0.86 (0.80, 0.92) | −1.9 to 1.2
Total MI Events | ≤100 mg | 11 | 134,470 | 0.89 (0.82, 0.96) | −1.9 to 1.2
Nonfatal MI Events | All | 13 | 161,680 | 0.83 (0.76, 0.90) | −2.0 to 0.2
Nonfatal MI Events | ≤100 mg | 11 | 134,470 | 0.88 (0.80, 0.96) | −2.0 to 0.2
Total Stroke (all types) | All | 13 | 161,680 | 0.94 (0.87, 1.02) | −2.0 to 0.4
Total Stroke (all types) | ≤100 mg | 11 | 134,470 | 0.91 (0.84, 0.99) | −2.0 to 0.1
Nonfatal Stroke (all types) | All | 11 | 130,344 | 0.92 (0.84, 1.00) | −1.9 to 0.2
Nonfatal Stroke (all types) | ≤100 mg | 9 | 103,134 | 0.88 (0.80, 0.97) | −1.9 to 0.05
Total Ischemic Stroke | All | 7 | 106,554 | 0.86 (0.77, 0.97) | −0.6 to 0.2
Total Ischemic Stroke | ≤100 mg | 5 | 79,334 | 0.82 (0.72, 0.92) | −0.6 to −0.2
Nonfatal Ischemic Stroke | All | 7 | 82,157 | 0.92 (0.82, 1.03) | −0.3 to 0.1
Nonfatal Ischemic Stroke | ≤100 mg | 5 | 54,947 | 0.88 (0.78, 1.00) [Note: p<0.05] | −0.3 to −0.1
CRC incidence (RCT+obs, 20-year f/u) | 1° prevention, all doses | 2 | 50,100 | 0.79 (0.68, 0.93) | −1.1 to −0.2
CRC incidence (RCT+obs, 20-year f/u) | 1° prevention, ≤100 mg | 1 | 39,876 | 0.82 (0.69, 0.98) | −0.2
CRC incidence (RCT+obs, 20-year f/u) | 1° and 2° prevention, all doses | 3 | 47,464 | 0.79 (0.68, 0.92) | −1.1 to −0.2
CRC incidence (obs, 10+ years only) | 1° prevention, all doses | 3 | 67,086 | 0.66 (0.53, 0.82) | −0.8 to −0.06
CRC incidence (obs, 10+ years only) | 1° prevention, ≤100 mg | 1 | 39,876 | 0.63 (0.47, 0.83) | −0.2
CRC incidence (obs, 10+ years only) | 1° and 2° prevention, all doses | 4 | 69,535 | 0.64 (0.52, 0.79) | −0.9 to −0.06
CRC mortality (RCT+obs, 18-year f/u) | 1° prevention, all doses | 3 | 50,100 | 0.76 (0.62 to 0.94) | −0.8 to −0.06
CRC mortality (RCT+obs, 18-year f/u) | 1° prevention, ≤100 mg | 2 | 44,961 | 0.77 (0.61, 0.98) | −0.8 to −0.06
CRC mortality (RCT+obs, 18-year f/u) | 1° and 2° prevention, all doses | 5 | 53,909 | 0.74 (0.61 to 0.90) | −0.8 to −0.06
Total Major Bleeding | All | 12 | 160,404 | 1.45 (1.33, 1.58) | −0.1 to 1.0
Total Major Bleeding | ≤100 mg | 10 | 133,194 | 1.44 (1.32, 1.57) | 0.1 to 1.0
ECH | All | 12 | 160,404 | 1.53 (1.39, 1.69) | −0.1 to 0.9
ECH | ≤100 mg | 10 | 133,194 | 1.53 (1.39, 1.70) | 0.2 to 0.9
Major GI Bleeding | All | 12 | 146,340 | 1.57 (1.37, 1.78) | −0.1 to 0.6
Major GI Bleeding | ≤100 mg | 10 | 119,130 | 1.58 (1.38, 1.80) | 0.06 to 0.6
ICH | All | 13 | 161,680 | 1.33 (1.13, 1.56) | −0.2 to 0.4
ICH | ≤100 mg | 11 | 134,470 | 1.31 (1.11, 1.54) | −0.2 to 0.4
Total Hemorrhagic Stroke | All | 12 | 160,404 | 1.23 (1.01, 1.48) | −0.07 to 0.2
Total Hemorrhagic Stroke | ≤100 mg | 10 | 133,194 | 1.18 (0.97, 1.45) | −0.07 to 0.2
Nonfatal Hemorrhagic Stroke | All | 8 | 100,947 | 1.38 (1.04, 1.82) | −0.04 to 0.2
Nonfatal Hemorrhagic Stroke | ≤100 mg | 6 | 73,737 | 1.37 (1.01, 1.85) | −0.04 to 0.2

Abbreviations: 1° = primary; CI = confidence interval; CVD = cardiovascular disease; ECH = extracranial hemorrhage; F/U = followup; GI = gastrointestinal; ICH = intracranial hemorrhage; k = number of studies; mg = milligram; MI = myocardial infarction; n = number of participants; obs = observational; OR = odds ratio; RCT = randomized controlled trial

Sensitivity analyses limited to low-dose aspirin, defined as ≤100 mg/day, show similar reductions in major CVD events (Peto OR 0.90 [95% CI, 0.85 to 0.95]), MI events (Peto OR 0.89 [0.82 to 0.96]), and ischemic strokes (Peto OR 0.82 [95% CI, 0.72 to 0.92]) compared to the main analyses with all aspirin doses (Table 5, Figure 4). All-cause mortality and CVD mortality remained nonstatistically significant in low-dose sensitivity analyses.

Figure 4 Pooled Analyses for KQ 1 and KQ 2 Outcomes, Daily Aspirin Dose of 100 mg or Less

* Pooled results for outcomes with only 2 trials are shown only for illustrative purposes. Individual trial results are consistent with the pooled results.

Abbreviations: CI = confidence interval; CRC = colorectal cancer; CVD = cardiovascular disease; GI = gastrointestinal; k = number of studies; n = number of participants; Obs = observational; OR = odds ratio; RCT = randomized controlled trial

Figure 4 displays a pooled analysis for KQ1 and KQ2 outcomes for daily aspirin dose of 100 mg or less.

Findings for three stroke-related outcomes became statistically significant in low-dose sensitivity analyses. For all stroke types—ischemic and hemorrhagic combined— sensitivity analysis showed that low-dose aspirin was associated with a statistically significant reduction in total stroke (k=11, N=134,470; Peto OR, 0.91 [95% CI, 0.84 to 0.99]; I^2^=0%) and nonfatal stroke (k=9, N=103,134; Peto OR, 0.88 [95% CI, 0.80 to 0.97]; I^2^=0%). Likewise, nonsignificant findings in the main analysis for nonfatal ischemic stroke became statistically significant when only the low-dose trials were pooled, (k=5, N=54,947; Peto OR, 0.88 [95% CI, 0.78 to 1.00], p<0.05; I^2^=0%) however less than half of the low-dose trials reported ischemic stroke.

Sensitivity analyses limited to trials partly or fully conducted since ATP III (2001)—a proxy for more widespread statin use—demonstrate smaller reductions in major CVD events and MI, but larger reductions in ischemic stroke. However, heterogeneity by dose and other population and trial characteristics may impact effects. Further exploration of data by trial completion dates did not reveal any consistent patterns.

Compared to the evidence for CVD outcomes, CRC data are far more sparse and findings for the effect of aspirin on CRC appear to vary based on the followup period considered. Aspirin at any dose does not appear to have a statistically significant effect on CRC incidence at 10 years or less (k=5, N=108,208; Peto OR, 1.08 [0.94 to 1.24]; I^2^=16.7%) in pooled analysis of primary CVD prevention trials with events accrued during the randomized trial periods only.

However, two primary CVD prevention trials with extended observational followup both demonstrate that aspirin at any dose is associated with a decrease in CRC incidence at approximately 20 years of followup. A sensitivity analysis including one secondary prevention study showed similar CRC incidence results at long term post-trial observational followup. In the short term (5-10 years), one trial suggests a potential harm where aspirin use was associated with a statistically significant increased risk of CRC mortality; results were not significant in the other trial. At longer followup (approximately 20 years), aspirin use was associated with a statistically significant reduction in CRC mortality (k=3 all dose primary CVD prevention RCTs with observational followup periods, N=50,100; Peto OR, 0.76 [0.62 to 0.94]; I^2^=0%). A sensitivity analysis including two secondary CVD prevention studies for all doses of aspirin showed similar CRC mortality results at long term post-trial observational followup. However, CRC mortality conclusions are limited by few CRC deaths. For both CRC incidence and mortality post-trial observation results, the pooled effects are heavily weighted by one large trial but results of other trials are consistent.

In the body of evidence for aspirin for the primary prevention of CVD, there is credible reporting for CVD outcomes for specific populations as defined by age and sex. Reporting is less robust, but still credible, for CVD outcomes by diabetes status and baseline CVD risk strata. Analyses by race and ethnicity are extremely sparse. For all subpopulation analyses examined, all-cause mortality, CRC, and harms were reported less frequently than CVD outcomes. Findings consistently showed no difference in treatment effect across all specific populations evaluated and CVD outcomes, all-cause mortality, and CRC, with one notable exception. There was an inconsistent signal in analyses by age where the Women’s Health Study and Physicians’ Health Study reported statistically significant interaction testing with greater benefit in older age groups for MI. This finding was not consistent with findings for CVD composite outcomes in other trials and such suggestion of treatment effect modification was not confirmed in a prior IPD MA.^50^

In cases where time-to-event analyses suggest benefit for individual CVD outcomes, benefit generally accrues within the first 1-2 years. In one trial reporting statistically significant time-to-event analyses for composite CVD outcomes, benefit realized over the 9 years of maximum followup accrues within the first 5 years without further benefit seen beyond 5 years. For the CRC outcomes, followup rather than duration of use appeared to show a trend towards effects appearing after 10 years and continuing through approximately 17 to 20 years.

### Detailed Results

#### Trial Characteristics

Thirteen RCTs (N=161,680)—three good-quality^59,^ ^83,^ ^101^ and ten fair-quality^45,^ ^55,^ ^56,^ ^64,^ ^66,^ ^69,^ ^70,^ ^81,^ ^82,^ ^91^—investigated the benefits of aspirin for the primary prevention of cardiovascular morbidity and mortality (Table 7). Seven^49,^ ^56,^ ^59,^ ^81–83,^ ^91,^ ^92,^ ^101,^ ^103,^ ^108,^ ^112–114,^ ^131^ of these trials also reported CRC incidence (N=115,973) and three^45,^ ^49,^ ^82,^ ^93,^ ^101,^ ^131^ reported CRC mortality (N=64,159). As a sensitivity analysis for the CRC outcomes only, we included two additional trials^94,^ ^111^ examining the use of aspirin in secondary CVD prevention populations (N=3,812).

Table 7 Characteristics of Included Trials

Study name; Author, year | Quality | Country | Study design, cotreatment | N relevant | Brief Population Description | ASA dose Formulation | Control group | ASA duration Mean followup, years
Primary CVD prevention
AAA; Fowkes, 2010^69^ | Fair | UK | RCT | 3,350 | Males and females age 50-75 years old with ABI ≤0.95 | 100 mg QD, enteric-coated | Placebo QD | 8.2
ARRIVE; Gaziano, 2018^56^ | Fair | Multi-site^*^ | RCT | 12,546 | Males age ≥55 years with 2-4 CVD risk factors and females aged ≥60 years with 3+ CVD risk factors | 100 mg QD, enteric-coated | Placebo QD | 5 (median)
ASCEND; ASCEND Study Collaborative, 2018^55^ | Fair | UK | 2x2 RCT, omega-3 fatty acid supplements | 15,480 | Males and females age ≥40 years with diabetes | 100 mg QD, unspecified | Placebo QD | 7.4
ASPREE; McNeil, 2018^101^ | Good | US, Australia | RCT | 19,114 | Males and females age ≥70 years (≥65 years of age among Black and Hispanic populations in the United States) | 100 mg QD, enteric-coated | Placebo QD | 4.7
BMD; Peto, 1988^82^ | Fair | UK | RCT | 5,139 | Male physicians (age range NR) | 500 mg QD (300 mg enteric coated aspirin could be requested as an alternate to 500 mg soluble or effervescent aspirin) | No placebo tablets used. Told to avoid aspirin and use paracetamol if analgesics were needed | 6
HOT; Hanson, 1998^70^ | Fair | Multi-site^†^ | 3x2 RCT, HTN treatment goals | 18,790 | Males and females age 50-80 with hypertension | 75 mg QD, unspecified | Placebo | 3.8
JPAD; Ogawa, 2008^81^ | Fair | Japan | RCT | 2,539 | Males and females age 30-85 years with diabetes | 81 mg or 100 mg QD, not enteric coated | Nonaspirin details not reported | 4.37 (median)^‡^
JPPP; Ikeda, 2014^91^ | Fair | Japan | RCT | 14,658 | Males and females age 60-85 years with hypertension, dyslipidemia, or diabetes | 100 mg QD, enteric-coated | No ASA | 5.02 (median)
PHS; Physician’s Health Study, 1989^59^ | Good | US | 2x2 RCT, Beta-carotene | 22,071 | Male physicians age 40-84 years | 325 mg QOD, not enteric coated^§^ | Placebo | 5
POPADAD; Belch, 2008^66^ | Fair | Scotland | 2x2 RCT, Antioxidant | 1,276 | Males and females age ≥40 years with diabetes and ABI ≤0.99 | 100 mg QD, not enteric coated | Placebo QD | 6.7 (median)
PPP; Rongaclioni, 2001^64^ | Fair | Italy | 2x2 RCT, Vitamin E | 4,495 | Males and females age ≥50 years with ≥1 risk factor for CVD | 100 mg QD, enteric coated tablet | No ASA | 3.6
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | Fair | UK | 2x2 RCT, Warfarin | 2,540 | Males age 45-69 years at high risk for ischemic heart disease | 75 mg QD, controlled release capsule | Placebo QD | 6.8 (median)
WHS; Ridker, 2005^83^ | Good | US | 2x2 RCT, Vitamin E | 39,876 | Female health professionals age ≥45 years | 100 mg QOD, not enteric coated | Placebo QOD | 10.1^ǁ^
Secondary CVD prevention
SALT; The SALT Collaborative Group, 1991^94^ | Fair | Sweden | RCT | 1,363 | Males and females age 50-79 years old with history of TIA, minor ischemic stroke, or retinal artery occlusion in prior 3 months | 75 mg QD | Placebo QD | 2.7
UK-TIA; UK-TIA Study Group, 1990^111^ | Fair | UK | RCT | 2,449 | Males and females age >40 years with recent TIA or minor ischemic stroke | IG1: 300 mg (two 150 mg aspirin tablets in the morning and two placebo tablets in the evening), unspecified; IG2: 1200 mg (two 300 mg aspirin tablets twice a day), unspecified | IG1: Placebo (two tablets twice a day); IG2: Placebo (two tablets twice a day) | 4.4

* US, UK, Germany, Ireland, Italy, Poland, Spain

† UK, Austria, Belgium, Canada, Denmark, Finland, France, Germany, Greece, Israel, Italy, the Netherlands, Norway, Spain, Sweden, Switzerland, China

‡ 10.7 year extended followup

§ 624 participants in IG requested enteric-coated preparation and 16 requested Ecotrin

ǁ 26-year extended followup

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = Ankle-brachial Index; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CVD = cardiovascular disease; F/U = followup; g = grams; HOT = Hypertension Optimal Treatment Study; HTN = hypertension; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligrams; NR = not reported; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; QD = every day; QOD = every other day; Rand = randomized; RCT = randomized controlled trial; SALT = Swedish Aspirin Low-dose Trial; TIA = transient ischemic attack; TPT Thrombosis Prevention Trial; tx = treatment; UK-TIA = United Kingdom Transient Ischaemic Attack; US = United States; WHS = Women’s Health Study

These thirteen primary prevention trials were conducted in the United Kingdom,^45,^ ^55,^ ^66,^ ^69,^ ^82^ Italy,^64^ Japan,^81,^ ^91^ the United States,^59,^ ^83^ or were multinational,^56,^ ^70,^ ^101^ with two of these international trials including sites in the United States.^56,^ ^101^ Five trials^45,^ ^59,^ ^64,^ ^70,^ ^82^ were conducted prior to the publication of ATP III in 2001,^132^ a proxy for lower levels of background statin use, and 8 were conducted after 2001.^55,^ ^56,^ ^66,^ ^69,^ ^81,^ ^83,^ ^91,^ ^101^ Recent trials published since the last review for the USPSTF^2^ focus on special populations with older age,^101^ cardiovascular risk factors,^56^ and diabetes.^55^ Three of the 13 randomized control trials were open label: British Medical Doctors (BMD),^82^ the Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes (JPAD) trial,^81^ and the Primary Prevention Project (PPP).^91^ Six of the 13 trials included 2x2 factorial designs with cotreatments of vitamins/antioxidants^55,^ ^59,^ ^64,^ ^66,^ ^83^ or warfarin.^45^ Three of these 2x2 factorial trials reported no interaction between the cotreatment and aspirin,^45,^ ^66,^ ^83^ and the remaining three cotreatment trials did not report interaction testing.^55,^ ^59,^ ^64^ One trial, the Hypertension Optimal Treatment (HOT) trial, was a 3x2 factorial design wherein patients were initially randomized to one of three diastolic blood pressure targets, then each of the target blood pressure groups were randomized to aspirin or placebo.^70^

The 13 primary prevention RCTs randomized and analyzed a total of 161,680 participants with individual trial sizes ranging from 1,276^66^ to 39,876^83^ participants. The largest two trials were substantially larger than any other trials and both funded by the National Institutes of Health; WHS included more than 39,000 participants and its male counterpart, the PHS, included more than 22,000 participants.^59,^ ^83^ Overall, trial duration ranged from 3.6 years^64^ to 10.1 years^83^ with extended followup after trial completion available for a mean of 10.3 and 26 years, in JPAD and WHS, respectively.^49,^ ^81,^ ^83^ Further CRC incidence and/or mortality data were available for extended followup as abstracted and reported by separate IPD MA authors^92,^ ^93^ for three additional primary CVD prevention trials.^45,^ ^59,^ ^82^ Three trials were terminated early: PHS (due to apparent aspirin benefit), PPP (because other trial publications supported aspirin benefit), and the Japanese Primary Prevention Project (JPPP), due to futility as sufficient power to find between group differences in primary endpoint would not be reached.^59,^ ^64,^ ^91^

The vast majority of primary CVD prevention trials (11 of 13) administered low-dose aspirin at ≤100 mg/day or every other day.^45,^ ^55,^ ^56,^ ^64,^ ^66,^ ^69,^ ^81,^ ^83,^ ^91,^ ^101^ In the two higher dose trials, one trial used 325 mg every other day,^59^ and one used 300 or 500 mg daily.^82^ The seven most recent trials used low-dose aspirin, so there may be interaction between aspirin dose, trial recency, and contemporary CVD risk management.^55,^ ^56,^ ^66,^ ^69,^ ^81,^ ^91,^ ^101^ Five trials used enteric coated formulations;^56,^ ^64,^ ^69,^ ^91,^ ^101^ the remainder administered non-enteric-coated, effervescent or unspecified formulations.^45,^ ^55,^ ^59,^ ^66,^ ^70,^ ^81–83^ Control groups received placebo in most studies except the three open label trials,^81,^ ^82,^ ^91^ where control groups received nothing and/or were advised to avoid aspirin. Six trials were solely government sponsored,^59,^ ^66,^ ^81,^ ^83,^ ^91,^ ^101^ six trials were at least partially funded by pharmaceutical industry sponsorship;^55,^ ^56,^ ^64,^ ^69,^ ^70,^ ^82^ and one trial was funded by both government and a professional organization.^45^

Primary outcomes for all but one trial were study-defined composites of fatal and nonfatal CVD events or CVD mortality with highly variable definitions (Appendix D, Table 1). Aspirin in Reducing Events in the Elderly (ASPREE) was the only trial with a nonCVD focused primary composite endpoint of death, dementia, or persistent physical disability.^101^ All trials were powered for these variably defined composites and in two trials, the composite definitions were altered after study design in order to increase power.^55,^ ^56^ Only four trials performed adjustments for confounders for their primary CVD outcomes,^59,^ ^69,^ ^83,^ ^91^ and only one trial performed adjustments for CRC outcomes.^81^ Individual CVD-related events and bleeding harms were reported as secondary outcomes. Cancer (of any type) was identified as a pre-specified outcome for only four trials,^56,^ ^59,^ ^83,^ ^91^ although none of these trials were powered to detect a difference in colorectal cancer incidence or mortality between groups. With the exception of WHS—where participants self-reported colonoscopy or sigmoidoscopy screening—CRC screening rates were not reported in any of the trials. For WHS, endoscopy screening rates over the course of the followup were generally similar between aspirin and placebo groups; at the end of the trial (10.3 years), 51.4 percent of females in the aspirin group and 52.4 percent of females in the control group self-reported a screening endoscopy during the trial.

CVD-related events were ascertained using a combination of death certificates, national registries, hospital and outpatient records, autopsies (when available), and physician and patient questionnaires. Independent blinded endpoint committees confirmed events in all trials. Colorectal cancer incidence was confirmed by blinded committees with access to patient records, medial record review by a blinded assessor, or a combination of death and national cancer registries. One trial^56^ did not report how CRC incidence was ascertained. All but two trials (ASPREE, WHS) reporting CRC mortality determined this outcome through national registries. In ASPREE, blinded assessors determined if the cause of death was colorectal cancer through a review of medical records and death certificates.^101^ WHS confirmed cancer deaths with medical record, death certificate, and/or National Death Index reports.^112^

Four trials had run-in periods ranging from 4 to 18 weeks.^55,^ ^59,^ ^83,^ ^101^ Two of these trials with run-in periods reported that 11 percent^101^ and 36 percent^55^ used aspirin prior to the run-in periods. Adherence with aspirin therapy in the intervention group was variably reported and wide-ranging, from 50 to 90 percent by trials’ end (Appendix D, Table 2). Adherence was generally ascertained from participant questionnaires; pill counts were only performed in two trials.^45,^ ^101^ Most trials reported excellent followup of over 90 percent.^55,^ ^59,^ ^64,^ ^66,^ ^69,^ ^70,^ ^81,^ ^83,^ ^91,^ ^101^ High withdrawal rates were reported in two trials (Thrombosis Prevention Trial [TPT], Aspirin to Reduce Risk of Initial Vascular Events [ARRIVE]); ARRIVE reported 29 percent withdrawals in each group over 5 years and TPT reported 42 percent withdrawal rate at 5 years.^45,^ ^56^ All trials reported ITT analyses.

For the colorectal cancer outcomes, results were reported at various followup time periods (Figure 5). Four primary CVD prevention trials^56,^ ^59,^ ^83,^ ^91,^ ^108,^ ^112,^ ^114^ report CRC incidence during the RCT stage of the study, with median followup ranging from 5 to 10 years. Two studies conducted an observational followup of the RCT (where intervention allocation was no longer maintained) and extended their average followup to 10.7^103^ and 26^49,^ ^112^ years. Retention rates in the observational periods from those two trials were initially high, with 99.9 percent at 10 years for JPAD and 88.6 percent at 17.5 years for WHS. However, by 26 years of followup WHS retained 67 percent of the original randomized participants. Two studies^82^ ^111^—one of which was a secondary CVD prevention study—had observational followup at 9 and 20 years that were completed by authors conducting an IPD meta-analysis.^92^ CRC mortality was reported at the end of the two trials’ randomized stages at approximately 5 and 10 years of followup^49,^ ^101^; one trial additionally reported CRC mortality at extended observational followups at 17.5 and 26 years;^49^ otherwise, for four studies^45,^ ^82,^ ^94,^ ^111^ (including two secondary CVD prevention populations) CRC mortality was measured through a median observational followup of 18 years by authors conducting an IPD meta-analysis.^93^

Figure 5 Duration of Randomized Aspirin Use and Timepoints for CRC Incidence and Mortality

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CRC = colorectal cancer; HOT = Hypertension Optimal Treatment Study; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; SALT = Swedish Aspirin Low-dose Trial; TPT Thrombosis Prevention Trial; UK-TIA = United Kingdom Transient Ischaemic Attack; WHS = Women’s Health Study

Figure 5 displays the duration of randomized aspirin use and timepoints for colorectal cancer incidence and mortality.

#### Participant Characteristics

The thirteen trials include a broad range of participants for whom primary prevention interventions are applicable, including higher risk populations. Nine trials included participants who would be considered at higher than average cardiovascular risk: patients with diabetes^55,^ ^81^; patients with diabetes and ankle brachial index (ABI) ≤0.99^66^; patients with hypertension^70^; individuals with abnormal ABI ≤ 0.95^69^; individuals with at least one CVD risk factor^56,^ ^64,^ ^91^; or those at high risk for ischemic disease based on the Northwick Park Heart Study algorithm.^45^ Estimated 10-year CVD or CHD risk based on well-known risk estimation scores such as the Pooled Cohort Equations or Framingham were reported in only two trials, and risk varied widely in these trials.^56,^ ^83^ The vast majority of participants in WHS had a very low CVD risk: 84 percent had an estimated 10-year CHD risk of <5 percent based on the Framingham CHD risk tool. ARRIVE, which specifically recruited high-risk participants, had mean 10-year CHD risk of 14 percent based on Framingham, and a mean 10-year CVD risk score of 17.4 percent based on the Pooled Cohort Equations. The annualized major CVD event rates in the control groups reflect the wide, greater than 10-fold variation in observed CVD risk and ranged from an annualized rate of 0.26 percent in WHS to as high 3.09 percent in the Prevention of Progression of Arterial Disease and Diabetes (POPADAD) trial.^66,^ ^83^ Cumulative CRC incidence over the followup periods ranged from 0.1 percent at 5 years to 3.7 percent at 20 years.

The 13 primary prevention trials included a balanced number of males and females and reflected a broad distribution of ages. Three of the thirteen trials were conducted in healthy males only or among female-only health care professionals^59,^ ^82,^ ^83^; one additional trial solely recruited men,^45^ and the remaining trials included both sexes. Overall, 52 percent of participants in the 13 primary prevention trials were women. Mean age was reported in all but one trial^82^ and ranged from 53 years in PHS^59^ to 74 years in ASPREE^101^ which solely recruited older adults (Figure 6).

Figure 6 Age Distribution for the Primary CVD Prevention Aspirin Trials

Note: Lighter shading and thinner bars both indicate a smaller proportion of the sample in that age group.

Abbreviations: ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CVD = cardiovascular disease; HOT = Hypertension Optimal Treatment Study; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; WHS = Women’s Health Study

Figure 6 shows the age distribution for the primary CVD prevention trials.

The largest two trials, PHS and WHS, had relatively young participants, with mean ages of 53 years and 54 years, respectively.^59,^ ^83^ Ninety percent of WHS participants were younger than 65 years and 75 percent of PHS participants were younger than 60 years. Five trials^55,^ ^59,^ ^82,^ ^91,^ ^101^ reported the proportion of participants who were 70 or older: 7 percent in PHS, 14 percent in BMD (70-79 years), 24 percent in ASCEND, 55 percent in JPPP, and 97 percent in ASPREE. All studies excluded those taking current or regular aspirin therapy, as well as those with aspirin contraindications or allergies. Eight excluded those taking anticoagulants, antithrombotic, or other antiplatelet agents.^56,^ ^59,^ ^64,^ ^69,^ ^81,^ ^83,^ ^91,^ ^101^ Five trials excluded those with long term, current or regular non-steroidal anti-inflammatory drug (NSAID) use.^56,^ ^59,^ ^64,^ ^83,^ ^91^ Eight of the trials specifically excluded those with a history of peptic ulcer disease,^45,^ ^56,^ ^59,^ ^66,^ ^69,^ ^81,^ ^82,^ ^91^ GI hemorrhage,^56^ or severe indigestion.^66^ Two secondary prevention trials were included for CRC sensitivity analyses only.^94,^ ^111^ Briefly, these trials recruited patients with a recent mild ischemic stroke, transient ischemic attack (TIA), or retinal artery occlusion (Table 7).

Participants in the thirteen primary prevention trials were overwhelmingly White when race was reported, and studies displayed an exceedingly wide range of prevalence of single CVD risk factors, such as smoking, BMI, diabetes, and hypertension (Table 8). Over 90 percent of participants were White in the four trials reporting race^55,^ ^56,^ ^83,^ ^101^; ASPREE reported the highest rate of Black and Hispanic participants with 5 percent and 3 percent, respectively.^101^ Percent of current smokers at baseline ranged from 4^101^ to 41^45^ percent. Mean BMI at baseline ranged from 24^81^ to 31^55^ kg/m^2^ in nine trials.^45,^ ^55,^ ^56,^ ^64,^ ^66,^ ^70,^ ^81,^ ^83,^ ^91^ ASPREE and ASCEND reported that 30 and 46 percent had BMIs >30, respectively.^55,^ ^101^ Eight trials reported the percent of participants with hypertension at baseline ranging from 10^82^ to 85^91^ percent, and one trial was exclusively in participants with hypertension.^70^ Dyslipidemia was variably reported with mean total cholesterol levels over 200 mg/dL in six trials^45,^ ^64,^ ^66,^ ^69,^ ^70,^ ^91^; one trial reported a mean of 161 mg/dL.^55^ When reported, baseline statin use varied widely, ranging from 4^69^ to 75^55^ percent. All but one trial^45^ reported diabetes comorbidity: one trial excluded participants with diabetes,^56^ five trials included <10 percent of participants with diabetes at baseline,^59,^ ^69,^ ^70,^ ^82,^ ^83^ three trials reported 11 to 34 percent with diabetes,^64,^ ^91,^ ^101^ and three trials were exclusively conducted in those with diabetes.^55,^ ^66,^ ^81^ HOT and BMD reported 9 and 12 percent of participants had a previous history of CVD, respectively,^70,^ ^82^ while the remaining trials had no participants with CVD^45,^ ^56,^ ^64,^ ^69,^ ^81,^ ^83,^ ^91,^ ^101^ or did not report prior CVD history.^55,^ ^59,^ ^66^

Table 8 Baseline Characteristics of Included Randomized, Controlled Trials

Study name, Author, Year | N rand | Mean age, years | % Female | % HTN | SBP/DBP mm Hg, mean | TC LDL HDL mg/dL, mean | % DM | % Statin use | % Current smokers | Mean BMI | BMI >30 | Calculated CVD Risk | % Prior CVD | Control group CVD event rate per year, %^*^
Primary CVD prevention
AAA; Fowkes, 2010^69^ | 3,350 | 62 | 72 | NR | 148/84 | 238; NR; NR | 3 | 4 | 33 | NR | NR | NR | 0 | 0.99
ARRIVE; Gaziano, 2018^56^ | 12,546 | 64 | 30 | 65^†^ | 145/NR | NR | 0 | NR | 29 | 28.4 | NR | 14.0% (mean 10 year Framingham CHD risk score); 17.4% (mean ACC/AHA 10 year CVD risk score) | 0 | 0.69
ASCEND; ASCEND Study Collaborative, 2018^55^ | 15,480 | 63 | 37 | 62 | 136/77 | 161; NR; 49 | 100 | 75 | 8 | 31 | 46 | Vascular risk score^‡^ (5 year risk of serious vascular event w/o aspirin or n-3 acids): low (<5%): 40%, moderate (5% - <10%): 42%, high (> or = 10%): 17%. | NR | 1.02
ASPREE; McNeil, 2018^101^ | 19,114 | 74 | 56 | 74 | NR | NR | 11 | 34 | 4 | BMI, %:; UW, <20: 2; Norm, 20-24: 24; OW, 25-29: 44 | 30 | NR | 0 | 0.82
BMD; Peto, 1988^82^ | 5,139 | NR | 0 | 10 | 136/NR | NR | 2 | NR | <20 cigs/day: 7; >=20 cigs/day: 6 | NR | NR | NR | Heart disease (excluding MI): 6.2, Other vascular disease: 3.6, TIA: 2.6 | 1.39
HOT; Hanson, 1998^70^ | 18,790 | 62 | 47 | 100 | 170/105 | 236; NR; NR | 8 | NR | 16 | 28 | NR | NR | 9^§^ | 1.03
JPAD; Ogawa, 2008^81^ | 2,539 | 64 | 45 | 58 | 135/76 | NR; NR; 55 | 100 | 26 | 21 | 24 | NR | NR | 0 | 0.82
JPPP; Ikeda, 2014^91^ | 14,658 | 71 | 58 | 85 | 137/78 | 203; 120; 58 | 34 | 72 | 13 | 24 | NR | | 0 | 0.57
PHS; Physician’s Health Study, 1989^59^ | 22,071 | 53.2 | 0 | NR | SBP, %:; <109: 3.2^§^; 110-129: 52.6^§^; 130-149: 39.7^§^; ≥150: 4.5^§^; DBP, mm Hg, %:; ≤69: 5.9^§^; 70-79: 31.4^§^; 80-89:52.4^§^; ≥90: 10.4^§^ | TC, %:; <159: 10.0^§^; 160-209: 39.1^§^; 210-259: 36.4^§^; ≥260: 14.6^§^; NR; NR | 2 | NR | 11 | BMI (kg/m2), %:; ≤23.0126: 25.7^§^; 23.0127-24.4075: 24.1^§^; 24.4076-26.3865: 25.1^§^; ≥ 26.3866: 25.0^§^ | NR | NR | 0 | 0.67
POPADAD; Belch, 2008^66^ | 1,276 | 60 | 56 | NR | 145/79 | 212; 120; 46 | 100 | NR | 31 | 29 | NR | NR | 0 | 3.09
PPP; Rongaclioni, 2001^64^ | 4,495 | 64 | 58 | 68 | 145/85 | 236; 151; 54 | 17 | 16 | 15 | 28 | 23 | NR | 0 | 0.78
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | 2,540 | 58 | 0 | NR | 139/NR | 248; NR; NR | NR | NR | 41 | 27 | NR | All participants in top 20% or 25% (if in high IHD region) according to risk assessment tool derived from Northwick Park Heart Study variables. | 0 | 1.54
WHS; Ridker, 2005^83^ | 39,876 | 55 | 100 | 26 | SBP/DBP, mm Hg, %:; <120/<75: 33; 120-29/75-84: 32; 130-39/85-89: 19; ≥140/≥90: 16 | NR | 3 | NR | 13 | 26 | 18 | 10-year risk of CHD (Framingham), %:; <5.0%: 84; 5.0-9.9%: 12; ≥10.0%: 4 | 0 (CHD) | 0.26
Secondary CVD prevention^ǁ^
SALT; The SALT Collaborative Group, 1991^94^ | 1,360 | 67 | 34 | 42.5^†^; 4.7^¶^ | NR | NR | 12.8 | NR | 27.0 | NR | NR | NR | Angina: 17.6; MI: 11.4; CHF: 5.2; Previous TIA: 9.5; Previous stoke: 9.1
UK-TIA; UK-TIA Study Group, 1990^111^ | 2,435 | 60 | 27 | 27^†^ | 151/88 | NR | 4^††^ | 0.4 | 53 | NR | NR | NR | Past MI: 9.9%; Angina: 14.7%; Cardiac failure: 1.3%; A fib: 2.0%; Cardiac valvular disease: 2.3%; Previous non-disabling stroke: 3.3%

* Calculated as the percentage with major cardiovascular events (fatal and nonfatal stroke, fatal and nonfatal myocardial infarction, and CVD death) in the control group divided by the years of follow-up

† Taking HTN medication

‡ Vascular risk score is from an internal study model, not a published risk score.

§ Calculated

ǁ Secondary prevention trials included for CRC sensitivity analyses only

¶ Known untreated HTN

†† Treated diabetes

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = Ankle Brachial Index; ACC/AHA = American College of Cardiology/American Heart Association; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Doctor’s Trial; BMI = Body Mass Index; CHD = Coronary heart disease; CHF = Coronary Heart Failure; Cigs = cigarettes; CVD = Cardiovascular Disease; DBP = Diastolic Blood Pressure; dL = deciliter; DM = diabetes mellitus; HDL = High Density Lipoprotein; HOT = Hypertension Optimal Treatment; HTN = Hypertension; IHD= Ischemic Heart Disease; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; JPPP= Japanese Primary Prevention Project; kg = kilogram; LDL = Low Density Lipoprotein; m2 = square meter; MI = Myocardial Infarction; mg = milligram; mmHg = millimeters mercury; N = number; Norm = Normal weight; NR = not reported; OW = overweight; PAD = Peripheral Arterial Disease; PHS = Physician’s Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; Rand = randomized; SALT = Swedish Aspirin Low Dose Trial; SBP = Systolic Blood Pressure; TC = Total Cholesterol; TIA = Transient Ischemic Attack; TPT = Thrombosis Prevention Trial; UK = United Kingdom; UK-TIA = United Kingdom Transient Ischemic Attack; UW = Underweight; WHS = Women’s Health Study; W/o = without

#### Detailed Results by Outcome

##### Effect of Aspirin on Major CVD Events

Pooled analysis from 13 trials (N=161,680) showed that aspirin use was associated with a decrease in major CVD events, defined as a composite of cardiovascular death, nonfatal MI, and nonfatal stroke of all types (Peto OR, 0.89 [95% CI, 0.85 to 0.94]; I^2^=0%) (Figure 7 and Table 9). Absolute differences between intervention and control in CVD events ranged from −2.5 to −0.08 percent (Table 6). When restricted to low-dose studies for a sensitivity analysis, the association between aspirin and major CVD events was unchanged (k=11, N=134,470; Peto OR, 0.90 [95% CI, 0.85 to 0.95]; I^2^=0%).

Figure 7 Key Question 1: Pooled Analysis of Major CVD Event (CVD Mortality, Nonfatal Stroke, or Nonfatal MI) Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; CVD = cardiovascular disease; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; MI = myocardial infarction; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 7 displays a pooled analysis of major CVD event (CVD mortality, nonfatal stroke, or nonfatal MI) risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

Table 9 Key Question 1: Effect of Aspirin on Major Cardiovascular Events (Total Stroke, Total MI, CVD Mortality), Cardiovascular-Related Mortality, and All-Cause Mortality

Study name; Author, year | Mean F/U, years | Outcome | IG n/n analyzed | CG n/n analyzed | Peto OR (95% CI)
AAA; Fowkes, 2010^69^ | 8.2 | Major CVD events | 134/1675 | 136/1675 | 0.98 (0.77, 1.26)
AAA; Fowkes, 2010^69^ | 8.2 | CVD-related mortality | 35/1675 | 30/1675 | 1.17 (0.72, 1.91)
AAA; Fowkes, 2010^69^ | 8.2 | All-cause mortality | 176/1675 | 186/1675 | 0.94 (0.76, 1.17)
ARRIVE; Gaziano, 2018^56^ | 5; (median) | Major CVD events | 208/6270 | 218/6276 | 0.95 (0.79, 1.16)
ARRIVE; Gaziano, 2018^56^ | 5; (median) | CVD-related mortality | 38/6270 | 39/6276 | 0.98 (0.62, 1.53)
ARRIVE; Gaziano, 2018^56^ | 5; (median) | All-cause mortality | 160/6270 | 161/6276 | 0.99 (0.80, 1.24)
ASCEND; ASCEND Study Collaborative, 2018^55^ | 7.4 | Major CVD events | 542/7740 | 587/7740 | 0.92 (0.81, 1.04)
ASCEND; ASCEND Study Collaborative, 2018^55^ | 7.4 | CVD-related mortality | 210/7740 | 226/7740 | 0.93 (0.77, 1.12)
ASCEND; ASCEND Study Collaborative, 2018^55^ | 7.4 | All-cause mortality | 748/7740 | 792/7740 | 0.94 (0.84, 1.04)
ASPREE; McNeil, 2018^101^ | 4.7 | Major CVD events | 329/9525 | 372/9589 | 0.89 (0.76, 1.03)
ASPREE; McNeil, 2018^101^ | 4.7 | CVD-related mortality | 78/9525 | 81/9589 | 0.97 (0.71, 1.32)
ASPREE; McNeil, 2018^101^ | 4.7 | All-cause mortality | 558/9525 | 494/9589 | 1.15 (1.01, 1.30)
BMD; Peto, 1988^82^ | 6 | Major CVD events | 284/3429 | 143/1710 | 0.99 (0.80, 1.22)
BMD; Peto, 1988^82^ | 6 | CVD-related mortality | 143/3429 | 75/1710 | 0.95 (0.71, 1.26)
BMD; Peto, 1988^82^ | 6 | All-cause mortality | 270/3429 | 151/1710 | 0.88 (0.71, 1.09)
HOT; Hanson, 1998^70^ | 3.8 | Major CVD events | 315/9399 | 368/9391 | 0.85 (0.73, 0.99)
HOT; Hanson, 1998^70^ | 3.8 | CVD-related mortality | 133/939 | 140/9391 | 0.95 (0.75, 1.20)
HOT; Hanson, 1998^70^ | 3.8 | All-cause mortality | 284/9399 | 305/9391 | 0.93 (0.79, 1.09)
JPAD; Ogawa, 2008^81^ | 4.37; (median) | Major CVD events | 40/1262 | 46/1277 | 0.88 (0.57, 1.35)
JPAD; Ogawa, 2008^81^ | 4.37; (median) | CVD-related mortality | 1/1262 | 10/1277 | 0.20 (0.06, 0.64)
JPAD; Ogawa, 2008^81^ | 4.37; (median) | All-cause mortality | 34/1262 | 38/1277 | 0.90 (0.57, 1.44)
JPPP; Ikeda, 2014^91^ | 5; (median) | Major CVD events | 193/7220 | 207/7244 | 0.93 (0.77, 1.14)
JPPP; Ikeda, 2014^91^ | 5; (median) | CVD-related mortality | 58/7220 | 57/7244 | 1.02 (0.71, 1.47)
JPPP; Ikeda, 2014^91^ | 5; (median) | All-cause mortality | 297/7220 | 303/7244 | 0.98 (0.83, 1.16)
PHS; Physician’s Health Study, 1989^59^ | 5 | Major CVD events | 307/11037 | 370/11034 | 0.83 (0.71, 0.96)
PHS; Physician’s Health Study, 1989^59^ | 5 | CVD-related mortality | 81/11037 | 83/11034 | 0.98 (0.72, 1.33)
PHS; Physician’s Health Study, 1989^59^ | 5 | All-cause mortality | 217/11037 | 227/11034 | 0.95 (0.79, 1.15)
POPADAD; Belch, 2008^66^ | 6.7; (median) | Major CVD events | 127/638 | 132/638 | 0.95 (0.73, 1.25)
POPADAD; Belch, 2008^66^ | 6.7; (median) | CVD-related mortality | 43/638 | 35/638 | 1.24 (0.79, 1.97)
POPADAD; Belch, 2008^66^ | 6.7; (median) | All-cause mortality | 94/638 | 101/638 | 0.92 (0.68, 1.25)
PPP; Rongaclioni, 2001^64^ | 3.6 | Major CVD events | 45/2226 | 64/2269 | 0.71 (0.49, 1.04)
PPP; Rongaclioni, 2001^64^ | 3.6 | CVD-related mortality | 17/2226 | 31/2269 | 0.57 (0.32, 1.00)
PPP; Rongaclioni, 2001^64^ | 3.6 | All-cause mortality | 62/2226 | 78/2269 | 0.81 (0.58, 1.13)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | 6.8; (median) | Major CVD events | 101/1268 | 133/1272 | 0.74 (0.57, 0.97)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | 6.8; (median) | CVD-related mortality | 42/1268 | 40/1272 | 1.06 (0.68, 1.64)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | 6.8; (median) | All-cause mortality | 113/1268 | 110/1272 | 1.03 (0.79, 1.36)
WHS; Ridker, 2005^83^ | 10.1 | Major CVD events | 477/19934 | 522/19942 | 0.91 (0.80, 1.03)
WHS; Ridker, 2005^83^ | 10.1 | CVD-related mortality | 120/19934 | 126/19942 | 0.95 (0.74, 1.22)
WHS; Ridker, 2005^83^ | 10.1 | All-cause mortality | 609/19934 | 642/19942 | 0.95 (0.85, 1.06)

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; CVD = cardiovascular disease; F/U = followup; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; PHS = Physician’s Health Study; n = number of participants; OR = odds ratio; p-y = person-years; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT = Thrombosis Prevention Trial; WHS = Women’s Health Study

##### Effect of Aspirin on MI Events

Total MI events. Pooled analysis from 13 trials (N=161,680) demonstrated that aspirin is associated with a reduction in total MI events (Peto OR, 0.86 [95% CI, 0.80 to 0.92]; I^2^=45.7%) (Figure 8 and Table 10). Absolute differences ranged from −1.9 to 1.2 percent (Table 6). Three trials showed large statistically significant benefit with point estimates ranging from 0.58 to 0.74.^59,^ ^70,^ ^91^ Most trials showed point estimates less than 1 that were not statistically significant but 2 trials did have nonstatistically significant point estimates above 1.^66,^ ^69^ Sensitivity analyses by dose demonstrated a similar reduction in total MI events in the low-dose aspirin trials (k=11, N=134,470; Peto OR, 0.89 [95% CI, 0.82 to 0.96]; I^2^=26.8%).

Figure 8 Key Question 1: Pooled Analysis of Total MI^*^ * Includes fatal coronary heart disease and sudden death in addition to MI events. Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; MI = myocardial infarction; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 8 displays a pooled analysis of total MI risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

Table 10 Key Question 1: Effect of Aspirin on MI^*^

Study name; Author, year; Quality | Mean F/U, yrs | Outcome | IG n/n analyzed | CG n/n analyzed | Peto OR (95% CI)
AAA; Fowkes, 2010^69^; Fair | 8.2 | MI - Total | 90/1675 | 86/1675 | 1.05 (0.77, 1.42)
AAA; Fowkes, 2010^69^; Fair | 8.2 | MI - Fatal | 28/1675 | 18/1675 | 1.55 (0.87, 2.78)
AAA; Fowkes, 2010^69^; Fair | 8.2 | MI - Nonfatal | 62/1675 | 68/1675 | 0.91 (0.64, 1.29)
ARRIVE; Gaziano, 2018^56^; Fair | 5; (median) | MI - Total | 95/6270 | 112/6276 | 0.85 (0.64, 1.11)
ARRIVE; Gaziano, 2018^56^; Fair | 5; (median) | MI - Fatal | 7/6270 | 14/6276 | 0.51 (0.22, 1.21)
ARRIVE; Gaziano, 2018^56^; Fair | 5; (median) | MI - Nonfatal | 88/6270 | 98/6276 | 0.90 (0.67, 1.20)
ASCEND; ASCEND Study Collaborative, 2018^55^; Fair | 7.4 | MI - Total | 296/7740 | 317/7740 | 0.93 (0.79, 1.09)
ASCEND; ASCEND Study Collaborative, 2018^55^; Fair | 7.4 | MI - Fatal | 105/7740 | 122/7740 | 0.86 (0.66, 1.12)
ASCEND; ASCEND Study Collaborative, 2018^55^; Fair | 7.4 | MI - Nonfatal | 191/7740 | 195/7740 | 0.98 (0.80, 1.20)
ASPREE; McNeil, 2018^101^; Good | 4.7 | MI - Total | 181/9525 | 205/9589 | 0.89 (0.72, 1.08)
ASPREE; McNeil, 2018^101^; Good | 4.7 | MI - Fatal | 31/9525 | 45/9589 | 0.70 (0.44, 1.09)
ASPREE; McNeil, 2018^101^; Good | 4.7 | MI - Nonfatal | 150/9525 | 160/9589 | 0.94 (0.75, 1.18)
BMD; Peto, 1988^82^; Fair | 6 | MI - Total | 169/3429 | 88/1710 | 0.96 (0.73, 1.25)
BMD; Peto, 1988^82^; Fair | 6 | MI - Fatal | 89/3429 | 47/1710 | 0.94 (0.66, 1.35)
BMD; Peto, 1988^82^; Fair | 6 | MI – Nonfatal | 80/3429 | 41/1710 | 0.97 (0.66, 1.43)
HOT; Hanson, 1998^70^; Fair | 3.8 | MI - Total | 153/9399 | 207/9391 | 0.74 (0.60, 0.91)
HOT; Hanson, 1998^70^; Fair | 3.8 | MI - Fatal | 85/9399 | 94/9391 | 0.90 (0.67, 1.21)
HOT; Hanson, 1998^70^; Fair | 3.8 | MI - Nonfatal | 68/9399 | 113/9391 | 0.60 (0.45, 0.81)
JPAD; Ogawa, 2008^81^; Fair | 4.37; (median) | MI - Total | 12/1262 | 14/1277 | 0.87 (0.40, 1.88)
JPAD; Ogawa, 2008^81^; Fair | 4.37; (median) | MI - Fatal | 0/1262 | 5/1277 | 0.14 (0.02, 0.79)
JPAD; Ogawa, 2008^81^; Fair | 4.37; (median) | MI - Nonfatal | 12/1262 | 9/1277 | 1.35 (0.57, 3.19)
JPAD; Ogawa, 2008^81^; Fair | 10.3^†^; (median) | MI - Total | 28/1262 | 29/1277 | 0.98 (0.58, 1.65)
JPAD; Ogawa, 2008^81^; Fair | 10.3^†^; (median) | MI - Fatal | 3/1262 | 6/1277 | 0.52 (0.14, 1.92)
JPAD; Ogawa, 2008^81^; Fair | 10.3^†^; (median) | MI - Nonfatal | 25/1262 | 23/1277 | 1.10 (0.62, 1.95)
JPPP; Ikeda, 2014^91^; Fair | 5; (median) | MI - Total | 27/7220 | 47/7244 | 0.58 (0.37, 0.92)
JPPP; Ikeda, 2014^91^; Fair | 5; (median) | MI - Fatal | 7/7220 | 9/7244 | 0.78 (0.29, 2.08)
JPPP; Ikeda, 2014^91^; Fair | 5; (median) | MI - Nonfatal | 20/7220 | 38/7244 | 0.54 (0.32, 0.90)
PHS; Physician’s Health Study, 1989^59^; Good | 5 | MI - Total | 185/11037 | 276/11034 | 0.67 (0.56, 0.80)
PHS; Physician’s Health Study, 1989^59^; Good | 5 | MI - Fatal | 56/11037 | 65/11034 | 0.86 (0.60, 1.23)
PHS; Physician’s Health Study, 1989^59^; Good | 5 | MI - Nonfatal | 139/11037 | 239/11034 | 0.58 (0.48, 0.72)
POPADAD; Belch, 2008^66^; Fair | 6.7 | MI - Total | 90/638 | 82/638 | 1.11 (0.81, 1.54)
POPADAD; Belch, 2008^66^; Fair | 6.7 | MI - Fatal | 35/638 | 26/638 | 1.36 (0.82, 2.28)
POPADAD; Belch, 2008^66^; Fair | 6.7 | MI - Nonfatal | 55/638 | 56/638 | 0.98 (0.66, 1.45)
PPP; Rongaclioni, 2001^64^; Fair | 3.6 | MI - Total | 19/2226 | 28/2269 | 0.69 (0.39, 1.23)
PPP; Rongaclioni, 2001^64^; Fair | 3.6 | MI - Fatal | 4/2226 | 6/2269 | 0.68 (0.20, 2.36)
PPP; Rongaclioni, 2001^64^; Fair | 3.6 | MI - Nonfatal | 15/2226 | 22/2269 | 0.70 (0.36, 1.33)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^; Fair | 6.8; (median) | MI - Total | 83/1268 | 107/1272 | 0.76 (0.57, 1.03)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^; Fair | 6.8; (median) | MI - Fatal | 36/1268 | 34/1272 | 1.06 (0.66, 1.71)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^; Fair | 6.8; (median) | MI - Nonfatal | 47/1268 | 73/1272 | 0.64 (0.44, 0.92)
WHS; Ridker, 2005^83^; Good | 10.1 | MI - Total | 198/19934 | 193/19942 | 1.03 (0.84, 1.25)
WHS; Ridker, 2005^83^; Good | 10.1 | MI - Fatal | 14/19934 | 12/19942 | 1.17 (0.54, 2.52)
WHS; Ridker, 2005^83^; Good | 10.1 | MI - Nonfatal | 184/19934 | 181/19942 | 1.02 (0.83, 1.25)
WHS; Ridker, 2005^83^; Good | 17.5^†^ | MI - Total | Events: 320/19934 | Events: 323/19942 | HR: 0.98 (0.84, 1.15)

* Includes fatal coronary heart disease and sudden death in addition to MI events.

† Observational followup

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; F/U = followup; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; MI = myocardial infarction; n = number of participants; OR = odds ratio; p-y = person-years; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study; yrs = years

Fatal MI events. Pooled analysis from 13 trials (N=161,680) demonstrated no statistically significant effect on fatal MI/fatal coronary events (Peto OR, 0.91 [95% CI, 0.80 to 1.03]; I^2^=18.0%) (Figure 9 and Table 10). Sensitivity analyses by dose showed similar nonsignificant results.

Figure 9 Key Question 1: Pooled Analysis of Fatal MI^*^ * Includes fatal coronary heart disease and sudden death in addition to MI events. Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; MI = myocardial infarction; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 9 displays a pooled analysis of fatal MI risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

Nonfatal MI events. Results for nonfatal MI events paralleled the total MI event results. Pooled analysis from 13 trials (N=161,680) demonstrated that aspirin was associated with a reduction in nonfatal MI events (Peto OR 0.83 [95% CI, 0.76 to 0.90]; I^2^=62.1%) (Figure 10 and Table 10). Absolute differences ranged from −2.0 to 0.2 percent (Table 6). Sensitivity analyses by dose demonstrated a similar and statistically significant reduction in nonfatal MI events in the low-dose aspirin trials (k=11, N=134,470; Peto OR, 0.88 [95% CI, 0.80 to 0.96]; I^2^=44.2%).

Figure 10 Key Question 1: Pooled Analysis of Nonfatal MI Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; CVD = cardiovascular disease; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; MI = myocardial infarction; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 10 displays a pooled analysis nonfatal MI risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

##### Effect of Aspirin on Stroke

Total stroke. Pooled analysis of thirteen trials (N=161,680) showed that aspirin does not have a statistically significant effect on total stroke, including both ischemic and hemorrhagic (Peto OR, 0.94 [95% CI, 0.87 to 1.01]; I^2^=0%) (Figure 11 and Table 11). The finding for total stroke became statistically significant in sensitivity analyses restricted to low-dose aspirin (k=11, N=134,470; Peto OR, 0.91 [95% CI, 0.84 to 0.99]; I^2^=0%). The two higher dose trials of BMD and PHS had point estimates of 1.16 and 1.22, respectively, however confidence intervals crossed 1.^59,^ ^82^ In contrast, only 1 of 10 low-dose trials reporting this outcome showed a point estimate greater than 1.^56^

Figure 11 Key Question 1: Pooled Analysis of Total All-Type Stroke (Fatal and Nonfatal) Risk, Aspirin Compared With Placebo, Stratified by Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; F/U = followup; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 11 displays a pooled analysis of total all-type stroke (fatal and nonfatal) risk, aspirin compared with placebo, stratified by dose and sorted by trial end year.

Table 11 Key Question 1: Effect of Aspirin on Stroke

Study name; Author, year | Mean F/U, years | Outcome | IG n/n analyzed | CG n/n analyzed | Peto OR (95% CI)
AAA; Fowkes, 2010^69^ | 8.2 | Ischemic stroke - total | 30/1675 | 37/1675 | 0.81 (0.50, 1.31)
AAA; Fowkes, 2010^69^ | 8.2 | Ischemic stroke - fatal | 2/1675 | 7/1675 | 0.33 (0.09, 1.21)
AAA; Fowkes, 2010^69^ | 8.2 | Ischemic stroke - nonfatal | 28/1675 | 30/1675 | 0.93 (0.55, 1.57)
AAA; Fowkes, 2010^69^ | 8.2 | All-type stroke - total | 44/1675 | 50/1675 | 0.88 (0.58, 1.32)
AAA; Fowkes, 2010^69^ | 8.2 | All-type stroke - fatal | 7/1675 | 12/1675 | 0.59 (0.24, 1.45)
AAA; Fowkes, 2010^69^ | 8.2 | All-type stroke - nonfatal | 37/1675 | 38/1675 | 0.97 (0.62,1.54)
AAA; Fowkes, 2010^69^ | 8.2 | Unknown stroke - fatal | 2/1675 | 2/1675 | NR
AAA; Fowkes, 2010^69^ | 8.2 | Unknown stroke - nonfatal | 7/1675 | 7/1675 | NR
ARRIVE; Gaziano, 2018^56^ | 5; (median) | Total stroke | 75/6270 | 67/6276 | 1.12 (0.81, 1.56)
ASCEND; ASCEND Study Collaborative, 2018^55^ | 7.4 | Ischemic stroke - nonfatal | 202/7740 | 229/7740 | 0.88 (0.73, 1.06)
ASCEND; ASCEND Study Collaborative, 2018^55^ | 7.4 | All-type stroke | 254/7740 | 280/7740 | 0.90 (0.76, 1.07)
ASCEND; ASCEND Study Collaborative, 2018^55^ | 7.4 | All-type stroke - fatal | 38/7740 | 34/7740 | 1.12 (0.70, 1.78)
ASCEND; ASCEND Study Collaborative, 2018^55^ | 7.4 | All-type stroke - nonfatal | 216/7740 | 246/7740 | 0.87 (0.73, 1.05)
ASPREE; McNeil, 2018^101^ | 4.7 | Ischemic stroke – total^*^ | 148/9525 | 167/9589 | 0.89 (0.71, 1.11)
ASPREE; McNeil, 2018^101^ | 4.7 | Ischemic stroke - fatal | 15/9525 | 12/9589 | 1.26 (0.59, 2.68)
ASPREE; McNeil, 2018^101^ | 4.7 | Ischemic stroke - nonfatal | 133/9525 | 155/9589 | 0.86 (0.68, 1.09)
ASPREE; McNeil, 2018^101^ | 4.7 | All-type stroke | 195/9525 | 203/9589 | 0.97 (0.79, 1.18)
ASPREE; McNeil, 2018^101^ | 4.7 | All-type stroke - fatal | 34/9525 | 29/9589 | 1.18 (0.72, 1.94)
ASPREE; McNeil, 2018^101^ | 4.7 | All-type stroke - nonfatal | 161/9525 | 174/9589 | 0.93 (0.75, 1.15)
ASPREE; McNeil, 2018^101^ | 4.7 | Unknown stroke - total | 2/9525 | 1/9589 | NR
ASPREE; McNeil, 2018^101^ | 4.7 | Unknown stroke - fatal | 1/9525 | 1/9589 | NR
BMD; Peto, 1988^82^ | 6 | Ischemic stroke - total | 21/3429 | 7/1710 | 1.45 (0.66, 3.20)
BMD; Peto, 1988^82^ | 6 | Ischemic stroke - fatal | 8/3429 | 3/1710 | 1.31 (0.37, 4.60)
BMD; Peto, 1988^82^ | 6 | Ischemic stroke - nonfatal^†^ | 13/3429 | 4/1710 | 1.55 (0.57, 4.27)
BMD; Peto, 1988^82^ | 6 | All-type stroke | 91/3429 | 39/1710 | 1.16 (0.80, 1.68)
BMD; Peto, 1988^82^ | 6 | All-type stroke - fatal | 30/3429 | 12/1710 | 1.24 (0.65, 2.36)
BMD; Peto, 1988^82^ | 6 | All-type stroke - nonfatal^†^ | 61/3429 | 27/1710 | 1.13 (0.72, 1.76)
BMD; Peto, 1988^82^ | 6 | Unknown stroke - fatal | 12/3429 | 5/1710 | NR
BMD; Peto, 1988^82^ | 6 | Unknown stroke - nonfatal^†^ | 45/3429 | 21/1710 | NR
HOT; Hanson, 1998^70^ | 3.8 | All-type stroke | 146/9399 | 148/9391 | 0.99 (0.78,1.24)
JPAD; Ogawa, 2008^81^ | 4.37; (median) | Ischemic stroke - nonfatal | 22/1262 | 24/1277 | 0.93 (0.52, 1.66)
JPAD; Ogawa, 2008^81^ | 4.37; (median) | All-type stroke | 28/1262 | 32/1277 | 0.88 (0.53, 1.47)
JPAD; Ogawa, 2008^81^ | 4.37; (median) | All-type stroke - fatal | 1/1262 | 5/1277 | 0.27 (0.05, 1.32)
JPAD; Ogawa, 2008^81^ | 4.37; (median) | All-type stroke - nonfatal | 27/1262 | 27/1277 | 1.01 (0.59, 1.74)
JPAD; Ogawa, 2008^81^ | 10.3^**^; (median) | Ischemic stroke - nonfatal | 38/1262 | 46/1277 | HR: 0.85 (0.55, 1.31)
JPAD; Ogawa, 2008^81^ | 10.3^**^; (median) | All-type stroke - fatal | 10/1262 | 8/1277 | HR: 1.31 (0.52, 3.43)
JPPP; Ikeda, 2014^91^ | 5; (median) | Ischemic stroke - total | 85/7220 | 101/7244 | 0.84 (0.63, 1.13)
JPPP; Ikeda, 2014^91^ | 5; (median) | Ischemic stroke - fatal | 2/7220 | 7/7244 | 0.33 (0.09, 1.22)
JPPP; Ikeda, 2014^91^ | 5; (median) | Ischemic stroke - nonfatal | 83/7220 | 94/7244 | 0.88 (0.66, 1.19)
JPPP; Ikeda, 2014^91^ | 5; (median) | All-type stroke | 126/7220 | 130/7244 | 0.97 (0.76, 1.24)
JPPP; Ikeda, 2014^91^ | 5; (median) | All-type stroke - fatal | 9/7220 | 16/7244 | 0.57 (0.26, 1.25)
JPPP; Ikeda, 2014^91^ | 5; (median) | All-type stroke - nonfatal | 117/7220 | 114/7244 | 1.03 (0.79, 1.34)
JPPP; Ikeda, 2014^91^ | 5; (median) | Unknown stroke - nonfatal | 3/7220 | 5/7244 | NR
PHS; Physician’s Health Study, 1989^59^ | 5 | Ischemic stroke - total | 91/11037 | 82/11034 | 1.11 (0.82, 1.50
PHS; Physician’s Health Study, 1989^59^ | 5 | Ischemic stroke - fatal^‡^ | 3/11037 | 3/11034 | 1.0 (0.20, 4.95)
PHS; Physician’s Health Study, 1989^59^ | 5 | Ischemic stroke - nonfatal | 88/11037 | 79/11034 | 1.11 (0.82, 1.51)
PHS; Physician’s Health Study, 1989^59^ | 5 | All-type stroke^§^ | 119/11037 | 98/11034 | 1.22 (0.93, 1.59)
PHS; Physician’s Health Study, 1989^59^ | 5 | All-type stroke - fatal^‡^ | 9/11037 | 6/11034 | 1.49 (0.54, 4.11)
PHS; Physician’s Health Study, 1989^59^ | 5 | All-type stroke - nonfatal | 110/11037 | 92/11034 | 1.20 (0.91, 1.58)
PHS; Physician’s Health Study, 1989^59^ | 5 | Unknown stroke - total^§^ | 5/11037 | 4/11034 | NR
PHS; Physician’s Health Study, 1989^59^ | 5 | Unknown stroke - fatal^‡^ | 0/11037 | 2/11034 | NR
POPADAD; Belch, 2008^66^ | 6.7; (median) | Ischemic stroke - fatal | 3/638 | 5/638 | 0.60 (0.15, 2.43)
POPADAD; Belch, 2008^66^ | 6.7; (median) | All-type stroke | 37/638 | 50/638 | 0.73 (0.47, 1.12)
POPADAD; Belch, 2008^66^ | 6.7; (median) | All-type stroke - fatal | 8/638 | 9/638 | 0.89 (0.34, 2.31)
POPADAD; Belch, 2008^66^ | 6.7; (median) | All-type stroke - nonfatal | 29/638 | 41/638 | 0.70 (0.43, 1.13)
POPADAD; Belch, 2008^66^ | 6.7; (median) | Unknown stroke - fatal | 3/638 | 1/638 | NR
PPP; Rongaclioni, 2001^64^ | 3.6 | All-type stroke^ǁ^ | 16/2226 | 24/2269 | 0.68 (0.37, 1.27)
PPP; Rongaclioni, 2001^64^ | 3.6 | All-type stroke - fatal | 1/2226 | 6/2269 | 0.24 (0.06, 1.07)
PPP; Rongaclioni, 2001^64^ | 3.6 | All-type stroke - nonfatal | 15/2226 | 18/2269 | 0.85 (0.43, 1.68)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | 6.8; (median) | Ischemic stroke - total | 10/1268 | 18/1272 | 0.56 (0.27, 1.19)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | 6.8; (median) | All-type stroke | 18/1268 | 26/1272 | 0.69 (0.38, 1.26)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | 6.8; (median) | All-type stroke - fatal | 2/1268 | 1/1272 | 1.95 (0.20, 18.81)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | 6.8; (median) | All-type stroke - nonfatal | 16/1268 | 25/1272 | 0.64 (0.35, 1.19)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | 6.8; (median) | Unknown stroke | 5/1268 | 6/1272 | NR
WHS; Ridker, 2005^83^ | 10.1 | Ischemic stroke - total^¶^ | 170/19934 | 221/19942 | 0.77 (0.63, 0.94)
WHS; Ridker, 2005^83^ | 10.1 | All-type stroke | 221/19934 | 266/19942 | 0.83 (0.69, 0.99)
WHS; Ridker, 2005^83^ | 10.1 | All-type stroke - fatal | 23/19934 | 22/19942 | 1.05 (0.58, 1.88)
WHS; Ridker, 2005^83^ | 10.1 | All-type stroke - nonfatal | 198/19934 | 244/19942 | 0.81 (0.67, 0.98)
WHS; Ridker, 2005^83^ | 17.5^**^ | Ischemic stroke - total | Events: 306/19934 | Events: 372/19942 | HR: 0.81 (0.70, 0.95)
WHS; Ridker, 2005^83^ | 17.5^**^ | All-type stroke | Events: 391/19934 | Events: 438/19942 | HR: 0.88 (0.77, 1.01)

* Includes 9 ischemic strokes with hemorrhagic transformation in 9 participants (6 aspirin and 3 placebo). Ischemic stroke only includes stroke events adjudicated as ischemic (does not include uncertain type).

† Nonfatal occurrences of a particular disease exclude occurrences in patients who later died of that disease

‡ Includes all deaths regardless of previous nonfatal events

§ First events only.

ǁ 3 strokes deemed disabling in the IG and 4 in the CG

¶ 4 unclassified strokes in CG

** Observational followup

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; F/U = followup; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; n = number of participants; OR = odds ratio; p-y = person-years; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Fatal stroke. Pooled analysis of eleven trials (N=130,344) showed that aspirin does not have a statistically significant effect on fatal strokes, including both ischemic and hemorrhagic (Peto OR, 0.98 [95% CI, 0.78 to 1.22]; I^2^=12.4%) (Figure 12 and Table 11). Sensitivity analysis likewise showed no statistically significant effect when stratified by dose.

Figure 12 Key Question 1: Pooled Analysis of Fatal All-Type Stroke Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 12 displays a pooled analysis of fatal all-type stroke risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

Nonfatal stroke. Pooled analysis of eleven trials (N=130,344) showed that aspirin is associated with a nonstatistically significant effect on nonfatal strokes, including both ischemic and hemorrhagic (Peto OR, 0.92 [95% CI, 0.84 to 1.00], p>0.05; I^2^=0%) (Figure 13 and Table 11). In contrast, sensitivity analysis restricted to low-dose aspirin trials shows that low-dose aspirin is associated with a statistically significant effect (k=9, n=103,134; Peto OR, 0.88 [95% CI, 0.80 to 0.97]; I^2^=0%).

Figure 13 Key Question 1: Pooled Analysis of Nonfatal All-Type Stroke Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 13 displays a pooled analysis of nonfatal all-type stroke risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

Ischemic stroke. Pooled analysis of seven trials (N=106,554) showed that aspirin is associated with a reduction in ischemic stroke (Peto OR, 0.86 [95% CI, 0.77 to 0.97]; I^2^=16.0%) (Figure 14 and Table 11). Absolute differences ranged from −0.6 to 0.2 percent (Table 6). Sensitivity analysis pooling five low-dose aspirin trials resulted in a similar benefit (k=5, N=79,334; Peto OR, 0.82 [95% CI, 0.72 to 0.92]; I^2^=0%).

Figure 14 Key Question 1: Pooled Analysis of Total Ischemic Stroke (Fatal and Nonfatal) Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ASA = aspirin; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; IG = intervention group; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 14 displays a pooled analysis of total ischemic stroke (fatal and nonfatal) risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

Fatal ischemic stroke. Pooled analysis of six trials (N=65,414) showed no statistically significant effect on fatal ischemic stroke (Peto OR, 0.80 [95% CI, 0.50 to 1.29]; I^2^=13.0%) (Figure 15 and Table 11). Events were rare as evidenced by five of six trials reporting fewer than ten events in each group. Due to this low event rate, sensitivity analysis by dose is limited.

Figure 15 Key Question 1: Pooled Analysis of Fatal Ischemic Stroke Risk, Aspirin Compared With Placebo, Stratified by Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ASA = aspirin; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; IG = intervention group; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial

Figure 15 displays a pooled analysis of fatal ischemic stroke risk, aspirin compared with placebo, stratified by dose and sorted by trial end year

Nonfatal ischemic stroke. Pooled analysis of seven trials (N=82,157) showed no statistically significant effect of aspirin on nonfatal ischemic stroke (Peto OR, 0.92 [95% CI, 0.82 to 1.03]; I^2^=0%) (Figure 16 and Table 11). Results became statistically significant in sensitivity analyses limited to low-dose trials (k=5, N=54947; Peto OR, 0.88 [95% CI, 0.78 to 1.00], p<0.05; I^2^=0%). Both higher dose trials showed point estimates above 1, although neither were statistically significant.^59,^ ^82^

Figure 16 Key Question 1: Pooled Analysis of Nonfatal Ischemic Stroke Risk, Aspirin Compared With Placebo, Stratified by Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study

Figure 16 displays a pooled analysis of nonfatal ischemic stroke risk, aspirin compared with placebo, stratified by dose and sorted by trial end year.

##### Effect of Aspirin on CVD Mortality

Cardiovascular deaths were variably defined across the primary prevention trials. In four trials, CVD mortality was comprised exclusively of fatal MI events and stroke.^66,^ ^69,^ ^81,^ ^101^ In other trials, definitions were broader and often included additional events such as deaths due to rheumatic fever, pulmonary embolism, abdominal aortic aneurysm, or hypertensive disease. Pooled analysis from 13 trials (N=161,680) demonstrated no statistically significant effect on CVD mortality (Peto OR, 0.95 [95% CI, 0.87 to 1.04]; I^2^=4.3%) (Figure 17 and Table 9). Sensitivity analysis by dose yielded similar nonstatistically significant results.

Figure 17 Key Question 1: Pooled Analysis of CVD Mortality Risk, Aspirin Compared With Placebo, Stratified by Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; CVD = cardiovascular disease; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 17 displays a pooled analysis of CVD mortality risk, aspirin compared with placebo, stratified by dose and sorted by trial end year.

##### Effect of Aspirin on All-Cause Mortality

Pooled analysis of 13 primary prevention trials (N=161,680) showed that aspirin is not associated with a change in all-cause mortality at 3.6 to 10.1 years (Peto OR, 0.97 [95% CI, 0.93 to 1.02]; I^2^=0%) (Figure 18 and Table 9). ASPREE was the only individual trial with a statistically significant finding and reported higher all-cause mortality in the aspirin group.^101^ TPT reported a similar trend favoring the control group, but it was not statistically significant.^45^ The remaining 11 trials all reported nonstatistically significant trends favoring the aspirin group. Sensitivity analyses by dose likewise yielded nonsignificant results.

Figure 18 Key Question 1: Pooled Analysis of All-Cause Mortality Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 18 displays a pooled analysis of all-cause mortality risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

##### Effect of Aspirin on CRC

CRC Incidence. Results for CRC incidence are highly variable by timing and length of followup. For events occurring within randomized periods only (k=5),^56,^ ^59,^ ^83,^ ^91,^ ^108,^ ^112–114,^ ^131^ aspirin at all doses had no statistically significant association with CRC incidence at 5 to 10 years of followup (Peto OR, 1.08 [95% CI, 0.94 to 1.24]; I^2^=16.7%) (Figure 19 and Table 12). None of the individual trials had individual relative comparisons that favored aspirin. A sensitivity analysis restricted to low-dose aspirin trials (k=4) produced similar results (Peto OR, 1.07 [(95% CI, 0.92 to 1.24]; I^2^=36.0%).

Figure 19 Key Question 1: Pooled Analysis of CRC Incidence Risk During the Trial Phase of Primary CVD Prevention RCTs From 5 to 10 Years, Aspirin Compared With Placebo, Stratified by Dose and Sorted by Trial End Year

Abbreviations: ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASPREE = Aspirin in Reducing Events in the Elderly; CG = control group; CI = confidence interval; CRC = colorectal cancer; IG = intervention group; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; WHS = Women’s Health Study

Figure 19 displays a pooled analysis of CRC incidence risk during the trial phase of primary CVD prevention RCTs from 5-10 years, aspirin compared with placebo, stratified by dose and sorted by trial end year

Table 12 Key Question 1: Effect of Aspirin on CRC Incidence and CRC-Related Mortality

Study name; Author, year | Outcome | Mean F/U, years | IG n/n analyzed | CG n/n analyzed | Peto OR (95% CI)
ARRIVE; Gaziano, 2018^56^ | CRC incidence | 5; (median) | 14/6270 | 6/6276 | 2.23 (0.93, 5.36)
ASPREE; McNeil, 2018^101,^ ^131^ | CRC incidence | 4.7 | 139/9525 | 137/9589 | 1.02 (0.81, 1.30)
ASPREE; McNeil, 2018^101,^ ^131^ | CRC-related mortality | 4.7 | 35/9525 | 20/9589 | 1.74 (1.02, 2.95)
BMD; Peto, 1988^82,^ ^92,^ ^93^ | CRC incidence | 9 | 28/3429 | 17/1710 | 0.82 (0.44, 1.52)
BMD; Peto, 1988^82,^ ^92,^ ^93^ | CRC incidence | 10-19 | 50/3429 | 38/1710 | 0.64 (0.41, 0.99)
BMD; Peto, 1988^82,^ ^92,^ ^93^ | CRC incidence | 20 | 92/3429 | 64/1710 | 0.70 (0.50, 0.98)
BMD; Peto, 1988^82,^ ^92,^ ^93^ | CRC-related mortality | 18.3 | 59/3429 | 40/1710 | 0.72 (0.47, 1.10)
JPAD; Ogawa, 2008^81,^ ^103^ | CRC incidence | 10.7; (median) | 27/1259 | 31/1277 | 0.88 (0.52, 1.48)
JPPP; Ikeda, 2014^91,^ ^108^ | CRC incidence | 5; (median) | 66/7297 | 50/7304 | 1.32 (0.92, 1.90)
PHS; Physician’s Health Study, 1989^59,^ ^113,^ ^114^ | CRC incidence | 5 | 63/11037 | 55/11034 | 1.15 (0.80, 1.65)
PHS; Physician’s Health Study, 1989^59,^ ^113,^ ^114^ | CRC incidence | 6-12 | 97/11037 | 94/11034 | 1.03 (0.78, 1.37)
PHS; Physician’s Health Study, 1989^59,^ ^113,^ ^114^ | CRC incidence | 10-12 | 28/11037 | 35/11034 | 0.80 (0.49, 1.31)
PHS; Physician’s Health Study, 1989^59,^ ^113,^ ^114^ | CRC incidence | 12 | 173/11037 | 168/11034 | 1.03 (0.83, 1.28)
SALT; The SALT Collaborative Group, 1991^93,^ ^94^ | CRC-related mortality | 18.3 | 7/676 | 10/684 | 0.71 (0.27, 1.84)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45,^ ^93^ | CRC-related mortality | 18.3; (median) | 34/2545 | 55/2540 | 0.62 (0.41, 0.94)
UK-TIA; UK-TIA Study Group, 1990^93,^ ^111^ | CRC incidence | 9 | 18/1632 | 8/817 | 1.12 (0.50, 2.55)
UK-TIA; UK-TIA Study Group, 1990^93,^ ^111^ | CRC incidence | 10-19 | 15/1632 | 15/817 | 0.47 (0.22, 1.01)
UK-TIA; UK-TIA Study Group, 1990^93,^ ^111^ | CRC incidence | 20 | 37/1632 | 23/817 | 0.80 (0.46, 1.37)
UK-TIA; UK-TIA Study Group, 1990^93,^ ^111^ | CRC-related mortality | 18.3 | 300 mg/d: 8/811 | 16/817 | 0.51 (0.23, 1.15)
UK-TIA; UK-TIA Study Group, 1990^93,^ ^111^ | CRC-related mortality | 18.3 | 1200 mg/d: 11/821 | 16/817 | 0.68 (0.32, 1.46)
UK-TIA; UK-TIA Study Group, 1990^93,^ ^111^ | CRC-related mortality | 18.3 | 300 or 1200 mg/d: 19/1632 | 16/817 | 0.57 (0.28, 1.15)
WHS; Ridker, 2005^49,^ ^83,^ ^112^ | CRC-related mortality | 0-10.3 | 41/19934 | 36/19942 | 1.14 (0.73, 1.78)
WHS; Ridker, 2005^49,^ ^83,^ ^112^ | CRC-related mortality | 0-17.5 | 83/19934 | 96/19942 | 0.86 (0.64, 1.16)
WHS; Ridker, 2005^49,^ ^83,^ ^112^ | CRC-related mortality | 0-26 | 114/19934 | 119/19942 | 0.96 (0.74, 1.24)
WHS; Ridker, 2005^49,^ ^83,^ ^112^ | CRC-related mortality | 10.3-17.5 | 42/19934 | 60/19942 | 0.70 (0.48, 1.04)
WHS; Ridker, 2005^49,^ ^83,^ ^112^ | CRC-related mortality | 17.5-26 | 31/19934 | 23/19942 | 1.35 (0.79, 2.30)
WHS; Ridker, 2005^49,^ ^83,^ ^112^ | CRC incidence | 0-10.3 | 147/19934 | 150/19942 | 0.98 (0.78, 1.23)
WHS; Ridker, 2005^49,^ ^83,^ ^112^ | CRC incidence | 0-17.5 | 222/19934 | 270/19942 | 0.82 (0.69, 0.98)
WHS; Ridker, 2005^49,^ ^83,^ ^112^ | CRC incidence | 0-26 | 274/19934 | 315/19942 | 0.87 (0.74, 1.02)
WHS; Ridker, 2005^49,^ ^83,^ ^112^ | CRC incidence | 10.3-17.5 | 75/19934 | 120/19942 | 0.63 (0.47, 0.83)
WHS; Ridker, 2005^49,^ ^83,^ ^112^ | CRC incidence | 17.5-26 | 52/19934 | 45/19942 | 1.16 (0.78, 1.72)

Abbreviations: ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; CRC = colorectal cancer; F/U = followup; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; SALT = Swedish Aspirin Low-dose Trial; TPT Thrombosis Prevention Trial; United Kingdom Transient Ischaemic Attack; WHS = Women’s Health Study

Four primary CVD prevention studies (N=69,622) reported RCT or observational followup at approximately ten years; the pooled result did not show an association between aspirin use and CRC incidence (Peto OR, 0.98 [95% CI, 0.85 to 1.14]; I^2^=0%) (Figure 20). Incorporating the secondary CVD prevention trial reporting CRC incidence at approximately ten years, United Kingdom Transient Ischaemic Attack (UK-TIA), did not change the pooled effect (Peto OR, 0.99 [95% CI, 0.86 to 1.14]).

Figure 20 Key Question 1: Pooled Analysis of CRC Incidence Risk During the Trial or Observational Phases of Primary and Secondary CVD Prevention Studies at Approximately 10 Years’ Followup, Aspirin Compared With Placebo, Stratified by Dose and Sorted by Trial End Year

Abbreviations: BMD = British Male Doctors; CG = control group; CI = confidence interval; CRC = colorectal cancer; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; UK-TIA = United Kingdom Transient Ischaemic Attack; WHS = Women’s Health Study

Figure 20 displays a pooled analysis of CRC incidence risk during the trial or observational phases of primary and secondary CVD prevention studies at approximately 10 years followup, aspirin compared with placebo, stratified by dose and sorted by trial end year.

Two primary CVD prevention studies reported observational followup at approximately 20 years; both showed that the group randomized during the trial period to aspirin experienced a lower incidence of CRC (k=2, N=45,015; Peto OR, 0.70 [95% CI, 0.50 to 0.98] and Peto OR, 0.82 [95% CI, 0.69 to 0.98] (Figure 21). Only one of these trials—WHS—used low-dose aspirin. The addition of the secondary CVD prevention study reporting CRC incidence at 20 years (UK-TIA) did not change the conclusions (k=3, N=47,464; pooled Peto OR, 0.79 [95% CI, 0.68 to 0.92]). Three primary prevention trials (BMD, PHS, WHS) and one secondary prevention trial (UK-TIA) provided post-trial observational data measured after 10 years and up to 19 years, not including incident CRC cases at earlier periods. This selected analysis showed a statistically significant reduction in CRC incidence in primary CVD prevention populations (Peto OR, 0.66 [95% CI, 0.53 to 0.82]; I^2^=0%) (Figure 22), suggesting that the impact on CRC incidence does not occur until ten years after aspirin use has been initiated. Again, only one of these trials, WHS, used low-dose aspirin. The addition of the secondary CVD prevention observational study, UK-TIA, yielded similar results (Peto OR, 0.64 [95% CI, 0.52 to 0.79]). Further, WHS reported longer followup for CRC incidence through 26 years.^49^ From 17.5 to 26 years, the group initially randomized to aspirin for 10 years of usage no longer experienced any reduction in CRC incidence (Peto OR, 1.16 [95% CI, 0.78 to 1.72]). When the entire followup period from baseline to 26 years was analyzed, aspirin use from 0-10 years continued to be associated with a decrease in CRC incidence, but the association was no longer statistically significant (Peto OR 0.87 [95% CI, 0.74 to 1.02]).

Figure 21 Key Question 1: Pooled Analysis of CRC Incidence Risk During the Trial and Observational Phases of Primary and Secondary CVD Prevention Studies Up to 20 Years, Aspirin Compared With Placebo, Stratified by Dose and Sorted by Trial End Year

Abbreviations: BMD = British Male Doctors; CG = control group; CI = confidence interval; CRC = colorectal cancer; IG = intervention group; mg = milligram; n = number of participants; OR = odds ratio; UK-TIA = United Kingdom Transient Ischaemic Attack; WHS = Women’s Health Study

Figure 21 displays a pooled analysis of CRC incidence risk during the trial and observational phases of primary and secondary CVD prevention studies up to 20 years, aspirin compared with placebo, stratified by dose and sorted by trial end year.

Figure 22 Key Question 1: Pooled Analysis of CRC Incidence Risk During the Observational Phases of Primary and Secondary CVD Prevention Studies From 10 to 19 Years,^*^ * Does not include any CRC cases that occurred prior to 10 years of followup. Aspirin Compared With Placebo, Stratified by Dose and Sorted by Trial End Year

Abbreviations: BMD = British Male Doctors; CG = control group; CI = confidence interval; CRC = colorectal cancer; IG = intervention group; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; UK-TIA = United Kingdom Transient Ischaemic Attack; WHS = Women’s Health Study

Figure 22 displays a pooled analysis of CRC incidence risk during the observational phases of primary and secondary CVD prevention studies from 10 to 19 years, aspirin compared with placebo, stratified by dose and sorted by trial end year.

WHS contributed the largest proportion of participants and CRC cases to each of the previously mentioned pooled effects for CRC incidence and is heavily weighted in the statistically significant pooled 20-year effects (WHS N/total N=39,876/47,464 or 84.0%). It is also the only low-dose trial represented in studies reporting long-term observational followup. At 26 years, WHS retained 67 percent of its participants for outcomes analysis; of these participants, 36 percent of participants were taking aspirin more than 3 days per month without any differences seen by original allocation.^49^ While CRC-specific risk factors such as family history are not reported, WHS participants had the lowest observed CVD event rates and 90 percent of the trial population was less than 65 years. As such, WHS may reflect a generally healthy population. WHS is also the only trial that captured CRC screening using endoscopy (although it was self-reported). While participants reporting CRC screening were more likely to opt in to the post-trial followup, weighting by the inverse probability of opting in did not change the overall effects of aspirin on CRC incidence at 17.5 years. However, posttrial outside aspirin use was associated with cancer risk factors, and additional confounding during the posttrial followup cannot be ruled out.

CRC Mortality. Two RCTs reported CRC mortality during the trial phase (ASPREE^101^ and WHS^49^). ASPREE reported that aspirin use was associated with statistically significantly higher CRC mortality at 4.7 years followup (Peto OR, 1.74 [95% CI, 1.02 to 2.95]). Although not statistically significant, WHS also reported an increase in CRC mortality for those taking aspirin at ten years (Peto OR, 1.14 [95% CI, 0.73 to 1.78]) (Figure 23 and Table 12). Observational followup at approximately 18 years was available for WHS^49^ as well as two additional primary CVD prevention trials.^45,^ ^82^ These three studies showed that aspirin use for 6-10 years was associated with a lower risk of CRC mortality at long term followup, including both the trial and observational period events (Peto OR, 0.76 [95% CI, 0.62 to 0.94]; I^2^=0%) (Figure 24). When two secondary CVD prevention trials were added to the analyses, the pooled long-term effect on CRC mortality did not differ (Peto OR, 0.74 [95% CI, 0.61 to 0.90]; I^2^=0%). WHS also provided CRC mortality at 26 years; similar to CRC incidence, the effect from baseline to 26 years showed CRC mortality was reduced for the aspirin group, but the effect was attenuated from 17.5 to 26 years. Overall, among studies the number of deaths due to CRC were relatively low, and these studies were likely not powered to assess the effect of aspirin on CRC mortality. Further, these effects were not adjusted for CRC screening or CRC risk factors.

Figure 23 Key Question 1: Pooled Analysis of CRC Mortality Risk During the Trial Phase of Primary CVD Prevention Studies From 5 to 10 Years, Aspirin Compared With Placebo, Stratified by Dose and Sorted by Trial End Year

Abbreviations: ASPREE = Aspirin in Reducing Events in the Elderly; CG = control group; CI = confidence interval; CRC = colorectal cancer; IG = intervention group; mg = milligram; n = number of participants; OR = odds ratio; WHS = Women’s Health Study

Figure 23 displays a pooled analysis of CRC mortality risk during the trial phase of primary CVD prevention studies from 5-10 years, aspirin compared with placebo, stratified by dose and sorted by trial end year.

Figure 24 Key Question 1: Pooled Analysis of CRC Mortality Risk During the Trial and Observational Phases of Primary and Secondary CVD Prevention Studies Up to 18 Years, Aspirin Compared With Placebo, Stratified by Dose and Sorted by Trial End Year

Abbreviations: BMD = British Male Doctors; CG = control group; CI = confidence interval; CRC = colorectal cancer; IG = intervention group; mg = milligram; n = number of participants; OR = odds ratio; SALT = Swedish Aspirin Low-dose Trial; TPT Thrombosis Prevention Trial; UK-TIA = United Kingdom Transient Ischaemic Attack; WHS = Women’s Health Study

Figure 24 displays a pooled analysis of CRC mortality risk during the trial and observational phases of primary and secondary CVD prevention studies up to 18 years, aspirin compared with placebo, stratified by dose and sorted by trial end year.

#### Sensitivity Analyses

##### Pooling Method

Primary analyses were conducted using the Peto OR fixed effects model because of rare events. Sensitivity analyses using the fixed effects Mantel-Haenszel model and the random effects REML model yielded similar results for all outcomes (Table 5).

##### Pre- and Post- Cholesterol Management Guidelines

We conducted sensitivity analyses to explore the potential influence of contemporary cardiovascular risk management, particularly background statin use, on the effect of aspirin. The publication of ATP III in 2001 was chosen as a proxy for statin use as only six of 13 primary prevention trials reported actual baseline statin use. Sensitivity analyses restricted to the eight trials conducted after ATP III^55,^ ^56,^ ^66,^ ^69,^ ^81,^ ^83,^ ^91,^ ^101^ showed diminished benefit for major CVD events and MI compared to trials conducted prior to ATP III^45,^ ^59,^ ^64,^ ^70,^ ^82^ (Table 5). However, pooled estimates for ischemic and total stroke appear greater and became statistically significant in these most contemporary trials compared to older trials. This finding may be influenced by dose because the highest ORs for these stroke outcomes occurred in PHS and BMD, high-dose trials conducted prior to ATP III. In contrast, statistical significance was lost for total MI events and nonfatal MI when restricted to post-ATP III trials. This loss of statistical significance is likely due to the removal of large older trials which reported moderate to large relative effect sizes for MI event outcomes. For example, three trials showed large statistically significant benefits for nonfatal MI with point estimates ranging from 0.58 to 0.64.^45,^ ^59,^ ^70^ Further exploration of results by trial completion dates did not reveal any consistent patterns (analysis not shown).

##### Small-Study Effects

Funnel plots added little to our exploration of heterogeneity as this body of evidence is populated almost exclusively by large studies (Appendix E).

#### Duration of Aspirin Use

Eleven RCTs report time-to-event analyses for CVD benefits.^45,^ ^55,^ ^56,^ ^64,^ ^66,^ ^69,^ ^70,^ ^81,^ ^83,^ ^91,^ ^101^ In cases where time-to-event analyses suggest benefit for individual outcomes, benefit generally accrues within the first 1-2 years. However, time-to-benefit analyses for primary composite CVD outcomes were significant only in ASCEND. When benefits are significant, there is no compelling evidence to suggest a delay in CVD benefit. ASCEND reports that composite CVD benefit realized over the 9 years of maximum followup accrues within the first 5 years without further benefit seen beyond 5 years.^55^ Four trials reporting significant differences in time-to-event analyses for individual outcomes suggested that benefits appeared relatively soon after aspirin administration. These outcomes were MI in HOT,^70^ CVD death in PPP,^64^ ischemic heart disease in TPT,^45^ and stroke in WHS.^83^ For HOT and PPP, benefit began within the first year and continued throughout the trial, but their followup ended before 5 years.^64,^ ^70^ TPT showed nonfatal ischemic heart disease benefit within the first year continuing through 7 years.^45^ WHS^83^ showed that total stroke and ischemic stroke benefits were not seen until 1-2 years and continued until 7 or 8 years.

To further explore potential effects by duration, we sorted forest plots by duration of use. For CVD and mortality outcomes, no patterns were apparent by duration of aspirin use. However, in most of the trials, aspirin administration continued for only the 4 to 6-year trial duration, so it is difficult to make any conclusions about effect of aspirin on CVD outcomes for longer term use. For CRC incidence and mortality, followup rather than duration of use appeared to show a trend towards effects appearing after 10 years and continuing through 17.5 years.^103,^ ^112^ ^83^ Furthermore, the longest followup available from WHS (26 years) indicates the effect on CRC is attenuated in the period between 17.5 and 26 years.

### Findings in Specific Populations (KQ1a)

#### Age

##### Summary

Despite numerous prespecified analyses by age in this body of literature, few trials found a heterogeneity of treatment effect by age. In the few cases where interaction testing was significant, which occurred only in the largest trials, a greater benefit in older age groups was suggested. However, most subgroup analysis findings were inconsistent and not statistically significant. There are few trials reporting CRC incidence or mortality by age, showing conflicting results.

##### Trial Characteristics

Populations included in aspirin primary CVD prevention trials include a wide range of ages, and a new trial published since the last review, ASPREE, provides evidence in older populations that was previously lacking (Figure 6). Mean age was reported in all but one trial^82^ and ranged from 53 years in PHS^59^ to 74 years in ASPREE.^101^ The largest two trials, PHS and WHS, had relatively young participants with mean ages of 53 years and 54 years, respectively.^59,^ ^83^ Ninety percent of WHS participants were younger than 65 years and 75 percent of PHS participants were younger than 60 years. Most trials’ lower age limit was 40 to 50 years of age; JPAD had the widest age range for recruitment of 30 to 85 years.^81^ ASPREE solely recruited older participants: ≥70 years or ≥65 among Black and Hispanic participants in the U.S.-based centers, so unsurprisingly this trial had the highest mean age at 74 years.^101^ The upper age limit was specified in the inclusion criteria for six trials, ranging from 69 to 85 years.^45,^ ^59,^ ^69,^ ^70,^ ^81,^ ^91^ Five trials^55,^ ^59,^ ^82,^ ^91,^ ^101^ reported the proportion of participants who were 70 or older: 7 percent in PHS, 14 percent in BMD (70-79 years), 24 percent in ASCEND, 55 percent in JPPP, and 97 percent in ASPREE.

Almost all primary CVD prevention trials (11 of 13) reported age-specific results (Appendix D, Table 3). Seven trials^55,^ ^56,^ ^69,^ ^81,^ ^83,^ ^91,^ ^101^ reported a priori analyses by age for all-cause mortality or CVD outcomes with varying age strata: JPAD (<65 and ≥65 years), Aspirin for Asymptomatic Atherosclerosis (AAA) (<62 and ≥62 years), WHS (45 to 54, 55 to 64, and ≥65 years), JPPP (<70 and ≥70 years), ASCEND (<60, 60-69, ≥70 years), ASPREE (65-73, ≥74 years) and ARRIVE (<65 and ≥65 years). Four trials^45,^ ^59,^ ^66,^ ^70^ reported all-cause mortality or CVD outcomes by age, however, the timing of subanalyses are either post-hoc or unreported.

##### Results

Overall, nine trials reported trial-defined CVD composite outcomes by age and findings were inconsistent (Appendix D, Table 4). Analyses were prespecified in seven trials^55,^ ^56,^ ^69,^ ^81,^ ^83,^ ^91,^ ^101^ and interaction testing was performed in seven trials for CVD composites.^55,^ ^56,^ ^66,^ ^81,^ ^83,^ ^91,^ ^101^ Only WHS reported statistically significant interaction testing supporting a differential effect of aspirin on composite CVD outcomes whereby benefit was greater in older compared to younger age groups (p for interaction=0.05) and was statistically significant only in those 65 or older (relative risk [RR] 0.74 [95% CI, 0.59 to 0.92]).^83^ JPAD and POPADAD followed this pattern, but without statistical significance.^66,^ ^81^ Several trials reported a greater benefit among younger compared to older age groups for composite CVD outcomes, although the interaction tests were not significant and the confidence intervals overlapped.^55,^ ^56,^ ^69,^ ^70,^ ^101^ For example, ASPREE’s prespecified age analysis for its CVD composite outcome showed a nonsignificant interaction test (65-73 years: hazard ratio [HR] 0.81 [95% CI, 0.65 to 1.01]; ≥74 years: HR 1.03 [95% CI, 0.88 to 1.20]); p for interaction=0.09).^101^ Similarly, aspirin was not associated with a benefit for the CVD composite outcome for the overall population in ASPREE, of whom 97 percent were 70 or older (HR 0.95 [95% CI, 0.83 to 1.08]).^101^ There was no suggestion of a differential effect of aspirin for all-cause mortality in three trials,^70,^ ^91,^ ^101^ but only ASPREE reported prespecified analyses with interaction testing (p for interaction=0.66).

For MI, only the large WHS trial prespecified subanalyses by age (Appendix D, Table 5).^83^ WHS and one other trial, PHS, reported interaction testing. Both trials reported greater MI benefit in older age groups (interaction testing p=0.03 for WHS and 0.02 for PHS).^59,^ ^83^ JPPP reported rare MI events (<1%) with apparently greater benefit in the older age group, however no statistical testing was performed.^91,^ ^97^ In HOT, the older and younger age groups had similar point estimates.^70,^ ^79^

For stroke, only two trials^45,^ ^91^ reported interaction testing and only one trial^83^ had prespecified analyses. There were with no consistent patterns emerging for effect of aspirin on stroke by age (Appendix D, Table 6).^45,^ ^70,^ ^83,^ ^91,^ ^101^

Three trials reported CRC outcomes for different age groups, showing mixed results (Appendix D, Table 7).^83,^ ^101,^ ^103,^ ^131^ ASPREE, which solely recruited older adults (≥70 years or ≥65 years in Hispanic and Black participants), reported no difference in CRC incidence at 4.7 years of followup (HR 1.02 [95% CI, 0.81 to 1.30]) but an increase in CRC mortality in the aspirin group compared to the control group, also at 4.7 years of followup (HR 1.77 [95% CI, 1.02 to 3.06]).^101,^ ^131^ Two trials, WHS and JPAD, reported CRC incidence by age strata for their extended observational period.^83,^ ^103^ In both studies it was unclear whether analyses by age were prespecified and only WHS conducted interaction testing. In both WHS and JPAD, aspirin use was associated with a statistically significant reduction in CRC incidence in the youngest age strata only (WHS: HR 0.71 [95% CI, 0.52 to 0.98] at 17.5 years in women 45-54 years; JPAD: 0.41 [95% CI, 0.15 to 0.97] at 10.7 years for adults <65 years). However, interaction testing in WHS was not statistically significant (p=0.28) and in both studies, confidence intervals overlapped among age strata.^81,^ ^103^

#### Sex

##### Summary

Robust and credible trial-level data are available to evaluate whether there is a differential effect of aspirin by sex. These data offer no compelling evidence to support a differential treatment effect of aspirin on CVD composites, all-cause mortality, MI, stroke, or CRC outcomes. For within-study comparisons, interaction testing was not significant for any reported outcome when conducted. In cases when interaction testing was not conducted, confidence intervals overlapped for estimates in males and females.

##### Trial Characteristics

All thirteen primary prevention trials provide within-study comparisons of CVD or mortality outcomes by sex or were conducted in a single sex (Appendix D, Table 3). Four trials included participants of only a single sex. The largest trial, WHS, recruited more than 39,000 female health professionals.^83^ Three trials solely recruited men: PHS^59^ and BMD^82^ recruited healthy male health professionals and TPT recruited high CVD-risk men.^45^ The remaining nine trials included both sexes, with females comprising 30 to 72 percent of participants. Six trials performed prespecified subanalyses by sex^55,^ ^56,^ ^69,^ ^81,^ ^91,^ ^101^ and three reported sex-specific analyses where it was unclear whether analyses were a priori or post hoc.^64,^ ^66,^ ^68,^ ^70,^ ^79^ Interaction testing was performed in five trials.^55,^ ^56,^ ^66,^ ^81,^ ^101^

##### Results

Nine trials of both sexes and four single-sex trials report CVD composite outcomes by sex, providing no compelling evidence for a differential treatment effect by sex (Appendix D, Table 8). For within-study comparisons for composite CVD outcomes, interaction testing for heterogeneity of treatment effect was nonsignificant when conducted.^55,^ ^56,^ ^66,^ ^81,^ ^101^ In cases when interaction testing was not conducted, confidence intervals overlapped for estimates in males and females.^64,^ ^68–70,^ ^79,^ ^91^ The only trial reporting statistically significant results for any sex-specific analysis of the primary CVD composite was ASCEND in males only (RR 0.86 [95% CI, 0.77 to 0.96]), however confidence intervals overlapped with analyses in females (RR 0.92 [95% CI, 0.78 to 1.09]) and again, interaction testing was not significant (p=0.49).^55^

Of the nine trials including both sexes, three reported all-cause mortality by sex.^54,^ ^64,^ ^68,^ ^70,^ ^79,^ ^101^ There was no evidence for a differential effect in these trials, either based on interaction testing^54,^ ^101^ or comparison of confidence intervals.^64,^ ^68,^ ^70,^ ^79^ For the four trials solely recruiting a single sex, no pattern emerges for aspirin’s effect on CVD composite outcomes by sex. Point estimates for aspirin’s relative effect ranged from 0.76 to 0.99 in the all-male trials and was 0.91 in the all-female trial; all confidence intervals overlapped. For all-cause mortality, point estimates for aspirin’s relative effect ranged from 0.88 to 1.03 in the all-male trials and was 0.95 in WHS; again, all confidence intervals overlapped.

A smaller number of trials report MI outcomes by sex, but these data similarly offer no compelling evidence for modification of aspirin’s effect by sex (Appendix D, Table 9). Two trials recruiting both sexes^64,^ ^68,^ ^70,^ ^79^ and the four single sex trials^45,^ ^59,^ ^82,^ ^83^ reported MI outcomes by sex. Neither of the trials with participants of both sexes performed prespecified analysis and neither reported formal interaction testing.^64,^ ^68,^ ^70,^ ^79^ Both HOT and PPP reported point estimates for MIs reflecting a greater benefit seen in males with HOT reporting a statistically significant reduction in MI only in men, however, confidence intervals overlapped with the results for women. For the trials recruiting a single sex, point estimates for aspirin’s relative effect ranged from 0.56 to 0.96 in the three all-male trials and were statistically significant in two of three trials.^59,^ ^82^ In WHS, the point estimate was 1.02 and not statistically significant.^83^ Given the low MI event rates and overlapping confidence intervals, no conclusions can be made about aspirin’s treatment effects on MI by sex.

Two trials including both sexes^64,^ ^68,^ ^70,^ ^79^ and the four single sex-trials^45,^ ^59,^ ^82,^ ^83^ reported total stroke and ischemic stroke outcomes by sex, and this evidence does not support a differential effect of aspirin on stroke by sex (Appendix D, Table 10). Neither of the trials with the participants of both sexes performed prespecified analysis or interaction testing.^64,^ ^68,^ ^70,^ ^79^ HOT and PPP reported point estimates for total stroke and ischemic stroke, respectively, reflecting a greater benefit in women, however, confidence intervals overlapped, event rates were very low (<1%), and results were not statistically significant for either males or females in these individual trials. For the four trials recruiting a single sex, point estimates for ischemic stroke varied widely. In the three all-male trials, relative effects for aspirin ranged from 0.56 to 1.45, and none were statistically significant.^45,^ ^59,^ ^82^ In the one all-female trial, WHS, aspirin was associated with a statistically significant benefit (adjusted RR 0.76 [95% CI, 0.63 to 0.93]).^83^ Similar patterns were seen for the total stroke outcome.

Evidence for CRC-related outcomes by sex is limited to the four single-sex trials, providing no compelling evidence for a differential treatment benefit of aspirin by sex (Appendix D, Table 11).^45,^ ^59,^ ^82,^ ^83^ For the randomized trial periods, none of the trials reported statistically significant results for CRC incidence and the point estimates were largely overlapping, with estimates of Peto OR 0.96 (95% CI, 0.76 to 1.21) in WHS (10.3 years randomized followup), and Peto OR 1.15 (95% CI, 0.80 to 1.65) in PHS (5 years randomized followup). With trial plus observational followup periods included in the analyses, both the all-female WHS (17.5 year followup) and all-male BMD (at 20 year followup) yielded statistically significant results with reasonably consistent point estimates for CRC incidence of 0.80 and 0.70, respectively. The CRC incidence effect in WHS was attenuated by the 26-year observational followup (Peto OR 0.87 [95% CI, 0.74 to 1.02]). The all-male PHS showed nonsignificant association of aspirin with CRC incidence at 12 years (IRR 1.03 [95% CI, 0.83 to 1.28]). CRC mortality at 17-18 years in WHS, BMD and TPT was reported with ORs of 0.86^49^, 0.72^82^ and 0.62^45^ but only TPT showed a statistically significant benefit for their trial plus post-trial observational followup at 18.3 years (Peto OR 0.62 [95% CI, 0.41 to 0.94]). At 26 years of observational followup, WHS reported a nonstatistically significant effect on CRC mortality (Peto OR 0.96 [95% CI, 0.74 to 1.24])

#### Race and Ethnicity

##### Summary

Evidence for the effect of aspirin by race and ethnicity is very sparse, and these limited data suggest no differential effect. Only one trial, ASPREE, reported outcomes by race and ethnicity; these were prespecified analyses with interaction testing. For both composite CVD outcomes and all-cause mortality, confidence intervals were wide and overlapping for White, Black, and Hispanic participants, and individuals of other races with nonstatistically significant interaction testing. There are no trials reporting CRC outcomes by race. There are insufficient data to make conclusions about any differential effects of aspirin for CVD-related mortality or CRC outcomes based on race or ethnicity.

##### Trial Characteristics

Only four trials report participant race or ethnicity.^55,^ ^56,^ ^83,^ ^101^ In these trials, participants were almost exclusively White, with proportions ranging from 91 to 98 percent.

##### Results

ASPREE’s prespecified analyses reported results by race and ethnicity, showing nonsignificant heterogeneity testing for both the CVD composite outcome (p for interaction=0.86) and all-cause mortality (p for interaction=0.19) (Appendix D, Table 12).^54,^ ^101^

#### Diabetes

##### Summary

There is no compelling evidence to suggest that aspirin has a differential effect on CVD outcomes based on diabetes status. Subgroup analyses were of limited credibility in that they were not prespecified in most trials, and few performed interaction testing. Moreover, results were conflicting in the rare presence of interaction testing. Confidence intervals consistently overlapped in estimates of aspirin’s effect on outcomes in participants with and without diabetes, with estimates most commonly being nonsignificant in subgroup analyses. There is scant information from only a single trial in participants with diabetes showing that aspirin has no significant effect on CRC incidence in this population.

##### Trial Characteristics

All but one trial^45^ reported diabetes comorbidity (Table 8). One trial excluded participants with diabetes,^56^ five trials included <10 percent of participants with diabetes at baseline;^59,^ ^69,^ ^70,^ ^82,^ ^83^ three trials reported 11 to 34 percent with diabetes comorbidity;^64,^ ^91,^ ^101^ and three trials were exclusively conducted in those with diabetes.^55,^ ^66,^ ^81^ One of these trials, ASCEND, is newly published since the last review.^55^

Trials providing analyses by diabetes status included the three trials solely recruiting participants with diabetes^55,^ ^66,^ ^81^ and an additional 6 trials that performed subgroup analyses on patients with and without diabetes.^59,^ ^64,^ ^70,^ ^83,^ ^91,^ ^101^

##### Results

Eight trials^55,^ ^64,^ ^66,^ ^70,^ ^80,^ ^81,^ ^83,^ ^91,^ ^101,^ ^126^ reported results for composite CVD outcomes or all-cause mortality for participants with diabetes (Appendix D, Table 13). Three of these trials solely recruited patients with diabetes,^55,^ ^66,^ ^81^ three trials^83,^ ^91,^ ^101^ reported diabetes as an a priori subanalysis and two trials had post-hoc or unclear timing of their analyses.^64,^ ^70,^ ^80,^ ^126^ Only two trials performed interaction testing,^64,^ ^101^ showing mixed results. One of these trials^64,^ ^126^ with post-hoc analysis reported a differential effect of aspirin on CVD mortality, where participants without diabetes had a statistically significant reduction (RR 0.32 [95% CI, 0.14 to 0.72]) and results were not significant in participants with diabetes (RR 1.23 [95% CI, 0.49 to 3.10]; p for interaction=0.03).

In the other trial with interaction testing where analyses were prespecified,^101^ there was no signal of effect modification by diabetes status for the primary CVD composite outcome (p for interaction=0.74). Of the three trials conducted solely in individuals with diabetes, only one^55^ reported a statistically significant effect for their primary composite that included TIA (RR 0.88 [95% CI, 0.79 to 0.97]) however, when TIA was excluded, the results were no longer statistically significant. The remaining two trials in individuals with diabetes reported nonstatistically significant results for their study-defined primary CVD composites (POPADAD: HR 0.98 [95% CI, 0.76 to 1.26]; JPAD: HR 0.80 [95% CI, 0.58 to 1.10]).^66,^ ^81^ In all five trials reporting within-study comparisons of CVD composite outcomes by diabetes status, confidence intervals for aspirin effects in those with and without diabetes overlapped.^64,^ ^70,^ ^80,^ ^83,^ ^91,^ ^101,^ ^126^ The three trials conducted solely in individuals with diabetes showed no statistically significant effect of aspirin on all-cause mortality.^55,^ ^66,^ ^81^ Three trials reporting within-trial comparisons for all-cause mortality^54,^ ^64,^ ^70,^ ^80,^ ^101,^ ^126^ by diabetes status similarly showed no significant effect of aspirin for individuals with or without diabetes; confidence intervals overlapped for all within-study comparisons and interaction testing was nonsignificant in the one trial reporting this testing.^54,^ ^101^

Seven trials^55,^ ^59,^ ^64,^ ^66,^ ^70,^ ^81,^ ^83^ reported results for MI events for participants with diabetes (Appendix D, Table 14). Only one trial prespecified their subgroup analysis^83^ and two trials reported interaction testing,^59,^ ^83^ with both finding no differential effect of aspirin on MI outcomes based on diabetes status (PHS: p for interaction=0.22; WHS: NS [value not reported]). Other trials reporting within-study comparisons of those with and without diabetes showed overlapping confidence intervals for the effect of aspirin.^64,^ ^70,^ ^80,^ ^126^ All trials solely recruiting individuals with diabetes reported nonsignificant effects of aspirin on MI with point estimates ranging from Peto ORs of 0.87 to 1.11.^55,^ ^66,^ ^81^

Six trials^55,^ ^64,^ ^66,^ ^70,^ ^80,^ ^81,^ ^83,^ ^126^ reported results for total stroke for participants based on diabetes status (Appendix D, Table 15). Only one trial^83^ was a prespecified analysis and performed interaction testing; this trial reported nonsignificant interaction of effect by diabetes status (p for interaction =NS, value not reported). In WHS, there was a statistically significant reduction in stroke for participants with diabetes (RR 0.46 [95% CI, 0.25 to 0.85]) that was not significant for participants without diabetes (RR 0.87 [95% CI, 0.72 to 1.05]) but confidence intervals overlapped.^83^

JPAD, conducted exclusively in individuals with diabetes, reported CRC outcomes (Appendix D, Table 16).^81^ This trial showed no significant effect of aspirin on CRC incidence at 5 years followup (HR 0.92 [95% CI, 0.55 to 1.55]).

#### Estimated CVD Risk

##### Summary

There is no compelling evidence to suggest that the relative effect of aspirin on CVD outcomes is modified by baseline CVD risk. Six trials provided evidence by estimated CVD risk strata; four were prespecified analyses and five performed interaction testing. Each trial used a different CVD risk calculator and different risk thresholds. Interaction testing was nonsignificant for all outcomes, and confidence intervals by risk strata were consistently overlapping. These analyses have limited applicability in the context of current clinical practice in that no trials reported results for CVD risk strata defined by the Pooled Cohort Equations and one used a published Framingham CHD-only calculator; others were study-derived scores not available or validated for use in clinical practice.

##### Trial Characteristics

Populations included in aspirin primary prevention trials include a wide range of baseline CVD risk with several trials recruiting participants with one or more individual CVD risk factors or moderate-to-high 10-year CVD risk scores. Six trials^55,^ ^56,^ ^70,^ ^77,^ ^81,^ ^83,^ ^91,^ ^95^ reported results in populations defined by 5- to-10-year CVD risk strata (Appendix D, Table 3). These trials used a variety of risk calculators to define CVD risk. Most of the risk calculators were study-specific and not used in clinical practice; only one study^83^ reported results by Framingham 10-year CHD-only risk score, and no studies reported risk strata using the Pooled Cohort Equations (Appendix D, Table 17). These analyses by CVD risk strata were prespecified in four trials, including WHS, which used Framingham.^55,^ ^56,^ ^83,^ ^91^ The timing of analyses in HOT and JPAD were unclear.^70,^ ^77,^ ^81,^ ^95^

##### Results

Overall, six trials reported their primary composite CVD outcomes by CVD risk score strata (Appendix D, Table 17).^55,^ ^56,^ ^70,^ ^77,^ ^81,^ ^83,^ ^91,^ ^95^ The four prespecified^55,^ ^56,^ ^83,^ ^91^ and two unspecified^70,^ ^77,^ ^81,^ ^95^ subanalyses all reported overlapping confidence intervals for composite CVD outcomes. Interaction testing was not significant in all five trials conducting such analyses,^55,^ ^56,^ ^70,^ ^77,^ ^81,^ ^83,^ ^95^ suggesting that aspirin has no differential treatment effect on composite CVD outcomes based on CVD risk score strata. The individual CVD outcomes of MI and stroke showed similar findings (Appendix D, Tables 18 and 19). One prespecified analysis^83^ and one unspecified analysis^77^ reported overlapping confidence intervals for MI based on CVD risk and nonsignificant interaction testing. Outcomes for stroke by risk strata are limited to WHS’ prespecified analyses of total stroke and ischemic stroke, both showing overlapping confidence intervals and nonsignificant interaction testing.

#### Other Specific Populations

We audited the included trials for data addressing other specific populations and concluded that there was insufficient evidence for synthesis as only 1-2 trials reported CVD or CRC outcomes for any other specific populations.

## KQ2 Does Regular Aspirin Use Increase Major Gastrointestinal Bleeding, Intracranial Bleeding, or Other Serious Harms?

KQ2a Does the Effect Vary in Specific a Priori Populations Defined by Age, Sex, 10-Year Cardiovascular Risk, Diagnosis of Diabetes Mellitus, Race/Ethnicity, or Bleeding Risk Factors?
KQ2b Does the Effect Vary by Dose or Duration of Aspirin Use?

### Summary of Results

There are three new trials^55,^ ^56,^ ^101^ and three new cohorts^98,^ ^106,^ ^107^ published since the previous reviews on this topic.^2–4^

Aspirin at doses of 50 to 500 mg/day is associated with a 57 percent increase in major GI bleeding (k=12, N=146,340; Peto OR, 1.57 [95% CI, 1.37 to 1.78]; I^2^=37.2%) (Table 5). Low-dose aspirin of 100 mg/day or less is associated with a similar increase in major GI bleeding (k=10, N=119,130; Peto OR, 1.58 [95% CI, 1.38 to 1.80]; I^2^=25.5%). Aspirin at doses of 50 to 500 mg daily is also associated with a 22 percent increase in hemorrhagic stroke (k=12, N=160,404; Peto OR, 1.23 [95% CI, 1.01 to 1.48]; I^2^=0), however sensitivity analyses restricted to low-dose trials did not yield a statistically significant association between low-dose aspirin and hemorrhagic stroke (k=10, N=133,194; Peto OR, 1.18 [95% CI, 0.97 to 1.45]; I^2^=0.0%). Hemorrhagic strokes were rare events so there is uncertainty in estimates. Pooled estimates for intracranial hemorrhage—a broader outcome including subarachnoid hemorrhage and subdural hemorrhage in addition to hemorrhagic stroke—yielded a statistically significant 33 percent increase in events in the aspirin group for all doses and a similar statistically significant finding for low-dose aspirin ≤100 mg/day (k=11, N= 134,470; Peto OR 1.31 [95% CI, 1.11 to1.54]; I^2^=0%).

Cohorts were included to explore whether harms associated with aspirin were similar in studies with broader populations and larger sample sizes, which may be better able to detect rare events for serious harms (Table 13). Similar to trial evidence, there was a wide range of absolute event rates of serious harm and similar relative increases in major gastrointestinal bleeding, intracranial hemorrhage and hemorrhagic stroke associated with aspirin. Exploration of observational studies by dose was limited because many of the studies reported bleeding harms for participants using a range of doses.

Table 13 Key Question 2: Characteristics of Cohorts Included for Harms

Study name, Author, year, Quality rating | Country | Mean F/U | Population inclusion and exclusion | N | Mean age (range), years | % Female | % DM | % Current smokers | ASA Dose & Duration | Indication
De Berardis, 2012^117^; Good | ITA | 5.7 | Included: New users of low-dose ASA (≤300 mg) during the index period; aged ≥30 years on index date with no prescription for ASA in the past year; current users those who had the last ASA prescription filled ≤75 days before hospitalization for major bleeding events; Excluded: Aged <30 years or >95 years, former ASA user (i.e., last ASA prescription ≥75 days before event) and those with DM treated prior to cohort entry but without antidiabetic prescription during study period | 372,850 | 69 (30-95) | 53 | 15 | NR | ≤300 mg 5.7 (median) | ASA for the prevention of CVD is available to all citizens at high CVD risk only by prescription and is free of charge so assuming CVD prevention indication.
HPFS; Huang, 2010^120^; Fair | US | 11.4 | Included: Male health professionals who returned 1994 questionnaire on ASA use; Excluded: Males with a prior history of GIB, cancer or peptic ulcer disease | 32,989 | 61 (NR) | 0 | 5 | 5 | 81-325 mg QD^*^; NR | Assessed only in subsample of 211 men. Indications were CVD, 25.4%; to decrease risk for CVD, 58.4%; headaches, 25.4%; joint or musculoskeletal pain, 33.0%; and other reasons, 7.0%.
Korean National Health Insurance Service-Senior Cohort Jung, 2020^107^; Fair | KOR | 7.8 | Included: Males and females; aged 60–90 years; newly diagnosed with HTN, type 2 DM, or dyslipidemia; Excluded: Patients with a history of IHD, stroke, or heart failure before their index dates; patients with a history of hemorrhagic events, coagulation defects; peptic ulcer diseases, or severe diseases, including end-stage renal disease or end-stage liver disease before enrollment | 13,455 | 71 (60-90) | 58 | 18 | 4 | NR (“low-dose”); 4.8 years | Newly started receiving ASA based on prescribing records, ASA prescriptions were given to those with CVD risk factors and authors state that this prescription was covered through national health insurance, so assuming CVD prevention indication.
NHIRD; Chen, 2017^106^; Fair | TWN | 1 | Included: New low-dose ASA (75-325 mg daily) users age ≥20 years; Excluded: Active GIB at enrollment; malignant tumor of the GI tract; disease associated with alcohol; inflammatory bowel disease radiation gastroenteritis or colitis; intestinal vascular insufficiency; coagulopathy before low-dose ASA use^†^ | 322,830 | 41 (20-80+) | 49 | 0.3 | NR | 75-325 mg daily; 1 year | Unclear
NHIRD; Luo, 2019^98^; Fair | TWN | 10 (mean 2.55 years; range 0.08-10.96 years) | Included: Males and females age >20 years, taking ASA with an average dose more than 14 defined daily dose per month; Excluded: Malignancy of the GI tract, alcohol-related diseases, inflammatory bowel disease, coagulopathy, vascular insufficiency of the intestine, gastroenteritis or colitis due to radiation, and nonvariceal UGIB^‡^ | 22,210 | 64 (20+) | 47 | 24 | NR | “Average dose more than 14 defined daily dose per month.”; 2.55 years | Unclear
NHS; Huang, 2011^121^; Fair | US | 24 | Included: Female registered nurses, aged 30-55 years in 1976 who returned in 1990 ASA questionnaire; Excluded: Prior history of GIB, cancer, peptic ulcer disease, bleeding related to cancer or polypectomy, or without a date of bleeding diagnosis | 87,680 | 57 (NR) | 100 | 5 | 18 | 325 mg QD^§^; 24 years | Assessed only in subsample of the cohort taking 1 to 6 ASA/wk and ≥7 ASA/wk: headache (32% and 18%, respectively); arthritis/musculoskeletal pain (46% and 65%); CVD prevention (9% and 8%); and other reasons (13% and 9%).
SNDR; Ekstrom, 2013^118^; Fair | SWE | 3.9 | Included: Patients with type 2 DM, age 30–80 years, and with data available for all analyzed variables at baseline in 2006; Excluded: History of CVD, cancer or bleeding; taking ASA dose other than 75 mg/day; BMI <18 and/or plasma Cr >150 umol/L; incomplete records; taking other anticoagulant drugs (except ASA), cardiac glycosides, or organic nitrates, history of CHD, CABG, PCI, stroke including cerebral bleeding, CHF, AFib, PVD, amputation, renal failure, GI ulcer; ventricular, respiratory, other bleeding | 18,646 | 62 (30-80) | 45 | 100 | 15 | 75 mg QD; >12 months | Assumed primary prevention based on study aims, use of national prescription data for ASA, and a DM quality assurance register

* Regular users defined as 2 or more times per week

† ICD9-CM codes: Active GIB at enrollment; malignant tumor of the GI tract (150.xx, 151.xx, 152.xx, 153.xx, 154.xx); disease associated with alcohol (291.xx, 303.xx, 305.xx, 571.0, 571.1, 571.2, 571.3); inflammatory bowel disease (556.x, 555.x); radiation gastroenteritis or colitis (558.1); intestinal vascular insufficiency (557.xx); coagulopathy (286.xx) before low-dose ASA use

‡ ICD9-CM codes: Malignancy of the GI tract (150.xx, 151.xx, 152.xx, 153.xx, and 154.xx); alcohol-related diseases (291.xx, 303.xx, 305.xx, 571.0, 571.1, 571.2, and 571.3); inflammatory bowel disease ((556.x and 555.x); coagulopathy ((286.xx); vascular insufficiency of the intestine (557.xx); gastroenteritis or colitis due to radiation (558.1); and nonvariceal UGIB (530.7, 530.82, 531.0, 531.00, 531.01, 531.2531.2x, 531.4, 531.4x, 531.6531.6x, 532.0, 532.00, 532.01, 532.2532.2x, 532.4, 532.4x, 32.6532.6x, 533.0, 533.00, 533.01, 33.2533.2x, 533.4, 533.4x, 533.6533.6x, 534.0, 534.00, 534.01, 534.2534.2x, 534.4, 534.4x, 534.6534.6x, 535.x1, 537.83, 537.84, and 578.0.)

§ Early in the study most participants used 325 mg tablets; based on changes in secular trends, questionnaires after 1992 asked participants to convert intake of 4 baby aspirin into one tablet

Abbreviations: Afib = atrial fibrillation; ASA = aspirin; BMI = Body Mass Index; CABG = coronary artery bypass grafting; CHD = Coronary heart disease; CHF = Coronary Heart Failure; CM = Clinical Modification; Cr = creatine; CVD = Cardiovascular Disease; D = day; DM = diabetes mellitus; F/U = followup; g = grams; GI = gastrointestinal; GIB = gastrointestinal bleeding; HPFS = Health Professionals Followup Study’ HTN = hypertension; ICD = International Classification of Diseases; IHD= Ischemic Heart Disease; ITA = Italy; KOR = Korea; mg = milligrams; n = number of participants; NHIRD = National Health Insurance Research Database; NHS = Nurses’ Health Study; NR = not reported; PCI = percutaneous coronary intervention; PVD = peripheral vascular disease; Q = every; SNDR = Swedish National Diabetes Register; SWE = Sweden; UGIB = upper GI bleeding; umol/L = micromole per liter; US = United States; TWN = Taiwan; wk = week

We also examined whether the relative effect of aspirin varied in prespecified specific populations or by the duration of use. There is no convincing data to suggest that aspirin has a differential bleeding risk based on age, sex, diabetes, estimated CVD risk, or race and ethnicity. Few trials report bleeding events in specific populations and due to the rare occurrence of total bleeding events in the trials, conclusions are limited by this scant evidence base. Regarding duration of use, few trials (4 of 14) reported time-to-event analyses, limiting examination of harms by this variable. Examining Kaplan-Meier curves, it appears that the bleeding harms occur immediately or at about 1 year of aspirin use.

### Detailed Results for Trials

Fourteen RCTs in CVD primary prevention populations reported one or more bleeding harms of interest: total major bleed (defined as a composite of intracranial hemorrhage, major GI bleeding, or major bleeding from other sites), major GI bleed (defined as a GI bleed that required a transfusion, hospital admission, or resulted in death), extracranial bleed (defined as major bleeding that was not intracranial), hemorrhagic stroke, and intracranial bleeding (defined as hemorrhagic stroke or other major intracranial bleeds).^45,^ ^55,^ ^56,^ ^59,^ ^64,^ ^66,^ ^69,^ ^70,^ ^81–83,^ ^91,^ ^101,^ ^127,^ ^130^ These trials include the 13 primary prevention RCTs included for KQ1 and an additional pilot RCT that reported major GI bleeding. These trials used doses ranging from 100 mg every other day to 500 mg daily.

#### Effect of Aspirin on Total Major Bleed

Twelve trials (N=160,404) reported serious bleeding complications allowing calculation of total major bleeding events.^45,^ ^55,^ ^56,^ ^59,^ ^64,^ ^69,^ ^70,^ ^81–83,^ ^91,^ ^101,^ ^130^ There was a statistically significant increase in total major bleeds associated with aspirin use (Peto OR, 1.45 [95% CI, 1.33 to 1.58]; I^2^=12.1%) with similar results seen in the low-dose trials (k=10; N=133,194; Peto OR, 1.44 [95% CI, 1.32 to 1.57]; I^2^=4.7%) (Figure 25 and Table 5). For the analysis using all doses, absolute differences ranged from −0.1 to 1.0 percent (Table 6). Although there was variation amongst the trials in what is included in this composite, in order to maximize number of trials pooled, we used any major bleeding events reported in those trials.

Figure 25 Key Question 2: Pooled Analysis of Total Major Bleed Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 25 displays a pooled analysis of total major bleed risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

#### Effect of Aspirin on Extracranial Bleed

Twelve trials (N=160,404) reported serious bleeding complications allowing calculation of extracranial bleeding events.^45,^ ^55,^ ^56,^ ^59,^ ^64,^ ^69,^ ^70,^ ^81–83,^ ^91,^ ^101,^ ^130^ There was a statistically significant increase in extracranial bleeds associated with aspirin use (Peto OR, 1.53 [95% CI, 1.39 to 1.69]; I^2^=66.2%) with similar results seen in the low-dose trials (k=10; N=133,194; Peto OR, 1.53 [95% CI, 1.39 to 1.70]; I^2^=67.4%) (Figure 26 and Table 14). For the analysis using all doses, absolute differences ranged from −0.1 to 0.9 percent (Table 6).

Figure 26 Key Question 2: Pooled Analysis of Extracranial Bleed Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 26 displays a pooled analysis of extracranial bleed risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

Table 14 Key Question 2: Effect of Aspirin on Extracranial Bleeding as Variably Defined in Randomized, Controlled Trials

Study name; Author, year | Mean F/U, years | Outcome | IG n/n analyzed | CG n/n analyzed | Peto OR (95% CI)
AAA; Fowkes, 2010^69^ | 8.2 | Extracranial hemorrhage | 23/1675 | 13/1675 | 1.75 (0.91, 3.38)
ARRIVE; Gaziano, 2018^56^ | 5; (median) | Total GI bleed | 19/6270 | 7/6276 | 2.52 (1.17, 5.45)
ASCEND; ASCEND Study Collaborative, 2018^55^ | 7.4 | Extracranial hemorrhage | 268/7740 | 208/7740 | 1.30 (1.08, 1.56)
ASPREE; McNeil, 2018^101^ | 4.7 | Extracranial hemorrhage | 270/9525 | 200/9589 | 1.37 (1.14, 1.64)
BMD; Peto, 1988^82^ | 6 | Total GI bleed | 1/3429 | 3/1710 | 0.15 (0.02, 1.22)
HOT; Hanson, 1998^70^ | 3.8 | Extracranial hemorrhage | 122/9399 | 41/9391 | 2.72 (2.00, 3.71)
JPAD; Ogawa, 2008^81^ | 4.37; (median) | GI bleeding requiring transfusion | 4/1262 | 0/1277 | 7.50 (1.05, 53.27)
JPPP; Ikeda, 2014^91^ | 5; (median) | Extracranial bleeding requiring transfusion or hospitalization | 62/7220 | 34/7244 | 1.80 (1.21, 2.70)
PHS; Physician’s Health Study, 1989^59^ | 5 | Bleeding requiring transfusion or hospitalization | 48/11037 | 28/11034 | 1.70 (1.08, 2.66)
PPP; Rongaclioni, 2001 | 3.6 | Extracranial hemorrhage | 22/2226 | 6/2269 | 3.22 (1.53, 6.77)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | 6.8; (median) | Total major bleeds | 11/1268 | 6/1272 | 1.81 (0.70, 4.71)
WHS; Ridker, 2005^83^ | 10.1 | Total GI bleed | 129/19934 | 94/19942 | 1.37 (1.05, 1.78)

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; F/U = followup; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; PHS = Physician’s Health Study; n = number of participants; OR = odds ratio; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

#### Effect of Aspirin on Major GI Bleed

Pooled analysis from 12 trials (N=146,340) showed that aspirin is associated with an increase in major GI bleeds (Peto OR, 1.57 [95% CI, 1.37 to 1.78]; I^2^=37.2%) (Figure 27 and Table 15). Eleven of 12 trials report point estimates for GI bleeding associated with aspirin use that were greater than 1,^45,^ ^55,^ ^56,^ ^59,^ ^64,^ ^69,^ ^70,^ ^81,^ ^83,^ ^91,^ ^101^ and seven were statistically significant.^55,^ ^56,^ ^64,^ ^70,^ ^81,^ ^83,^ ^101^ Sensitivity analyses showed similar results for low-dose aspirin (k=10; N=119,130; Peto OR, 1.58 [95% CI, 1.38 to 1.80]; I^2^=25.5%). However, the two high-dose trials had extremely rare events with four total events in BMD^82^ and one event in PHS,^59^ so estimates in the trials are unstable. Five trials reported fatal GI bleeding, showing extremely rare outcomes so data were not pooled.^59,^ ^70,^ ^82,^ ^83,^ ^101^

Figure 27 Key Question 2: Pooled Analysis of Major GI Bleed Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; GI = gastrointestinal; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 27 displays a pooled analysis of major GI bleed risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

Table 15 Key Question 2: Effect of Aspirin on Major GI Bleeding in Randomized, Controlled Trials

Study name; Author, year | Mean F/U, years | Outcome | IG n/n analyzed | CG n/n analyzed | Peto OR (95% CI)
AAA; Fowkes, 2010^69^ | 8.2 | Major GI bleed | 9/1675 | 8/1675 | 1.13 (0.43, 2.92)
ARRIVE; Gaziano, 2018^56^ | 5; (median) | Major GI bleed | 19/6270 | 7/6276 | 2.52 (1.17, 5.45)
ASCEND; ASCEND Study Collaborative, 2018^55^ | 7.4 | Major GI bleed | 137/7740 | 101/7740 | 1.36 (1.05, 1.76)
ASPREE; McNeil, 2018^101^ | 4.7 | Major GI bleed | 158/9525 | 99/9589 | 1.60 (1.25, 2.05)
ASPREE Pilot; Silagy, 1993^127^ | 1 | Major GI bleed | 1/200 | 0/200 | 7.39 (0.15, 372.38)
BMD; Peto, 1988^82^ | 6 | Fatal GI bleed^*^ | 1/3429 | 3/1710 | 0.15 (0.02, 1.22)
HOT; Hanson, 1998^70^ | 3.8 | Major GI bleed | 77/9399 | 37/9391 | 2.02 (1.40, 2.93)
JPAD; Ogawa, 2008^81^ | 4.37; (median) | Major GI bleed | 4/1262 | 0/1277 | 7.50 (1.05, 53.27)
PHS; Physician’s Health Study, 1989^59^ | 5 | Fatal GI bleed | 1/11037 | 0/11034 | 7.39 (0.15, 372.28)
PPP; Rongaclioni, 2001 | 3.6 | Major GI bleed | 17/2226 | 5/2269 | 3.05 (1.32, 7.05)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | 6.8; (median) | Major GI bleed | 6/1268 | 2/1272 | 2.73 (0.68, 10.95)
WHS; Ridker, 2005^83^ | 10.1 | Major GI bleed | 129/19934 | 94/19942 | 1.37 (1.05, 1.78)

* Includes fatal gastric hemorrhage and fatal hemorrhagic peptic. Does not include perforated ulcer.

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; F/U = followup; GI = gastrointestinal; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; PHS = Physician’s Health Study; n = number of participants; OR = odds ratio; p-y = person-years; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

#### Effect of Aspirin on Peptic Ulcer

Seven trials reported a consistently higher rate of upper GI ulcer events in the aspirin compared to the control groups, although the location and severity of the reported ulcer events varied (Table 16).^59,^ ^69,^ ^81–83,^ ^91,^ ^127^ PHS and WHS reported statistically significantly higher upper GI ulcers or peptic ulcers in the aspirin compared to the control group while the other trials reported few ulcer events without statistical testing, but trends confirmed the PHS and WHS findings.

Table 16 Key Question 2: Effect of Aspirin on Peptic Ulcers in Randomized, Controlled Trials

Study name; Author, year | Mean F/U, years | Outcome | IG n/n analyzed | CG n/n analyzed | Relative Comparison (95% CI)
AAA; Fowkes, 2010^69^ | 8.2 | GI ulcer | 14/1675 | 8/1675 | NR
ASPREE (pilot); Silagy, 1993^127^ | 1 | Duodenal ulcer | 2/200 | 0/200 | NR
ASPREE (pilot); Silagy, 1993^127^ | 1 | Deep bleeding duodenal ulcer | 1/200 | 0/200 | NR
BMD; Peto, 1988^82^ | 6 | Fatal hemorrhagic peptic ulcer | 0.0/10,000 p-y | 3.2/10,000 p-y | NR
BMD; Peto, 1988^82^ | 6 | Nonfatal peptic ulcer | 46.8/10,000 p-y | 29.6/10,000 p-y | NR; p<0.05
BMD; Peto, 1988^82^ | 6 | Fatal perforated peptic ulcer | 2/3429 | 0/1710 | NR
JPAD; Ogawa, 2008^81^ | 4.37; (median) | Nonhemorrhagic duodenal ulcer | 1/1262 | 1/1277 | NR
JPAD; Ogawa, 2008^81^ | 4.37; (median) | Nonhemorrhagic gastric ulcer | 17/1262 | 3/1277 | NR
JPAD; Ogawa, 2008^81^ | 4.37; (median) | Hemorrhagic gastric ulcer | 5/1262 | 3/1277 | NR
JPPP; Ikeda, 2014^91^ | 5; (median) | Gastroduodenal ulcer | 191/7323 | 91/7335 | NR
PHS; Physician’s Health Study, 1989^59^ | 5 | Hemorrhagic ulcer | 38/11037 | 22/11034 | Adj RR: 1.77 (1.07, 2.94); p=0.04
PHS; Physician’s Health Study, 1989^59^ | 5 | Upper GI ulcer | 169/11037 | 138/11034 | Adj RR: 1.22 (0.98, 1.53); p=0.08
WHS; Ridker, 2005^8^ | 10.1 | Peptic ulcer | 542/19934 | 413/19942 | Adj RR: 1.32 (1.16, 1.50); p<0.001

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; adj = adjusted; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CI = confidence interval; F/U = followup; GI = gastrointestinal; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; p-y = person-years; PHS = Physician’s Health Study; SNDR = Swedish National Diabetes Register; WHS = Women’s Health Study

#### Effect of Aspirin on Intracranial Bleed

Pooled data from 13 trials (N=161,680) showed an increase in intracranial bleeds in the aspirin compared to the control group (Peto OR, 1.33 [95% CI, 1.13 to 1.56]; I^2^=0%) (Figure 28 and Table 17). Sensitivity analysis of 11 low-dose trials (N=134,470) yielded similar results (Peto OR, 1.31 [95% CI, 1.11 to 1.54]; I^2^=0%). For the analysis using all doses, absolute differences ranged from −0.2 to 0.4 percent (Table 6).

Figure 28 Key Question 2: Pooled Analysis of Total Intracranial Bleed Risk, Aspirin Compared With Placebo, Stratified by Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 28 displays a pooled analysis of total intracranial bleed risk, aspirin compared with placebo, stratified by dose and sorted by trial end year.

Table 17 Key Question 2: Effect of Aspirin on Intracranial Bleeding in Randomized, Controlled Trials

Study name; Author, year; Quality | Mean F/U, years | Outcome | IG n/n analyzed | CG n/n analyzed | Peto OR (95% CI)
AAA; Fowkes, 2010^69^ | 8.2 | Intracranial bleeding | 11/1675 | 7/1675 | 1.08 (0.42, 2.81)
ARRIVE; Gaziano, 2018^56^ | 5; (median) | Total hemorrhagic stroke^*^ | 8/6270 | 11/6276 | 1.88 (0.97, 3.64)
ASCEND; ASCEND Study Collaborative, 2018^55^ | 7.4 | Total intracranial hemorrhage | 55/7740 | 45/7740 | 1.50 (0.26, 8.66)
ASPREE; McNeil, 2018^101^ | 4.7 | Intracranial bleeding | 107/9525 | 72/9589 | 0.93 (0.45, 1.93)
BMD; Peto, 1988^82^ | 6 | Total hemorrhagic stroke^*^ | 13/3429 | 6/1710 | 1.36 (0.31, 5.98)
HOT; Hanson, 1998^70^ | 3.8 | Total hemorrhagic stroke^*^ | 14/9399 | 15/9391 | 1.24 (0.83, 1.87)
JPAD; Ogawa, 2008^81^ | 4.37; (median) | Intracranial bleeding | 8/1262 | 7/1277 | 0.67 (0.12, 3.87)
JPPP; Ikeda, 2014^91^ | 5; (median) | Total intracranial hemorrhage | 52/7220 | 36/7244 | 1.16 (0.42, 3.19)
PHS; Physician’s Health Study, 1989^59^ | 5 | Total hemorrhagic stroke^*^ | 23/11037 | 12/11034 | 1.56 (0.62, 3.95)
POPADAD; Belch, 2008^66^ | 6.7; (median) | Fatal hemorrhagic stroke^*^ | 2/638 | 3/638 | 1.22 (0.83, 1.81)
PPP; Rongaclioni, 2001^64^ | 3.6 | Intracranial bleeding | 4/2226 | 3/2269 | 1.45 (0.95, 2.20)
TPT; The Medical Research Council’s General Practice Research Framework, 1998^45^ | 6.8; (median) | Total hemorrhagic stroke^*^ | 3/1268 | 2/1272 | 0.73 (0.30, 1.79)
WHS; Ridker, 2005^83^ | 10.1 | Total hemorrhagic stroke^*^ | 51/19934 | 41/19942 | 1.49 (1.11, 2.01)

* Includes neurological deficits as a result of intracerebral hemorrhage and subarachnoid hemorrhage.

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; F/U = followup; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; PHS = Physician’s Health Study; n = number of participants; OR = odds ratio; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

#### Effect of Aspirin on Total Hemorrhagic Stroke

Pooled analysis of 12 trials (N=160,404) showed that aspirin is associated with an increase in total hemorrhagic stroke (Peto OR, 1.23 [95% CI, 1.01 to 1.48]; I^2^=0) (Figure 29). Individual trials reported wide confidence intervals all crossing 1.0, reflecting the rarity of hemorrhagic stroke events (0.13% to 0.55% in control groups). Five of the 12 trials showed point estimates less than 1 and seven trials showed estimates greater than 1 with no single trial reporting statistically significant results. Sensitivity analysis pooling 10 low-dose aspirin trials (N=133,194) did not yield statistically significant results (Peto OR, 1.18 [95% CI, 0.97 to 1.45]; I^2^=0).

Figure 29 Key Question 2: Pooled Analysis of Total Hemorrhagic Stroke^*^ * Includes neurological deficits as a result of intracerebral hemorrhage and subarachnoid hemorrhage. Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ARRIVE = Aspirin to Reduce Risk of Initial Vascular Events; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; PPP = Primary Prevention Project; TPT Thrombosis Prevention Trial; WHS = Women’s Health Study

Figure 29 displays a pooled analysis of total hemorrhagic stroke risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

#### Effect of Aspirin on Fatal Hemorrhagic Stroke

Pooled analysis of nine trials (N=102,223) did not demonstrate a statistically significant association between aspirin and fatal hemorrhagic stroke (Peto OR, 1.06 [95% CI, 0.73 to 1.54]; I^2^=0) (Figure 30). Likewise, sensitivity analyses using only low-dose aspirin trials did not yield statistically significant results. Event rates were exceedingly rare (0.02% to 0.47% in control groups) making estimates unstable.

Figure 30 Key Question 2: Pooled Analysis of Fatal Hemorrhagic Stroke^*^ * Includes neurological deficits as a result of intracerebral hemorrhage and subarachnoid hemorrhage. Risk, Aspirin Compared With Placebo, Stratified by Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; CVD = cardiovascular disease; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study; POPADAD = The Prevention of Progression of Arterial Disease and Diabetes trial

Figure 30 displays a pooled analysis of fatal hemorrhagic stroke risk, aspirin compared with placebo, stratified by dose and sorted by trial end year.

#### Effect of Aspirin on Nonfatal Hemorrhagic Stroke

Pooled analysis of eight trials (N=100,947) showed that aspirin is associated with an increase in nonfatal hemorrhagic stroke (Peto OR, 1.38 [95% CI, 1.04 to 1.82]; I^2^=0) (Figure 31). Sensitivity analysis remained statistically significant when restricting to six low-dose aspirin trials (N=73,737; Peto OR, 1.37 [95% CI, 1.01 to 1.85]; I^2^=0.1%).

Figure 31 Key Question 2: Pooled Analysis of Nonfatal Hemorrhagic Stroke^*^ * Includes neurological deficits as a result of intracerebral hemorrhage and subarachnoid hemorrhage. Risk, Aspirin Compared With Placebo, Stratified by Daily Dose and Sorted by Trial End Year

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ASA = aspirin; ASCEND = A Study of Cardiovascular Events in Diabetes; ASPREE = Aspirin in Reducing Events in the Elderly; BMD = British Male Doctors; CG = control group; CI = confidence interval; CVD = cardiovascular disease; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes; JPPP = Japanese Primary Prevention Project; mg = milligram; n = number of participants; OR = odds ratio; PHS = Physician’s Health Study

Figure 31 displays a pooled analysis of nonfatal hemorrhagic stroke risk, aspirin compared with placebo, stratified by daily dose and sorted by trial end year.

### Sensitivity Analyses

#### Pre- and Post- Cholesterol Management Guidelines

The sensitivity analyses for trials conducted after ATP III in 2001, a proxy for more widespread statin use, suggested diminished harm for total major bleeding, extracranial bleeding, and major GI bleeding associated with aspirin compared to trials conducted prior to 2001 (Table 5). For example, aspirin was associated with a 48 percent relative increase in major GI bleeding in newer trials (k=6, N=92,905, Peto OR 1.48 [95% CI, 1.28 to 1.71]) but a 109 percent relative increase in older trials (k=6, N=53,435, Peto OR 2.09 [95% CI, 1.52 to 2.88]). In contrast, pooled estimates for intracranial bleeding were similar in both pre- and post-ATP III periods, but statistically significant only in later trials (pre-ATP III: k=5, N=53,035, Peto OR 1.32 [95% CI, 0.88 to 1.98]; post-ATP III: k=8, N=108,645, Peto OR 1.33 [95% CI, 1.12 to 1.58]). However, rare events and heterogeneity by dose limit conclusions of sensitivity analyses.

#### Pooling Method

Primary analyses were conducted using the Peto OR fixed effects model because of rare events. Sensitivity analyses using the fixed effects Mantel-Haenszel model and the random effects REML model yielded similar results for all outcomes.

### Detailed Results for Observational Studies

#### Study Characteristics

We identified six observational cohorts (seven publications) reporting the rates of major bleeding in aspirin users (Table 13).^98,^ ^106,^ ^107,^ ^117,^ ^118,^ ^120,^ ^128^ Populations in these observational studies varied widely. We attempted to identify studies evaluating primary prevention populations with primary CVD prevention as the indication for aspirin use. No study perfectly met these criteria, or studies were unclear on whether these aims were met. Thus, a slightly broader set of studies, where the vast majority of participants (>80%) had no CVD event history, were included as a complement to trial data.

Two of six cohorts were U.S.-based and both included health professionals, females in the Nurses’ Health Study (NHS)^121^ and males in the Health Professional Followup Study (HPFS).^120^ Three studies were population-based cohorts: the Puglia, Italy cohort by De Berardis,^117^ the Korean National Health Insurance database,^107^ and the Taiwanese National Health Insurance Research Database.^98,^ ^106^ One study was from the Swedish National Diabetes Register.^118^ Study size ranged from 13,455 in the Korean cohort^107^ to 372,850 in the Italian cohort.^117^ Half of the studies specifically aimed to identify new aspirin users.^106,^ ^107,^ ^117^

The studies reported a large range of aspirin doses: 75 mg daily,^118^ 325 mg daily,^121^ 75 to 325 mg daily,^106^ 81 to 325 mg daily,^120^ or ≤300 mg daily^117^; two studies reported nonspecific information about dosage and frequency (“low-dose”^107^ or “average dose more than 14 defined daily doses per month.”^106^ ^117^ Mean duration of aspirin use and followup ranged from 1 year^106^ to 24 years.^121^ Three studies were most likely to capture primary prevention populations as they excluded participants with previous CVD or a had very low proportion of participants with previous hospitalization for CVD: the Korean health insurance database,^107^ the Swedish diabetes registry,^118^ and the Italian population based cohort by De Berardis.^117^

The indications for aspirin use were sparsely reported and likely varied. The two U.S.-based observational studies examined indications for aspirin use in small subsets of the cohorts, reporting that 8 percent in NHS^121^ and 58 percent in HPFS^120^ used aspirin for CVD prevention. The Taiwanese database did not report the indication for aspirin use.^98,^ ^106^ In one analysis of this cohort, 0.11 percent had coronary artery disease and 0.02 percent had a history of ischemic stroke.^106^ In the other analysis from this database, the proportion was much higher at 11 and 5 percent, respectively.^98^ In the Italian and Korean cohorts, a primary prevention indication is assumed based on prescriptions that are available through national health insurance for CVD prevention^107,^ ^117^ or through explicit study aims.^118^

The participants recruited were as young as 20^98,^ ^106^ or 30 years^117,^ ^118,^ ^121^ to as old as 90 years.^107^ Mean age ranged from 41^106^ to 71 years.^107^ In the studies examining both sexes, approximately half of participants were female. Two studies specifically recruited participants with CVD risk factors: the Korean study^107^ recruited individuals newly diagnosed with hypertension, diabetes, or dyslipidemia and the Swedish registry exclusively included those with diabetes.^118^ In various analyses of the Taiwan health insurance database, participants with diabetes ranged from as low as 0.3 to 24 percent.^98,^ ^106^ Five percent of participants in NHS and HPFS had diabetes and these cohorts also included a large representation of participants with CVD risk factors—approximately 30 percent with hypertension and approximately 40 percent with hypercholesteremia in each cohort.^120,^ ^121^ The percent who were current smokers ranged from 5^120^ to 18 percent^121^ among reporting trials. Race and ethnicity were not reported in any study. Two cohorts were conducted in the United States,^120,^ ^121^ two in Europe,^117,^ ^118^ and two in Asia.^98,^ ^106,^ ^107^

#### Results by Outcome

Table 18 shows crude absolute incidence rates and relative risk for bleeding harms in aspirin and nonaspirin users in both cohorts and trials. Absolute rates in trials and cohorts were not pooled because of extremely variable event rates^48^ and ranges are shown to explore whether the broader populations and larger sample sizes from cohort studies would show similar patterns to trials for rare harms events. Unlike for trials, relative bleeding rates associated with aspirin use were not pooled for cohorts because of heterogeneity of aspirin indication, exposure ascertainment, and wide range of duration. Tables 19 and 20 show the bleeding harms in the individual cohort studies for KQ2.

Table 18 Key Question 2: Crude Absolute Incidence Rates and Relative Rates of Bleeding Harms in Aspirin and Nonaspirin Users as Reported in Trials and Cohort Studies

Outcome | K (N) | Aspirin; Crude absolute rates per 100k p-y; Range | | No Aspirin^*^; Crude absolute rates per 100k p-y; Range | | Relative Comparison of Aspirin vs No Aspirin; (95% CI)
Outcome | K (N) | Trials^†^ | Cohorts | Trials^†^ | Cohorts | Trials; Pooled Peto OR for all doses; (95% CI) | Cohorts; IRR, HR, or RR; (95% CI)
Total major bleed | RCTs: 12 (160,404); Cohorts: 1 (372,850) | 68 to 550 | 558 | 57 to 430 | 360 | 1.45 (1.33, 1.58) | 1.55 (1.48, 1.63)
Major gastrointestinal bleeding | RCTs: 12 (146,340); Cohorts: 5 (852,014) | 58 to 500 | 193 to 380 | 0 to 230 | 107 to 340 | 1.57 (1.37, 1.78) | 0.97 (0.77, 1.16) to 1.67 (1.20, 2.33)^‡^
Hemorrhagic stroke | RCTs: 12 (160,404); Cohorts: 3 (119,781) | 25 to 114 | 13.2 to 360 | 20 to 125 | 15.8 to 470 | 1.23 (1.01, 1.48) | 0.85 (0.53, 1.10) to 1.26 (0.70, 2.25)
Intracranial hemorrhage | RCTs: 13 (161,680); Cohorts: 1 (372,850) | 26 to 250 | 209.8^§^ | 20 to 170 | 122.1^§^ | 1.33 (1.13, 1.56) | 1.54 (1.43, 1.67)

* In cohorts, controls were propensity-score matched or relative risks were adjusted for population characteristics

† When event rates and person-years were not reported, we calculated the event rate using the people with an event and the median followup time. We assumed that each person contributed the same median followup time.

‡ An additional cohort reports upper and lower gastrointestinal bleeding separately and these relative risks are not included in this range, but are reasonably consistent

§ Calculated using 603,797 p-y in aspirin group and 980,166 p-y in no aspirin group

Abbreviations: Adj. = adjusted; GI = gastrointestinal; HR = hazard ratio; IRR = incidence rate ratio; K = number of studies; NR = not reported; OR = odds ratio; p-y; person years; RR = relative risk

Table 19 Key Question 2: Effect of Aspirin on Major GI Bleeding in Cohort Studies

Study name; Author, year | Mean F/U, years | Dose and duration | Outcome | Population | IG N with events/N analyzed; Events per 100,000 p-y | CG N with Events/N analyzed; Events per 100,000 p-y | Results (95% CI)
NHIRD; Luo, 2019^98^ | 2.55 | >14 defined daily doses per month (75-325 mg daily); 2.55 years | Major upper GI bleeding | Total | 379/11105; p-y NR | 326/11105; p-y NR | Adj HR: 1.48 (1.28, 1.72)
NHIRD; Chen, 2017^106^ | 1 | 75-325 mg daily; 1 year | Major lower GI bleeding | Total | 108^*^/53805; p-y NR | 161^*^/269025; p-y NR | Adj HR: 2.75 (2.06, 3.65)
NHIRD; Chen, 2017^106^ | 1 | 75-325 mg daily; 1 year | Major lower GI bleeding | <75 years | 89^*^/52242; p-y NR | 131^*^/261263; p-y NR | Adj HR: 2.62 (1.92, 3.58)
NHIRD; Chen, 2017^106^ | 1 | 75-325 mg daily; 1 year | Major lower GI bleeding | ≥75 years | 21^*^/1547; p-y NR | 22^*^/7755; p-y NR | Adj HR: 3.95 (2.13, 7.32)
Korean National Health Insurance Service-Senior Cohort; Jung, 2020^107^ | 7.8 | “Low-dose” (not further specified); Mean 4.8 (minimum ≥6 months, IQR 2.7-7.3 years) | Major GI bleeding | Total | 85/3366; 300/100,000 p-y | 288/10089; 340/100,000 p-y | Adj HR: 0.97 (0.77, 1.16)
De Berardis, 2012^117^ | 5.7 | ≤300 mg (frequency NR); Median 5.7 (IQR 2.4-6.0) | Major GI bleeding | Total | 2294/186425; 380^†^/100,000 p-y | 2193/186425; 220^†^/100,000 p-y | IRR: 1.55 (1.46, 1.65)
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major GI bleeding | Total (regular users defined as ≥2/wk) | 463/18230; 231/100,000 p-y | 244/14759; 138/100,000 p-y | Adj RR: 1.32 (1.12, 1.55)
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major GI bleeding | 1-5 years continuous regular use | 241/NR; 232/100,000 p-y | 244/14759; 138/100,000 p-y | Adj RR: 1.19 (0.95, 1.48)^¶^
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major GI bleeding | 6-10 years continuous regular use | 130/NR; 229/100,000 p-y | 244/14759; 138/100,000 p-y | Adj RR: 1.18 (0.91, 1.53)^¶^
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major GI bleeding | >10 years continuous regular use | 92/NR; 230/100,000 p-y | 244/14759; 138/100,000 p-y | Adj RR: 1.01 (0.75, 1.35)^¶^
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major GI bleeding | 81 mg daily use | 94/NR; 271/100,000 p-y | 139/NR; 196/100,000 p-y | Adj RR: 1.17 (0.89, 1.53)
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major GI bleeding | 325 mg daily use | 52/NR; 347/100,000 p-y | 139/NR; 196/100,000 p-y | Adj RR: 1.67 (1.20, 2.33)
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major GI bleeding | ≤60 years, regular users | 64/NR; 120/100,000 p-y | 66/NR; 87/100,000 p-y | NR^#^
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major GI bleeding | >60 years, regular users | 399/NR; 270/100,000 p-y | 178/NR; 176/100,000 p-y | NR^#^
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major lower GI bleeding | Total (regular users defined as ≥2/wk) | 193/18230; 96/100,000 p-y | 110/14759; 62/100,000 p-y | Adj RR: 1.22 (0.95, 1.56)
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major lower GI bleeding | 1-5 years continuous regular use | 102/NR; 98/100,000 p-y | 110/14759; 62/100,000 p-y | Adj RR: 1.20 (0.86, 1.68)^**^
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major lower GI bleeding | 6-10 years continuous regular use | 49/NR; 86/100,000 p-y | 110/14759; 62/100,000 p-y | Adj RR: 1.05 (0.70, 1.57)^**^
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major lower GI bleeding | >10 years continuous regular use | 42/NR; 105/100,000 p-y | 110/14759; 62/100,000 p-y | Adj RR: 1.10 (0.71, 1.70)^**^
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major upper GI bleeding | Total (regular users defined as ≥2/wk) | 204/18230; 102/100,000 p-y | 99/14759; 56/100,000 p-y | Adj RR: 1.49 (1.16, 1.92)
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major upper GI bleeding | 1-5 years continuous regular use | 101/NR; 0.97/1,000 p-y | 99/14759; 0.56/1,000 p-y | Adj RR: 1.18 (0.84, 1.66)^††^
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major upper GI bleeding | 6-10 years continuous regular use | 61/NR; 107/100,000 p-y | 99/14759; 56/100,000 p-y | Adj RR: 1.33 (0.90, 1.96)^††^
HPFS; Huang, 2010^120^ | 14 | 81-325 mg; NR | Major upper GI bleeding | >10 years continuous regular use | 42/NR; 105/100,000 p-y | 99/14759; 56/100,000 p-y | Adj RR: 1.11 (0.71, 1.71)^††^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major GI bleeding | Total (regular users defined as ≥2/wk) | 818/32187; 193/100,000 p-y | 719/55493; 107/100,000 p-y | Adj RR: 1.43 (1.29, 1.59)
NHS; Huang, 2011^121^ | 24 | 325 mg | Major GI bleeding | 1-5 years continuous regular use | 302/NR; 162/100,000 p-y | 1015/NR; 129/100,000 p-y | Adj RR: 0.99 (0.87, 1.13)^‡‡^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major GI bleeding | 6-10 years continuous regular use | 119/NR; 183/100,000 p-y | 1015/NR; 129/100,000 p-y | Adj RR: 0.98 (0.81, 1.20)^‡‡^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major GI bleeding | 11-20 years continuous regular use | 61/NR; 207/100,000 p-y | 1015/NR; 129/100,000 p-y | Adj RR: 0.98 (0.74, 1.28)^‡‡^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major GI bleeding | >20 years continuous regular use | 40/NR; 151/100,000 p-y | 1015/NR; 129/100,000 p-y | Adj RR: 0.79 (0.57, 1.11)^‡‡^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major GI bleeding | ≤60 years | 146/NR; 94/100,000 p-y | 158/NR; 50/100,000 p-y | NR^§§^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major GI bleeding | >60 years | 672/NR; 270/100,000 p-y | 561/NR; 176/100,000 p-y | NR^§§^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major GI bleeding | High CVD risk^║║^ | NR/NR | NR/NR | Adj RR: 1.55 (1.31, 1.83)
NHS; Huang, 2011^121^ | 24 | 325 mg | Major upper GI bleeding | Total (regular users defined as ≥2/wk) | 369/32187; 87/100,000 p-y | 267/55493; 40/100,000 p-y | Adj RR: 1.70 (1.45, 2.00)
NHS; Huang, 2011^121^ | 24 | 325 mg | Major upper GI bleeding | 1-5 years continuous regular use | 123/NR; 66/100,000 p-y | 406/NR; 52/100,000 p-y | Adj RR: 0.97 (0.79, 1.19)^¶¶^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major upper GI bleeding | 6-10 years continuous regular use | 58/NR; 89/100,000 p-y | 406/NR; 52/100,000 p-y | Adj RR: 1.13 (0.85, 1.51)^¶¶^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major upper GI bleeding | 11-20 years continuous regular use | 31/NR; 105/100,000 p-y | 406/NR; 52/100,000 p-y | Adj RR: 1.09 (0.74, 1.61)^¶¶^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major upper GI bleeding | >20 years continuous regular use | 18/NR; 68/100,000 p-y | 406/NR; 52/100,000 p-y | Adj RR: 0.76 (0.46, 1.26)^¶¶^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major lower GI bleeding | Total (regular users defined as ≥2/wk) | 319/32187; 75/100,000 p-y | 345/55493; 51/100,000 p-y | Adj RR: 1.21 (1.03, 1.41)
NHS; Huang, 2011^121^ | 24 | 325 mg | Major lower GI bleeding | 1-5 years continuous regular use | 127/NR; 68/100,000 p-y | 460/NR; 58/100,000 p-y | Adj RR: 0.98 (0.80, 1.20)^##^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major lower GI bleeding | 6-10 years continuous regular use | 41/NR; 63/100,000 p-y | 460/NR; 58/100,000 p-y | Adj RR: 0.82 (0.59, 1.14)^##^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major lower GI bleeding | 11-20 years continuous regular use | 23/NR; 78/100,000 p-y | 460/NR; 58/100,000 p-y | Adj RR: 0.97 (0.62, 1.51)^##^
NHS; Huang, 2011^121^ | 24 | 325 mg | Major lower GI bleeding | >20 years continuous regular use | 13/NR; 49/100,000 p-y | 460/NR; 58/100,000 p-y | Adj RR: 0.70 (0.39, 1.26)^##^

* Ns calculated from percents

† Calculated using 603,797 p-y in aspirin group and 980,166 p-y in no aspirin group

¶ p-value for trend by duration: 0.749; multivariate analyses for adjustment minus dose available

# p-value for interaction 0.81; HR displayed in figure but data not reported (for ≤60 years; estimate to the right of 1.0, 95% CI appears to cross 1.0; for >60 years, estimate to the right of 1.0, 95% CIs appear to not cross 1.0)

** p-value for trend=0.932; multivariate analysis adjusted for everything minus dose available

†† p-value for trend=0.641; multivariate analysis adjusted for everything minus dose available

‡‡ p-value for trend=0.280

§§ P-value for interaction 0.15. HR shown in graph, but data not reported (for ≤60 years, estimate appears to be to the right of 1.0, with CIs not crossing the line; for >60 years, appears to be to the right of 1.0, with CIs not crossing the line.

║║ High CVD risk defined as participants with history of prior MI or coronary artery bypass grafting or had at least 2 cardiac risk factors (BMI ≥30 kg/m2, DM, HTN, current smoking, hypercholesterolemia)

¶¶ p-value for trend=0.744

## p-value for trend=0.212

Abbreviations: Adj = adjusted; BMI = body mass index; CG = control group; CI = confidence interval; CVD = Cardiovascular Disease; DM = diabetes mellitus; F/U = followup; g = grams; GI = gastrointestinal; HPFS = Health Professionals Followup Study; HR = hazard ratio; HTN = hypertension; IG = intervention group; IQR = interquartile range; mg = milligrams; n = number of participants; NHIRD = National Health Insurance Research Database; NHS = Nurses’ Health Study; NR = not reported; p-y = person-years; RR = relative risk; SNDR = Swedish National Diabetes Register; wk = week

Table 20 Key Question 2: Effect of Aspirin on Intracranial Bleeding in Cohort Studies

Study name; Author, year | F/U, mean years | Dose and duration, years | Outcome | Population | IG N with events/N analyzed; Events per 100,000 p-y | CG N with events/N analyzed; Events per 100,000 p-y | Results (95% CI)
Korean National Health Insurance Service-Senior Cohort; Jung, 2020^107^ | 7.8 | “Low-dose” (not further specified); Mean 4.8 (minimum ≥6 months IQR 2.7-7.3 years) | Hemorrhagic stroke - total | Total | 101/3366; 360/100,000 p-y | 397/10089; 470/100,000 p-y | Adj HR: 0.85 (0.53, 1.10)
De Berardis, 2012^117^ | 5.7 | ≤300 mg (frequency NR); 5.7 (IQR 2.4-6) years | Intracranial hemorrhage - total | Total | 1267/186425; 209.8^*^/100,000 p-y | 1197/186425; 122.1^*^/100,000 p-y | IRR: 1.54 (1.43, 1.67)
SNDR; Ekstrom, 2013^118^ | 3.9 | 75 mg QD; >12 months | Cerebral hemorrhage - total | Total | NR/4608 | NR/14038 | Adj HR: 1.26 (0.70, 2.25)^†^
SNDR; Ekstrom, 2013^118^ | 3.9 | 75 mg QD; >12 months | Cerebral hemorrhage - total | Male | NR/2585 | NR/7721 | Adj HR: 1.13 (0.54, 2.38)^‡^
SNDR; Ekstrom, 2013^118^ | 3.9 | 75 mg QD; >12 months | Cerebral hemorrhage - total | Female | NR/2023 | NR/6317 | Adj HR: 1.42 (0.57, 3.58)^§^
SNDR; Ekstrom, 2013^118^ | 3.9 | 75 mg QD; >12 months | Cerebral hemorrhage - fatal | Total | NR/4608 | NR/14038 | Adj HR: 1.60 (0.51, 6.05)^║^
SNDR; Ekstrom, 2013^118^ | 3.9 | 75 mg QD; >12 months | Cerebral hemorrhage - fatal | Female | NR/2023 | NR/6317 | Adj HR: 1.26 (0.11, 14.3)^¶^
SNDR; Ekstrom, 2013^118^ | 3.9 | 75 mg QD; >12 months | Cerebral hemorrhage - fatal | Male | NR/2585 | NR/7721 | Adj HR: 1.68 (0.46, 6.15)^#^
NHS; Huang, 2011^121,^ ^122^ | 14 | 325 mg per aspirin; NR | Hemorrhagic stroke - total | 1-6 aspirin per week | 53/35960; 13.2/100,000 p-y | 61/19233; 15.8/100,000 p-y | Unadj IRR: 0.84 (0.58, 1.21)^**^
NHS; Huang, 2011^121,^ ^122^ | 14 | 325 mg per aspirin; NR | Hemorrhagic stroke - total | 7-14 aspirin per week | 22/7900; 21.4/100,000 p-y | 61/19233; 15.8/100,000 p-y | Adj RR: 1.25 (0.76, 2.05)^**^
NHS; Huang, 2011^121,^ ^122^ | 14 | 325 mg per aspirin; NR | Hemorrhagic stroke - total | ≥15 aspirin per week | 16/4694; 30.0/100,000 p-y | 61/19233; 15.8/100,000 p-y | Adj RR: 1.63 (0.93, 2.86)^**^
NHS; Huang, 2011^121,^ ^122^ | 14 | 325 mg per aspirin; NR | Subarachnoid hemorrhagic stroke - total | 1-6 aspirin per week | 38/35960; 9.5/100,000 p-y | 37/19233; 9.6/100,000 p-y | Unadj IRR: 0.99 (0.63 to 1.56)^**^
NHS; Huang, 2011^121,^ ^122^ | 14 | 325 mg per aspirin; NR | Subarachnoid hemorrhagic stroke - total | 7-14 aspirin per week | 13/7900; 12.7/100,000 p-y | 37/19233; 9.6/100,000 p-y | Adj RR: 1.28 (0.67, 2.43)^**^
NHS; Huang, 2011^121,^ ^122^ | 14 | 325 mg per aspirin; NR | Subarachnoid hemorrhagic stroke - total | ≥15 aspirin per week | 12/4694; 22.5/100,000 p-y | 37/19233; 9.6/100,000 p-y | Adj RR: 2.02 (1.04, 3.91)^**^

* Calculated using 603,797 p-y in aspirin group and 980,166 p-y in no aspirin group

† 59 events in all participants total; not reported by group. 90 events per 100,000 p-y overall.

‡ 36 events in all males total; not reported by group. 100 events per 100,000 p-y overall.

§ 23 events in all females total; not reported by group. 80 events per 100,000 p-y overall.

║ 14 events in all participants total; not reported by group. 20 events per 100,000 p-y overall.

¶ 3 events in all females total; not reported by group. 10 events per 1000 p-y overall.

# 11 events in all males total; not reported by group. 30 events per 1000 p-y overall.

** p-value for trend by aspirin frequency=0.02 (for both outcomes)

Abbreviations: Adj=adjusted; CG=control group; CI=confidence interval; CVD=cardiovascular disease; F/U=followup; HR=hazard ratio; IG=intervention group; IQR=interquartile range; IRR=incidence rate ratio; ITA=Italy; NHS=Nurses’ Health Study; NR=not reported; p-y=person-years; KOR=Korea; RR=relative risk; SNDR=Swedish National Diabetes Register; SWE=Sweden

##### Total Major Bleed

One large Italian population-based cohort (N=372,850) evaluating aspirin ≤300 mg with mean 5.7 year followup reported total major bleed. The absolute rates of total major bleeds in the aspirin group were 558 per 100,000 person-years (p-y) and 360 per 100,000 in the control group. These absolute rates corresponded to the higher end or above the range reported in the trials which were 68 to 550 per 100,000 p-y in the aspirin group and 57 to 430 per 100,000 p-y in the no-aspirin group. This corresponded to a statistically significant 55 percent relative increase in total major bleeds in the aspirin group in this cohort study (incidence rate ratio [IRR]: 1.55 [95% CI, 1.48 to 1.63]). This relative increase was consistent with the pooled estimate for total major bleeds from trials (Peto OR 1.45 [95% CI, 1.33, 1.58]).

##### Major GIB

Six cohorts (N=852,014) report major GIB with absolute bleeding risk showing wide ranges in both the nonaspirin and aspirin groups. In the nonaspirin control group, rates ranged from 107/100,000 p-y^121^ to 340/100,000 p-y^107^ (Table 19). In the aspirin group, the absolute rate of major GIB ranged from 193/100,000 p-y^121^ to 380/100,000 p-y.^117^ In the trials, the absolute bleeding risk was generally similar to the cohorts, with smaller lower ranges, but wide ranges that overlapped those from the cohorts. In the trials, major GIB ranged from 0 to 230/100,000 in the nonaspirin group and 58 to 500/100,000 p-y in the aspirin group. The relative effect of aspirin on major GI bleeding ranged from an adjusted HR of 0.97 (95% CI, 0.77 to 1.16) for “low-dose” aspirin^107^ to an adjusted RR of 1.67 (95% CI, 1.20 to 2.33) for aspirin in a dose of 325 mg daily compared to no aspirin^120^. Aside from the lowest estimate from the Korean database which was not statistically significant, showing a reduction in bleeding in the aspirin group, results from the other cohorts were all statistically significant, ranging from 1.43^121^ to 1.67.^120^ These were all within the confidence interval in the pooled analysis of major GI bleeding in trials (Peto OR 1.57 [95% CI, 1.37 to 1.78]).

Analyses by dose were limited because many cohorts reported wide ranges of doses. However, within-study comparisons from HPFS suggest that higher dose is associated with higher rates of major GI bleeding (81 mg/d: adjusted RR 1.17 [95% CI, 0.89 to 1.53]; 325 mg/d: adjusted RR 1.67 [95% CI, 1.20 to 2.33]).^120^

The Swedish National Diabetes Register^118^ reported a higher number of ventricular ulcers in those taking aspirin (adjusted HR, 1.64 [95% CI, 1.06 to 2.53]).

##### Total Hemorrhagic Stroke

Three cohorts (N=119,781) reported hemorrhagic stroke outcomes.^107,^ ^118,^ ^121^ The range of absolute hemorrhagic strokes in the nonaspirin control group in the cohorts was exceedingly wide, ranging from 15.8^121^ to 470^107^ per 100,000 p-y. This compares to a tighter range in the trials’ control groups of 20^45^ to 125^81^ per 100,000 p-y. The range of absolute hemorrhagic stroke rates in the cohort aspirin groups was 13.2^121^ to 360^107^ per 100,000 p-y while the trials again reported a tighter range—25^64^ to 114^101^ per 100,000 p-y in the aspirin groups.

The relative effects of aspirin on hemorrhagic stroke in the three cohorts ranged from an adjusted HR of 0.85 (95% CI, 0.53 to 1.10)^107^ to an adjusted HR of 1.26 (95% CI, 0.70 to 2.25).^118^ Two cohorts reported hemorrhagic stroke point estimates similar to the trial evidence for all doses of aspirin,^118,^ ^121^ although unlike the pooled trial evidence, these estimates were not statistically significant (pooled trial estimate: Peto OR 1.23 [95% CI, 1.01 to 1.48]). The third cohort^107^ reported fewer hemorrhagic strokes in the aspirin group, however, this also did not reach statistical significance (adjusted HR 0.85 [95% CI, 0.53 to 1.10]). Reflecting the low event rates, the range of the confidence intervals for the cohorts was wide and overlapped with the pooled trial estimate.

Analyses by dose were limited because many cohorts reported wide ranges of doses. However, within-study comparisons suggest that increased days of aspirin per week are associated with a statistically significant trend for increased hemorrhagic stroke risk (p=0.02) (1-6 doses/week: IRR 0.84 [95% CI, 0.58 to 1.21]; 7-14 doses/week: adjusted RR 1.25 [95% CI, 0.76 to 2.05]; ≥15 doses/week adjusted RR 1.63 [95% CI, 0.93 to 2.86]).^121,^ ^122^

##### Fatal Hemorrhagic Stroke

The Swedish diabetes registry (N=18,646) was the only cohort reporting fatal hemorrhagic stroke, showing a nonstatistically significant increase in fatal cerebral hemorrhage (adjusted HR 1.60 (95% CI, 0.51 to 6.05).^118^

##### Intracranial Hemorrhage

One large Italian population-based cohort (N=372,850) evaluating aspirin ≤300 mg with mean 5.7 year followup reported intracranial hemorrhage (Table 20).^117^ The absolute rates of ICH in the aspirin group were 209.8 per 100,000 p-y and 122.1 per 100,000 in the control group. These absolute rates corresponded to the higher end of the range reported in the trials which were 26 to 250 per 100,000 p-y in the aspirin group and 20 to 170 per 100,000 p-y in the no-aspirin group. This corresponded to a statistically significant 54 percent relative increase in intracranial hemorrhages in the aspirin group in this cohort study (IRR: 1.54 [95% CI, 1.43 to 1.67]). This relative increase was consistent with the pooled estimate for intracranial hemorrhage from trials (Peto OR 1.33 [95% CI 1.13 to 1.56]).

### Duration

Only 4 of 14 trials report time-to-event analyses for any bleeding harms.^56,^ ^83,^ ^91,^ ^101^ Using Kaplan-Meier curves, it appears that the bleeding harms occur immediately or at about 1 year. However, results are statistically significant in only two of four trials reporting time-to-event analyses.^56,^ ^101^ In these two trials, Kaplan-Meier curves diverge immediately for major hemorrhage,^101^ GI bleeding^56,^ ^101^ and increased risk for these bleeding events persisted for the 6 year duration of trial followup. While the other two trials^83,^ ^91^ showed nonstatistically significant results for hemorrhagic stroke^83^ and intracranial hemorrhage,^91^ point estimates were above 1. When forest plots were sorted by duration of aspirin use, no patterns were apparent linking bleeding harms to duration of aspirin administration. Again, in most of the trials, aspirin administration continued for 4-6 years so it is difficult to make any conclusions about longer-term effects of aspirin on bleeding outcomes by duration of use.

In the cohorts, no pattern was revealed between duration of use and bleeding. For within-study comparisons, NHS and HPFS examined bleeding rates by duration of use (1-5, 6-10, >10, and >20 years continuous use) and the data did not suggest any difference in bleeding risk by duration of use.^120,^ ^121^

### Harms Findings in Specific Populations (KQ2a)

#### Summary

There is no convincing data to suggest that aspirin has a differential relative bleeding risk based on age, sex, diabetes, CVD risk, or race and ethnicity. Few trials report bleeding events in specific populations, and due to the rare occurrence of total bleeding harm events in the trials, conclusions are limited by this scant evidence base.

#### Age

There is no convincing data to suggest that aspirin has a differential relative bleeding risk based on age. Four trials^55,^ ^70,^ ^91,^ ^101^ report bleeding risk by age (Appendix D, Table 20). Analyses were prespecified in two trials^55,^ ^101^ and interaction testing was performed in three^55,^ ^91,^ ^101^ of the four trials. ASPREE reported an interaction p-value of 0.05 for aspirin’s effect on major hemorrhagic events by age, where the younger group had a greater risk of bleeding associated with aspirin use compared to the older group (65-73 years: HR 1.74 [95% CI, 1.31 to 2.31]; ≥74 years: HR 1.23 [95% CI, 1.01 to 1.49]).^101^ However, the trial’s post-hoc analyses for major hemorrhagic events with narrower age strata (65-69, 70-74, 75-84, ≥85 years) did not confirm this pattern and there were very few events in some age groups (nine total hemorrhagic events in participants 65-73 years), limiting power. ASPREE’s prespecified major GI bleeding outcome also showed a trend with greater risk seen in the younger age groups, but interaction testing was nonsignificant (p=0.40) and confidence intervals overlapped for the age strata (65-74 years: HR 1.99 [95% CI, 1.32 to 3.02]; 75-79 years: HR 1.49 [95% CI, 0.95 to 2.34]; ≥80 years: 1.33 [95% CI, 0.85 to 2.08]).^130^ Results for the composite of major hemorrhage in ASCEND^55^ showed no consistent pattern by age and bleeding events in JPPP and HOT were too rare (<1%) in the age categories for conclusions.^70,^ ^91^

#### Sex

Sex-specific data on harms are available from eight trials without any evidence to suggest a differential relative bleeding risk based on sex. Four trials were conducted either exclusively in males or females^45,^ ^59,^ ^82,^ ^83^ and four trials including both males and females^55,^ ^64,^ ^70,^ ^101,^ ^130^ performed subanalyses by sex for bleeding harms (Appendix D, Table 21). Only two trials with both sexes prespecified their analysis and these same two trials performed interaction testing.^55,^ ^101^ For all major bleeding, ASPREE reported statistically significant increase in major bleeding in females only while ASCEND reported statistically significant results in males only, however, both trials reported nonsignificant interaction testing (ASCEND: p for interaction=0.79; ASPREE: p for interaction=0.1).^55,^ ^101^ HOT reported nonfatal major bleeding events by sex^70^ with a higher crude risk seen with aspirin in males than females, but events were rare and statistical testing was not performed (men: 1.6 excess cases in the aspirin group per 1,000 p-y; women: 1.4 excess cases in the aspirin group per 1,000 p-y). In the trials recruiting a single sex, PHS reported a statistically significant increase in bleeding requiring transfusion or hospitalization (Adjusted RR: 1.71 [95% CI, 1.09, 2.69]).^59^ TPT reported few events, making estimates unreliable.^45^

Within-study comparisons for the effect of aspirin on major GI bleeding in males and females are available in only one trial. ASPREE showed similar and statistically significant point estimates for the effect of aspirin on major GI bleeding for males and females with relative risks of 1.62 and 1.61, respectively, and nonsignificant interaction testing (p for interaction=0.98).^101,^ ^130^ For the single sex trials, WHS reported a statistically significant increase in GI bleeding requiring a transfusion (Peto OR 1.37 [95% CI, 1.05 to 1.78)].^83^ For the male-only trials, GI bleeding events were exceedingly rare with imprecise estimates (BMD: Peto OR 0.15 [95% CI, 0.02 to 1.22]; TPT: Peto OR 2.73 (95% CI, 0.68 to 10.95]).^45,^ ^59^ Of note, the GI bleeding events in BMD were fatal only, and there were 4 total deaths from this cause; TPT reported a total of only eight major GI bleeding events.

Within-study comparisons for the effect of aspirin on hemorrhagic stroke in males and females are available in only one trial. PPP reported this outcome, but events were exceedingly rare with two total events in females and three total events in males, resulting in wide confidence intervals and unreliable point estimates.^64^ Similarly, three male-only trials reported hemorrhagic stroke with rare events (<1%); so while point estimates were greater than 1 in all three trials, results were nonstatistically significant with wide confidence intervals. The all-male trial with the largest number of hemorrhagic strokes (45 total), reported an adjusted relative risk of 2.14 (95% CI, 0.96 to 4.77).^59^ The only all-female trial, WHS, included 92 total hemorrhagic strokes, and aspirin was similarly associated with a nonstatistically significant increase in this outcome (RR 1.24 [95% CI, 0.82 to 1.87]).^83^

#### Race and Ethnicity

No trials report bleeding harms by race and ethnicity.

#### Diabetes

Because of rare harms events, there is limited data from which to evaluate a potential differential relative harm of aspirin in participants with and without diabetes. Prespecified within-trial comparisons from one study suggest no differential harm and only one of three trials conducted exclusively in participants with diabetes, ASCEND, had sufficient power to detect differences in aspirin-associated bleeding outcomes. Four trials^55,^ ^66,^ ^81,^ ^101^ reported bleeding risk in individuals with diabetes, with three of these trials solely recruiting participants with diabetes^55,^ ^66,^ ^81^ and one trial, ASPREE,^101^ performing a prespecified analysis with interaction testing (Appendix D, Table 22). ASCEND, recruiting solely participants with diabetes, reported statistically significant increases in major GI bleeding and a composite of major hemorrhage and a nonstatistically significant increase in total intracranial hemorrhage. JPAD and POPADAD, which also exclusively included those with diabetes, had small numbers of bleeding events, making estimates unstable. JPAD had 13 total hemorrhagic strokes and POPADAD had five total fatal hemorrhagic strokes. Within-study comparisons from ASPREE showed an increase in composite major hemorrhagic events and major GI bleeding which was not statistically significant in those with diabetes (HR 1.30 [95% CI, 0.81 to 2.10), N=2,057) but statistically significant in those without diabetes (HR 1.39 [95% CI, 1.17 to 1.64], N=17,057).^101^ Point estimates were similar in the separate analyses, suggesting that limited power may have led to nonstatistically significant results in those with diabetes. Eleven percent of ASPREE participants had diabetes at baseline.^101^

#### Estimated CVD Risk

No trials reported bleeding outcomes by CVD risk.

#### Other Specific Populations

We audited the included trials for data addressing other specific populations and concluded that there was insufficient evidence for synthesis as only 1-2 trials reported harms outcomes for any other specific populations.