# Chapter 2 Methods

## Scope and Purpose

This review is a combined update of three reviews that supported the 2016 USPSTF recommendation^1^ and decision model^43^: a review on aspirin to prevent CVD,^2^ a review on aspirin to prevent CRC,^4^ and a review on aspirin to prevent all cancers as well as the harms of aspirin.^3^ Our update includes studies published since the previous reviews and studies from the previous reviews that met updated inclusion criteria. The most substantive changes in scope were to remove the outcomes of all cancer incidence, all cancer mortality, and colorectal adenomas. Only CRC incidence and mortality outcomes are carried forward in this review as previously it was the cancer outcome with the most evidence.

## Analytic Framework and Key Questions

We followed USPSTF procedures and methods to define study inclusion and exclusion criteria (Appendix A, Table 1) and developed an analytic framework (Figure 2) with two Key Questions (KQs).

Figure 2 Analytic Framework

Abbreviations: CRC = Colorectal cancer; CVD = cardiovascular disease

Figure 2 is the analytic framework that depicts the two Key Questions to be addressed in the systematic review. The figure illustrates how regular aspirin use in patients without known cardiovascular disease (CVD) may reduce CVD- and colorectal cancer (CRC) incidence and mortality, or all-cause mortality (KQ1). Additionally, the figure depicts the possibility that regular aspirin use increases the incidence of major GI bleeding, intracranial bleeding, or other serious harms (KQ2).

1. Does regular aspirin use in patients without known cardiovascular disease (CVD) reduce CVD- and colorectal cancer (CRC) incidence and mortality, or all-cause mortality?
  a. Does the effect vary in specific a priori populations defined by age, sex, 10-year cardiovascular risk, race and ethnicity, or diagnosis of diabetes mellitus?
  b. Does the effect vary by dose or duration of aspirin use?
2. Does regular aspirin use increase major GI bleeding, intracranial bleeding, or other serious harms?
  a. Does the effect vary in specific a priori populations defined by age, sex, 10-year cardiovascular risk, diagnosis of diabetes mellitus, race and ethnicity, or bleeding risk factors?
  b. Does the effect vary by dose or duration of aspirin use?

## Data Sources and Searches

We considered all studies from the previous reviews on this topic for inclusion in the current review and performed a comprehensive search for new literature. We searched MEDLINE, PubMed (publisher-supplied only), Embase, and the Cochrane Collaboration Registry of Controlled Trials for relevant studies published between January 2014 and January 14, 2021. Studies included in the previous USPSTF review were evaluated for inclusion against the inclusion and exclusion criteria for the current review. A research librarian developed and executed the search, which was peer-reviewed by a second research librarian (Appendix A).

We also examined the reference lists of other previously published reviews, meta-analyses, and primary studies to identify additional potential studies for inclusion. We supplemented our searches with suggestions from experts and articles identified through news and table-of-contents alerts. We also searched ClinicalTrials.gov (https://ClinicalTrials.gov/) for ongoing trials (Appendix E). Active surveillance was conducted after our searches through January 21, 2022 via article alerts and targeted journal searches to identify major studies that might affect the conclusions or understanding of the evidence. We managed all literature search results from these sources directly into EndNote® X9 (Thomson Reuters, New York, NY).

## Study Selection

Detailed inclusion and exclusion criteria were developed to guide study selection (Appendix A, Table 1). Two reviewers independently reviewed the titles and abstracts of all identified articles to determine whether studies met these criteria. Two reviewers then independently evaluated the full text of potentially relevant studies. Disagreements regarding the abstract and/or full text review were resolved by discussion and consultation with a third reviewer if necessary. Excluded studies and reasons for exclusion are listed in Appendix C. We used DistillerSR (Evidence Partners, Ottawa, Canada) to conduct abstract and full-text review.

### Population

We included populations age 40 years and older without known CVD and at average risk for CRC or unselected for CRC risk. Nongeneralizable populations such as those selected for genetic susceptibility syndromes, or a personal history of cancer, were excluded. For CRC outcomes only, populations with a history of CVD were also included for a prespecified sensitivity analysis. Studies needed to be conducted in countries categorized as “very high” on the 2017 Human Development Index, as defined by the United Nations Development Programme.^44^

### Interventions and Comparators

We included studies examining any dose of regular oral aspirin use compared to no treatment or a placebo. We defined regular oral aspirin use as a minimum of 75 milligrams (mg) every other day for 12 months. Aspirin use for analgesic indication was not eligible as use patterns for this indication are likely more intermittent and inconsistent. We excluded interventions including nonaspirin antithrombotic medications, and aspirin as a cotreatment to another active intervention. Multifactorial trials including other eligible agents (e.g., vitamin E) or interventions (e.g., blood pressure reduction) were acceptable and results were combined for aspirin versus no aspirin arms. In a trial with additional randomization to warfarin or placebo,^45^ we did not include any arms receiving warfarin, as we considered warfarin an excluded cotreatment.

### Outcomes

For KQ1 (benefits), cardiovascular outcomes of interest included MI, stroke, death from MI or CHD, death from stroke, and composite outcomes of major CVD events. We also included colorectal cancer incidence, colorectal cancer mortality, and all-cause mortality. For KQ2 (harms), we were interested in hemorrhagic stroke, intracranial hemorrhage (ICH) and major bleeding, defined as bleeding requiring a transfusion or hospitalization, or leading to death. This could include, but was not limited to, serious gastrointestinal bleeding. Other serious harms were also abstracted. Detailed definitions and the handling of composite outcomes are further described in the Data Analysis section.

### Study Design

For both KQs, randomized controlled trials (RCTs), controlled clinical trials, and individual patient-data meta-analyses (IPD MA) were included. For KQ2 (harms), large observational studies were also considered. Eligible observational studies needed to report an aspirin group and non-aspirin control group. Case control studies, case series, and case reports were excluded. The inclusion of observational studies was limited to primary prevention CVD populations reporting major bleeding in an aspirin group and nonaspirin control group. Intent-to-treat (ITT) analyses from long-term observational followup from randomized trials were included (see additional details under Data Synthesis and Analysis).

## Quality Assessment

Two reviewers applied USPSTF design-specific criteria^46^ to assess the methodological quality of all eligible studies (Appendix A, Table 2). We assigned each study a quality rating of “good,” “fair,” or “poor.” Discordant quality ratings were resolved by discussion or adjudicated by a third reviewer as needed. Studies rated as poor quality were not eligible for the review.

Good-quality RCTs were those that met all or nearly all of the specified quality criteria. Specifically, comparable groups were assembled initially and maintained throughout the study, followup was 90 percent or higher, assessment procedures were described and blinded if they involved direct interviews, randomization methods were described, and allocation was concealed. Fair-quality studies did not meet all criteria but did not have serious threats to their internal validity related to design, execution, or reporting. To be rated as poor quality, intervention studies generally have several important limitations, including at least one of the following risks of bias: very high attrition (generally >40%); differential attrition between intervention arms (generally >20%); lack of baseline comparability between groups without adjustment; or problematic issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting; inappropriate exclusion of participants from analyses; questionable validity of allocation or assessment procedures).

## Data Abstraction

For all included studies, one reviewer extracted key elements into standardized abstraction forms in DistillerSR (Evidence Partners, Ottawa, Canada). Key elements included general characteristics of the study (e.g., author, year, study design), clinical and demographic characteristics of the sample and setting (e.g., age, race and ethnicity, baseline clinical characteristics, setting, country), intervention details (e.g., aspirin dose, duration) analytic methods (e.g., adjustments), and outcomes relevant to KQ1 and KQ2. A second reviewer checked the data for accuracy.

## Data Synthesis and Analysis

The primary outcomes of this review were:

- Major CVD events (nonfatal MI, nonfatal stroke, and CVD mortality)
- Total MI
- Total stroke
- Total ischemic stroke
- CVD mortality
- All-cause mortality
- CRC incidence
- CRC mortality
- Total major bleed
- Major GI bleed (GIB)
- Hemorrhagic stroke
- Intracranial hemorrhage
- Extracranial hemorrhage

Nonfatal and fatal events were also analyzed separately as secondary outcomes.

### Cardiovascular Disease

Because of substantial heterogeneity in the primary composite outcomes defined by individual trials, and the fact that these composites often included outcomes that were not eligible for our review (i.e., angina, revascularization), trial-defined composite outcomes were not necessarily included as a primary outcome in our review. Instead, we constructed our own primary composite outcome—major CVD events—which was comprised of nonfatal MI, nonfatal stroke, and CVD mortality as a broad measure of CVD benefit. If an individual study did not report this outcome, we calculated it from individual outcomes. This approach may overestimate events if the reporting of separate outcomes included individuals with nonfatal events followed by a fatal event. For the outcomes of total MI and fatal MI, we included fatal coronary heart disease and sudden death in addition to MI events.

There was heterogeneity in the individual trials with regard to the outcomes contributing to CVD mortality. For several trials, CVD mortality was exclusively comprised of fatal MI (including CHD death and sudden death) and fatal stroke. In other trials, additional events such as aortic aneurysm, hypertensive heart disease, and pulmonary embolism were included. For comparability, we preferentially used the broader definition of CVD death because this was available from most trials. The narrower definition of fatal MI and fatal stroke was used when broader definitions were not reported.

#### Stroke

Where possible, our stroke outcomes are consistent with the 2013 definition of stroke from the AHA and the American Stroke Association (ASA).^47^ Stroke outcomes were grouped into two categories by their mechanism—ischemia or hemorrhage. Hemorrhagic stroke includes neurological deficits as a result of intracerebral hemorrhage and subarachnoid hemorrhage. Intracranial bleeding encompasses intracerebral hemorrhage and subarachnoid hemorrhage as well as subdural hematoma (subdural hematoma is not considered a stroke). Intracranial bleeding does not necessarily have to manifest neurological deficits.

#### Colorectal Cancer

We included both CRC incidence and mortality, as reported by the trials. We also accepted the narrower outcomes of colon cancer as reported by the trials, with the knowledge that this could be underestimating cases in comparison to trials that looked for both colon and rectal cancer. We did not accept the broad category of GI cancer, as this could include other cancers of the GI tract, such as gastric cancer.

#### Major Bleeding

For harms (KQ2), we evaluated major bleeding, defined as bleeding requiring transfusion or hospitalization or leading to death. If a trial reported transfusions and death from bleeding separately, we added these events together. If a trial only reported deaths from bleeding, we used that number for major bleeding. If a trial reported bleeding without any mention of severity, we did not include it in our analysis. We further categorized major bleeding by location: GI (upper and lower), extracranial (inclusive of all bleeds except intracranial bleeds), and intracranial (inclusive of hemorrhagic stroke, subarachnoid hemorrhage, and subdural hemorrhage). If studies did not report these outcomes, we calculated them when data were available to calculate a composite. At times, studies only reported a subset of these bleeding locations and in those cases that subset was used in the pooled analysis for the larger category. For example, hemorrhagic stroke was substituted for intracranial hemorrhage if intracranial hemorrhage was not reported.

### Analysis

We prespecified the following sensitivity analyses:

- Low-dose aspirin, defined as ≤100 mg/day.
- CRC incidence to include secondary CVD prevention populations in addition to primary CVD prevention.
- CRC incidence in studies that prespecified that outcome.
- Trials partly or fully conducted after Adult Treatment Panel (ATP) III (2001), a proxy for more widespread statin use. We hypothesize that there may be lower potential benefit of aspirin in contemporary trials because of greater statin use, more aggressive blood pressure (BP) control, lower smoking rates, and more pervasive CRC screening. Trial date was chosen as a proxy for statin use because only about half of primary prevention trials reported actual baseline statin use.

Because these studies were conducted in relatively healthy primary prevention populations, most outcomes were rare (i.e., generally <10% of participants experienced any given event, and <1% to 2% for some outcomes). Due to these rare events, we used the Peto fixed effects model for our primary statistical method.^48^ Sensitivity analyses were conducted with the Mantel-Haenszel fixed effects model and the random effects restricted maximum likelihood (REML) model. We assessed the proportion of statistical heterogeneity using the I^2^ statistic. We assessed small study bias using funnel plots and the Harbord test of bias for extracranial bleed, intracranial bleed, all-cause mortality, CVD mortality, and major CVD events. All analyses were conducted in Stata version 16 (StataCorp LP, College Station, TX).

Forest plots show calculated Peto odds ratios (OR) using the number of individuals with an event and the numbers of people analyzed in each randomized group. When events were reported as per unit of patient-years and the number of patient-years in each group was reported, we calculated the number of events in each group. We used first-event analyses when trials reported both first and total event analyses. We chose this more conservative approach because after a first event, patients are more likely to have a second event in the same category.

The range of absolute benefits or harms in the individual trials were calculated when the pooled outcomes showed statistically significant relative effects. These absolute benefits or harms do not represent pooled estimates. Absolute risk differences were not pooled due to rare events or differing event rates among studies; combined estimates of absolute risk differences typically have lower statistical power and result in more conservative confidence intervals.^48^

For CRC outcomes, IPD MAs were only used to obtain CRC incidence and mortality data for individual trials. We did not pool the results of IPD MAs with primary trials. Further, because these IPD MAs include only a subset of our included studies, we do not discuss their pooled results.

The handling of long-term observational followup from the randomized trials differed by outcome. We do not hypothesize a direct persistent effect of aspirin on CVD or bleeding outcomes for extended periods after discontinuation, thus, long-term observational followup for these outcomes are acknowledged in tables but were not pooled with randomized followup periods. In contrast, there could be persistent effects of aspirin on CRC incidence or mortality if aspirin prevents adenomas or adenoma progression and the randomized periods were too short to detect eventual reductions in CRC incidence or mortality. We report long-term observational followup for CRC outcomes in tables and pool estimates including long-term observational followup together. In addition to published results, Women’s Health Study (WHS) investigators provided unpublished trial period and observational followup data for CRC incidence and mortality.^49^

For our subquestions on duration (KQ1b, KQ2b), we evaluated Kaplan-Meier curves as published in the primary literature. For each relevant outcome, we assessed if there were timepoints where Kaplan-Meier curves diverged, and whether separation of curves persisted.

### Analysis Methods in Specific Populations

We prespecified analyses in specific populations defined by age, sex, 10-year cardiovascular risk, race and ethnicity, and diagnosis of diabetes mellitus to determine if there is evidence that the relative effects of aspirin differ in specific populations. During data abstraction we entered results for these subgroup analyses into our database and developed population-specific summary tables. In addition to outcomes, population-specific summary tables included information relevant to the credibility of each trial’s subgroup analyses, including timing of the analysis and interaction testing for heterogeneity of treatment effect. Direct evidence from within-study comparisons was emphasized over across-study comparisons, which can be confounded by trial-level differences in populations and their risk factors.

During the data abstraction phase, we also catalogued the availability and characteristics of other subgroup analyses reported in the primary literature that we did not prespecify for our systematic review. This audit was used to assess whether additional post hoc formal subgroup analyses were warranted, based on the number of contributing studies and the credibility of subgroup analyses for each subpopulation of interest.

Because of trial-level heterogeneity in population recruitment, dose, duration, and recency, there are limitations to using trial-level analyses to investigate heterogeneity of treatment effect in specific populations, and we were unable to pool results. The most appropriate method for investigating a differential effect of aspirin in specific populations is with the use of individual patient-data meta-analyses. The 2009 Antithrombotic Trialists’ (ATT) Collaboration IPD MA is a robust source for these data; however, it does not include the most recently published trials.^50^ An update to this analysis is in progress and is expected in 2021.^51^ In the absence of an updated IPD MA, we have prioritized within-trial analyses in our investigation of effects in specific populations.

For our subquestions KQ1a and KQ2a on whether the benefits or harms of aspirin vary in specific a priori identified populations, we constructed a population-specific credibility rating table to organize findings related to the credibility of subpopulation analyses and consistency of conclusions.

## Grading the Strength of the Body of Evidence

The strength of evidence for each primary outcome as identified in the Data Analysis section was graded using an adaptation of the Evidence-based Practice Center approach,^52^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^53^ This adaptation explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations, risk of bias). We do not evaluate the fifth domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there was insufficient evidence for a particular outcome). Study quality summarizes the quality ratings of the individual trials included for an outcome and indicates the degree to which the results are likely to have adequately low risk of bias. The limitations domain highlighted important restrictions in answering the overall KQ (e.g., lack of replication of interventions, nonreporting of outcomes important to patients or nonreporting of outcomes in some trials).

The overall strength of evidence was graded as “high,” “moderate,” “low,” or “insufficient.” “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. At least two independent reviewers rated the overall strength of evidence for each intervention type. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft of the analytic framework, KQs, and inclusion/exclusion criteria was posted on the USPSTF website for public comment from January 30, 2020 to February 26, 2020. In response to public comment, analyses by race and ethnicity were added as a priori analyses for both key questions. In addition, the availability of other subgroup analyses, such as those based on CRC risk, was audited and addressed in the report according to USPSTF methods for analyses in specific populations. A final Research Plan was posted on the USPSTF website on May 14, 2020. The draft version of this report was reviewed by six invited experts and four individuals at USPSTF Federal Partner agencies. Experts were selected based on their expertise with both methodologic and content aspects of the review and were selected to obtain diverse informed perspectives. All expert comments were considered, and the report was updated to improve clarity, ensure accuracy, and address scientifically relevant concerns. The draft report was posted for public comment from October 5, 2021 to November 16, 2021. Based on public comment, text was edited for clarity and several references were added. All comments were shared with members of the USPSTF and the Agency for Healthcare Research and Quality (AHRQ).

## USPSTF and AHRQ Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions and to resolve issues around scope for the final evidence synthesis.

AHRQ staff provided oversight for the project, coordinated the systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.