# Chapter 1 Introduction

The 2016 U.S. Preventive Services Task Force (USPSTF) recommendation Aspirin Use to Prevent Cardiovascular Disease and Colorectal Cancer^1^ considered data from multiple systematic reviews^2–4^ and a decision analysis^5^ in order to estimate the net benefits of aspirin use for the prevention of two highly prevalent diseases: cardiovascular disease (CVD) and colorectal cancer (CRC). This single systematic review summarizes the findings related to aspirin for the prevention of both conditions as well as bleeding risks associated with aspirin use for primary prevention.

## Condition Definition

In the context of this systematic review, aspirin has been considered for the primary prevention of two conditions: CVD and CRC.

CVD refers to a class of diseases that affect the cardiovascular system. CVD can affect the heart, blood vessels, brain, kidneys, and arteries.^6^ Atherosclerosis and hypertension are the most common underlying causes of CVD. Types of CVD include coronary heart disease, cardiomyopathy, hypertensive heart disease, heart failure, cardiac dysrhythmias, inflammatory heart diseases, valvular heart disease, stroke, cerebrovascular disease, and peripheral arterial disease.^6^

CRC is a cancer that originates in the large intestine and includes the following segments: the cecum, ascending colon, transverse colon, descending colon, sigmoid, and rectum.

## Prevalence and Burden

### Cardiovascular Disease

Cardiovascular disease is the leading cause of mortality in the United States for both sexes.^7,^ ^8^ Although the relative rate of CVD mortality steadily declined from 1980 to 2010, recent years have witnessed an increase in CVD mortality rates.^7^ Researchers have posited that increases in rates of obesity, metabolic syndrome, and type 2 diabetes may be related to CVD mortality increases.^9,^ ^10^ In addition to high rates of mortality, 2015-2018 National Health and Nutrition Examination Survey (NHANES) data estimate that as many as 26.1 million adults in the United States live with the burden of a CVD diagnosis, defined as coronary heart disease (CHD), heart failure, or the consequences of a stroke.^7^

Each year, an estimated 605,000 Americans have a first heart attack and about 610,000 experience a first stroke.^7^ High rates of CVD mortality and morbidity represent a significant economic burden to the health care system in the United States. The estimated direct and indirect cost of CVD for 2016 to 2017 was $363.4 billion.^11^ While CVD impacts much of the population, the distribution of burden and risk factors varies among specific populations.

The prevalence of CVD increases progressively with age and is strongly influenced by the presence of risk factors. NHANES estimates from 2015-2018 show that while CVD is rare in males and females 20 to 39 years of age (1.1% and 1.2%, respectively), prevalence is highly common by the sixth or seventh decade (27.1% and 18.2% for males and females, respectively) (Table 1).^7^ By the age of 45 years, the lifetime risk of CVD events in adults with optimal risk factor profiles (total cholesterol level <180 mg/dL, blood pressure <120/80 mm Hg, nonsmoking status, and nondiabetic status) compared to adults with one major risk factor varies greatly: 1.4 versus 39.6 percent among males and 4.1 versus 20.2 percent among females. Having two or more major risk factors further increases lifetime risk to 49.5 percent in males and 30.7 percent in females.^12^ While males carry a higher overall burden of cardiovascular disease after age 60, females experience higher mortality from certain cardiovascular events, such as stroke.^7^ Males tend to experience CVD events earlier in life. For myocardial infarction (MI), the mean age of first event is 65.6 years for males and 72.0 years for females.^7^ In addition to age and sex differences, the burden of CVD also differs by race and ethnicity (Table 2). Among both sexes, Black Americans have the highest prevalence of CVD.^7^ Differences in CVD prevalence by race and ethnicity are likely multifactorial with recent studies suggesting that disparities are more likely driven by nonbiologic and societal factors rather than genetic factors.^13,^ ^14^ Structural racism, socioeconomic inequality, environmental disparities, unequal access to care, and medication acceptance are all mechanisms contributing to inequities.^13^

Table 1 Prevalence of CVD (CHD, HF, and Stroke) by Age From NHANES 2015-2018^7^

Age, years | Males, % | Females, %
20-39 | 1.1 | 1.2
40-59 | 8.6 | 8.4
60-79 | 27.1 | 18.2
80+ | 42.9 | 31.3

Abbreviations: CHD = coronary heart disease; CVD = cardiovascular disease; HF = heart failure; NHANES = National Health and Nutrition Examination Survey

Table 2 Age-Adjusted Prevalence of CVD (CHD, HF, and Stroke) in Adults Age ≥20 Years by Race and Ethnicity From NHANES 2015-2018^7^

Race and Ethnicity | Males, % | Females, %
All | 10.4 | 8.4
Non-Hispanic White | 10.4 | 7.8
Black | 11.0 | 11.5
Hispanic | 8.7 | 8.1
Asian | 6.8 | 4.2
American Indian/Alaska Native | Not reported | Not reported

Abbreviations: CHD = coronary heart disease; CVD = cardiovascular disease; HF = heart failure; NHANES = National Health and Nutrition Examination Survey

### Colorectal Cancer

CRC is the third leading cause of cancer death for both males and females^15^; it is estimated that 53,200 people in the United States will die from CRC in 2020.^16^ Although death rates due to CRC have been falling on average 2.2 percent each year in the past decade, the burden of disease remains high. In 2020, CRC was estimated to represent 8.2 percent of incident cancers, with an estimated 147,950 people receiving a new diagnosis of CRC.

CRC incidence is higher for those who are male, older, and Black (Figure 1). Black males and females have the highest incidence of CRC among all racial/ethnic groups and also the highest CRC mortality: the annual CRC-related death rate overall is 16.3 deaths per 100,000 males and 11.5 deaths per 100,000 females of all races, but it is 22.5 deaths per 100,000 in Black males and 14.8 deaths per 100,000 in Black females.^16^ While CRC is more common with increasing age, recent trends indicate CRC is increasing among those under 50 years of age.^17,^ ^18^ In 2018, 69 percent of U.S. adults 50 years and older were up to date with CRC screening and aspirin’s role in CRC prevention may be lessened by increased screening rates.^19^

Figure 1 Age-Specific Colorectal Cancer Incidence Rates/100,000 by Race and Ethnicity, United States, 1999-2014

Note: Data combined from the Center for Disease Control and Prevention National Program of Cancer Registries and the National Cancer Institute Surveillance, Epidemiology and End Results Program.^195^

* Not mutually exclusive from race categories

Abbreviations: AI = American Indian; AN = Alaska Native; CRC = colorectal cancer; PI = Pacific Islander

Figure 1 shows the age-specific colorectal cancer incidence rates/100,000 by race and ethnicity in the United States for the years 1999-2014.

## Risk Factors and Risk Assessment

### Cardiovascular Disease

Risk factors for CVD are well established and include both modifiable and nonmodifiable components. Modifiable risk factors include high cholesterol, high blood pressure, diabetes, overweight and obesity, smoking, lack of physical activity, excessive alcohol use, and unhealthy diet. Nonmodifiable risk factors include age, sex, and family history of CVD.^20^

Cardiovascular risk can be estimated using multivariate equations that predict the risk of an event over 10 years. The Pooled Cohort Equations (PCE) are currently the standard of practice for risk assessment and provide sex- and race-specific estimates for Black and White males and females 40 to 79 years of age for 10-year risk of atherosclerotic cardiovascular disease events (CHD death, nonfatal MI, and fatal or nonfatal stroke).^21^ In addition to sex and race, risk predictors include age, total cholesterol, high-density lipoprotein (HDL) cholesterol, systolic blood pressure (including treatment status), diabetes, and current smoking status. PCE risk thresholds are included in several recommendations from the USPSTF, including the prior aspirin recommendation and the recommendation for statins,^22,^ ^23^ and are also part of recommendations from other professional societies.^24^ The 2019 American College of Cardiology/American Heart Association (ACC/AHA) primary prevention guidelines discuss the limitations of risk assessment scores, including known under- and overestimation in specific populations, and state that it may be reasonable to use additional risk-enhancing factors and then coronary artery calcium scores to guide decision-making for borderline risk (5 to <7.5% 10-year risk) or intermediate risk (≥7.5% to <20% 10-year risk) individuals if uncertainty remains.^24^ Ongoing research gaps and areas needing clinical guidance involve risk estimation for Hispanic, Asian, and “American Indian” populations, for which there are not separate equations in the PCE. The original 2013 ACC/AHA guideline stated that the equations for nonHispanic White individuals could be considered for use in these groups, however, that risk may be overestimated for Hispanic and Asian populations and underestimated for “American Indian” men and women.^21^ Further discussion of PCE limitations can be found in the Discussion section.

Based on NHANES 2015-2018 data, the vast majority of Americans aged 40 to 49 years have an estimated 10-year CVD risk of 10 percent or less using the PCE (96% of females and 92% of males).^25^ For ages 50 to 59 years, 87 percent of females and 68 percent of males have estimated 10-year risk of 10 percent or less; at ages 60 to 69, 66 percent of females and 20 percent of males have estimated 10-year risk at this level. Estimated 10-year risk using the PCE is substantially different by race. For example, among Black males aged 50 to 59 years, 37 percent have an estimated 10-year risk less than 10 percent; this prevalence is 73 percent among White males.^25^

### Colorectal Cancer

Many risk factors for CRC overlap with prominent risk factors also associated with CVD. Modifiable risk factors associated with higher incidence of CRC include excessive alcohol use, cigarette smoking, and physical inactivity.^26^ Nonmodifiable risk factors include older age, history of adenomas, inflammatory bowel disease, family history of CRC or adenomas, and inherited conditions such as Lynch syndrome, Peutz-Jeghers syndrome, and MHY-associated polyposis.^27^

Risk assessment models for CRC are not routinely used in clinical practice, although many different risk models have been developed.^28^ Risk factors commonly used in models include age, sex, family history (generally specified as first degree relatives), body mass index (BMI), and lifestyle factors (e.g., smoking, alcohol, diet, and exercise).

## Mechanism of Action

Aspirin’s mechanism of action to promote CVD prevention is well-known, but its role in CRC prevention is less understood. Aspirin, an irreversible cyclooxygenase (COX)-1 and -2 enzyme inhibitor, reduces the risk for atherothrombosis through the inhibition of platelet function (through COX-1 inhibition), and has been used widely for decades for the prevention of CVD events, particularly in secondary prevention populations.^29^ The biomolecular mechanism for aspirin’s possible anti-neoplastic effects are not well-understood nor widely accepted. The postulated mechanism includes both COX-dependent (increased cell apoptosis, reduced COX-catalyzed prostaglandin production), and non-COX dependent anti-cancer activity. Lower doses of aspirin preferentially inhibit COX-1 pathways while higher doses additionally inhibit COX-2 pathways; it has been postulated that aspirin’s antineoplastic effects may be mediated through the COX-1 and COX-2 pathway along with modulation of oncogene-induced expression of transcription factors.^30^

The COX-1 enzyme is also responsible for producing a variety of prostaglandins with roles to protect the gastrointestinal (GI) mucosa.^31^ By inhibiting this enzyme, aspirin use can promote GI bleeding.^32^ At higher doses (≥300 mg/day), aspirin begins to inhibit COX-2 activity, taking on greater anti-inflammatory effects, but also increases the inhibition of prostaglandins produced by COX-1, further increasing the risk of GI bleeding.^32–34^

## Recommendations of Others

Several guidelines have addressed aspirin’s role in primary CVD prevention to accompany other CVD risk modification interventions including behavioral interventions for healthy eating, exercise and smoking cessation, blood pressure management, and statin therapy. Recommendations for aspirin for CVD primary prevention have focused on identifying primary prevention patients at sufficiently high CVD risk to outweigh bleeding harms. Recent U.S.-based recommendations by the ACC/AHA^24^ and the American Diabetes Association (ADA)^35^ recommend aspirin for selected patients, but neither recommend a specific PCE threshold for aspirin consideration (Table 3). European recommendations^36–38^ do not recommend the use of aspirin in primary prevention. The Cancer Council of Australia is the only organization advising consideration of aspirin for primary CRC prevention (Table 4), with other organizations recommending aspirin only for groups at increased risk of CRC.

Table 3 Recommendations of Others for the Primary Prevention of CVD Using Aspirin

Organization/Professional Society | Year | Recommendation
American Diabetes Association (ADA)^196^ | 2020 | Aspirin therapy (75–162 mg/day) may be considered as a primary prevention strategy in those with diabetes who are at increased cardiovascular risk, after a comprehensive discussion with the patient on the benefits versus the comparable increased risk of bleeding. Recommendations for using aspirin as primary prevention include both men and women aged ≥50 years with diabetes and at least one additional major risk factor (family history of premature ASCVD, hypertension, dyslipidemia, smoking, or chronic kidney disease/albuminuria) who are not at increased risk of bleeding (e.g., older age, anemia, renal disease). Noninvasive imaging techniques such as coronary calcium scoring may potentially help further tailor aspirin therapy, particularly in those at low risk. For patients over the age of 70 years (with or without diabetes), the balance appears to have greater risk than benefit. Thus, for primary prevention, the use of aspirin needs to be carefully considered and may generally not be recommended. Aspirin may be considered in the context of high cardiovascular risk with low bleeding risk, but generally not in older adults. Aspirin therapy for primary prevention may be considered in the context of shared decision-making, which carefully weighs the cardiovascular benefits with the fairly comparable increase in risk of bleeding.
American College of Cardiology/American Heart Association (ACC/AHA)^24^ | 2019 | Low-dose aspirin (75 to 100 mg/day) might be considered for the primary prevention of ASCVD among select adults 40 to 70 years of age at higher CVD risk but not at increased bleeding risk. Low-dose aspirin use is not recommended on a routine basis for primary prevention of CVD in adults over 70 years, or among adults of any age who are at increased risk of bleeding.
NICE Clinical Knowledge Summaries^36^ | 2018 | Do not routinely prescribe antiplatelet treatment for the primary prevention of CVD. Consider prescribing aspirin in people with a high risk of stroke or myocardial infarction.
American Academy of Family Physicians (AAFP)^197^ | 2016 | Previous and current recommendations from the AAFP regarding aspirin use reflect those of the USPSTF.
Scottish Intercollegiate Guidelines Network (SIGN)^38^ | 2017 | Aspirin is not recommended for primary prevention of cardiovascular disease.
European Guidelines on CVD Prevention in Clinical Practice^37^ | 2016 | Antiplatelet therapy is not recommended in individuals without CVD due to the increased risk of major bleeding.; Antiplatelet therapy (e.g. with aspirin) is not recommended for people with DM who do not have CVD.

Abbreviations: ASCVD = atherosclerotic cardiovascular disease; CVD = cardiovascular disease; mg = milligram; DM = diabetes mellitus; USPSTF = United States Preventive Services Task Force

Table 4 Recommendations of Others for the Primary Prevention of CRC Using Aspirin

Organization/Professional Society | Year | Recommendation
American College of Gastroenterology (ACG)^41^ | 2021 | Low-dose aspirin in individuals between ages 50–69 years with a cardiovascular disease risk of ≥10% over the next 10 years, who are not at an increased risk for bleeding and willing to take aspirin for at least 10 years may be considered to reduce the risk of CRC.; Aspirin as a substitute for CRC screening is not recommended.
American Gastroenterological Association (AGA)^42^ | 2021 | In individuals at average risk for CRC who are 1) younger than 70 years with a life expectancy of at least 10 years, 2) have a 10-year cardiovascular disease risk of at least 10%, and 3) not at high risk for bleeding, clinicians should use low-dose aspirin to reduce CRC incidence and mortality.; In individuals with a history of CRC, clinicians should consider using aspirin to prevent recurrent colorectal neoplasia.; In individuals at average risk for CRC, clinicians should not use non-aspirin NSAIDs to prevent colorectal neoplasia because of a substantial risk of cardiovascular and gastrointestinal adverse events.
American Cancer Society (ACS)^198,^ ^199^ | 2019 | The ACS has not formally reviewed evidence or released an official guideline advocating for or against aspirin use but has publicly acknowledged that long-term regular aspirin use has both harms and benefits, including reducing risk for CRC.
Cancer Council of Australia (CCA)^40^ | 2019 | For all people aged 50–70 years who are at average risk of colorectal cancer, aspirin should be actively considered to prevent colorectal cancer. A low dose (100–300 mg per day) is recommended for at least 2.5 years, commencing at age 50 to 70 years. The benefit may extend to older ages with longer duration of use. Benefit for cancer prevention (though shorter for cardiovascular risk) is evident only 10 years after initiation so a life expectancy of at least 10 years should be taken into consideration in the advice to use aspirin.; The choice to take aspirin should be personalized based on age, sex and potential reduction in cardiovascular events, cerebrovascular events and thrombotic stroke. The individual should take into account the potential risks of taking aspirin. Aspirin should be avoided in patients with current dyspepsia, any history of peptic ulcer, aspirin allergy, bleeding diathesis, an increased risk of gastrointestinal hemorrhage (such as associated with use of oral anticoagulants or antiplatelet agents), or renal impairment.; The benefit in colorectal cancer risk reduction in women over 65 is less clear cut. However, based on limited data available, older women with cardiovascular risk factors may derive a greater overall benefit than harm.; People who are at high risk of colorectal cancer due to Lynch Syndrome carrier status should be advised to begin aspirin from the commencement of their colonoscopy screening (usually at age 25 years).; Non-syndromic familial cancer patients should be actively considered for aspirin, bearing in mind the possibility of adverse events.; 600 mg/day has been shown to be effective, but lower dose (100 mg/day) may be as effective and is recommended based on the data available at the time of the systematic review.
National Institute for Health and Care Excellence (NICE)^*^,^200^ | 2020 | Patients diagnosed with Lynch Syndrome should begin daily aspirin therapy to reduce risk of CRC. No statement regarding aspiring for CRC prevention in other populations has been made.
National Comprehensive Care Network (NCCN) | 2015 | Aspirin should only be used for patients at increased risk of CRC.

* Update in progress

Abbreviations: CRC = colorectal cancer; mg = milligram

## Current U.S.-Based Clinical Practice

In the United States, aspirin use for the primary prevention of CVD is common and is often self-initiated rather than recommended by a physician. Data from the 2017 National Health Interview Survey (NHIS) found that 23.4 percent of adults age 40 or older and without CVD took aspirin for primary prevention and of these, 22.8 percent took aspirin without a physician’s recommendation.^39^ Older age, male sex, and the presence of CVD risk factors such as hypertension, high cholesterol, and diabetes, were associated with increased aspirin use. Among adults 50-59 years, 18.4 percent reported aspirin use; among adults 60-69 years, 34.7 percent reported aspirin use. Nearly half of adults aged 70 or older reported aspirin use; this is an age range for which the USPSTF has an I recommendation (insufficient evidence to make a recommendation) and the ACC/AHA has a recommendation against.

Several organizations have recently recommended that aspirin be considered for the primary prevention of CRC.^40–42^ There are no data currently available regarding physician practices for aspirin in the prevention of CRC in populations at average or high risk for CRC.