# Appendix F Ongoing Studies

Trial | Location | N | Duration (years) | Intervention | Relevant outcomes | Trial registry no. | Est. completion date
Aspirin Withdrawal and Clinical Outcome in Patients With Moderate to High Cardiovascular Risk But Without Cardiovascular Disease | Korea | 4,118 | 5 | Aspirin (dose NR) | CVD events | NCT03757156 | November 2024
ASPREE Cancer Endpoints Study (ACES) | US | 14,500 | NR | Low-dose aspirin (100 mg/day) | Incidence or recurrence of cancer | NCT01968798 | April 2024
ASCEND Cancer Long Term Followup | UK | 15,480 | NR | Low-dose aspirin (100 mg/day) | Incidence of cancer | NCT00135226 | Long-term completion NR
ENgAGE-HK (cohort) | Hong Kong | NR | NR | Low-dose aspirin (details NR) | Incidence of colorectal, gastric, and esophageal cancer; related mortality | NCT04081831 | November 2019
Patient-centered Benefit-risk Observational Study of Low-dose Aspirin for CVD and CRC Prevention | Italy | 1,028 | NR | Low-dose aspirin (details NR) | Patient risk/benefit trade off; change in likelihood of adverse events; preferences of aspirin use in specific populations | NCT03603366 | October 2019

Abbreviations: ACCEPT-D = Aspirin and simvastatin Combination for Cardiovascular Events Prevention Trial in Diabetes; CVD = cardiovascular disease; CRC = colorectal cancer; ENgAGE-HK = Effectiveness of Low-dose Aspirin in Decreasing Chance of Getting Stomach and Intestine cancer – Hong Kong; Est = estimated; ICH = intracranial hemorrhage; ISRCTN = International Standard Randomised Controlled Trial Number; mg/day = milligrams per day; MI = myocardial infarction; N = number of participants; NCT = National Clinical Trial number; no = number; NR = not reported; UK = United Kingdom; US = United States