# Appendix E Funnel Plots

Appendix E Figure 1 Extracranial Bleeds Funnel Plot

Harbord test for small study effects p=0.02

This figure displays a funnel plot of extracranial bleeds reported in the included trials. The Harbord effect for small study effects shows p=0.02.

Appendix E Figure 2 Intracranial Bleed Funnel Plot

Harbord test for small study effects p=0.35

This figure displays a funnel plot of intracranial bleeds reported in the included trials. The Harbord effect for small study effects shows p=0.35.

Appendix E Figure 3 Major CVD Events Funnel Plot

Harbord test for small study effects p=0.61

This figure displays a funnel plot of major CVD events reported in the included trials. The Harbord effect for small study effects shows p=0.61.

Appendix E Figure 4 All-Cause Mortality Funnel Plot

Harbord test for small study effects p=0.37

This figure displays a funnel plot of all-cause mortality reported in the included trials. The Harbord effect for small study effects shows p=0.37.

Appendix E Figure 5 CVD Mortality Funnel Plot

Harbord test for small study effects p=0.19

This figure displays a funnel plot of CVD mortality reported in the included trials. The Harbord effect for small study effects shows p=0.19.