# Appendix D Evidence Tables

Appendix D Table 1 Primary and Secondary Outcomes in Included Trials

Appendix D Table 2 Adherence and Crossover in Included Trials

Appendix D Table 3 Landscape of Included Trials’ Reporting Analyses in Specific Populations

Appendix D Table 4 Key Question 1: Effect of Aspirin on Major CVD Events by Age

Appendix D Table 5 Key Question 1: Effect of Aspirin on Myocardial Infarction by Age

Appendix D Table 6 Key Question 1: Effect of Aspirin on Stroke by Age

Appendix D Table 7 Key Question 1: Effect of Aspirin on Colorectal Cancer by Age

Appendix D Table 8 Key Question 1: Effect of Aspirin on Major CVD Events by Sex

Appendix D Table 9 Key Question 1: Effect of Aspirin on Myocardial Infarction By Sex

Appendix D Table 10 Key Question 1: Effect of Aspirin on Stroke by Sex

Appendix D Table 11 Key Question 1: Effect of Aspirin on Colorectal Cancer by Sex

Appendix D Table 12 Key Question 1: Effect of Aspirin on Major CVD Events by Race/Ethnicity

Appendix D Table 13 Key Question 1: Effect of Aspirin on Major CVD Events by Diabetes Mellitus

Appendix D Table 14 Key Question 1: Effect of Aspirin on Myocardial Infarction by Diabetes Mellitus

Appendix D Table 15 Key Question 1: Effect of Aspirin on Stroke by Diabetes Mellitus

Appendix D Table 16 Key Question 1: Effect of Aspirin on Colorectal Cancer by Diabetes Mellitus

Appendix D Table 17 Key Question 1: Effect of Aspirin on Major CVD Events by CVD Risk

Appendix D Table 18 Key Question 1: Effect of Aspirin on MI by CVD Risk

Appendix D Table 19 Key Question 1: Effect of Aspirin on Stroke by CVD Risk

Appendix D Table 20 Key Question 2: Effect of Aspirin on Serious Harms by Age

Appendix D Table 21 Key Question 2: Effect of Aspirin on Serious Harms by Sex

Appendix D Table 22 Key Question 2: Effect of Aspirin on Serious Harms by Diabetes Mellitus

Appendix D Table 23 Credibility Rating for Evidence in Specific Populations

Appendix D Table 24 Selected Multivariate Analyses Reporting Risk Factors Associated With Major GI Bleeding