# Appendix C Excluded Studies

Code | Exclusion
E1 | Study relevance
E2 | Setting (not a very high index country)
E3 | Population
E3a | Population: Patients with existing cardiovascular disease diagnosis or history
E3b | Population: Patients with a-fib, familial hypercholesterolemia, or hypercoagulable disorders
E3c | Population: Children or adults less than 40 years of age
E3d | Population: Observational study with less than 10,000 patients
E4 | Study design: Not a randomized controlled trial or clinical control trial (Key Question 1 only)
E5 | Intervention: Not relevant intervention/agent
E5a | Intervention: Duration less than 1 year
E5b | Intervention: Dose - Aspirin dose less than 75 milligrams every other day, dose not reported, or irregular or occasional use
E5c | Intervention: Non-oral or non-tablet forms of aspirin
E5d | Intervention: Aspirin as a co-treatment
E6 | Comparisons: Any active substance or intervention
E7 | Outcomes
E8 | Study quality
E9 | Non-English publication
E10 | Publication type (i.e., conference abstracts)

Reference | Code
Allison, Matthew, Garland, Cedric, . The association between aspirin use and the incidence of colorectal cancer in women. Am J Epidemiol. 164(6): 567–575. 2006. PMID: 16847042. 10.1093/aje/kwj250 16847042 16847042 | KQ1E4; KQ2E7
Almas A, Ghazni MS, Hashmani S, Mushtaq Z. Aspirin in Primary Prevention of Myocardial Infarction/Angina and Stroke in Hypertensive Patients. Jcpsp, Journal of the College of Physicians & Surgeons - Pakistan. 28(7): 574. 2018. PMID: 29950269. 10.29271/jcpsp.2018.07.574 29950269 | KQ1E2; KQ2E2
Aspirin in coronary heart disease. The Coronary Drug Project Research Group. Circulation. 62(6 Pt 2): V59–62. 1980. PMID: 7002353.7002353 | KQ1E3a; KQ2E3a
Aspirin in coronary heart disease. The Coronary Drug Project Research Group. J Chronic Dis. 29(10,0021-9681 (Print),0021-9681 (Linking): 625–642. 1976. PMID: None.789390 | KQ1E3a; KQ2E3a
Aspirin Myocardial Infarction Study: design, methods and baseline results. US Department of Health and Human Services, Public Health Services, National Institutes of Health, 1980. 1980. PMID: None. | KQ1E3a; KQ2E3a
At Chan, P Gibbs, S Orchard, J Lockery, . Effect of initiating aspirin on cancer events in the healthy elderly: Primary results from the aspree randomized controlled trial. Gastroenterology. Conference: 2019 DDW. United States. 156(6 s1): S-78–s-79. 2019. PMID: None. | KQ1E10; KQ2E10
Baigent, C, Blackwell, L, . Aspirin in the primary and secondary prevention of vascular disease: collaborative meta-analysis of individual participant data from randomised trials. Lancet. 373(9678): 1849–60. 2009. PMID: 19482214. 10.1016/s0140-6736(09)60503-1 19482214 | KQ1E11; KQ2E11
Barker AL, McNeil JJ, Seeman E, Ward SA, . A randomised controlled trial of low-dose aspirin for the prevention of fractures in healthy older people: protocol for the ASPREE-Fracture substudy. Injury Prevention. 22(4): 297–301. 2016. PMID: 26002770. 10.1136/injuryprev-2015-041655 26002770 | KQ1E7; KQ2E7
Baron, JA, Cole, BF, . A randomized trial of aspirin to prevent colorectal adenomas. N Engl J Med. 348(10): 891–899. 2003. PMID: 12621133. 10.1056/NEJMoa021735 12621133 | KQ1E3; KQ2E3
Bavry AA, Thomas F, Allison M, Johnson KC, . Nonsteroidal anti-inflammatory drugs and cardiovascular outcomes in women: results from the women’s health initiative. Circ Cardiovasc Qual Outcomes. 7(4): 603–10. 2014. PMID: 25006185. 10.1161/CIRCOUTCOMES.113.000800 25006185 | KQ1E5; KQ2E5
Becattini, C, Agnelli, G, . Aspirin for preventing the recurrence of venous thromboembolism.. N Engl J Med. 366(21): 1959–1967. 2012. PMID: 22621626.22621626 | KQ1E3; KQ2E3
Belcaro G, Cesarone MR, Scipione C, Scipione V, . Delayed progression of atherosclerosis and cardiovascular events in asymptomatic patients with atherosclerotic plaques: 3-year prevention with the supplementation with Pycnogenol R+Centellicum R. Minerva Cardioangiol. 68(1): 15–21. 2020. PMID: 31625707. 10.23736/S0026-4725.19.05051-5 31625707 | KQ1E1; KQ2E1
Benamouzig R, Uzzan B, Deyra J, Martin A, . Prevention by daily soluble aspirin of colorectal adenoma recurrence: 4-year results of the APACC randomised trial. Gut. 61(2): 255–61. 2012. PMID: 21890814. 10.1136/gutjnl-2011-300113 21890814 | KQ1E3; KQ2E3
Benamouzig, R, Deyra, J, . Daily soluble aspirin and prevention of colorectal adenoma recurrence: one-year results of the APACC trial. Gastroenterology. 125(2): 328–36. 2003. PMID: 12891533. 10.1016/s0016-5085(03)00887-4 12891533 | KQ1E3; KQ2E3
Benamouzig, R, Yoon, H, . APACC, a French prospective study on aspirin efficacy in reducing colorectal adenoma recurrence: design and baseline findings. Eur J Cancer Prev. 10(4,0959-8278 (Print),0959-8278 (Linking): 327–335. 2001. PMID: 11535875. 10.1097/00008469-200108000-00006 11535875 | KQ1E3; KQ2E3
Bernard-Hardy, JM, Cunha, L, . European Stroke Prevention Study 2: baseline data. J Neurol Sci. 131(Suppl): 1–58. 1995. PMID: 7500119.7500119 | KQ1E3a; KQ2E3a
Bouget, J, Balusson, F, . Major bleeding risk and mortality associated with antiplatelet drugs in real-world clinical practice. A prospective cohort study. PLoS One. 15(8): e0237022. 2020. PMID: 32764775. 10.1371/journal.pone.0237022 32764775 | KQ1E7; KQ2E4
Bowman L, Mafham M, Wallendszus K, Stevens W, . Effects of aspirin for primary prevention in persons with diabetes mellitus: the ASCEND Study Collaborative Group. J Vasc Surg. 69(1): 305. 2019. PMID: None. 10.1016/j.jvs.2018.10.072 | KQ1E10; KQ2E10
Brasky TM, Liu J, White E, Peters U, . Non-steroidal anti-inflammatory drugs and cancer risk in women: results from the Women’s Health Initiative. Int J Cancer. 135(8): 1869–83. 2014. PMID: 24599876. 10.1002/ijc.28823 24599876 | KQ1E4; KQ2E7
Brasky, TM, Potter, JD, . Non-steroidal anti-inflammatory drugs and cancer incidence by sex in the VITamins And Lifestyle (VITAL) cohort. Cancer Causes Control. 23(3): 431–44. 2012. PMID: 22212612. 10.1007/s10552-011-9891-8 22212612 | KQ1E4; KQ2E7
Brighton, TA, Eikelboom, JW, . Low-dose aspirin for preventing recurrent venous thromboembolism. N Engl J Med. 367(21): 1979–1987. 2012. PMID: 23121403. 10.1056/NEJMoa1210384 23121403 | KQ1E3; KQ2E3
Cea Soriano L, Gaist D, Soriano-Gabarro M, Bromley S, . Low-dose aspirin and risk of intracranial bleeds: An observational study in UK general practice. Neurology. 89(22): 2280–2287. 2017. PMID: 29093065. 10.1212/WNL.0000000000004694 29093065 | KQ1E4; KQ2E4
Cea Soriano L, Gaist D, Soriano-Gabarro M, Garcia Rodriguez LA. Incidence of intracranial bleeds in new users of low-dose aspirin: a cohort study using The Health Improvement Network. Journal of Thrombosis & Haemostasis. 15(6): 1055–1064. 2017. PMID: 28371181. 10.1111/jth.13686 28371181 | KQ1E4; KQ2E6
Cea Soriano L, Gaist D, Soriano-Gabarró M, García Rodríguez LA. The importance of validating intracranial bleeding diagnoses in The Health Improvement Network, United Kingdom: Misclassification of onset and its impact on the risk associated with low-dose aspirin therapy. Pharmacoepidemiol Drug Saf. 28(2): 134–139. 2019. PMID: 29806168. 10.1002/pds.4561 29806168 | KQ1E4; KQ2E4
Cea Soriano L, Lanas A, Soriano-Gabarro M, Garcia Rodriguez LA. Incidence of Upper and Lower Gastrointestinal Bleeding in New Users of Low-Dose Aspirin. Clinical Gastroenterology & Hepatology. 17(5): 887–895.e6. 2019. PMID: 29908361. 10.1016/j.cgh.2018.05.061 29908361 | KQ1E4; KQ2E6
Cea Soriano L, Soriano-Gabarroé M, Lanas A, Garciéa Rodriéguez LA. New use of low-dose aspirin and risk of upper and lower gastrointestinal bleeding: Associations by case-fatality, hospitalisation status, bleeding location, aspirin dose and duration in a large observational study in the united kingdom. United European Gastroenterology Journal. 5(5): A136–A137. 2017. PMID: None. 10.1177/2050640617725668 | KQ1E10; KQ2E10
Cea Soriano L, Vora P, Soriano-Gabarro M, Garcia Rodriguez LA. The effect of low-dose aspirin on colorectal cancer prevention and gastrointestinal bleeding according to bodyweight and body mass index: Analysis of UK primary care data. Int J Cardiol. 297: 135–139. 2019. PMID: 31515060. 10.1016/j.ijcard.2019.08.001 31515060 | KQ1E4; KQ2E4
Chan, AT, Giovannucci, EL, . Aspirin dose and duration of use and risk of colorectal cancer in men. Gastroenterology. 134(1): 21–8. 2008. PMID: 18005960. 10.1053/j.gastro.2007.09.035 18005960 | KQ1E4; KQ2E7
Chan, AT, Giovannucci, EL, . Long-term use of aspirin and nonsteroidal anti-inflammatory drugs and risk of colorectal cancer. JAMA. 294(8): 914–923. 2005. PMID: 16118381. 10.1001/jama.294.8.914 16118381 | KQ1E4; KQ2E5b
Chan, AT, McNeil, J. Aspirin and Cancer Prevention in the Elderly: Where Do We Go From Here?. Gastroenterology. 156(3): 534–538. 2019. PMID: 30529298. 10.1053/j.gastro.2018.11.063 30529298 | KQ1E10; KQ2E10
Chiang C, Chen TC, Yeh YC, Chen YY. Aspirin as a primary prevention of cardiovascular disease in high-risk new diabetes patients: A retrospective cohort study in Taiwan. Neurology. 92(15). 2019. PMID: None. | KQ1E10; KQ2E10
Chowdhury EK, Nelson MR, Ernst ME, Margolis KL, . Factors associated with treatment and control of hypertension in a healthy elderly population free of cardiovascular disease: a cross-sectional study. Am J Hypertens. 33(4):350–361. 2020. PMID: 31807750. 10.1093/ajh/hpz192 31807750 | KQ1E7; KQ2E7
Cloud G, Donnan G, Williamson J, Eaton C, . The effect of aspirin on ischemic stroke sub-types in the healthy elderly. European Stroke Journal. 4: 69. 2019. PMID: None. 10.1177/2396987319845560 | KQ1E10; KQ2E10
Cote, R, Battista, RN, . Lack of effect of aspirin in asymptomatic patients with carotid bruits and substantial carotid narrowing. The Asymptomatic Cervical Bruit Study Group. Ann Intern Med. 123(9): 649–655. 1995. PMID: 7574219. 10.7326/0003-4819-123-9-199511010-00002 7574219 | KQ1E3a; KQ2E3a
DAMAD Study Group. Effect of aspirin alone and aspirin plus dipyridamole in early diabetic retinopathy. A multicenter randomized controlled clinical trial. The DAMAD Study Group. Diabetes. 38(4): 491–498. 1989. PMID: 2647556.2647556 | KQ1E3; KQ2E3
de Groot NL, Hagenaars MP, Smeets HM, Steyerberg EW, . Primary non-variceal upper gastrointestinal bleeding in NSAID and low-dose aspirin users: development and validation of risk scores for either medication in two large Dutch cohorts. J Gastroenterol. 49(2): 245–53. 2014. PMID: 23609946. 10.1007/s00535-013-0817-y 23609946 | KQ1E4; KQ2E4
Design of a multicenter randomized trial for the Stroke Prevention in Atrial Fibrillation Study. The Stroke Prevention in Atrial Fibrillation Investigators. Stroke. 21(4,0039-2499 (Print),0039-2499 (Linking): 538–545. 1990. PMID: 2183405. 10.1161/01.str.21.4.538 2183405 | KQ1E3b; KQ2E3b
Diener, HC. European Stroke Prevention Study 2. Efficacy and safety data. J Neurol Sci. 151(Suppl 1): S1–S77. 1997. PMID: 9276859. 10.1016/s0022-510x(97)86566-5 9276859 | KQ1E3a; KQ2E3a
Dumbleton JS, Avery AJ, Coupland C, Hobbs FD, . The Helicobacter Eradication Aspirin Trial (HEAT): A Large Simple Randomised Controlled Trial Using Novel Methodology in Primary Care. EBioMedicine. 2(9): 1200–4. 2015. PMID: 26501118. 10.1016/j.ebiom.2015.07.012 26501118 | KQ1E5; KQ2E5
Effects of aspirin treatment on diabetic retinopathy. Ophthalmology. 98(5 Suppl): 757–765. 1991. PMID: 2062511.2062511 | KQ1E3; KQ2E3
ETDRS Investigators. Aspirin effects on mortality and morbidity in patients with diabetes mellitus. Early treatment Diabetic Retinopathy Study report 12. ETDRS Investigators. JAMA. 268(10): 1292–1300. 1992. PMID: 1507375. 10.1001/jama.1992.03490100090033 1507375 | KQ1E3; KQ2E3
ETDRS Investigators. Aspirin effects on mortality and morbidity in patients with diabetes mellitus. Early Treatment Diabetic Retinopathy Study report 14. ETDRS Investigators. JAMA. 268(10): 1292–1300. 1992. PMID: 1507375. 10.1001/jama.1992.03490100090033 1507375 | KQ1E3; KQ2E3
ETDRS Investigators. Early Treatment Diabetic Retinopathy Study design and baseline patient characteristics. ETDRS report number 7. Ophthalmology. 98(5 Suppl): 741–756. 1991. PMID: 2062510. 10.1016/s0161-6420(13)38009-9 2062510 | KQ1E3; KQ2E3
Fasey, N, BRENNAN, PJ, . Thrombosis prevention trial: follow-up study of practical implications. Br J Gen Pract. 52(476): 208–209. 2002. PMID: 12030663.12030663 | KQ1E7; KQ2E7
Fernandez-Jimenez R, Latina J, Hajjar R, Fuster V, . Low dose aspirin for primary prevention of cardiovascular disease: Use patterns and impact across race in the southern community cohort study. J Am Coll Cardiol. 71(11 Suppl): A1892. 2018. 10.1016/S0735-1097(18)32433-1 | KQ1E4; KQ2E7
Friis, S, Poulsen, AH, . Aspirin and other non-steroidal anti-inflammatory drugs and risk of colorectal cancer: a Danish cohort study. Cancer Causes Control. 20(5): 731–40. 2009. PMID: 19122977. 10.1007/s10552-008-9286-7 19122977 | KQ1E4; KQ2E7
Galli M, Andreotti F, D’Amario D, Vergallo R, . Aspirin in Primary Prevention of Cardiovascular Disease in the Elderly. Eur Heart J Cardiovasc Pharmacother. 2019. PMID: 31504373. 10.1093/ehjcvp/pvz046 31504373 | KQ1E4; KQ2E4
Garcia Rodriguez LA, Lanas A, Soriano-Gabarro M, Cea Soriano L. Low-dose aspirin and risk of upper/lower gastrointestinal bleeding by bleed severity: a cohort study with nested case-control analysis using primary care electronic health records from the United Kingdom. Ann Med. 51(2): 182–192. 2019. PMID: 31025592. 10.1080/07853890.2019.1591635 31025592 | KQ1E4; KQ2E4
Garcia Rodriguez LA, Soriano-Gabarro M, Cea Soriano L. Incidence of colorectal cancer in new users and non-users of low-dose aspirin for primary prevention of cardiovascular or cerebrovascular disease in the United Kingdom. Eur Heart J. 37(1 Suppl): 634. 2016. PMID: None. 10.1093/eurheartj/ehw433 | KQ1E10; KQ2E10
Garcia Rodriguez LA, Soriano-Gabarro M, Gaist D, Cea Soriano L. New use of low-dose aspirin and risk of intracerebral haemorrhage, subdural haematoma and subarachnoid haemorrhage: Associations by sex, case-fatality and trauma status in a large observational study. Eur Heart J. 38: 645. 2017. PMID: None. 10.1093/eurheartj/ehx504.3107 | KQ1E10; KQ2E10
García Rodríguez, LA, Vora, P, . Bleeding associated with low-dose aspirin: Comparison of data from the COMPASS randomized controlled trial and routine clinical practice. Int J Cardiol. 318: 21–24. 2020. PMID: None. 10.1016/j.ijcard.2020.06.048 32629007 | KQ1E3a; KQ2E3a
Garcia-Rodriguez L, Gabarró MS, Vora P, Soriano LC. THE EFFECT OF LOW-DOSE ASPIRIN ON COLORECTAL CANCER PREVENTION AND GASTROINTESTINAL BLEEDING ACCORDING TO BODYWEIGHT AND BODY MASS INDEX: ANALYSIS OF PRIMARY CARE DATA FROM THE UNITED KINGDOM. Gastroenterology. 156(6): S-742. 2019. PMID: None. 10.1016/S0016-5085(19)38790-6 | KQ1E4; KQ2E4
Garcia-Rodriguez L, Lanas A, Gabarró MS, Soriano LC. Risk of Both upper and Lower Gastrointestinal Bleeding Associated with Low-Dose Acetylsalicylic Acid and Proton Pump Inhibitors Among Nearly 400,000 Individuals in Routine General Practice in the United Kingdom. Gastroenterology. 154(6): S-136–S-137. 2018. PMID: None. 10.1016/S0016-5085(18)30882-5 | KQ1E10; KQ2E10
Goicoechea, M, De Vinuesa, MSG, . Aspirin treatment in primary cardiovascular prevention and renal disease progression in CKD patients: A randomized clinical trials (AASER study). J Am Soc Nephrol. 28: B5. 2017. PMID: None. | KQ1E10; KQ2E10
Guo, CG, Zhang, F, . 340 PREDICTING TREND OF UPPER AND LOWER GASTROINTESTINAL BLEEDING BASED ON POPULATION PRESCRIPTION OF ASPIRIN AND PROTON PUMP INHIBITORS. Gastroenterology. 158(6): S-59. 2020. PMID: None. 10.1016/S0016-5085(20)30829-5 | KQ1E10; KQ2E10
H Soejima, T Morimoto, S Okada, M Sakuma, . 44 % of patients with myocardial infarction are silent manifestation in diabetics. Circulation. 134. 2016. | KQ1E10; KQ2E10
Hall KT, Kessler T, Buring JE, Passow D, . Genetic variation at the coronary artery disease risk locus GUCY1A3 modifies cardiovascular disease prevention effects of aspirin. Eur Heart J. 40(41): 3385–3392. 2019. PMID: 31228190. 10.1093/eurheartj/ehz384 31228190 | KQ1E4; KQ2E4
Hirsch, C. Daily aspirin for primary prevention increased risk for major GI bleeding in healthy older adults. Ann Intern Med. 05(): 05. 2021. PMID: 19122977. 10.7326/ACPJ202101190-004 19122977 | KQ1E10; KQ2E10
Hsu J, Donnelly JP, Chaudhary NS, Moore JX, . Aspirin use and long-term rates of sepsis: A population-based cohort study. PLoS ONE [Electronic Resource]. 13(4): e0194829. 2018. PMID: 29668690. 10.1371/journal.pone.0194829 29668690 | KQ1E7; KQ2E7
Huang WY, Daugherty SE, Shiels MS, Purdue MP, . Aspirin Use and Mortality in Two Contemporary US Cohorts. Epidemiology. 29(1): 126–133. 2018. PMID: 28863047. 10.1097/EDE.0000000000000746 28863047 | KQ1E4; KQ2E7
I Hammami, M Mafham, J Armitage, S Parish. Risk of major gastrointestinal bleed in relation to vascular disease risk in 0.5M UK Biobank participants. Eur Heart J. 40(1 Suppl): 265. 2019. PMID: None. 10.1093/eurheartj/ehz747.0263 | KQ1E10; KQ2E10
Iwamoto, J, Murakami, M, . Current states of prevention of drug-induced gastroduodenal ulcer in real clinical practice: A cross-sectional study. J Clin Biochem Nutr. 66(2): 158–162. 2020. PMID: 32231413. 10.3164/jcbn.19-66 32231413 | KQ1E4; KQ2E3d
J Armitage, G Santulli. In diabetes with no CVD, aspirin reduced serious vascular events but increased major bleeding at 7.4 years. Ann Intern Med. 169(12): Jc67-. 2018. PMID: 30557420. 10.7326/ACPJC-2018-169-12-067 30557420 | KQ1E10; KQ2E10
J Ryan, E Storey, A Murray, R Woods, . A randomized controlled trial of the effect of aspirin versus placebo on incident dementia and probable alzheimer’s disease. Alzheimer’s & dementia. 15(7): P1277–p1278. 2019. PMID: None. 10.1016/j.jalz.2019.06.3671 | KQ1E10; KQ2E10
Jacobs, EJ, Thun, MJ, . A large cohort study of long-term daily use of adult-strength aspirin and cancer incidence. J Natl Cancer Inst. 99(8): 608–15. 2007. PMID: 17440162. 10.1093/jnci/djk132 17440162 | KQ1E4; KQ2E7
Jaspers Focks J, Tielemans MM, van Rossum LG, Eikendal T, . Gastrointestinal symptoms in low-dose aspirin users: a comparison between plain and buffered aspirin. Netherlands Heart Journal. 22(3): 107–12. 2014. PMID: 24522950. 10.1007/s12471-014-0522-3 24522950 | KQ1E4; KQ2E6
Juul-Moller, S, Edvardsson, N, . Double-blind trial of aspirin in primary prevention of myocardial infarction in patients with stable chronic angina pectoris. The Lancet. 340(8833): 1421–1425. 1992. PMID: 1360557. 10.1016/0140-6736(92)92619-q 1360557 | KQ1E3a; KQ2E3a
Kim J, Lee J, Shin CM, Lee DH, . Risk of gastrointestinal bleeding and cardiovascular events due to NSAIDs in the diabetic elderly population. BMJ Open Diabetes Research & Care. 3(1): e000133. 2015. PMID:3 26719806. 10.1136/bmjdrc-2015-000133 26719806 | KQ1E4; KQ2E5
Kim TG, Kim SH. Analysis of the Occurrence of Major Hemorrhagic Incidents in Patients with Low-Dose Aspirin Usage in Korean Populations - Does Low-Dose Aspirin Really Increase the Risk of Bleeding?. Neurointervention. 15(1): 52–54. 2020. PMID: 32070087. 10.5469/neuroint.2019.00297 32070087 | KQ1E10; KQ2E10
Kim YJ, Choi NK, Kim MS, Lee J, . Evaluation of low-dose aspirin for primary prevention of ischemic stroke among patients with diabetes: a retrospective cohort study. Diabetol Metab Syndr. 7: 8. 2015. PMID: 25733983. 10.1186/s13098-015-0002-y 25733983 | KQ1E4; KQ2E7
Kronmal, RA, Hart, RG, . Aspirin use and incident stroke in the cardiovascular health study. CHS Collaborative Research Group. Stroke. 29(5,0039-2499 (Print),0039-2499 (Linking): 887–894. 1998. PMID: 9596230. 10.1161/01.str.29.5.887 9596230 | KQ1E4; KQ2E3d
Kurata, JH, Abbey, DE. The effect of chronic aspirin use on duodenal and gastric ulcer hospitalizations. J Clin Gastroenterol. 12(3,0192-0790 (Print),0192-0790 (Linking)): 260–266. 1990. PMID: 2193980. 10.1097/00004836-199006000-00005 2193980 | KQ1E3a; KQ2E3a
Larsson, SC, Giovannucci, E, . Long-term aspirin use and colorectal cancer risk: a cohort study in Sweden. Br J Cancer. 95(9): 1277–9. 2006. PMID: 17060932. 10.1038/sj.bjc.6603442 17060932 | KQ1E4; KQ2E7
Lee WA, Cheng CL, Yang YHK. Risk of age-related macular degeneration in aspirin uses. Pharmacoepidemiol Drug Saf. 27: 79. 2018. 10.1002/pds.4629 | KQ1E10; KQ2E10
Lee WJA, Cheng CL, Yang YHK. Association of aspirin use and age-related macular degeneration in Taiwan. Pharmacoepidemiol Drug Saf. 25: 283. 2016. 10.1002/pds.4070 | KQ1E10; KQ2E10
Lee WJA, Cheng CL, Yang YHK. Does aspirin use increase the risk of age-related macular degeneration: A population-based comparative cohort study. Pharmacoepidemiol Drug Saf. 28: 340–341. 2019. 10.1002/pds.4864 | KQ1E4; KQ2E4
Leung, WY, So, WY, . Lack of benefits for prevention of cardiovascular disease with aspirin therapy in type 2 diabetic patients--a longitudinal observational study. Cardiovasc Diabetol. 8: 57. 2009.19878541 | KQ1E4; KQ2E3d
Lin BM, Curhan SG, Wang M, Eavey R, . Duration of Analgesic Use and Risk of Hearing Loss in Women. Am J Epidemiol. 185(1): 40–47. 2017. PMID: 27974293. 10.1093/aje/kww154 27974293 | KQ1E4; KQ2E5b
Lin KJ, De Caterina R, Garcia Rodriguez LA. Low-dose aspirin and upper gastrointestinal bleeding in primary versus secondary cardiovascular prevention: a population-based, nested case-control study. Circ Cardiovasc Qual Outcomes. 7(1): 70–7. 2014. PMID: 24254886. 10.1161/CIRCOUTCOMES.113.000494 24254886 | KQ1E4; KQ2E4
Lin, HMD, Vora, P, . Association between Low-Dose Aspirin Use and Colorectal Cancer Incidence in Taiwan. JAMA Network Open. 3(11):e2026494–e2026494. 2020. 10.1001/jamanetworkopen.2020.26494 33211109 | KQ1E4; KQ2E7
Lockery JE, Collyer TA, Abhayaratna WP, Fitzgerald SM, . Recruiting general practice patients for large clinical trials: lessons from the Aspirin in Reducing Events in the Elderly (ASPREE) study. Med J Aust. 210(4): 168–173. 2019. PMID: 30835844. 10.5694/mja2.12060 30835844 | KQ1E7; KQ2E7
Lockery, JE, Ernst, ME, . Prescription Medication Use in Older Adults Without Major Cardiovascular Disease Enrolled in the Aspirin in Reducing Events in the Elderly (ASPREE) Clinical Trial. Pharmacotherapy. 40(10): 1042–1053. 2020. 10.1002/phar.2461 33078479 | KQ1E7; KQ2E7
Logan, RF, Grainge, MJ, . Aspirin and folic acid for the prevention of recurrent colorectal adenomas. Gastroenterology. 134(1): 29–38. 2008.18022173 | KQ1E3; KQ2E3
M Riaz, J Ryan, A Huq, R Woods, . ASPREE: cohort stratification by APOE genotype. Twin research and human genetics. 21(5): 405–406. 2019. 10.1017/thg.2018.51 | KQ1E10; KQ2E10
Mahady S, Woods R, Polekhina G, Chan A, . Factors associated with aspirin-related upper gastrointestinal bleeding in the elderly: Data from a randomized controlled trial of 19 114 people. J Gastroenterol Hepatol. 34: 176. 2019. 10.1111/jgh.14803 | KQ1E10; KQ2E10
Mayor S. Long term NSAIDs are associated with lower colorectal cancer risk, study shows. BMJ. 351: h4599. 2015. PMID: 26306535. 10.1136/bmj.h4599 26306535 | KQ1E10; KQ2E10
McNeil J, Grimm R, Nelson M, Murray A, . The aspirin in reducing events in the elderly trial (ASPREE): Progress report. Glob Heart. 9(1): e215. 2014. 10.1016/j.gheart.2014.03.2003 | KQ1E10; KQ2E10
Meade, TW, WILKES, HC, . Randomized controlled trial of low dose warfarin in the primary prevention of ischaemic heart disease in men at high risk: design and pilot study. Eur Heart J. 9(8): 836–843. 1988. PMID: 3053176.3053176 | KQ1E7; KQ2E7
Modjtahedi BS, Fong DS, Jorgenson E, Van Den Eeden SK, . The Relationship Between Nonsteroidal Anti-inflammatory Drug Use and Age-related Macular Degeneration. Am J Ophthalmol. 188: 111–122. 2018. PMID: 29360460. 10.1016/j.ajo.2018.01.012 29360460 | KQ1E5; KQ2E5
Okada S, Morimoto T, Ogawa H, Sakuma M, . Does long-term use of low-dose aspirin develop proteinuria in diabetic patients?. Diabetes. 64: A414. 2015. PMID: . 10.2337/db1514721800 | KQ1E10; KQ2E10
Okada S, Morimoto T, Ogawa H, Sakuma M, . Is Long-Term Low-Dose Aspirin Therapy Associated with Renal Dysfunction in Patients with Type 2 Diabetes? JPAD2 Cohort Study. PLoS ONE [Electronic Resource]. 11(1): e0147635. 2016. PMID: 26808136. 10.1371/journal.pone.0147635 26808136 | KQ1E7; KQ2E7
Okada, S, Morimoto, T, . Association Between Statins and Cancer Incidence in Diabetes: a Cohort Study of Japanese Patients with Type 2 Diabetes. J Gen Intern Med. 36:632–639. 2020. 10.1007/s11606-020-06167-5 33063203 | KQ1E5; KQ2E5
Orchard, SG, Lockery, JE, . Cancer history and risk factors in healthy older people enrolling in the ASPREE clinical trial. Contemp Clin Trials. 96:106095. 2020. 10.1016/j.cct.2020.106095 32739494 | KQ1E7; KQ2E7
Orkaby AR, Yang L, Dufour AB, Travison TG, . Long-term aspirin use is associated with a lower prevalence of mobility limitation in older men. Circulation. 138(1 Suppl):A12007–A12007. 2018. | KQ1E10; KQ2E10
Palaniappan M, Selvarajan S, George M, Subramaniyan G, . Pattern of Adverse Drug Reactions Reported with Cardiovascular Drugs in a Tertiary Care Teaching Hospital. Journal of Clinical and Diagnostic Research JCDR. 9(11): FC01–4. 2015. PMID: 26675485. 10.7860/JCDR/2015/13810.6704 26675485 | KQ1E2; KQ2E2
Persantine-aspirin reinfarction study. Design, methods and baseline results. By the persantine-aspirin reinfarction study research group. Circulation. 62(3 Pt 2,0009-7322 (Print),0009-7322 (Linking)): II1–42. 1980.7408140 | KQ1E3a; KQ2E3a
Petersen, P, Boysen, G, . Placebo-controlled, randomised trial of warfarin and aspirin for prevention of thromboembolic complications in chronic atrial fibrillation. The Copenhagen AFASAK study. Lancet. 1(8631): 175–179. 1989.2563096 | KQ1E3b; KQ2E3b
Preliminary report of the Stroke Prevention in Atrial Fibrillation Study. N Engl J Med. 322(12,0028-4793 (Print),0028-4793 (Linking): 863–868. 1990.2407959 | KQ1E3b; KQ2E3b
Robman LD, Guymer RH, Woods R, Hodgson L, . The role of aspirin in age-related macular degeneration: The ASPREE-AMD randomized controlled trial. Invest Ophthalmol Vis Sci. 59(9): 5539. 2018. | KQ1E10; KQ2E10
Rodriguez LG, Gaist D, Soriano-Gabarró M, Soriano LC. New use of low-dose aspirin is not associated with a significantly increased risk of intracranial bleeds: Results from a population-based nested case-control study in the united kingdom. Circulation. 134(1 Suppl):A12926. 2016. | KQ1E10; KQ2E10
Rothwell PM, Cook NR, Gaziano JM, Price JF, . Effects of aspirin on risks of vascular events and cancer according to bodyweight and dose: analysis of individual patient data from randomised trials. Lancet. 392(10145): 387–399. 2018. 10.1016/S0140-6736(18)31133-4 30017552 | KQ1E11; KQ2E11
Rothwell PM, Fowkes FG, Belch JF, Ogawa H, . Effect of daily aspirin on long-term risk of death due to cancer: analysis of individual patient data from randomised trials. Lancet. 377(9759): 31–41. 2011. PMID: 21144578. 10.1016/S0140-6736(10)62110-1 21144578 | KQ1E7; KQ2E7
Rothwell PM, Price JF, Fowkes FG, Zanchetti A, . Short-term effects of daily aspirin on cancer incidence, mortality, and non-vascular death: analysis of the time course of risks and benefits in 51 randomised controlled trials. Lancet. 379(9826): 1602–12. 2012. PMID: 22440946. 10.1016/S0140-6736(11)61720-0 22440946 | KQ1E7; KQ2E7
RUDNICKA, AR, MT-ISA, S, . Associations of plasma fibrinogen and factor VII clotting activity with coronary heart disease and stroke: prospective cohort study from the screening phase of the Thrombosis Prevention Trial. Journal of Thrombosis and Haemostasis. 4(11): 2405–2410. 2006. PMID: 17002654.17002654 | KQ1E7; KQ2E7
Rydberg DM, Holm L, Mejyr S, Loikas D, . Sex differences in spontaneous reports on adverse bleeding events of antithrombotic treatment. Eur J Clin Pharmacol. 70(1): 117–26. 2014. PMID: 24096684. 10.1007/s00228-013-1591-8 24096684 | KQ1E4; KQ2E4
Sasso FC, Marfella R, Pagano A, Porta G, . Lack of effect of aspirin in primary CV prevention in type 2 diabetic patients with nephropathy: results from 8 years follow-up of NID-2 study. Acta Diabetol. 52(2): 239–47. 2015. PMID: 25109286. 10.1007/s00592-014-0623-x 25109286 | KQ1E4; KQ2E4
Sato, H, Ishikawa, K, . Low-dose aspirin for prevention of stroke in low-risk patients with atrial fibrillation: Japan Atrial Fibrillation Stroke Trial. Stroke. 37(2): 447–451. 2006.16385088 | KQ1E3b; KQ2E3b
Secondary prevention in non-rheumatic atrial fibrillation after transient ischaemic attack or minor stroke. EAFT (European Atrial Fibrillation Trial) Study Group. Lancet. 342(8882): 1255–62. 1993. PMID: 7901582.7901582 | KQ1E3a; KQ2E3a
Seidu S, Kunutsor SK, Sesso HD, Gaziano JM, . Aspirin has potential benefits for primary prevention of cardiovascular outcomes in diabetes: updated literature-based and individual participant data meta-analyses of randomized controlled trials. Cardiovasc Diabetol. 18(1): 70. 2019. PMID: 31159806. 10.1186/s12933-019-0875-4 31159806 | KQ1E11; KQ2E11
Selak V, Jackson R, Poppe K, Kerr A, . Are the benefits of aspirin likely to exceed the risk of major bleeds among people in whom aspirin is recommended for the primary prevention of cardiovascular disease?. N Z Med J. 131(1484): 19–25. 2018. PMID: 30359352.30359352 | KQ1E4; KQ2E4
Selak V, Jackson R, Poppe K, Wu B, . Personalized Prediction of Cardiovascular Benefits and Bleeding Harms From Aspirin for Primary Prevention: A Benefit-Harm Analysis. Ann Intern Med. 171(8):529–542. 2019. 10.7326/M19-1132 31525775 | KQ1E4; KQ2E4
Selak V, Jackson R, Poppe K, Wu B, . Predicting Bleeding Risk to Guide Aspirin Use for the Primary Prevention of Cardiovascular Disease: A Cohort Study. Ann Intern Med. 170(6): 357–368. 2019. 10.7326/M18-2808 30802900 | KQ1E4; KQ2E4
Selak V, Kerr A, Poppe K, Wu B, . Annual Risk of Major Bleeding Among Persons Without Cardiovascular Disease Not Receiving Antiplatelet Therapy. JAMA. 319(24): 2507–2520. 2018. 10.1001/jama.2018.8194 29946729 | KQ1E6; KQ2E6
Selvaraj S, Bhatt D, Claggett B, Djousse L, . Heart failure is not associated with increased cancer incidence among participants in the physicians’ health study. Circulation. 136(1 Suppl): A13644. 2017. | KQ1E10; KQ2E10
Seshasai, SR, Wijesuriya, S, . Effect of aspirin on vascular and nonvascular outcomes: meta-analysis of randomized controlled trials. Arch Intern Med. 172(3): 209–216. 2012.22231610 | KQ1E4; KQ2E4
Sirois C, Moisan J, Poirier P, Gregoire JP. Myocardial infarction and gastro-intestinal bleeding risks associated with aspirin use among elderly individuals with type 2 diabetes. Ann Med. 46(5): 335–40. 2014. PMID: 24785356. 10.3109/07853890.2014.902636 24785356 | KQ1E4; KQ2E4
Slattery, J, Warlow, CP, . Risks of gastrointestinal bleeding during secondary prevention of vascular events with aspirin--analysis of gastrointestinal bleeding during the UK-TIA trial. Gut. 37(4,0017-5749 (Print),0017-5749 (Linking): 509–511. 1995.7489937 | KQ1E7; KQ2E3a
Soriano LC, Gaist D, Soriano-Gabarró M, Rodríguez LAG. Incidence of intracranial bleeds in new users and non-users of low-dose aspirin in the UK. Pharmacoepidemiol Drug Saf. 25: 570. 2016. 10.1002/pds.4070 | KQ1E10; KQ2E10
Soriano LC, Soriano-Gabarro M, Lanas A, Rodríguez LAG. Incidence of upper and lower gastrointestinal bleeds in new users and non-users of low-dose aspirin in the UK. Pharmacoepidemiol Drug Saf. 26: 392–393. 2017. 10.1002/pds.4275 | KQ1E10; KQ2E10
Soriano LC, Soriano-Gabarró M, Rodríguez LAG. Protection against colorectal cancer with use of low-dose aspirin: Selection bias is unlikely based on results using three different study designs. Pharmacoepidemiol Drug Saf. 25: 561. 2016. 10.1002/pds.4070 | KQ1E4; KQ2E7
Stampfer, MJ, Buring, JE, . The 2 × 2 factorial design: its application to a randomized trial of aspirin and carotene in U.S. physicians. Stat Med. 4(2): 111–116. 1985.4023472 | KQ1E7; KQ2E7
Stocks NP, Gonzalez-Chica DA, Woods RL, Lockery JE, . Quality of Life for 19,114 participants in the ASPREE (ASPirin in Reducing Events in the Elderly) study and their association with sociodemographic and modifiable lifestyle risk factors. Qual Life Res. 28(4): 935–946. 2019. PMID: 30411180. 10.1007/s11136-018-2040-z 30411180 | KQ1E4; KQ2E4
Stroke Prevention in Atrial Fibrillation Study. Final results. Circulation. 84(2): 527–539. 1991.1860198 | KQ1E3b; KQ2E3b
Sundstrom J, Hedberg J, Thuresson M, Aarskog P, . Low-Dose Aspirin Discontinuation and Risk of Cardiovascular Events: A Swedish Nationwide, Population-Based Cohort Study. Circulation. 136(13): 1183–1192. 2017. 10.1161/CIRCULATIONAHA.117.028321 28947478 | KQ1E4; KQ2E4
Sung J, Tsoi KKF. Comparing mortality of colorectal cancer and gastrointestinal bleeding among patients with long-term use of low dose aspirin: A population-based study of 689,209 patients. J Clin Oncol. 35(4). 2017. | KQ1E10; KQ2E10
Sung JJY, Tsoi KK. Risk of gastrointestinal bleeding and benefit from colorectal cancer reduction. A 10-year population-based study for long-term use of low dose aspirin. United European Gastroenterology Journal. 4(5): A62. 2016. 10.1177/2050640616663688 | KQ1E10; KQ2E10
Takada M, Fujimoto M, Hosomi K. Difference in risk of gastrointestinal complications between users of enteric-coated and buffered low-dose aspirin. Int J Clin Pharmacol Ther. 52(3): 181–91. 2014.24472400 | KQ1E6; KQ2E6
The Persantine-Aspirin Reinfarction Study Research Group. Persantine and aspirin in coronary heart disease. The Persantine-Aspirin Reinfarction Study Research Group. Circulation. 62(3): 449–461. 1980. | KQ1E3a; KQ2E3a
Thorat MA, Cuzick J. Prophylactic use of aspirin: systematic review of harms and approaches to mitigation in the general population. Eur J Epidemiol. 30(1): 5–18. 2015. PMID: 25421783. 10.1007/s10654-014-9971-7 25421783 | KQ1E4; KQ2E4
Tsoi KK, Chan FC, Hirai HW, Sung JJ. Risk of gastrointestinal bleeding and benefit from colorectal cancer reduction from long-term use of low-dose aspirin: A retrospective study of 612 509 patients. J Gastroenterol Hepatol. 33(10): 1728–1736. 2018. PMID: 29665624. 10.1111/jgh.14261 29665624 | KQ1E4; KQ2E3
Uchiyama S. Aspirin for primary stroke prevention in elderly patients with vascular risk factors. Journal of General and Family Medicine. 18(6): 331–335. 2017. PMID: 29264061. 10.1002/jgf2.102 29264061 | KQ1E10; KQ2E10
UK-TIA Study Group. United Kingdom transient ischaemic attack (UK-TIA) aspirin trial: interim results. BMJ. 296(6618): 316–320. 1988.2894232 | KQ1E3a; KQ2E3a
van Kruijsdijk RC, Visseren FL, Ridker PM, Dorresteijn JA, . Individualised prediction of alternate-day aspirin treatment effects on the combined risk of cancer, cardiovascular disease and gastrointestinal bleeding in healthy women. Heart. 101(5): 369–76. 2015. PMID: 25475110. 10.1136/heartjnl-2014-306342 25475110 | KQ1E4; KQ2E4
Ward SA, Raniga P, Ferris NJ, Woods RL, . ASPREE-NEURO study protocol: A randomized controlled trial to determine the effect of low-dose aspirin on cerebral microbleeds, white matter hyperintensities, cognition, and stroke in the healthy elderly. International Journal of Stroke. 12(1): 108–113. 2017. PMID: 27634976. 10.1177/1747493016669848 27634976 | KQ1E7; KQ2E7
Warle-van Herwaarden MF, Koffeman AR, Valkhoff VE, t Jong GW, . Time-trends in the prescribing of gastroprotective agents to primary care patients initiating low-dose aspirin or non-steroidal anti-inflammatory drugs: a population-based cohort study. Br J Clin Pharmacol. 80(3): 589–98. 2015. PMID: 25777983. 10.1111/bcp.12626 25777983 | KQ1E1; KQ2E1
Wu IC, Hsieh HM, Wu MT. A short-term risk-benefit analysis of occasional and regular use of low-dose aspirin in primary prevention of vascular diseases: a nationwide population-based study. BMJ Open. 5(1): e006694. 2015. PMID: 25575876. 10.1136/bmjopen-2014-006694 25575876 | KQ1E4; KQ2E5a
Wu IC, Lin MY, Yu FJ, Hsieh HM, . A short-term effect of low-dose aspirin on major hemorrhagic risks in primary prevention: a case-crossover design. PLoS ONE [Electronic Resource]. 9(5): e98326. 2014. PMID: 24879431. 10.1371/journal.pone.0098326 24879431 | KQ1E4; KQ2E5a
Wu S, Han J, Qureshi AA. Use of aspirin, non-steroidal anti-inflammatory drugs, and acetaminophen (paracetamol), and risk of psoriasis and psoriatic arthritis: a cohort study. Acta Derm Venereol. 95(2): 217–23. 2015. PMID: 24691893. 10.2340/00015555-1855 24691893 | KQ1E4; KQ2E7
Wu, Y, Yang, J, . Bleeding Risk in Randomized Controlled Trials Comparing Aspirin, Clopidogrel, and Vitamin K Antagonists: A Network Meta-analysis of 204,989 Patients. Am J Ther. 28(1): e156–e162. 2021. PMID: 33369919. 10.1097/MJT.0000000000001003 33369919 | KQ1E7; KQ2E3
Xu, Y, Wang, C, . PCV9 A 5-YEAR REAL WORLD PATIENT LEVEL ANALYSIS OF LOW-DOSE ASPIRIN PRIMARY PREVENTION BENEFIT AND RISK ANALYSIS BASED ON A MULTI-HOSPITAL EMR DATABASE. Value in Health. 23: S91. 2020. 10.1016/j.jval.2020.04.114 | KQ1E2; KQ2E2
Y Saito, S Okada, H Ogawa, H Soejima, . The long-term therapy with low-dose aspirin did not reduce cardiovascular events in patients with type 2 diabetes in primary prevention setting: 10-year follow-up of a randomized controlled trial. Circulation. 134(1 Suppl): A13428. 2016. | KQ1E10; KQ2E10
Yusuf, S, Joseph, P, . Polypill with or without Aspirin in Persons without Cardiovascular Disease. N Engl J Med. 384(3): 216–228. 2020. 10.1056/NEJMoa2028220 33186492 | KQ1E2; KQ2E2
Zhang, SM, Cook, NR, . Low-dose aspirin and breast cancer risk: results by tumour characteristics from a randomised trial. Br J Cancer. 98(5,0007-0920 (Print),0007-0920 (Linking): 989–991. 2008.18268496 | KQ1E7; KQ2E7
Zhou, Z, Ofori-Asenso, R, . Association of Statin Use With Disability-Free Survival and Cardiovascular Disease Among Healthy Older Adults. J Am Coll Cardiol. 76(1): 17–27. 2020. 10.1016/j.jacc.2020.05.016 32616158 | KQ1E5; KQ2E5