# Appendix B Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

Key Question 1:

1. Ascend Study Collaborative Group, Bowman L, Mafham M, . Effects of Aspirin for Primary Prevention in Persons with Diabetes Mellitus. N Engl J Med. 2018;379(16):1529–39. PMID: 30146931. 10.1056/NEJMoa1804988 30146931
  a. Aung T, Haynes R, Barton J, . Cost-effective recruitment methods for a large randomised trial in people with diabetes: A Study of Cardiovascular Events iN Diabetes (ASCEND). Trials [Electronic Resource]. 2016;17(1):286. PMID: 27296091. 10.1186/s13063-016-1354-9 27296091
  b. Wolfe R, Murray AM, Woods RL, . The aspirin in reducing events in the elderly trial: Statistical analysis plan. International Journal of Stroke. 2018;13(3):335–8. PMID: 29111960. 10.1177/1747493017741383 29111960
2. Belch J, MacCuish A, Campbell I, . The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ (Clinical research ed). 2008;337:a1840. PMID: 18927173.18927173
3. Farrell B, Godwin J, Richards S, . The United Kingdom transient ischaemic attack (UK-TIA) aspirin trial: final results. J Neurol Neurosurg Psychiatry. 1991;54(12):1044–54. PMID: 1783914. 10.1136/jnnp.54.12.1044 1783914
  a. Flossmann E, Rothwell PM, British Doctors Aspirin T, . Effect of aspirin on long-term risk of colorectal cancer: consistent evidence from randomised and observational studies. Lancet (London, England). 2007;369(9573):1603–13. PMID: 17499602. 10.1016/S0140-6736(07)60747-8 17499602
  b. Rothwell PM, Wilson M, Elwin CE, . Long-term effect of aspirin on colorectal cancer incidence and mortality: 20-year follow-up of five randomised trials. Lancet (London, England). 2010;376(9754):1741–50. PMID: 20970847. 10.1016/S0140-6736(10)61543-7 20970847
4. Final report on the aspirin component of the ongoing Physicians’ Health Study. Steering Committee of the Physicians’ Health Study Research Group. N Engl J Med. 1989;321(3):129–35. PMID: 2664509.2664509
  a. Christen WG, Glynn RJ, Ajani UA, . Age-related maculopathy in a randomized trial of low-dose aspirin among US physicians. Arch Ophthalmol. 2001;119(8):1143–9. PMID: 11483080.11483080
  b. Cook NR, Cole SR, Hennekens CH. Use of a Marginal Structural Model to Determine the Effect of Aspirin on Cardiovascular Mortality in the Physicians’ Health Study. American Journal of Epidemiology. 2002;155(11):1045–53. PMID: 12034583.12034583
  c. Cook NR, Cole SR, Hennekens CH. Use of a Marginal Structural Model to Determine the Effect of Aspirin on Cardiovascular Mortality in the Physicians’ Health Study. American Journal of Epidemiology. 2002;155(11):1045–53. PMID: 12034583.12034583
  d. Gann PH, Manson JE, Glynn RJ, . Low-dose aspirin and incidence of colorectal tumors in a randomized trial. Journal of the National Cancer Institute. 1993;85(15):1220–4. PMID: 8331682. 10.1093/jnci/85.15.1220 8331682
  e. Kurth T, Glynn RJ, Walker AM, . Inhibition of Clinical Benefits of Aspirin on First Myocardial Infarction by Nonsteroidal Antiinflammatory Drugs. Circulation. 2003;108(10):1191–5. PMID: 12939216.12939216
  f. Physicians’ Health Study Research Group. Preliminary Report: Findings From the Aspirin Component of The Ongoing Physicians’ Health Study. New England Journal of Medicine. 1988;318:262–4.
  g. Sturmer T, Glynn RJ, Lee IM, . Aspirin use and colorectal cancer: post-trial follow-up data from the Physicians’ Health Study. Annals of internal medicine. 1998;128(9):713–20. PMID: 9556464. 10.7326/0003-4819-128-9-199805010-00003 9556464
5. Fowkes FG, Price JF, Stewart MC, . Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. Jama. 2010;303(9):841–8. PMID: 20197530.20197530
6. Gaziano JM, Brotons C, Coppolecchia R, . Use of aspirin to reduce risk of initial vascular events in patients at moderate risk of cardiovascular disease (ARRIVE): a randomised, double-blind, placebo-controlled trial. Lancet (London, England). 2018;392(10152):1036–46. PMID: 30158069. 10.1016/S0140-6736(18)31924-X 30158069
7. Hansson L, Zanchetti A, Carruthers SG, . Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet (London, England). 1998;351(9118):1755–62. PMID: 9635947.9635947
  a. Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study--patient characteristics: randomization, risk profiles, and early blood pressure results. Blood Press. 1994;3(5):322–7. PMID: 78665977866597
  b. Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study: 12-month data on blood pressure and tolerability. With special reference to age and gender. Blood Press. 1995;4(5):313–9. PMID: 85355548535554
  c. Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study: 24-month data on blood pressure and tolerability. Blood Press. 1997;6(5):313–7. PMID: 9360003.9360003
  d. Jardine MJ, Ninomiya T, Perkovic V, . Aspirin is beneficial in hypertensive patients with chronic kidney disease: a post-hoc subgroup analysis of a randomized controlled trial. Journal of the American College of Cardiology. 2010;56(12):956–65.20828648
  e. Kjeldsen SE, Kolloch RE, Leonetti G, . Influence of gender and age on preventing cardiovascular disease by antihypertensive treatment and acetylsalicylic acid. The HOT study. Hypertension Optimal Treatment. J Hypertens. 2000;18(5):629–42. PMID: 10826567.10826567
  f. Meade TW, Brennan PJ. Determination of who may derive most benefit from aspirin in primary prevention: subgroup results from a randomised controlled trial. BMJ (Clinical research ed). 2000;321(7252):13–7. PMID: 10875825.10875825
  g. The Hypertension Optimal Treatment Study (the HOT Study). Blood Press. 1993;2(1):62–8. PMID: 8193735.8193735
  h. Zanchetti A, Hansson L, Dahlof B, . Benefit and harm of low-dose aspirin in well-treated hypertensives at different baseline cardiovascular risk. J Hypertens. 2002;20(11):2301–7. PMID: 12409970.12409970
  i. Zanchetti A, Hansson L, Dahlof B, . Effects of individual risk factors on the incidence of cardiovascular events in the treated hypertensive patients of the Hypertension Optimal Treatment Study. HOT Study Group. J Hypertens. 2001;19(6):1149–59. PMID: 11403365.11403365
  j. Zanchetti A, Hansson L, Menard J, . Risk assessment and treatment benefit in intensively tre136: The Hypertension Optimal Treatment Study (the HOT Study). Blood Press. 1993;2(1):62–8. PMID: 8193735.8193735
8. Ikeda Y, Shimada K, Teramoto T, . Low-dose aspirin for primary prevention of cardiovascular events in Japanese patients 60 years or older with atherosclerotic risk factors: a randomized clinical trial. Jama. 2014;312(23):2510–20. PMID: 25401325.25401325
  a. Sugawara M, Goto Y, Yamazaki T, . Low-Dose Aspirin for Primary Prevention of Cardiovascular Events in Elderly Japanese Patients with Atherosclerotic Risk Factors: Subanalysis of a Randomized Clinical Trial (JPPP-70). American Journal of Cardiovascular Drugs. 2019;19(3):299–311. PMID: 30565155. 10.1007/s40256-018-0313-0 30565155
  b. Uchiyama S, Ishizuka N, Shimada K, . Aspirin for Stroke Prevention in Elderly Patients With Vascular Risk Factors: Japanese Primary Prevention Project. Stroke. 2016;47(6):1605–11. PMID: 27165949. 10.1161/STROKEAHA.115.012461 27165949
  c. Yokoyama K, Ishizuka N, Uemura N, . Effects of daily aspirin on cancer incidence and mortality in the elderly Japanese. Research And Practice In Thrombosis And Haemostasis. 2018;2(2):274–81. PMID: 30046729. 10.1002/rth2.12097 30046729
9. McNeil JJ, Wolfe R, Woods RL, . Effect of Aspirin on Cardiovascular Events and Bleeding in the Healthy Elderly. New England Journal of Medicine. 2018;379(16):1509–18. PMID: 30221597. 10.1056/NEJMoa1805819 30221597
  a. ASPREE. ASPrin in Reducing Events in the Elderly Protocol Version 9. https://aspree.org/usa/wp-content/uploads/sites/3/2014/04/ASPREE-Protocol-Version-9_-Nov2014_FINAL.pdf. Accessed June 3, 2020. PMID.: None.
  b. Margolis KL, Mahady SE, Nelson MR, . Development of a standardized definition for clinically significant bleeding in the ASPirin in Reducing Events in the Elderly (ASPREE) trial. Contemporary Clinical Trials Communications. 2018;11:30–6. PMID: 30023457. 10.1016/j.conctc.2018.05.015 30023457
  c. McNeil JJ, Gibbs P, Orchard SG, . Effect of aspirin on cancer incidence and mortality in older adults. Journal of the National Cancer Institute. 2020. 10.1093/jnci/djaa114
  d. McNeil JJ, Nelson MR, Woods RL, . Effect of Aspirin on All-Cause Mortality in the Healthy Elderly. N Engl J Med. 2018;379(16):1519–28. PMID: 30221595. 10.1056/NEJMoa1803955 30221595
  e. McNeil JJ, Woods RL, Nelson MR, . Baseline Characteristics of Participants in the ASPREE (ASPirin in Reducing Events in the Elderly) Study. J Gerontol A Biol Sci Med Sci. 2017;72(11):1586–93. PMID: 28329340. 10.1093/gerona/glw342 28329340
  f. McNeil JJ, Woods RL, Nelson MR, . Effect of Aspirin on Disability-free Survival in the Healthy Elderly. New England Journal of Medicine. 2018;379(16):1499–508. PMID: 30221596. 10.1056/NEJMoa1800722 30221596
  g. Nelson MR, Reid CM, Ames DA, . Feasibility of conducting a primary prevention trial of low-dose aspirin for major adverse cardiovascular events in older people in Australia: results from the ASPirin in Reducing Events in the Elderly (ASPREE) pilot study. Med J Aust. 2008;189(2):105–9. PMID: 18637782.18637782
  h. Wolfe R, Murray AM, Woods RL, . The aspirin in reducing events in the elderly trial: Statistical analysis plan. International Journal of Stroke. 2018;13(3):335–8. PMID: 29111960. 10.1177/1747493017741383 29111960
10. Ogawa H, Nakayama M, Morimoto T, . Low-dose aspirin for primary prevention of atherosclerotic events in patients with type 2 diabetes: a randomized controlled trial.[Erratum appears in JAMA. 2009 May 13;301(18):1882]. Jama. 2008;300(18):2134–41. PMID: 18997198.18997198
  a. Okada S, Morimoto T, Ogawa H, . Differential effect of low-dose aspirin for primary prevention of atherosclerotic events in diabetes management: a subanalysis of the JPAD trial. Diabetes care. 2011;34(6):1277–83. PMID: 21515838.21515838
  b. Okada S, Morimoto T, Ogawa H, . Effect of Aspirin on Cancer Chemoprevention in Japanese Patients With Type 2 Diabetes: 10-Year Observational Follow-up of a Randomized Controlled Trial. Diabetes care. 2018;41(8):1757–64. PMID: 29909377. 10.2337/dc18-0368 29909377
  c. Okada S, Morimoto T, Ogawa H, . Effect of low-dose aspirin on primary prevention of cardiovascular events in Japanese diabetic patients at high risk. Circ J. 2013;77(12):3023–8. PMID: 24042256. 10.1253/circj.cj-13-0307 24042256
  d. Saito Y, Morimoto T, Ogawa H, . Low-dose aspirin therapy in patients with type 2 diabetes and reduced glomerular filtration rate: subanalysis from the JPAD trial. Diabetes care. 2011;34(2):280–5. PMID: 21270185.21270185
  e. Saito Y, Okada S, Ogawa H, . Low-Dose Aspirin for Primary Prevention of Cardiovascular Events in Patients With Type 2 Diabetes Mellitus: 10-Year Follow-Up of a Randomized Controlled Trial. Circulation. 2017;135(7):659–70. PMID: 27881565. 10.1161/CIRCULATIONAHA.116.025760 27881565
  f. Soejima H, Ogawa H, Morimoto T, . Aspirin possibly reduces cerebrovascular events in type 2 diabetic patients with higher C-reactive protein level: subanalysis from the JPAD trial. Journal of Cardiology. 2013;62(3):165–70. PMID: 23778008.23778008
  g. Soejima H, Ogawa H, Morimoto T, . Aspirin reduces cerebrovascular events in type 2 diabetic patients with poorly controlled blood pressure. Subanalysis from the JPAD trial. Circ J. 2012;76(6):1526–32. PMID: 22447019.22447019
11. Peto R, Gray R, Collins R, . Randomised trial of prophylactic daily aspirin in British male doctors. Br Med J (Clin Res Ed). 1988;296(6618):313–6. PMID: 3125882.3125882
  a. Flossmann E, Rothwell PM, British Doctors Aspirin T, . Effect of aspirin on long-term risk of colorectal cancer: consistent evidence from randomised and observational studies. Lancet (London, England). 2007;369(9573):1603–13. PMID: 17499602. 10.1016/S0140-6736(07)60747-8 17499602
  b. Rothwell PM, Wilson M, Elwin CE, . Long-term effect of aspirin on colorectal cancer incidence and mortality: 20-year follow-up of five randomised trials. Lancet (London, England). 2010;376(9754):1741–50. PMID: 20970847. 10.1016/S0140-6736(10)61543-7 20970847
12. Ridker PM, Cook NR, Lee IM, . A randomized trial of low-dose aspirin in the primary prevention of cardiovascular disease in women. N Engl J Med. 2005;352(13):1293–304. PMID: 15753114.15753114
  a. Buring JE, I-Min L. Personal communication. Updated WHS data. 2020. PMID: None.
  b. Buring JE, Hennekens CH. The Women’s Health Study: summary of the study design. J Myocardial Ischemia. 1992;4(3):27–9. PMID: None.
  c. Christen WG, Glynn RJ, Chew EY, . Low-dose aspirin and medical record-confirmed age-related macular degeneration in a randomized trial of women. Ophthalmology. 2009;116(12):2386–92. PMID: 19815293.19815293
  d. Cook NR, Lee IM, Gaziano JM, . Low-dose aspirin in the primary prevention of cancer: the Women’s Health Study: a randomized controlled trial. Jama. 2005;294(1):47–55. PMID: 15998890. 10.1001/jama.294.1.47 15998890
  e. Cook NR, Lee IM, Zhang SM, . Alternate-day, low-dose aspirin and cancer risk: long-term observational follow-up of a randomized trial. Annals of internal medicine. 2013;159(2):77–85. PMID: 23856681. 10.7326/0003-4819-159-2-201307160-00002 23856681
  f. Dorresteijn JA, Visseren FL, Ridker PM, . Aspirin for primary prevention of vascular events in women: individualized prediction of treatment effects. European heart journal. 2011;32(23):2962–9. PMID: 22090661.22090661
  g. Rexrode KM, Lee IM, Cook NR, . Baseline characteristics of participants in the Women’s Health Study. J Womens Health Gend Based Med. 2000;9(1):19–27. PMID: 10718501.10718501
  h. Rist PM, Buring JE, Kase CS, . Effect of low-dose aspirin on functional outcome from cerebral vascular events in women. Stroke. 2013;44(2):432–6.23306328
13. Roncaglioni M, Collaborative Group of the Primary Prevention Project. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general Practice. The Lancet. 2001;357(9250):89–95. PMID: 11197445.11197445
  a. Berger JS, Roncaglioni MC, Avanzini F, . Aspirin for the primary prevention of cardiovascular events in women and men: a sex-specific meta-analysis of randomized controlled trials. Jama. 2006;295(3):306–13. PMID: 16418466.16418466
  b. Sacco M, Pellegrini F, Roncaglioni MC, . Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general Practice. Diabetes care. 2003;26(12):3264–72. PMID: 14633812.14633812
  c. Sacco M, Pellegrini F, Roncaglioni MC, . Primary prevention of cardiovascular events with low-dose aspirin and vitamin E in type 2 diabetic patients: results of the Primary Prevention Project (PPP) trial. Diabetes care. 2003;26(12):3264–72. PMID: 14633812.14633812
14. The SALT Collaborative Group. Swedish Aspirin Low-Dose Trial (SALT) of 75 mg aspirin as secondary prophylaxis after cerebrovascular ischaemic events. The SALT Collaborative Group. Lancet (London, England). 1991;338(8779):1345–9. PMID: 1682734.1682734
  a. Rothwell PM, Wilson M, Elwin CE, . Long-term effect of aspirin on colorectal cancer incidence and mortality: 20-year follow-up of five randomised trials. Lancet (London, England). 2010;376(9754):1741–50. PMID: 20970847. 10.1016/S0140-6736(10)61543-7 20970847
15. The Medical Research Council’s General Practice Research Framework. Thrombosis prevention trial: randomised trial of low-intensity oral anticoagulation with warfarin and low-dose aspirin in the primary prevention of ischaemic heart disease in men at increased risk. Lancet (London, England). 1998;351(9098):233–41. PMID: 9457092.9457092
  a. Meade TW, Brennan PJ. Determination of who may derive most benefit from aspirin in primary prevention: subgroup results from a randomised controlled trial. BMJ (Clinical research ed). 2000;321(7252):13–7. PMID: 10875825.10875825
  b. Rothwell PM, Wilson M, Elwin CE, . Long-term effect of aspirin on colorectal cancer incidence and mortality: 20-year follow-up of five randomised trials. Lancet (London, England). 2010;376(9754):1741–50. PMID: 20970847. 10.1016/S0140-6736(10)61543-7 20970847

Key Question 2:

1. Ascend Study Collaborative Group, Bowman L, Mafham M, . Effects of Aspirin for Primary Prevention in Persons with Diabetes Mellitus. N Engl J Med. 2018;379(16):1529–39. PMID: 30146931. 10.1056/NEJMoa1804988 30146931
  a. Aung T, Haynes R, Barton J, . Cost-effective recruitment methods for a large randomised trial in people with diabetes: A Study of Cardiovascular Events iN Diabetes (ASCEND). Trials [Electronic Resource]. 2016;17(1):286. PMID: 27296091. 10.1186/s13063-016-1354-9 27296091
  b. Wolfe R, Murray AM, Woods RL, . The aspirin in reducing events in the elderly trial: Statistical analysis plan. International Journal of Stroke. 2018;13(3):335–8. PMID: 29111960. 10.1177/1747493017741383 29111960
2. Belch J, MacCuish A, Campbell I, . The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ (Clinical research ed). 2008;337:a1840. PMID: 18927173.18927173
3. Chen WC, Lin KH, Huang YT, . The risk of lower gastrointestinal bleeding in low-dose aspirin users. Alimentary Pharmacology & Therapeutics. 2017;45(12):1542–50. PMID: 28449186. 10.1111/apt.14079 28449186
4. de Berardis G, Lucisano G, D’Ettorre A, . Association of aspirin use with major bleeding in patients with and without diabetes. Jama. 2012;307(21):2286–94. PMID: 22706834.22706834
5. Ekstrom N, Cederholm J, Zethelius B, . Aspirin treatment and risk of first incident cardiovascular diseases in patients with type 2 diabetes: an observational study from the Swedish National Diabetes Register. BMJ Open. 2013;3(4):2013. PMID: 23604419.23604419
6. Final report on the aspirin component of the ongoing Physicians’ Health Study. Steering Committee of the Physicians’ Health Study Research Group. N Engl J Med. 1989;321(3):129–35. PMID: 2664509.2664509
  a. Christen WG, Glynn RJ, Ajani UA, . Age-related maculopathy in a randomized trial of low-dose aspirin among US physicians. Arch Ophthalmol. 2001;119(8):1143–9. PMID: 11483080.11483080
  b. Cook NR, Cole SR, Hennekens CH. Use of a Marginal Structural Model to Determine the Effect of Aspirin on Cardiovascular Mortality in the Physicians’ Health Study. American Journal of Epidemiology. 2002;155(11):1045–53. PMID: 12034583.12034583
  c. Cook NR, Cole SR, Hennekens CH. Use of a Marginal Structural Model to Determine the Effect of Aspirin on Cardiovascular Mortality in the Physicians’ Health Study. American Journal of Epidemiology. 2002;155(11):1045–53. PMID: 12034583.12034583
  d. Gann PH, Manson JE, Glynn RJ, . Low-dose aspirin and incidence of colorectal tumors in a randomized trial. Journal of the National Cancer Institute. 1993;85(15):1220–4. PMID: 8331682. 10.1093/jnci/85.15.1220 8331682
  e. Kurth T, Glynn RJ, Walker AM, . Inhibition of Clinical Benefits of Aspirin on First Myocardial Infarction by Nonsteroidal Antiinflammatory Drugs. Circulation. 2003;108(10):1191–5. PMID: 12939216.12939216
  f. Physicians’ Health Study Research Group. Preliminary Report: Findings From the Aspirin Component of The Ongoing Physicians’ Health Study. New England Journal of Medicine. 1988;318:262–4.
  g. Sturmer T, Glynn RJ, Lee IM, . Aspirin use and colorectal cancer: post-trial follow-up data from the Physicians’ Health Study. Annals of internal medicine. 1998;128(9):713–20. PMID: 9556464. 10.7326/0003-4819-128-9-199805010-00003 9556464
7. Fowkes FG, Price JF, Stewart MC, . Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. Jama. 2010;303(9):841–8. PMID: 20197530.20197530
8. Gaziano JM, Brotons C, Coppolecchia R, . Use of aspirin to reduce risk of initial vascular events in patients at moderate risk of cardiovascular disease (ARRIVE): a randomised, double-blind, placebo-controlled trial. Lancet (London, England). 2018;392(10152):1036–46. PMID: 30158069. 10.1016/S0140-6736(18)31924-X 30158069
9. Hansson L, Zanchetti A, Carruthers SG, . Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet (London, England). 1998;351(9118):1755–62. PMID: 9635947.9635947
  a. Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study--patient characteristics: randomization, risk profiles, and early blood pressure results. Blood Press. 1994;3(5):322–7. PMID: 78665977866597
  b. Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study: 12-month data on blood pressure and tolerability. With special reference to age and gender. Blood Press. 1995;4(5):313–9. PMID: 85355548535554
  c. Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study: 24-month data on blood pressure and tolerability. Blood Press. 1997;6(5):313–7. PMID: 9360003.9360003
  d. Jardine MJ, Ninomiya T, Perkovic V, . Aspirin is beneficial in hypertensive patients with chronic kidney disease: a post-hoc subgroup analysis of a randomized controlled trial. Journal of the American College of Cardiology. 2010;56(12):956–65.20828648
  e. Kjeldsen SE, Kolloch RE, Leonetti G, . Influence of gender and age on preventing cardiovascular disease by antihypertensive treatment and acetylsalicylic acid. The HOT study. Hypertension Optimal Treatment. J Hypertens. 2000;18(5):629–42. PMID: 10826567.10826567
  f. Meade TW, Brennan PJ. Determination of who may derive most benefit from aspirin in primary prevention: subgroup results from a randomised controlled trial. BMJ (Clinical research ed). 2000;321(7252):13–7. PMID: 10875825.10875825
  g. The Hypertension Optimal Treatment Study (the HOT Study). Blood Press. 1993;2(1):62–8. PMID: 8193735.8193735
  h. Zanchetti A, Hansson L, Dahlof B, . Benefit and harm of low-dose aspirin in well-treated hypertensives at different baseline cardiovascular risk. J Hypertens. 2002;20(11):2301–7. PMID: 12409970.12409970
  i. Zanchetti A, Hansson L, Dahlof B, . Effects of individual risk factors on the incidence of cardiovascular events in the treated hypertensive patients of the Hypertension Optimal Treatment Study. HOT Study Group. J Hypertens. 2001;19(6):1149–59. PMID: 11403365.11403365
  j. Zanchetti A, Hansson L, Menard J, . Risk assessment and treatment benefit in intensively tre136: The Hypertension Optimal Treatment Study (the HOT Study). Blood Press. 1993;2(1):62–8. PMID: 8193735.8193735
10. Huang ES, Strate LL, Ho WW, . A prospective study of aspirin use and the risk of gastrointestinal bleeding in men. PLoS ONE. 2010;5(12):e15721. PMID: 21209949.21209949
  a. Strate LL, Liu YL, Huang ES, . Use of aspirin or nonsteroidal anti-inflammatory drugs increases risk for diverticulitis and diverticular bleeding. Gastroenterology. 2011;140(5):1427–33. PMID: 21320500.21320500
11. Huang ES, Strate LL, Ho WW, . Long-term use of aspirin and the risk of gastrointestinal bleeding. American Journal of Medicine. 2011;124(5):426–33. PMID: 21531232.21531232
  a. Iso H, Hennekens CH, Stampfer MJ, . Prospective study of aspirin use and risk of stroke in women. Stroke. 1999;30(9):1764–71. PMID: 10471421.10471421
  b. Manson JE, Stampfer MJ, Colditz GA, . A prospective study of aspirin use and primary prevention of cardiovascular disease in women. Jama. 1991;266(4):521–7. PMID: 2061978.2061978
12. Ikeda Y, Shimada K, Teramoto T, . Low-dose aspirin for primary prevention of cardiovascular events in Japanese patients 60 years or older with atherosclerotic risk factors: a randomized clinical trial. Jama. 2014;312(23):2510–20. PMID: 25401325.25401325
  a. Sugawara M, Goto Y, Yamazaki T, . Low-Dose Aspirin for Primary Prevention of Cardiovascular Events in Elderly Japanese Patients with Atherosclerotic Risk Factors: Subanalysis of a Randomized Clinical Trial (JPPP-70). American Journal of Cardiovascular Drugs. 2019;19(3):299–311. PMID: 30565155. 10.1007/s40256-018-0313-0 30565155
  b. Uchiyama S, Ishizuka N, Shimada K, . Aspirin for Stroke Prevention in Elderly Patients With Vascular Risk Factors: Japanese Primary Prevention Project. Stroke. 2016;47(6):1605–11. PMID: 27165949. 10.1161/STROKEAHA.115.012461 27165949
  c. Yokoyama K, Ishizuka N, Uemura N, . Effects of daily aspirin on cancer incidence and mortality in the elderly Japanese. Research And Practice In Thrombosis And Haemostasis. 2018;2(2):274–81. PMID: 30046729. 10.1002/rth2.12097 30046729
13. Jung M, Lee S. Efficacy of Aspirin in the Primary Prevention of Cardiovascular Diseases and Cancer in the Elderly: A Population-Based Cohort Study in Korea. Drugs Aging. 2020;37(1):43–55. PMID: 31755069. 10.1007/s40266-019-00723-3 31755069
14. Luo PJ, Lin XH, Lin CC, . Risk factors for upper gastrointestinal bleeding among aspirin users: An old issue with new findings from a population-based cohort study. J Formos Med Assoc. 2019;118(5):939–44. PMID: 30366771. 10.1016/j.jfma.2018.10.007 30366771
15. McNeil JJ, Wolfe R, Woods RL, . Effect of Aspirin on Cardiovascular Events and Bleeding in the Healthy Elderly. New England Journal of Medicine. 2018;379(16):1509–18. PMID: 30221597. 10.1056/NEJMoa1805819 30221597
  a. ASPREE. ASPrin in Reducing Events in the Elderly Protocol Version 9. https://aspree.org/usa/wp-content/uploads/sites/3/2014/04/ASPREE-Protocol-Version-9_-Nov2014_FINAL.pdf. Accessed June 3, 2020. PMID.: None.
  b. Mahady SE, Margolis KL, Chan A, . Major GI bleeding in older persons using aspirin: incidence and risk factors in the ASPREE randomised controlled trial. Gut. 2020. 10.1136/gutjnl-2020-321585
  c. Margolis KL, Mahady SE, Nelson MR, . Development of a standardized definition for clinically significant bleeding in the ASPirin in Reducing Events in the Elderly (ASPREE) trial. Contemporary Clinical Trials Communications. 2018;11:30–6. PMID: 30023457. 10.1016/j.conctc.2018.05.015 30023457
  d. McNeil JJ, Nelson MR, Woods RL, . Effect of Aspirin on All-Cause Mortality in the Healthy Elderly. N Engl J Med. 2018;379(16):1519–28. PMID: 30221595. 10.1056/NEJMoa1803955 30221595
  e. McNeil JJ, Woods RL, Nelson MR, . Baseline Characteristics of Participants in the ASPREE (ASPirin in Reducing Events in the Elderly) Study. J Gerontol A Biol Sci Med Sci. 2017;72(11):1586–93. PMID: 28329340. 10.1093/gerona/glw342 28329340
  f. McNeil JJ, Woods RL, Nelson MR, . Effect of Aspirin on Disability-free Survival in the Healthy Elderly. New England Journal of Medicine. 2018;379(16):1499–508. PMID: 30221596. 10.1056/NEJMoa1800722 30221596
  g. Nelson MR, Reid CM, Ames DA, . Feasibility of conducting a primary prevention trial of low-dose aspirin for major adverse cardiovascular events in older people in Australia: results from the ASPirin in Reducing Events in the Elderly (ASPREE) pilot study. Med J Aust. 2008;189(2):105–9. PMID: 18637782.18637782
  h. Wolfe R, Murray AM, Woods RL, . The aspirin in reducing events in the elderly trial: Statistical analysis plan. International Journal of Stroke. 2018;13(3):335–8. PMID: 29111960. 10.1177/1747493017741383 29111960
16. Ogawa H, Nakayama M, Morimoto T, . Low-dose aspirin for primary prevention of atherosclerotic events in patients with type 2 diabetes: a randomized controlled trial.[Erratum appears in JAMA. 2009 May 13;301(18):1882]. Jama. 2008;300(18):2134–41. PMID: 18997198.18997198
  a. Okada S, Morimoto T, Ogawa H, . Differential effect of low-dose aspirin for primary prevention of atherosclerotic events in diabetes management: a subanalysis of the JPAD trial. Diabetes care. 2011;34(6):1277–83. PMID: 21515838.21515838
  b. Okada S, Morimoto T, Ogawa H, . Effect of low-dose aspirin on primary prevention of cardiovascular events in Japanese diabetic patients at high risk. Circ J. 2013;77(12):3023–8. PMID: 24042256. 10.1253/circj.cj-13-0307 24042256
  c. Saito Y, Morimoto T, Ogawa H, . Low-dose aspirin therapy in patients with type 2 diabetes and reduced glomerular filtration rate: subanalysis from the JPAD trial. Diabetes care. 2011;34(2):280–5. PMID: 21270185.21270185
  d. Saito Y, Okada S, Ogawa H, . Low-Dose Aspirin for Primary Prevention of Cardiovascular Events in Patients With Type 2 Diabetes Mellitus: 10-Year Follow-Up of a Randomized Controlled Trial. Circulation. 2017;135(7):659–70. PMID: 27881565. 10.1161/CIRCULATIONAHA.116.025760 27881565
  e. Soejima H, Ogawa H, Morimoto T, . Aspirin possibly reduces cerebrovascular events in type 2 diabetic patients with higher C-reactive protein level: subanalysis from the JPAD trial. Journal of Cardiology. 2013;62(3):165–70. PMID: 23778008.23778008
  f. Soejima H, Ogawa H, Morimoto T, . Aspirin reduces cerebrovascular events in type 2 diabetic patients with poorly controlled blood pressure. Subanalysis from the JPAD trial. Circ J. 2012;76(6):1526–32. PMID: 22447019.22447019
17. Peto R, Gray R, Collins R, . Randomised trial of prophylactic daily aspirin in British male doctors. Br Med J (Clin Res Ed). 1988;296(6618):313–6. PMID: 3125882.3125882
18. Ridker PM, Cook NR, Lee IM, . A randomized trial of low-dose aspirin in the primary prevention of cardiovascular disease in women. N Engl J Med. 2005;352(13):1293–304. PMID: 15753114.15753114
  a. Buring JE, Hennekens CH. The Women’s Health Study: summary of the study design. J Myocardial Ischemia. 1992;4(3):27–9. PMID: None.
  b. Christen WG, Glynn RJ, Chew EY, . Low-dose aspirin and medical record-confirmed age-related macular degeneration in a randomized trial of women. Ophthalmology. 2009;116(12):2386–92. PMID: 19815293.19815293
  c. Cook NR, Lee IM, Zhang SM, . Alternate-day, low-dose aspirin and cancer risk: long-term observational follow-up of a randomized trial. Annals of internal medicine. 2013;159(2):77–85. PMID: 23856681. 10.7326/0003-4819-159-2-201307160-00002 23856681
  d. Dorresteijn JA, Visseren FL, Ridker PM, . Aspirin for primary prevention of vascular events in women: individualized prediction of treatment effects. European heart journal. 2011;32(23):2962–9. PMID: 22090661.22090661
  e. Glynn RJ, Ridker PM, Goldhaber SZ, . Effect of low-dose aspirin on the occurrence of venous thromboembolism: a randomized trial. Annals of internal medicine. 2007;147(8):525–33. PMID: 17938390.17938390
  f. Rexrode KM, Lee IM, Cook NR, . Baseline characteristics of participants in the Women’s Health Study. J Womens Health Gend Based Med. 2000;9(1):19–27. PMID: 10718501.10718501
  g. Rist PM, Buring JE, Kase CS, . Effect of low-dose aspirin on functional outcome from cerebral vascular events in women. Stroke. 2013;44(2):432–6.23306328
19. Roncaglioni M, Collaborative Group of the Primary Prevention Project. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general Practice. The Lancet. 2001;357(9250):89–95. PMID: 11197445.11197445
  a. Berger JS, Roncaglioni MC, Avanzini F, . Aspirin for the primary prevention of cardiovascular events in women and men: a sex-specific meta-analysis of randomized controlled trials. Jama. 2006;295(3):306–13. PMID: 16418466.16418466
  b. Sacco M, Pellegrini F, Roncaglioni MC, . Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general Practice. Diabetes care. 2003;26(12):3264–72. PMID: 14633812.14633812
  c. Sacco M, Pellegrini F, Roncaglioni MC, . Primary prevention of cardiovascular events with low-dose aspirin and vitamin E in type 2 diabetic patients: results of the Primary Prevention Project (PPP) trial. Diabetes care. 2003;26(12):3264–72. PMID: 14633812.14633812
20. Silagy CA, McNeil JJ, Donnan GA, . Adverse effects of low-dose aspirin in a healthy elderly population. Clin Pharmacol Ther. 1993;54(1):84–9. PMID: 8330469.8330469
21. Thrombosis prevention trial: randomised trial of low-intensity oral anticoagulation with warfarin and low-dose aspirin in the primary prevention of ischaemic heart disease in men at increased risk. The Medical Research Council’s General Practice Research Framework. Lancet (London, England). 1998;351(9098):233–41. PMID: 9457092.9457092
  a. Meade TW, Brennan PJ. Determination of who may derive most benefit from aspirin in primary prevention: subgroup results from a randomised controlled trial. BMJ (Clinical research ed). 2000;321(7252):13–7. PMID: 10875825.10875825
  b. Meade TW, Roderick PJ, Brennan PJ, . Extra-cranial bleeding and other symptoms due to low-dose aspirin and low intensity oral anticoagulation. Thromb Haemost. 1992;68(1):1–6. PMID: 1514166.1514166