# Appendix A Detailed Methods

## Literature Search Strategies for Primary Literature

Key:

- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- pt = publication type
- * = truncation
- kw = keyword
- sb = subset
- pdat = publication date
- fs = floating subheading

### MEDLINE

Database: Ovid MEDLINE(R) and Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Daily and Versions(R)

1. Colorectal Neoplasms/
2. Colonic Neoplasms/
3. Sigmoid Neoplasms/
4. Colorectal Neoplasms, Hereditary Nonpolyposis/
5. Rectal Neoplasms/
6. Anus Neoplasms/
7. Anal Gland Neoplasms/
8. Colonic Polyps/
9. (colorectal or colon or colonic or rectal or rectum or rectosigmoid$).ti,ab.
10. (cancer$ or carcinoma$ or malignan$ or tumor$ or tumour$ or neoplas$ or polyp$).ti,ab.
11. 9 and 10
12. or/1-8,11
13. Aspirin/
14. Salicylates/
15. aspirin.ti,ab.
16. acetylsalicylic.ti,ab.
17. salicylate$.ti,ab.
18. or/13-17
19. 12 and 18
20. limit 19 to (english language and yr=“2014 -Current”)
21. Cardiovascular Diseases/
22. Heart Diseases/
23. Heart Arrest/
24. Death, Sudden, Cardiac/
25. Out-of-Hospital Cardiac Arrest/
26. Myocardial Ischemia/
27. Acute Coronary Syndrome/
28. Angina Pectoris/
29. Angina, Stable/
30. Angina, Unstable/
31. Angina Pectoris, Variant/
32. Microvascular Angina/
33. Coronary Disease/
34. Coronary Artery Disease/
35. Coronary Occlusion/
36. Coronary Stenosis/
37. Coronary Restenosis/
38. Coronary Thrombosis/
39. Myocardial Infarction/
40. Anterior Wall Myocardial Infarction/
41. Inferior Wall Myocardial Infarction/
42. No-Reflow Phenomenon/
43. Shock, Cardiogenic/
44. Myocardial Reperfusion Injury/
45. Myocardial Stunning/
46. Vascular Diseases/
47. Stroke/
48. Brain Infarction/
49. Brain Stem Infarctions/
50. Lateral Medullary Syndrome/
51. Cerebral Infarction/
52. Infarction, Anterior Cerebral Artery/
53. Infarction, Middle Cerebral Artery/
54. Infarction, Posterior Cerebral Artery/
55. Stroke, Lacunar/
56. cardiovascular disease$.ti,ab.
57. heart disease$.ti,ab.
58. myocardial infarction.ti,ab.
59. heart arrest.ti,ab.
60. myocardial ischemia.ti,ab.
61. myocardial ischaemia.ti,ab.
62. coronary artery disease.ti,ab.
63. heart attack$.ti,ab.
64. stroke.ti,ab.
65. cerebrovascular disease$.ti,ab.
66. cerebrovascular disorder$.ti,ab.
67. cardiac arrest.ti,ab.
68. acute coronary syndrome.ti,ab.
69. angina pectoris.ti,ab.
70. stable angina.ti,ab.
71. unstable angina.ti,ab.
72. microvascular angina.ti,ab.
73. coronary occlusion.ti,ab.
74. coronary disease.ti,ab.
75. coronary thrombosis.ti,ab.
76. coronary stenosis.ti,ab.
77. coronary restenosis.ti,ab.
78. myocardial stunning.ti,ab.
79. no-reflow phenomenon.ti,ab.
80. cardiogenic shock.ti,ab.
81. myocardial reperfusion.ti,ab.
82. vascular disease$.ti,ab.
83. brain infarction$.ti,ab.
84. brain stem infarction$.ti,ab.
85. artery infarction$.ti,ab.
86. cerebral infarction$.ti,ab.
87. lateral medullary syndrome.ti,ab.
88. or/21-87
89. (clinical trial or adaptive clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or randomized controlled trial or equivalence trial or pragmatic clinical trial or Meta-Analysis).pt.
90. clinical trials as topic/ or adaptive clinical trials as topic/ or clinical trials, phase i as topic/ or clinical trials, phase ii as topic/ or clinical trials, phase iii as topic/ or clinical trials, phase iv as topic/ or controlled clinical trials as topic/ or non-randomized controlled trials as topic/ or randomized controlled trials as topic/ or equivalence trials as topic/ or intention to treat analysis/ or pragmatic clinical trials as topic/ or meta-analysis as topic/
91. control groups/ or double-blind method/ or single-blind method/ or control groups/ or random allocation/ or placebos/
92. (randomized or randomised or placebo or randomly or phase iii or phase 3).ti,ab.
93. (RCT or placebo or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or random$).ti,ab.
94. ((control$ or clinical) adj3 (study or studies or trial$ or group$)).ti,ab.
95. (Nonrandom$ or non random$ or non-random$ or quasi-random$ or quasirandom$).ti,ab.
96. allocated.ti,ab.
97. ((open label or open-label) adj5 (study or studies or trial$)).ti,ab.
98. ((equivalence or superiority or non-inferiority or noninferiority) adj3 (study or studies or trial$)).ti,ab.
99. (pragmatic study or pragmatic studies).ti,ab.
100. ((pragmatic or practical) adj3 trial$).ti,ab.
101. ((quasiexperimental or quasi-experimental) adj3 (study or studies or trial$)).ti,ab.
102. (metaanaly$ or meta analy$).ti,ab.
103. or/89-102
104. 18 and 88 and 103
105. limit 104 to (english language and yr=“2014 -Current”)
106. remove duplicates from 105
107. Mortality/
108. Morbidity/
109. Death/
110. Hemorrhage/
111. Gastrointestinal Hemorrhage/
112. Stroke/
113. Intracranial Hemorrhages/
114. Cerebral Hemorrhage/
115. safety.ti,ab.
116. harm$.ti,ab.
117. mortality.ti,ab.
118. toxicity.ti,ab.
119. (adverse adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab.
120. gastrointestinal.ti,ab.
121. bleed$.ti,ab.
122. hemorrhag$.ti,ab.
123. haemorrhag$.ti,ab.
124. stroke$.ti,ab.
125. adverse effects.fs.
126. toxicity.fs.
127. or/107-126
128. 18 and 103 and 127
129. Animals/ not (Humans/ and Animals/)
130. 128 not 129
131. limit 130 to (english language and yr=“2014 -Current”)
132. cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or evaluation study/
133. cohort.ti,ab.
134. longitudinal.ti,ab.
135. (follow-up or followup).ti,ab.
136. prospective$.ti,ab.
137. (comparison group$ or control group$).ti,ab.
138. observational.ti,ab.
139. database$.ti,ab.
140. (nonrandomi$ or non-randomi$).ti,ab.
141. population$.ti,ab.
142. Registries/
143. (registr$ or register$).ti,ab.
144. cross-sectional studies/
145. cross-sectional.ti,ab.
146. multivariate analysis/ or chi-square distribution/ or logistic models/
147. multivariate.ti,ab.
148. comparative study/
149. or/132-148
150. 18 and 127 and 149
151. Animals/ not (Humans/ and Animals/)
152. 150 not 151
153. limit 152 to (english language and yr=“2014 -Current”)
154. 20 or 106 or 131 or 153

### PUBMED [publisher supplied references only]

1. Aspirin[tiab] OR acetylsalicylic[tiab] OR Salicylate*[tiab]
2. ((colorectal[tiab] OR colon[tiab] OR colonic[tiab] OR rectal[tiab] OR rectum[tiab] OR rectosigmoid*[tiab]) AND (cancer[tiab] OR cancers[tiab] OR cancerous[tiab] OR carcinoma*[tiab] OR malignan*[tiab] OR tumor[tiab] OR tumoro*[tiab] OR tumors[tiab] OR tumour*[tiab] OR neoplasm*[tiab] OR polyp OR polypo* OR polyps[tiab]))
3. stroke[tiab] OR cerebrovascular disease*[tiab] OR cerebrovascular disorder*[tiab] OR brain infarction*[tiab] OR cerebral infarction*[tiab] OR artery infarction*[tiab] OR “coronary thrombosis”[tiab] OR “coronary occlusion”[tiab] OR “cardiogenic shock”[tiab] OR “myocardial reperfusion”[tiab] OR “myocardial stunning”[tiab] OR “lateral medullary syndrome”[tiab]
4. cardiovascular disease*[tiab] OR heart disease*[tiab] OR coronary disease*[tiab] OR vascular disease*[tiab] OR “myocardial infarction”[tiab] OR “cardiac arrest”[tiab] OR “heart arrest”[tiab] OR heart attack*[tiab] OR “myocardial ischemia”[tiab] OR “myocardial ischaemia”[tiab] OR “coronary artery disease”[tiab] OR “acute coronary syndrome”[tiab] OR angina[tiab] OR “coronary restenosis”[tiab] OR “coronary stenosis”[tiab]
5. #1 AND (#2 OR #3 OR #4) AND publisher[sb] AND (2014:2020[pdat])) Filters: English

#### Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL)

#1 (Aspirin or acetylsalicylic or Salicylate*):ti,ab,kw
#2 (colorectal or colon or colonic or rectal or rectum or rectosigmoid ):ti,ab,kw
#3 (cancer* or carcinoma* or malignan* or tumor* or tumour* or neoplas* or polyp*):ti,ab,kw
#4 #2 AND #3
#5 (coronary or angina or myocardial or “cardiac arrest” or “cardiac death” or “heart arrest”):ti,ab,kw
#6 (heart near attack*):ti,ab,kw
#7 (Cardiovascular next Disease*):ti,ab,kw
#8 (Heart next Disease*):ti,ab,kw
#9 (vascular next disease*):ti,ab,kw
#10 stroke:ti,ab,kw
#11 (brain next infarction*):ti,ab,kw
#12 (“brain stem” near infarction*):ti,ab,kw
#13 “Lateral Medullary Syndrome”:ti,ab,kw
#14 (Cerebral near infarction*):ti,ab,kw
#15 (Cerebrovascular next disease*):ti,ab,kw
#16 (Cerebrovascular next disorder*):ti,ab,kw
#17 {OR #4-#16}
#18 #1 AND #17 with Publication Year from 2014 to 2020, in Trials
#19 #18 NOT (clinicaltrials or trialsearch):so

#### Embase

#1 ‘rectum tumor’/exp/mj OR ‘colon tumor’/exp/mj
#2 colorectal:ti,ab OR colon:ti,ab OR colonic:ti,ab OR rectal:ti,ab OR rectum:ti,ab OR rectosigmoid*:ti,ab
#3 cancer*:ti,ab OR carcinoma*:ti,ab OR malignan*:ti,ab OR tumor*:ti,ab OR tumour*:ti,ab OR neoplas*:ti,ab OR polyp*:ti,ab
#4 #2 AND #3
#5 #1 OR #4
#6 ‘acetylsalicylic acid’/mj
#7 aspirin:ti,ab OR acetylsalicylic:ti,ab OR salicylate*:ti,ab
#8 #6 OR #7
#9 #5 AND #8
#10 ‘cardiovascular disease’/exp/mj
#11 ‘cardiovascular disease*’:ti,ab OR ‘heart disease*’:ti,ab OR ‘myocardial infarction’:ti,ab OR ‘heart arrest’:ti,ab OR ‘myocardial ischemia’:ti,ab OR ‘myocardial ischaemia’:ti,ab OR ‘coronary artery disease’:ti,ab OR ‘heart attack*’:ti,ab OR stroke:ti,ab OR ‘cerebrovascular disease*’:ti,ab OR ‘cerebrovascular disorder*’:ti,ab OR ‘cardiac arrest’:ti,ab OR ‘acute coronary syndrome’:ti,ab OR ‘angina pectoris’:ti,ab OR ‘stable angina’:ti,ab OR ‘unstable angina’:ti,ab OR ‘microvascular angina’:ti,ab OR ‘coronary occlusion’:ti,ab OR ‘coronary disease’:ti,ab OR ‘coronary thrombosis’:ti,ab OR ‘coronary stenosis’:ti,ab OR ‘coronary restenosis’:ti,ab OR ‘myocardial stunning’:ti,ab OR ‘no-reflow phenomenon’:ti,ab OR ‘cardiogenic shock’:ti,ab OR ‘myocardial reperfusion’:ti,ab OR ‘vascular disease*’:ti,ab OR ‘brain infarction*’:ti,ab OR ‘brain stem infarction*’:ti,ab OR ‘artery infarction*’:ti,ab OR ‘cerebral infarction*’:ti,ab OR ‘lateral medullary syndrome’:ti,ab
#12 #10 OR #11
#13 #8 AND #12
#14 ‘clinical trial’/de OR ‘controlled clinical trial’/de OR ‘randomized controlled trial’/exp OR ‘randomization’/exp OR ‘single blind procedure’/de OR ‘double blind procedure’/de OR ‘crossover procedure’/de OR ‘placebo’/de OR ‘randomized controlled trial (topic)’/de OR ‘clinical trial (topic)’/de OR ‘controlled clinical trial (topic)’/de OR ‘meta analysis’/exp OR ‘meta analysis (topic)’/de
#15 trial:ti OR compare:ti OR compared:ti OR comparison:ti
#16 (evaluated:ab OR evaluate:ab OR evaluating:ab OR assessed:ab OR assess:ab) AND (compare:ab OR compared:ab OR comparing:ab OR comparison:ab)
#17 (open NEXT/1 label):ti,ab
#18 ((double OR single OR doubly OR singly) NEXT/1 (blind OR blinded OR blindly)):ti,ab
#19 (parallel NEXT/1 group*):ti,ab
#20 crossover:ti,ab OR ‘cross over’:ti,ab
#21 ((assign* OR match OR matched OR allocation) NEAR/6 (alternate OR group OR groups OR intervention OR interventions OR patient OR patients OR subject OR subjects OR participant OR participants)):ti,ab
#22 assigned:ti,ab OR allocated:ti,ab
#23 volunteer:ti,ab OR volunteers:ti,ab
#24 ‘phase iii’:ti,ab OR ‘phase 3’:ti,ab
#25 rct:ti,ab OR placebo:ti,ab OR sham:ti,ab OR dummy:ti,ab OR ‘single blind*’:ti,ab OR ‘double blind*’:ti,ab OR allocated:ti,ab OR allocation:ti,ab OR ‘triple blind*’:ti,ab OR ‘treble blind*’:ti,ab OR random*:ti,ab
#26 ((control* OR clinical) NEAR/3 (study OR studies OR trial* OR group* OR design)):ti,ab
#27 ((equivalence OR superiority OR ‘non inferiority’ OR noninferiority) NEAR/3 (study OR studies OR trial*)):ti,ab
#28 ‘pragmatic study’:ti,ab OR ‘pragmatic studies’:ti,ab
#29 ((pragmatic OR practical) NEAR/3 trial*):ti,ab
#30 ((quasiexperimental OR ‘quasi experimental’) NEAR/3 (study OR studies OR trial*)):ti,ab
#31 metaanaly*:ti,ab OR ‘meta analy*’:ti,ab
#32 #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31
#33 #9 OR #13
#34 #32 AND #33 AND [humans]/lim AND [english]/lim AND [2014-2020]/py AND ([young adult]/lim OR [adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim)
#35 ‘mortality’/exp/mj OR ‘morbidity’/exp/mj OR ‘death’/exp/mj OR ‘bleeding’/exp/mj OR ‘cerebrovascular accident’/exp/mj OR ‘adverse event’/exp/mj OR ‘toxicity’/exp/mj
#36 safety:ti,ab OR harm*:ti,ab OR mortality:ti,ab OR toxicity:ti,ab OR gastrointestinal:ti,ab OR bleed*:ti,ab OR hemorrhag*:ti,ab OR haemorrhag*:ti,ab OR stroke*:ti,ab
#37 #35 OR #36
#38 #8 AND #32 AND #37
#39 ‘longitudinal study’/exp OR ‘prospective study’/de OR ‘cohort analysis’/de OR ‘follow up’/de OR ‘register’/de OR ‘cross-sectional study’/de
#40 cohort*:ti,ab OR longitudinal:ti,ab OR ‘follow up’:ti,ab OR followup:ti,ab OR prospective*:ti,ab OR ‘comparison group*’:ti,ab OR ‘control group*’:ti,ab OR observational:ti,ab OR database*:ti,ab OR nonrandomi*:ti,ab OR population*:ti,ab OR registr*:ti,ab OR register*:ti,ab OR ‘cross-sectional’:ti,ab
#41 ‘multivariate analysis’/exp OR ‘chi square distribution’/de
#42 multivariate:ti,ab
#43 ‘comparative study’/de
#44 #39 OR #40 OR #41 OR #42 OR #43
#45 #8 AND #37 AND #44
#46 #38 OR #45
#47 (#38 OR #45) AND ([young adult]/lim OR [adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) AND [humans]/lim AND [english]/lim AND [2014-2020]/py
#48 #34 OR #47

Appendix A Table 1 Inclusion and Exclusion Criteria

| Inclusion | Exclusion
Aim | Primary prevention of CVD, CRC, and/or all-cause mortality | Secondary and tertiary prevention of CVD or CRC
Populations | Adults age ≥40 years without known CVD and at average risk for CRC or unselected for CRC risk^*^ | Other selected nongeneralizable populations (e.g., those with genetic susceptibility syndromes or personal history of cancer)
Interventions | Regular oral aspirin use (at least 75 mg every other day) for 12 months | Coadministration with other nonaspirin antithrombotic medications (e.g., warfarin)
Comparisons | Placebo or no treatment | Any active substance or intervention
Outcomes | KQ 1: Myocardial infarction, stroke, death from myocardial infarction or stroke, CRC incidence, CRC mortality, and all-cause mortality; KQ 2: Major bleeding, defined as bleeding requiring transfusion or hospitalization or leading to death (including but not limited to gastrointestinal bleeding), hemorrhagic stroke, or other serious harms | KQ 1: Intermediate markers of CVD (e.g., calcium scores, intimal medial thickness, or asymptomatic electrocardiography findings); intermediate markers of platelet function or clotting; KQ 2: Postoperative or minor bleeding
Study Designs | All KQs: Good- and fair-quality studies, according to USPSTF criteria; KQ 1: Randomized, controlled trials; controlled clinical trials; and individual patient data meta-analyses; KQ 2: Randomized, controlled trials; controlled clinical trials; individual patient data meta-analyses; and large observational studies | All KQs: Poor-quality studies, according to USPSTF criteria; KQ 1: Observational studies; KQ 2: Case control studies, case series, case reports, narrative reviews, commentaries, or editorials
Setting | Studies conducted in countries categorized as “very high” on the 2017 Human Development Index, as defined by the United Nations Development Programme^†^

* For CRC outcomes only, populations with and without a history of CVD will be included.

† Andorra, Argentina, Australia, Austria, Bahamas, Bahrain, Barbados, Belarus, Belgium, Brunei Darussalam, Bulgaria, Canada, Chile, Croatia, Cyprus, Czechia, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy, Japan, Kazakhstan, Korea (Republic of), Kuwait, Latvia, Liechtenstein, Lithuania, Luxembourg, Malaysia, Malta, Montenegro, Netherlands, New Zealand, Norway, Oman, Poland, Portugal, Qatar, Romania, Russian Federation, Saudi Arabia, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, UK, United Arab Emirates, Uruguay, US. Taiwan is not incorporated into HDI calculations for the People’s Republic of China and will be considered very high HDI based on calculations from Taiwan’s government.

Abbreviations: CRC = colorectal cancer; CVD = cardiovascular disease; KQ = key question; mg = milligram; USPSTF = United States Preventive Services Task Force

Appendix A Table 2 Quality Assessment Criteria^*^

Study Design | Adapted Quality Criteria
Cohort studies, adapted from Newcastle-Ottawa Scale ^201^ | Bias arising in randomization process or due to confounding; - Balance in baseline characteristics; - No baseline confounding; - No time-varying confounding; Bias in selecting participants into the study; - No evidence of biased selection of sample; - Start of followup and start of intervention coincide; Bias due to departures form intended interventions; - Participant intervention status is clearly and explicitly defined and measured; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome; Bias in classifying interventions; - Fidelity to intervention protocol; - Participants were analyzed as originally allocated; Bias from missing data; - Outcome data are reasonably complete and comparable between groups; - Confounding variables that are controlled for in analysis are reasonably complete; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported
Randomized clinical trials, adapted from U.S. Preventive Services Task Force Manual ^46^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported

* All randomized clinical trials were classified as good, fair, or poor according to the USPSTF Procedure Manual^46^

Appendix A Figure 1 Literature Flow Diagram

Abbreviations: KQ = key question; MA = meta-analysis

This figure is a flow chart that summarizes the search and selection of articles in the review. There were 12,586 citations identified through literature databases. An additional 8 citations were identified from outside sources such as reference lists and suggestions from peer reviewers, and 116 citations were from the previous review of this topic. After duplicates were removed, 12,710 unique citations were screened at the title/abstract stage. The full-text of 225 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=15) and Key Question 2 (k=21). Reasons for excluding the other articles are available in Appendix C.