# References

1 Prevention of dental caries in children from birth through five years of age: recommendation statement. Am Fam Physician. 2015 Feb 1;91(3):190a–e. PMID: 25822277.25822277
2 Moyer VA. Prevention of dental caries in children from birth through age 5 years: US Preventive Services Task Force recommendation statement. Pediatrics. 2014 Jun;133(6):1102–11. doi: 10.1542/peds.2014-0483. PMID: 24799546.24799546
3 Chou R, Cantor A, Zakher B, . Preventing dental caries in children <5 years: systematic review updating USPSTF recommendation. Pediatrics. 2013 Aug;132(2):332–50. doi: 10.1542/peds.2013-1469. PMID: 23858419.23858419
4 Chou R, Cantor A, Zakher B, . Prevention of Dental Caries in Children Younger Than 5 Years Old: Systematic Review to Update the U.S. Preventive Services Task Force Recommendation. Evidence Synthesis No. 104. AHRQ Publication No. 12-05170-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2014.
5 Calonge N. Prevention of dental caries in preschool children: recommendations and rationale. Am J Prev Med. 2004 May;26(4):326–9. doi: 10.1016/j.amepre.2004.01.008. PMID: 15110060.15110060
6 Centers for Disease Control and Prevention. Oral Health Surveillance Report: Trends in Dental Caries and Sealants, Tooth Retention, and Edentulism, United States, 1999–2004 to 2011–2016. Atlanta, GA: Centers for Disease Control and Prevention, US Dept of Health and Human Services; 2019.
7 Bader JD, Rozier RG, Lohr KN, . Physicians’ roles in preventing dental caries in preschool children: a summary of the evidence for the U.S. Preventive Services Task Force. Am J Prev Med. 2004 May;26(4):315–25. PMID: 15110059.15110059
8 Centers for Disease Control and Prevention. Dental Caries: Hygiene-related diseases. 2009. http://www.cdc.gov/healthywater/hygiene/disease/dental_caries.html. Accessed May 13, 2019.
9 Selwitz RH, Ismail AI, Pitts NB. Dental caries. Lancet. 2007 Jan 6;369(9555):51–9. doi: 10.1016/s0140-6736(07)60031-2. PMID: 17208642.17208642
10 American Dental Association. Statement on Early Childhood Caries. 2000. https://www.ada.org/en/about-the-ada/ada-positions-policies-and-statements/statement-on-early-childhood-caries. Accessed October 8, 2020.
11 Ismail AI, Sohn W, Tellez M, . The International Caries Detection and Assessment System (ICDAS): an integrated system for measuring dental caries. Community Dent Oral Epidemiol. 2007 Jun;35(3):170–8. doi: 10.1111/j.1600-0528.2007.00347.x. PMID: 17518963.17518963
12 Young DA, Nový BB, Zeller GG, . The American Dental Association Caries Classification System for clinical practice: a report of the American Dental Association Council on Scientific Affairs. J Am Dent Assoc. 2015 Feb;146(2):79–86. doi: 10.1016/j.adaj.2014.11.018 PMID: 25637205.25637205
13 National Center for Health Statistics. Healthy People 2010 Final Review. PHS Publication No. 2012–1038. Hyattsville, MD: U.S. Department of Health and Human Services. Centers for Disease Control and Prevention; 2012. https://www.cdc.gov/nchs/data/hpdata2010/hp2010_final_review.pdf.
14 U.S. Department of Health and Human Services. Oral Health in America: A Report of the Surgeon General. Rockville, MD: Department of Health and Human Services, National Institute of Dental and Craniofacial Research, National Institutes of Health; 2000. https://profiles.nlm.nih.gov/ps/access/NNBBJT.pdf.
15 Dye BA, Mitnik GL, Iafolla TJ, . Trends in dental caries in children and adolescents according to poverty status in the United States from 1999 through 2004 and from 2011 through 2014. J Am Dent Assoc. 2017 Aug;148(8):550–65.e7. doi: 10.1016/j.adaj.2017.04.013. PMID: 28619207.28619207
16 Dye BA, Thornton-Evans G, Li X, . Dental caries and sealant prevalence in children and adolescents in the United States, 2011-2012. NCHS data brief. 2015 Mar(191):1–8. PMID: 25932891.25932891
17 Kawashita Y, Kitamura M, Saito T. Early childhood caries. Int J Dent. 2011;2011:725320. doi: 10.1155/2011/725320. PMID: 22007218.22007218
18 Casamassimo PS, Thikkurissy S, Edelstein BL, . Beyond the dmft: the human and economic cost of early childhood caries. J Am Dent Assoc. 2009 Jun;140(6):650–7. PMID: 19491160.19491160
19 Jackson SL, Vann WF, Jr., Kotch JB, . Impact of poor oral health on children’s school attendance and performance. Am J Public Health. 2011 Oct;101(10):1900–6. doi: 10.2105/ajph.2010.200915. PMID: 21330579.21330579
20 Caufield PW, Griffen AL. Dental caries. An infectious and transmissible disease. Pediatr Clin North Am. 2000 Oct;47(5):1001–19, v. PMID: 11059347.11059347
21 Centers for Disease Control and Prevention. Recommendations for using fluoride to prevent and control dental caries in the United States. MMWR. Recommendations and reports : Morbidity and mortality weekly report. Recommendations and reports. 2001 Aug 17;50(RR-14):1–42. PMID: 11521913.11521913
22 Tinanoff N, Reisine S. Update on early childhood caries since the Surgeon General’s Report. Acad Pediatr. 2009 Nov-Dec;9(6):396–403. doi: 10.1016/j.acap.2009.08.006. PMID: 19945074.19945074
23 American Academy of Pediatrics. Profile of pediatric visits: annualized estimates 2000-2004. Elk Grove Village, IL; 2007.
24 Edelstein BL, Chinn CH. Update on disparities in oral health and access to dental care for America’s children. Acad Pediatr. 2009 Nov-Dec;9(6):415–9. doi: 10.1016/j.acap.2009.09.010. PMID: 19945076.19945076
25 Lewis CW, Boulter S, Keels MA, . Oral health and pediatricians: results of a national survey. Acad Pediatr. 2009 Nov-Dec;9(6):457–61. doi: 10.1016/j.acap.2009.09.016. PMID: 19945080.19945080
26 Task Force on Community Preventive Services. Recommendations on selected interventions to prevent dental caries, oral and pharyngeal cancers, and sports-related craniofacial injuries. Am J Prev Med. 2002 Jul;23(1 Suppl):16–20. PMID: 12091092.12091092
27 Levy SM, Broffitt B, Marshall TA, . Associations between fluorosis of permanent incisors and fluoride intake from infant formula, other dietary sources and dentifrice during early childhood. J Am Dent Assoc. 2010 Oct;141(10):1190–201. PMID: 20884921.20884921
28 Ismail AI, Bandekar RR. Fluoride supplements and fluorosis: a meta-analysis. Community Dent Oral Epidemiol. 1999 Feb;27(1):48–56. PMID: 10086926.10086926
29 Beltran-Aguilar ED, Barker L, Dye BA. Prevalence and severity of dental fluorosis in the United States, 1999-2004. NCHS data brief. 2010 Nov(53):1–8. PMID: 21211168.21211168
30 Neurath C, Limeback H, Osmunson B, . Dental Fluorosis Trends in US Oral Health Surveys: 1986 to 2012. JDR Clin Trans Res. 2019 Mar 6:2380084419830957. doi: 10.1177/2380084419830957. PMID: 30931722.30931722
31 American Dental Association Council on Scientific Affairs. Professionally applied topical fluoride: evidence-based clinical recommendations. J Am Dent Assoc. 2006 Aug;137(8):1151–9. PMID: 16873333.16873333
32 Ekstrand J, Koch G, Lindgren LE, . Pharmacokinetics of fluoride gels in children and adults. Caries Res. 1981;15(3):213–20. doi: 10.1159/000260517. PMID: 6938306.6938306
33 Ekstrand J, Koch G, Petersson LG. Plasma fluoride concentration and urinary fluoride excretion in children following application of the fluoride-containing varnish Duraphat. Caries Res. 1980;14(4):185–9. doi: 10.1159/000260452. PMID: 6929729.6929729
34 Garcia RI, Gregorich SE, Ramos-Gomez F, . Absence of Fluoride Varnish-Related Adverse Events in Caries Prevention Trials in Young Children, United States. Prev Chronic Dis. 2017 Feb 16;14:E17. doi: 10.5888/pcd14.160372. PMID: 28207379.28207379
35 Crystal YO, Marghalani AA, Ureles SD, . Use of silver diamine fluoride for dental caries management in children and adolescents, including those with special health care needs. Pediatr Dent. 2017 Sep 15;39(5):135–45. PMID: 29070149.29070149
36 Horst JA, Ellenikiotis H, Milgrom PL. UCSF protocol for caries arrest using silver diamine fluoride: rationale, indications and consent. J Calif Dent Assoc. 2016 Jan;44(1):16–28. PMID: 26897901.26897901
37 Gao SS, Zhao IS, Hiraishi N, . Clinical trials of silver diamine fluoride in arresting caries among children: a systematic review. JDR Clin Trans Res. 2016;1(3):201–10. doi: 10.1177/2380084416661474. PMID: 30931743.30931743
38 Monse B, Heinrich-Weltzien R, Mulder J, . Caries preventive efficacy of silver diammine fluoride (SDF) and ART sealants in a school-based daily fluoride toothbrushing program in the Philippines. BMC Oral Health. 2012 Nov 21;12:52. doi: 10.1186/1472-6831-12-52. PMID: 23171244.23171244
39 Ruff RR, Niederman R. Comparative effectiveness of treatments to prevent dental caries given to rural children in school-based settings: protocol for a cluster randomised controlled trial. BMJ Open. 2018 Apr 13;8(4):e022646. doi: 10.1136/bmjopen-2018-022646. PMID: 29654053.29654053
40 American Academy of Pediatric Dentistry. Guideline on xylitol use in caries prevention. American Academy of Pediatric Dentistry Reference Manual. 2012/2013;34(6):166–9.
41 § 101.80 Health claims: dietary noncariogenic carbohydrate sweeteners and dental caries. https://ecfr.federalregister.gov/current/title-21/chapter-I/subchapter-B/part-101/subpart-E/section-101.80. Accessed October 15, 2020.
42 Slayton RL, Urquhart O, Araujo MWB, . Evidence-based clinical practice guideline on nonrestorative treatments for carious lesions: A report from the American Dental Association. J Am Dent Assoc. 2018 Oct;149(10):837–49.e19. doi: 10.1016/j.adaj.2018.07.002. PMID: 30261951.30261951
43 American Academy of Pediatrics. Oral Health Risk Assessment Tool. 2011.
44 American Academy of Pediatric Dentistry. Caries-risk assessment and management for infants, children, and adolescents. Pediatr Dent. 2017 Sep 15;39(6):197–204. PMID: 29179357.29179357
45 U.S. Preventive Services Task Force. Procedure Manual. https://www.uspreventiveservicestaskforce.org/uspstf/procedure-manual. Accessed August 31, 2020.
46 Ismail AI, Hasson H. Fluoride supplements, dental caries and fluorosis: a systematic review. J Am Dent Assoc. 2008;139(11):1457–68. doi: 10.14219/jada.archive.2008.0071. PMID: 18978383.18978383
47 Jiang H, Bian Z, Tai BJ, . The effect of a bi-annual professional application of APF foam on dental caries increment in primary teeth: 24-month clinical trial. J Dent Res. 2005;84(3):265–8. doi: 10.1177/154405910508400311. PMID: 15723868.15723868
48 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002 Jun 15;21(11):1539–58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
49 Lopez L, Berkowitz R, Spiekerman C, . Topical antimicrobial therapy in the prevention of early childhood caries: a follow-up report. Pediatr Dent. 2002 May-Jun;24(3):204–6. PMID: 12064491.12064491
50 Autio-Gold JT, Courts F. Assessing the effect of fluoride varnish on early enamel carious lesions in the primary dentition. J Am Dent Assoc. 2001;132(9):1247–53. PMID: 1665349.11665349
51 Du MQ, Tai BJ, Jiang H, . A two-year randomized clinical trial of chlorhexidine varnish on dental caries in Chinese preschool children. J Dent Res. 2006;85(6):557–9. doi: 10.1177/154405910608500615. PMID: 16723655.16723655
52 Chu CH, Lo ECM, Lin HC. Effectiveness of silver diamine fluoride and sodium fluoride varnish in arresting dentin caries in Chinese pre-school children. J Dent Res. 2002;81(11):767–70. doi: 10.1177/0810767. PMID: 12407092.12407092
53 Weinstein P, Riedy C, Kaakko T, . Equivalence between massive versus standard fluoride varnish treatments in high caries children aged 3-5 years. Eur J Paediatr Dent. 2001;2(2):91–6.
54 Alamoudi NM, Hanno AG, Masoud MI, . Effects of xylitol on salivary mutans streptococcus, plaque level, and caries activity in a group of Saudi mother-child pairs. An 18-month clinical trial. Saudi Med J. 2012;33(2):186–92. PMID: 22327761.22327761
55 Kovari H, Pienihäkkinen K, Alanen P. Use of xylitol chewing gum in daycare centers: a follow-up study in Savonlinna, Finland. Acta Odontol Scand. 2003;61(6):367–70. doi: 10.1080/00016350310007806. PMID: 14960009.14960009
56 Milgrom P, Ly KA, Tut OK, . Xylitol pediatric topical oral syrup to prevent dental caries: a double-blind randomized clinical trial of efficacy. Arch Pediatr Adolesc Med. 2009;163(7):601–7. doi: 10.1001/archpediatrics.2009.77. PMID: 19581542.19581542
57 Weinstein P, Spiekerman C, Milgrom P. Randomized equivalence trial of intensive and semiannual applications of fluoride varnish in the primary dentition. Caries Res. 2009;43(6):484–90. doi: 10.1159/000264686. PMID: 20016179.20016179
58 Davies GM, Duxbury JT, Boothman NJ, . Challenges associated with the evaluation of a dental health promotion programme in a deprived urban area. Community Dent Health. 2007;24(2):117–21. PMID: 17615828.17615828
59 Davies GM, Duxbury JT, Boothman NJ, . A staged intervention dental health promotion programme to reduce early childhood caries. Community Dent Health. 2005;22(2):118–22. PMID: 15984138.15984138
60 Grodzka K, Augustyniak L, Budny J, . Caries increment in primary teeth after application of Duraphat fluoride varnish. Community Dent Oral Epidemiol. 1982 Apr;10(2):55–9. doi: 10.1111/j.1600-0528.1982.tb00362.x. PMID: 6952970.6952970
61 Holm AK. Effect of fluoride varnish (Duraphat) in preschool children. Community Dent Oral Epidemiol. 1979 Oct;7(5):241–5. doi: 10.1111/j.1600-0528.1979.tb01225.x. PMID: 295702.295702
62 Kressin NR, Nunn ME, Singh H, . Pediatric clinicians can help reduce rates of early childhood caries: effects of a practice based intervention. Med Care. 2009;47(11):1121–8. doi: 10.1097/MLR.0b013e3181b58867. PMID: 19786919.19786919
63 Petersson LG, Twetman S, Pakhomov GN. The efficiency of semiannual silane fluoride varnish applications: a two-year clinical study in preschool children. J Public Health Dent. 1998 Winter;58(1):57–60. doi: 10.1111/j.1752-7325.1998.tb02991.x. PMID: 9608447.9608447
64 Seki M, Karakama F, Kawato T, . Effect of xylitol gum on the level of oral mutans streptococci of preschoolers: block-randomised trial. Int Dent J. 2011;61(5):274–80. doi: 10.1111/j.1875-595X.2011.00073.x. PMID: 21995376.21995376
65 Twetman S, Petersson LG, Pakhomov GN. Caries incidence in relation to salivary mutans streptococci and fluoride varnish applications in preschool children from low- and optimal fluoride areas. Caries Res. 1996;30(5):347–53. PMID: 8877088.8877088
66 Pierce KM, Rozier RG, Vann WF, Jr. Accuracy of pediatric primary care providers’ screening and referral for early childhood caries. Pediatrics. 2002;109(5):E82. doi: 10.1542/peds.109.5.e82. PMID: 11986488.11986488
67 Serwint JR, Mungo R, Negrete VF, . Child-rearing practices and nursing caries. Pediatrics. 1993;92(2):233–7. PMID: 8337022.8337022
68 MacRitchie HM, Longbottom C, Robertson M, . Development of the Dundee Caries Risk Assessment Model (DCRAM)--risk model development using a novel application of CHAID analysis. Community Dent Oral Epidemiol. 2012 Feb;40(1):37–45. doi: 10.1111/j.1600-0528.2011.00630.x. PMID: 21838824.21838824
69 Cochrane N, Poureslami H. Necessity of water fluoridation in Iran: a review on water fluoridation and prevention of dental caries. J Oral Health Oral Epidemiol. 2014;3(1):1–7.
70 Basir L, Rasteh B, Montazeri A, . Four-level evaluation of health promotion intervention for preventing early childhood caries: a randomized controlled trial. BMC Public Health. 2017 10 02;17(1):767. doi: 10.1186/s12889-017-4783-9. PMID: 28969655.28969655
71 Beil H, Rozier RG, Preisser JS, . Effect of early preventive dental visits on subsequent dental treatment and expenditures. Med Care. 2012;50(9):749–56. doi: 10.1097/MLR.0b013e3182551713. PMID: 22525611.22525611
72 Beil H, Rozier RG, Preisser JS, . Effects of early dental office visits on dental caries experience. Am J Public Health. 2014;104(10):1979–85. doi: 10.2105/AJPH.2013.301325.24134364
73 Blackburn J, Morrisey MA, Sen B. Outcomes associated with early preventive dental care among Medicaid-enrolled children in Alabama. JAMA Pediatr. 2017;171(4):335–41. doi: 10.1001/jamapediatrics.2016.4514.28241184
74 Kranz AM, Rozier RG, Preisser JS, . Preventive services by medical and dental providers and treatment outcomes. J Dent Res. 2014;93(7):633–8. doi: 10.1177/0022034514536731.24891593
75 Kranz AM, Rozier RG, Preisser JS, . Comparing medical and dental providers of oral health services on early dental caries experience. Am J Public Health. 2014 Jul;104(7) doi: 10.2105/ajph.2014.301972. PMID: 24832418.24832418
76 Sen B, Blackburn J, Kilgore ML, . Preventive Dental Care and Long-Term Dental Outcomes among ALL Kids Enrollees. Health Serv Res. 2016;51(6):2242–57. doi: 10.1111/1475-6773.12469.26927421
77 Lin YT, Tsai CL. Comparative anti-caries effects of tablet and liquid fluorides in cleft children. J Clin Dent. 2000 2000;11(4):104–6. PMID: 11460274.11460274
78 Hamberg L. Controlled trial of fluoride in vitamin drops for prevention of caries in children. Lancet. 1971 Feb 27;1(7696):441–2. PMID: 4100412.4100412
79 Hennon DK, Stookey GK, Muhler JC. Prophylaxis of dental caries: Relative effectiveness of chewable fluoride preparations with and without added vitamins. J Pediatr. 1972;80(6):1018–21. PMID: 5026023.5026023
80 Hu D, Wan H, Li S. The caries-inhibiting effect of a fluoride drop program: a 3-year study on Chinese kindergarten children. Chin J Dent Res. 1998;1(3):17–20. PMID: 10557167.10557167
81 Margolis FJ, Macauley J, Freshman E. The effects of measured doses of fluoride. A five-year preliminary report. Am J Dis Child. 1967;113(6):670–2. PMID: 4381737.4381737
82 Margolis FJ, Reames HR, Freshman E, . Flouride. Ten-year prospective study of deciduous and permanent dentition. Am J Dis Child. 1975;129(7):794–800. PMID: 1096595.1096595
83 Lawrence HP, Binguis D, Douglas J, . A 2-year community-randomized controlled trial of fluoride varnish to prevent early childhood caries in Aboriginal children. Community Dent Oral Epidemiol. 2008;36(6):503–16. doi: 10.1111/j.1600-0528.2008.00427.x. PMID: 18422711.18422711
84 Slade GD, Bailie RS, Roberts-Thomson K, . Effect of health promotion and fluoride varnish on dental caries among Australian Aboriginal children: results from a community-randomized controlled trial. Community Dent Oral Epidemiol. 2011;39(1):29–43. doi: 10.1111/j.1600-0528.2010.00561.x. PMID: 20707872.20707872
85 Weintraub JA, Ramos-Gomez F, Jue B, . Fluoride varnish efficacy in preventing early childhood caries. J Dent Res. 2006;85(2):172–6. doi: 10.1177/154405910608500211. PMID: 16434737.16434737
86 Frostell G, Birkhed D, Edwardsson S, . Effect of partial substitution of invert sugar for sucrose in combination with Duraphat treatment on caries development in preschool children: the Malmo Study. Caries Res. 1991;25(4):304–10. doi: 10.1159/000261381. PMID: 1913770.1913770
87 Agouropoulos A, Twetman S, Pandis N, . Caries-preventive effectiveness of fluoride varnish as adjunct to oral health promotion and supervised tooth brushing in preschool children: a double-blind randomized controlled trial. J Dent. 2014 Oct;42(10):1277–83. doi: 10.1016/j.jdent.2014.07.020. PMID: 25123352.25123352
88 Anderson M, Dahllof G, Soares FC, . Impact of biannual treatment with fluoride varnish on tooth-surface-level caries progression in children aged 1-3 years. J Dent. 2017 Oct;65:83–8. doi: 10.1016/j.jdent.2017.07.009. PMID: 28739318.28739318
89 Anderson M, Dahllof G, Twetman S, . Effectiveness of early preventive intervention with semiannual fluoride varnish application in toddlers living in high-risk areas: A stratified cluster-randomized controlled trial. Caries Res. 2016;50(1):17–23. doi: 10.1159/000442675. PMID: 26795957.26795957
90 Jiang EM, Lo EC, Chu CH, . Prevention of early childhood caries (ECC) through parental toothbrushing training and fluoride varnish application: a 24-month randomized controlled trial. J Dent. 2014 Dec;42(12):1543–50. doi: 10.1016/j.jdent.2014.10.002. PMID: 25448437.25448437
91 Latifi-Xhemajli B, Begzati A, Veronneau J, . Effectiveness of fluoride varnish four times a year in preventing caries in the primary dentition: a 2 year randomized controlled trial. Community Dent Health. 2019 Aug 29;36(2):190–4. doi: 10.1922/CDH_4453Begzati05. PMID: 31436925.31436925
92 McMahon AD, Wright W, Anopa Y, . Fluoride Varnish in Nursery Schools: A Randomised Controlled Trial - Protecting Teeth @3. Caries Res. 2020 Sep 10;54(3):274–82. doi: 10.1159/000509680. PMID: 32911474.32911474
93 Memarpour M, Dadaein S, Fakhraei E, . Comparison of oral health education and fluoride varnish to prevent early childhood caries: A randomized clinical trial. Caries Res. 2016;50(5):433–42. doi: 10.1159/000446877. PMID: 27504845.27504845
94 Memarpour M, Fakhraei E, Dadaein S, . Efficacy of fluoride varnish and casein phosphopeptide-amorphous calcium phosphate for remineralization of primary teeth: a randomized clinical trial. Med Princ Pract. 2015;24(3):231–7. doi: 10.1159/000379750. PMID: 25895964.25895964
95 Munoz-Millan P, Zaror C, Espinoza-Espinoza G, . Effectiveness of fluoride varnish in preventing early childhood caries in rural areas without access to fluoridated drinking water: A randomized control trial. Community Dent Oral Epidemiol. 2018 02;46(1):63–9. doi: 10.1111/cdoe.12330. PMID: 28850712.28850712
96 Oliveira BH, Salazar M, Carvalho DM, . Biannual fluoride varnish applications and caries incidence in preschoolers: a 24-month follow-up randomized placebo-controlled clinical trial. Caries Res. 2014;48(3):228–36. doi: 10.1159/000356863. PMID: 24481085.24481085
97 Tickle M, O’Neill C, Donaldson M, . A randomised controlled trial to measure the effects and costs of a dental caries prevention regime for young children attending primary care dental services: the Northern Ireland Caries Prevention In Practice (NIC-PIP) trial. Health Technol Assess. 2016 09;20(71):1–96. doi: 10.3310/hta20710. PMID: 27685609.27685609
98 Tickle M, O’Neill C, Donaldson M, . A randomized controlled trial of caries prevention in dental practice. J Dent Res. 2017 Jul;96(7):741–6. doi: 10.1177/0022034517702330. PMID: 28375708.28375708
99 Oscarson P, Lif Holgerson P, Sjöström I, . Influence of a low xylitol-dose on mutans streptococci colonisation and caries development in preschool children. Eur Arch Paediatr Dent. 2006;7(3):142–7. doi: 10.1007/bf03262555. PMID: 17140543.17140543
100 Zhan L, Cheng J, Chang P, . Effects of xylitol wipes on cariogenic bacteria and caries in young children. J Dent Res. 2012;91(7 Suppl):85S–90S. doi: 10.1177/0022034511434354. PMID: 22699675.22699675
101 Bijella MFTB, Bijella VT, Silva MSMB, . Avaliação clínica da aplicação de diamino-fluoreto de prata a 12 / (Bioride) na dentição decídua e seu efeito na incidência de cárie em primeiros molares permanentes [Clinical evaluation of the application of 12silver diamino-fluoride on deciduous teeth and its effect on the caries incidence in first permanent molars]. Rev Paul Odontol. 1991;13(5):28–35.
102 Oliveira BH, Rajendra A, Veitz-Keenan A, . The effect of silver diamine fluoride in preventing caries in the primary dentition: A systematic review and meta-analysis. Caries Res. 2019;53(1):24–32. doi: 10.1159/000488686. PMID: 29874642.29874642
103 Dos Santos AP, Malta MC, de Marsillac MW, . Fluoride varnish applications in preschoolers and dental fluorosis in permanent incisors: results of a nested-cohort study within a clinical trial. Pediatr Dent. 2016 Oct 15;38(5):414–8. PMID: 28206898.28206898
104 Cheng LL. Limited evidence suggesting silver diamine fluoride may arrest dental caries in children. J Am Dent Assoc. 2017 Feb;148(2):120–2. doi: 10.1016/j.adaj.2016.11.022. PMID: 28129798.28129798
105 Chibinski AC, Wambier LM, Feltrin J, . Silver Diamine Fluoride Has Efficacy in Controlling Caries Progression in Primary Teeth: A Systematic Review and Meta-Analysis. Caries Res. 2017;51(5):527–41. doi: 10.1159/000478668. PMID: 28972954.28972954
106 Monse B, Heinrich-Weltzien R, Mulder J, . Caries preventive efficacy of silver diammine fluoride (SDF) and ART sealants in a school-based daily fluoride toothbrushing program in the Philippines. BMC Oral Health. 2012 Nov 21;12:52. doi: 10.1186/1472-6831-12-52. PMID: 23171244.23171244
107 Ruff RR, Niederman R. Silver diamine fluoride versus therapeutic sealants for the arrest and prevention of dental caries in low-income minority children: study protocol for a cluster randomized controlled trial. Trials. 2018 Sep 26;19(1):523. doi: 10.1186/s13063-018-2891-1. PMID: 30257696.30257696
108 Ruff RR, Niederman R. Comparative effectiveness of school-based caries prevention: a prospective cohort study. BMC Oral Health. 2018 Mar 27;18(1):53. doi: 10.1186/s12903-018-0514-6 PMID: 29587715.29587715
109 Llodra JC, Rodriguez A, Ferrer B, . Efficacy of silver diamine fluoride for caries reduction in primary teeth and first permanent molars of schoolchildren: 36-month clinical trial. J Dent Res. 2005 Aug;84(8):721–4. PMID: 16040729.16040729
110 Flores G, Tomany-Korman SC. Racial and ethnic disparities in medical and dental health, access to care, and use of services in US children. Pediatrics. 2008 Feb;121(2):e286–98. doi: 10.1542/peds.2007-1243 PMID: 18195000.18195000
111 Liu J, Probst JC, Martin AB, . Disparities in dental insurance coverage and dental care among US children: the National Survey of Children’s Health. Pediatrics. 2007 Feb;119 Suppl 1:S12–21. PMID: 17272579.17272579
112 Bader JD, Rozier G, Harris R, . Dental Caries Prevention: The Physician’s Role in Child Oral Health Systematic Evidence Review. Rockville (MD): Agency for Healthcare Research and Quality; 2004.
113 Bratthall D, Hansel Petersson G. Cariogram--a multifactorial risk assessment model for a multifactorial disease. Community Dent Oral Epidemiol. 2005 Aug;33(4):256–64. doi: 10.1111/j.1600-0528.2005.00233.x. PMID: 16008632.16008632
114 Harris R, Nicoll AD, Adair PM, . Risk factors for dental caries in young children: A systematic review of the literature. Community Dent Health. 2004;21(1 SUPPL.):71–85. PMID: 1507247615072476
115 Holgerson PL, Twetman S, Stecksen-Blicks C. Validation of an age-modified caries risk assessment program (Cariogram) in preschool children. Acta Odontol Scand. 2009;67(2):106–12. PMID: 19152150.19152150
116 Hong L, Levy SM, Broffitt B, . Timing of fluoride intake in relation to development of fluorosis on maxillary central incisors. Community Dent Oral Epidemiol. 2006;34(4):299–309. PMID: 16856950.16856950
117 Wiener RC, Shen C, Findley P, . Dental Fluorosis over Time: A comparison of National Health and Nutrition Examination Survey data from 2001-2002 and 2011-2012. J Dent Hyg. 2018 Feb;92(1):23–9. PMID: 29500282.29500282
118 Neurath C, Limeback H, Osmunson B, . Dental Fluorosis Trends in US Oral Health Surveys: 1986 to 2012. JDR Clin Trans Res. 2019 Oct;4(4):298–308. doi: 10.1177/2380084419830957 PMID: 30931722.30931722
119 National Center for Health Statistics, National Center for Chronic Disease Prevention and Health Promotion. Data quality evaluation of the dental fluorosis clinical assessment data from the National Health and Nutrition Examination Survey, 1999–2004 and 2011–2016. DHHS Publication No. 2019-1383. Vital Health Stat. 2019;2(183).
120 Autio-Gold J. Recommendations for fluoride varnish use in caries management. Dent Today. 2008 Jan;27(1):64–7. PMID: 18240633.18240633
121 Bawden JW. Fluoride varnish: a useful new tool for public health dentistry. J Public Health Dent. 1998;58(4):266–9. PMID: 10390707.10390707
122 Dooley D, Moultrie NM, Heckman B, . Oral health prevention and toddler well-child care: routine integration in a safety net system. Pediatrics. 2016 Jan;137(1) doi: 10.1542/peds.2014-3532. PMID: 26647374.26647374
123 IOM (Institute of Medicine) and NRC (National Research Council). Improving access to oral health care for vulnerable and underserved populations. Washington, DC: The National Academies Press; 2011.
124 Nicolae A, Levin L, Wong PD, . Identification of early childhood caries in primary care settings. Paediatr Child Health. 2018 Apr;23(2):111–5. doi: 10.1093/pch/pxx155. PMID: 29686495.29686495
125 Kranz AM, Preisser JS, Rozier RG. Effects of physician-based preventive oral health services on dental caries. Pediatrics. 2015 Jul;136(1):107–14. doi: 10.1542/peds.2014-2775. PMID: 26122805.26122805
126 Kranz AM, Duffy E, Dick AW, . Impact of Medicaid Policy on the Oral Health of Publicly Insured Children. Matern Child Health J. 2019 Jan;23(1):100–8. doi: 10.1007/s10995-018-2599-6. PMID: 30032444.30032444