# Chapter 4 Discussion

## Summary of Review Findings

Table 3 summarizes the evidence reviewed for this update. Dental caries is highly prevalent in children younger than 5 years of age. A high proportion of children in this age group do not receive recommended dental care and important disparities in oral health and access to care exist,^110,111^ suggesting a potential role for primary care clinicians in dental caries screening and prevention. This report builds upon prior reviews conducted for the USPSTF.^3,112^ A difference between this report and the prior USPSTF reviews is that it utilizes separate analytic frameworks for screening and prevention, to more clearly distinguish treatment of children with existing caries identified on screening (screening analytic framework) from treatment of children without caries to prevent the development of future caries (interventions to prevent dental caries analytic framework).

Table 3 Summary of Evidence

Key Question | Studies (k) Observations (n) Study Designs | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
Screening; KQ 1 and 3. Effectiveness and harms of screening by PCP | No studies | -- | -- | -- | -- | --
Screening; KQ 2a. Accuracy of screening by PCP: Identifying caries lesion | k=2 (N=368) diagnostic accuracy studies (both in prior USPSTF review) | - Sensitivity of 0.76 and specificity of 0.95 for identifying a child with one or more cavities and sensitivity of 0.63 and specificity of 0.98 for identifying a child in need of a dental referral (1 study); - Sensitivity of 1.0 and specificity of 0.87 for identifying nursing caries (1 study) | Unable to assess consistency due to differences between studies; Precision low to moderate | Nursing caries study rated fair-quality | Low | Primary care examiners underwent 2 or 4 hours of training; both studies conducted in the United States
Screening; KQ 2b. Accuracy of screening by PCP: Predicting future caries | k=1 (n=1681) diagnostic accuracy study (new) | Dundee Caries Risk Assessment Model associated with sensitivity of 0.53 and specificity of 0.77 for predicting future dentin caries in children 1 year of age | Unable to assess consistency (single study); Precise | Fair-quality; factors selected for model not pre-defined; no validation available | Low | Administered by health visitor nurses in Scotland
Prevention; KQ 1. Accuracy of screening by PCP^*^ | See Screening KQ 2b | See Screening KQ 2b | See Screening KQ 2b | See Screening KQ 2b | See Screening KQ 2b | See Screening KQ 2b
Prevention; KQ 2. Educational interventions | k=1 (n=104) RCT (new) | 1 RCT found oral health education for mothers of caries-free children 12 to 36 months of age associated with reduced risk of incident dental caries vs. usual care at 6 months (RR 0.39, 95% CI, 0.18 to 0.85). | Unable to assess consistency (1 study); Precise | Fair-quality; dental health behaviors not reported at baseline or followup | Low | Conducted in Iran in region with inadequate fluoridation of drinking water
Prevention; KQ 3. Referral to a dentist by a PCP | k=6 (N=92,476) observational studies; 1 study in prior review and 5 new | - No study directly compared referral by primary care clinician to a dentist vs. no referral; - Receiving a dental visit from a dentist associated with increased likelihood of subsequent caries-related treatment versus a dental visit from a primary care provider (4 studies); - Earlier versus later first preventive dental visit associated with no difference in rate of subsequent dental procedures, higher subsequent caries burden, and lower rates of untreated caries | Consistent; Precise | Observational studies; fair quality; studies not designed to determine referral source or compare effects of referral vs. no referral; findings susceptible to confounding by indication | Low | All studies conducted in U.S. children enrolled in Medicaid; some overlap in study populations conducted within the same state
Prevention; KQ 4. Preventive interventions: Dietary fluoride supplementation | k=1 (n=140) RCT and k=4 (N=3172) non-randomized trials (all in prior USPSTF review) | Dietary fluoride supplementation in settings with water fluoridation levels below 0.6 ppm fluoride associated with decreased caries incidence versus no fluoridation (percentage reduction ranged from 48% to 72% for primary teeth and 51% to 81% for primary tooth surfaces) | Consistent; Precise | 4 of 5 trials were non-randomized | Moderate | 2 trials conducted in Asia; 1 trial conducted in children with cleft lip; 3 trials conducted between 1967 and 1972
Prevention; KQ 4. Preventive interventions: Topical fluoride | k=15 (N=9541) RCTs (5 in prior USPSTF review and 10 new) | Topical fluoride associated with decreased caries increment (13 trials, mean difference −0.94, 95% CI −1.74 to −0.34) and decreased likelihood of incident caries (12 trials, RR 0.80, 95% CI 0.66 to 0.95) vs. placebo or no varnish | Inconsistent (high statistical heterogeneity); Precise | 11 trials rated fair quality (2 rated good quality); open-label design in some trials | Moderate | Almost all trials conducted in higher risk children or settings; almost all trials evaluated fluoride varnish; varnish applied by persons with dental training; some trials conducted in preschool or daycare setting; some trials conducted in non-very high human development index settings; some trials included children with high baseline caries burden
Prevention; KQ 4. Preventive interventions: Xylitol | k=2 (N=159) RCTs (both in prior USPSTF review) | Estimates imprecise from 2 trials, but favored xylitol over placebo for caries outcomes | Consistent; Imprecise | Trials rated fair-quality | Low | Trials conducted in U.S. and Sweden; 1 trial conducted in low socioeconomic status setting; xylitol administered as tablet or wipe
Prevention; KQ 4. Preventive interventions: Silver diamine fluoride | No studies | -- | -- | -- | -- | --
Prevention; KQ 5. Harms of interventions: Dietary fluoride supplements | k=1 SR of 19 observational studies (in prior USPSTF review) | Intake of fluoride supplements prior to 7 years of age (primarily before 3 years of age) associated with increased risk of mild to moderate fluorosis; odds ratio ranged from 1.1 to 10.8 in the studies that relied on retrospective recall and from 4.2 to 15.6 in the studies that recorded supplement use at the time of exposure | Consistent; Precise | Observational studies; most studies relied on retrospective recall to determine fluoride exposure | Low-moderate | Studies conducted in a variety of settings and countries, variability in recommended levels of fluoride supplementation and water fluoridation levels
Prevention; KQ 5. Harms of interventions | k=4 (N=4141) RCTs (all new) | No difference in risk of fluorosis or esthetically objectionable fluorosis (1 trial); no difference in risk of adverse events (1 trial); reports of complaints about odor | Consistency cannot be determined (single trials reported different adverse events); Precise | Harms not reported or suboptimal reporting in most trials | Low-moderate | See KQ 4
Prevention; KQ 5. Harms of interventions | No studies | RCTs of xylitol vs. placebo or no xylitol did not report harms | -- | -- | -- | --

* This is the same question as Screening KQ 2b.

Abbreviations: CI=confidence interval; KQ=key question; PCP=primary care physician; ppm=parts per million; RCT=randomized controlled trial; RR=relative risk; SR=systematic review; USPSTF=United States Preventive Services Task Force.

Nonetheless, the main findings of this report are consistent with the prior USPSTF review.^3,4^ With regard to screening, we found no direct evidence on the effects of screening for dental caries by primary care clinicians in children younger than 5 years of age versus no screening on caries incidence and related outcomes. Some interventions, in particular fluoride supplementation in children and fluoride varnish, appear to be effective in preventing caries, though findings appear most applicable to higher risk children.

Evidence remains limited on the accuracy of primary care clinicians in identifying caries lesions or predicting caries incidence in children younger than 5 years of age. Compared with a pediatric dentist examination, one study in the prior USPSTF review found low sensitivity of primary care pediatricians for identifying children in need of a dental referral or with caries^66^ and another study in the prior review found high accuracy of a pediatrician oral examination for identifying nursing caries.^67^ One new study found a novel caries risk assessment tool administered by health visitor nurses in 1 year old children associated with suboptimal diagnostic accuracy for predicting future caries.^68^ Other studies have assessed caries risk assessment instruments in young children, but did not meet inclusion criteria because the instruments were not administered by primary care clinicians or in primary care settings. These instruments often incorporate findings from an oral examination by a dental health professional and include tests not commonly obtained or available in primary care (such as mutans streptococci levels, saliva secretion level, or saliva buffer capacity),^68,113^ potentially limiting applicability of findings to primary care settings.^114,115^

Evidence on the effectiveness of parental or caregiver/guardian oral health education on caries outcomes also remains very limited. Two trials included in the prior USPSTF review were rated poor-quality (non-randomized) and not carried forward.^58,59,62^ One new trial found oral health education for mothers of caries-free children associated with reduced risk of incident dental caries versus usual care, but the study was relatively small and it was conducted in Iran, potentially reducing applicability to the United States.^70^

As in the prior USPSTF review, we identified no direct evidence on the effects of referral by a primary care clinician to a dentist on caries incidence. Observational studies of children enrolled in Medicaid found receiving a preventive dental visit from a dentist (vs. a primary care clinician) associated with increased likelihood of subsequent caries-related treatment compared with a primary dental visit.^73–76^ However, these findings are difficult to interpret because of susceptibility to confounding by indication related to greater need for dental services in children who have a dental visit and variation in provision of caries-related treatment. Two observational studies compared an earlier versus later first preventive dental visit in early childhood but are also difficult to interpret. None of the studies were designed to determine referral source to dental services or to compare effects of dental referral from primary care versus no referral.

We identified no new trials published since the 2004 USPSTF review on the effectiveness of dietary fluoride supplementation in children younger than 5 years of age. The 2004 USPSTF review found dietary fluoride supplementation to be effective at reducing caries incidence in children younger than 5 years of age in settings primarily with water fluoridation levels less than 0.6 ppm F, though conclusions were mostly based on non-randomized trials.^7^ We also found no new evidence on the association between early childhood intake of dietary fluoride supplementation and risk of enamel fluorosis. A systematic review included in the prior USPSTF review found an association between early childhood ingestion of systemic fluoride and enamel fluorosis of the permanent dentition.^46^ Risk of enamel fluorosis appears to be impacted by total intake of fluoride (from supplements, drinking water, other dietary sources, and dentifrices), as well as age at intake, with intake before 2 to 3 years of age appearing to confer highest risk.^116^ Although the prevalence of fluorosis may have increased among U.S. adolescents,^117,118^ observed trends could be related to variability in the accuracy or reliability of methods used to assess fluorosis.^119^ Regardless, severe fluorosis remains uncommon, with a prevalence of less than 2 percent.^117^

Our findings on the effectiveness of topical fluoride were also consistent with the prior USPSTF review, based on ten new trials, and five trials carried forward from the prior USPTF review. Seven of the ten new trials were conducted in very high human development index settings (compared to two of five prior trials), potentially increasing applicability of findings to U.S. primary care settings. A meta-analysis found topical fluoride associated with decreased caries increment (mean difference −0.94, 95% CI, −1.74 to −0.34) and decreased likelihood of experiencing incident caries (RR 0.80, 95% CI, 0.66 to 0.95). The number needed to treat to prevent one child with incident caries was about 14. Topical fluoride was administered as a varnish in all trials except for one,^47^ which used acidulated phosphate fluoride foam. Although pooled analyses were characterized by substantial statistical heterogeneity, results were consistent in stratified analyses based on a number of factors, including use of cluster randomization, varnish frequency, setting, baseline caries status, community water fluoridation status, provision of additional oral health measures, risk of bias, and followup duration. Although there was an interaction between younger age and greater effectiveness of topical fluoride in reducing the likelihood of experiencing incident caries, there was no interaction between age and mean caries increment. Because almost all trials were conducted in higher risk children (based on low socioeconomic status, high community caries burden, high baseline caries burden, or low rate of oral health behaviors), the applicability of findings to children not at increased risk may be reduced. Although some studies were conducted in countries and settings in which sources of fluoride and oral health behaviors differ markedly from the United States, findings were similar when trials were stratified according to whether they were conducting in very high human development index settings or not. In all trials the varnish was applied by dental personnel, though fluoride varnish is believed to be easily applied with minimal training.^120,121^ Evidence on harms associated with topical fluoride was limited but indicated no increased risk of fluorosis^103^ or adverse events^97,98^ versus placebo; serious adverse events were not reported though some children had difficulty tolerating varnish due to the odor.

Evidence on other preventive interventions was limited or unavailable. There were no new trials of xylitol in children younger than 5 years of age and evidence in the prior USPSTF review was limited to two trials with imprecise estimates.^99,100^ No trial evaluated SDF for prevention of caries in children younger than five years of age.

## Limitations

Our review had limitations. First, we excluded non-English language articles, which could result in language bias. However, we did not identify non-English language articles that appeared likely to impact conclusions. Although one non-English language trial^101^ evaluated SDF versus no treatment for prevention of caries in children younger than 5 years of age, a systematic review^102^ that included this trial noted that methods and results were reported poorly and excluded it from meta-analysis. Second, we did not search for studies published only as abstracts. Third, we did not assess for publication bias with graphical or statistical methods because of differences in study design, populations, and outcomes assessed, with substantial statistical heterogeneity. Fourth, statistical heterogeneity was substantial in meta-analyses of topical fluoride. Results were consistent in prespecified stratified analyses based on factors related to study design, population characteristics, intervention characteristics, and setting, though stratification did not explain the heterogeneity. Fifth, some trials were conducted in countries and settings in which oral health care and behaviors may differ substantially from typical U.S. primary care settings, potentially reducing applicability. Sixth, most studies had methodological limitations, reducing certainty in findings, and some key questions and interventions were addressed by little or no evidence.

## Emerging Issues/Next Steps

SDF was cleared for U.S. marketing by the FDA in 2014 as a desensitizing agent in adults.^36^ Although it has been evaluated for effectiveness in arresting existing caries, this use is off-label. There is also interest in using SDF off-label for prevention of caries. Two U.S. trials in elementary school-aged children are ongoing^39,107^ and could inform future trials in younger children. A potential disadvantage of SDF is permanent dark discoloration of active caries lesions by the silver component, which may impact acceptability, though this may be of less concern when applied prior to eruption of permanent teeth. In addition, active caries lesions themselves cause discoloration.

## Relevance for Priority Populations

Dental caries disproportionately affects minority children and economically disadvantaged children. Contributing factors include lack of access to dental health services or insurance and suboptimal oral health behaviors. Recent data indicate that the largest improvements in burden of caries in children 2 to 5 years of age have occurred in those below the federal poverty threshold, though significant disparities remain. In children below the federal poverty threshold, 17.6 percent had untreated caries in 2011 to 2014 compared with 6.2 percent at 200 percent or more above the threshold; corresponding rates for severe caries were 7.0 percent and 3.2 percent.^15^ Trials showing effectiveness of fluoride supplementation and topical fluoride have primarily been conducted in higher risk populations based on low socioeconomic status, caries burden, or low rates of oral health behaviors, indicating that increasing access and use of preventive treatments in disadvantaged populations could reduce disparities. Provision of oral care in primary care settings is considered an important strategy for improving access for vulnerable and underserved populations, because children who lack access to a dentist often have multiple encounters with a primary care clinician.^122–124^ For children enrolled in Medicaid or the Children’s Health Insurance Program (36 million as of May 2020), these programs are the primary source of dental coverage. In young children, receipt of preventive oral health services by nondental providers in medical settings is associated with reduced caries experience.^125^ State Medicaid policies to support primary care clinicians’ application of fluoride varnish to children expanded to all states following the publication of the 2014 USPSTF recommendation. Data indicate an association between implementation of such policies and increased likelihood of good or excellent teeth in this population.^126^

## Future Research

Research is needed to identify effective oral health educational and counseling interventions for parents and caregiver/guardians of young children. Research is also needed to validate the accuracy and utility of caries risk assessment instruments for use in primary care settings, and to determine how referral by primary care clinicians of young children for dental care affects caries outcomes. Additional trials would strengthen conclusions regarding the effectiveness of dietary fluoride supplementation in young children, especially in the current U.S. context of exposure to multiple sources of fluoride. Trials of fluoride varnish administered in primary care settings would be useful for confirming that effectiveness of fluoride varnish are reproducible in primary care settings and trials of varnish in lower-risk children and settings would be useful for determining applicability of findings. Studies on the effectiveness of SDF will clarify usefulness for prevention (rather than caries arrest) in young children; trials of SDF for prevention of caries in school-age children are expected to be completed in 2023.^107,108^

## Conclusions

Dietary fluoride supplementation and fluoride varnish appear to be effective at preventing caries outcomes in higher risk children younger than 5 years of age. Dietary fluoride supplementation in early childhood is associated with risk of enamel fluorosis, which is usually mild. More research is needed to understand the accuracy of oral health examination and caries risk assessment by primary care clinicians, primary care referral for dental care, and effective parental and caregiver/guardian educational and counseling interventions.