# Chapter 3 Results

A total of 2674 new references from electronic database searches and manual searches of recently published studies were reviewed and 368 full-text papers were evaluated for inclusion. We included a total of 33 studies (reported in 36 publications). Seventeen trials were newly identified as part of this update and 16 studies (in 17 publications) were carried forward from the previous review. We excluded 16 studies (in 17 publications) that were included in the prior review; one was excluded for not being an included preventive intervention,^49^ two for including children 5 years and older,^50,51^ two for treatment of existing caries,^52,53^ four for comparing active interventions,^54–57^ and eight for being poor-quality.^58–65^ Included studies and quality ratings are described in Appendix B.

## Screening for Dental Caries in Children Younger Than Age 5 Years

## Key Question 1 How Effective Is Oral Screening (Including Risk Assessment) Performed by a Primary Care Clinician in Preventing Dental Caries in Children Younger Than Age 5 Years?

No study compared clinical outcomes between children younger than 5 years of age screened and not screened by primary care clinicians.

## Key Question 2a How Accurate Is Screening Performed by a Primary Care Clinician in Identifying Children Younger Than Age 5 Years Who Have Cavitated or Noncavitated Caries Lesions?

### Summary

- One study (n=258) included in the prior USPSTF review found a pediatrician oral examination of children younger than 36 months of age associated with a sensitivity of 0.76 and specificity of 0.95 for identifying a child with one or more cavities, a sensitivity of 0.49 and specificity of 0.99 for identifying a tooth with a cavity, and a sensitivity of 0.63 and specificity of 0.98 for identifying children in need of a dental referral, compared with a pediatric dentist evaluation.
- One study included in the prior USPSTF review found a pediatrician oral health examination of children 18 to 36 months of age associated with a sensitivity of 1.0 and specificity of 0.87 for identifying nursing caries (n=61) compared with a pediatric dentist examination.
- No new studies on the accuracy of screening performed by a primary care clinician for identifying children younger than 5 years of age were identified.

### Evidence

The prior USPSTF review included two studies on the accuracy of screening by a primary care clinician for identifying children with cavitated or noncavitated caries lesions (Appendix B1). In both studies, screening was based on examination of the dentition for caries lesions. One good-quality study (n=258) evaluated the accuracy of caries screening of children younger than 36 months of age by primary care pediatricians following 2 hours of oral health education.^66^ The study enrolled Medicaid-eligible children (9.7% with a cavity, mean 0.3 cavities/child) attending a private pediatric group practice in North Carolina. Compared with a pediatric dentist evaluation, it found a pediatrician oral examination associated with sensitivity of 0.76 (95% CI, 0.55 to 0.91) and specificity of 0.95 (95% CI, 0.92 to 0.98) for identifying a child with one or more cavities, a sensitivity of 0.49 (95% CI, 0.37 to 0.60) and specificity of 0.99 (95% CI, 0.99 to 0.99) for identifying a tooth with a cavity, and a sensitivity of 0.63 (95% CI, 0.42 to 0.81) and specificity of 0.98 (95% CI, 0.95 to 0.99) for identifying children in need of a dental referral. The need for referral was based on the presence of a cavity, soft tissue pathology, or evidence of tooth or mouth trauma. A fair-quality study found a pediatrician oral health exam of children 18 to 36 months of age following 4 hours of training associated with a sensitivity of 1.0 and specificity of 0.87 for identifying nursing caries compared with a pediatric dentist exam (n=61, CIs not reported and could not be calculated).^67^ The number of true positives, true negatives, false positives, and false negatives were not reported and could not be calculated. Nursing caries were defined as caries involving one or more of the maxillary central or lateral incisors of the primary molars, but excluding the mandibular incisors. Methodological limitations of this study were unclear application of the reference standard to all patients and unclear inclusion of all patients in the analysis (Appendix B2).

No new study evaluated the accuracy of primary care clinician screening for carious lesions in children younger than 5 years of age.

## Key Question 2b How Accurate Is Screening Performed by a Primary Care Clinician in Identifying Children Younger Than Age 5 Years Who Are at Increased Risk for Future Dental Caries?

### Summary

- One new study found a novel caries risk assessment tool administered by health visitor nurses in children 1 year of age associated with sensitivity of 0.53 and specificity of 0.77 (n=697) for predicting any d_3_mft lesion at age 4 years and sensitivity of 0.65 and specificity of 0.69 (n=784) for predicting presence of three or more d_3_mft lesions.

### Evidence

One new study (n=1681) reported on the development and testing of a novel caries risk assessment tool (Dundee Caries Risk Assessment Model) administered by health visitors (registered nurses of midwives in Scotland with Masters level training who provide services to families with young children by visiting them in their homes) (Appendix B1).^68^ The cohort consisted of all children born and resident in Dundee, Scotland in one calendar year. The study examined 56 potential risk factors evaluated at age 1 year for prediction of caries at age 4 years, using a prediction tree-based analysis. The prevalence of any d_1_ (enamel or dentin) caries at baseline was 3 percent and the prevalence of any d_3_ (enamel of dentin) caries was 0.4 percent. At 4 years, the respective prevalence were 49 and 33 percent. Separate models were developed for prediction of any or at least three d_1_ or d_3_ caries. The final models included two to five risk factors, including health visitor assessment of risk, socioeconomic status, parental smoking status, being breast fed, use of a pacifier, housing type, use of vitamins, and food or drink intake at night. For predicting presence of any d_3_mft lesion at age 4 years, the sensitivity of the model was 0.53 and specificity 0.77 (n=697, CIs not reported), based on three risk factors (health visitor assessment of risk, parental smoking, and food or drinks at night). For predicting presence of at least three d_3_mft lesions at age 4 years, the sensitivity of the model was 0.65 and specificity was 0.69 (n=784, CIs not reported), based on three risk factors (type of housing, health visitor assessment of risk, and use of vitamins). Results were similar for prediction of any or at least three d_1_mft lesions. The study was rated fair-quality because it was unclear if the reference standard was assessed independent from the screening test and the risk factors selected for the models were not predefined (Appendix B2). We identified no study with independent validation of the Dundee Caries Risk Assessment Model.

## Key Question 3 What Are the Harms of Oral Health Screening Performed by a Primary Care Clinician in Children Younger Than Age 5 Years?

No study reported harms of children younger than 5 years of age screened and not screened by primary care clinicians.

## Interventions to Prevent Dental Caries in Children Younger Than Age 5 Years

## Key Question 1 How Accurate Is Screening Performed by a Primary Care Clinician in Identifying Children Younger Than Age 5 Years Who Are at Increased Risk of Future Dental Caries?

See Key Question 2b for Screening for Dental Caries in Children Younger Than Age 5 Years, which addresses the same question.

## Key Question 2 How Effective Is Parental or Caregiver/Guardian Oral Health Education Provided by a Primary Care Clinician in Preventing Dental Caries in Children Younger Than Age 5 Years?

### Summary

- The prior USPSTF review included two trials on effects of oral health education in preventing dental caries; however, the trials were rated poor-quality (not truly randomized) and not carried forward in the current review.
- One new fair-quality trial (n=104) found oral health education for mothers of caries-free children 12 to 36 months of age associated with reduced risk of incident dental caries versus usual care at 6 months (13.5% vs. 34.7%, RR 0.39, 95% CI, 0.18 to 0.85).

### Evidence

The 2014 USPSTF review^3,4^ included two trials (in 3 publications) of multicomponent health interventions that included an oral health education component targeted at medically underserved children younger than 5 years.^58,59,62^ Both trials found the intervention associated with decreased caries incidence at 1 to 4 years. However, both trials were rated poor-quality and were not carried forward in the current review. Neither trial was truly randomized; both utilized cluster allocation, but there were only two clusters. In addition, one of the trials had high attrition and did not adjust for confounders.^58,59^

One new, randomized trial conducted in Ahvaz, Iran (fluoride level in drinking water 0.31 to 0.51 ppm)^69^ compared provision of oral health education to mothers (n=104) of children age 12 to 36 months versus usual care without specific oral health education (Appendix B3).^70^ Children (mean age 18 months) were caries-free at the time of enrollment, with at least eight erupted teeth. The oral health education was delivered by a dental student at a well-child visit and included an oral health pamphlet, a brief individual session, a group session, and text message reminders every 2 weeks for 6 months. Dental health behaviors were not reported at baseline or followup. The study was open-label and rated fair-quality (Appendix B4).

At 6 months, oral health education was associated with decreased incidence of dental caries based on World Health Organization criteria (including white spot lesions noncavitated and categorized as D1) versus usual care (13.5% [7/52] vs. 34.7% [17/49]; risk ratio [RR] 0.39, 95% CI, 0.18 to 0.85). Harms were not reported.

## Key Question 3 How Effective Is Referral by a Primary Care Clinician to a Dental Health Care Professional in Preventing Dental Caries in Children Younger Than Age 5 Years?

### Summary

- No study directly evaluated the effects of referral by a primary care clinician to a dentist on caries incidence.
- Four new additional observational studies (N=61,194) of children enrolled in Medicaid found receiving a preventive dental visit from a dentist versus primary care clinician associated with increased likelihood of subsequent caries-related treatment, though findings are susceptible to confounding by indication. The studies were not designed to determine the referral source or effects of dental referral from primary care versus no referral.
- One study included in the prior USPSTF review (n=19,888) and one additional study (n=11,394) of children enrolled in Medicaid found an earlier (versus later) first preventive dental visit associated with no difference in subsequent dental procedures among treatment in children without caries at baseline; an earlier visit was associated with higher caries burden when assessed in kindergarten, but lower likelihood of untreated caries.

### Evidence

No study directly evaluated referral of children younger than 5 years of age by a primary care clinician to a dental care professional versus no referral and effects on caries incidence or other dental outcomes. One retrospective cohort study included in the prior USPSTF report (n=19,888)^71^ and five subsequent retrospective cohort studies (N=72,588)^72–76^ evaluated outcomes associated with earlier versus later timing of preventive visits or primary care clinician versus dental provision of preventive dental visits (Appendix B5). All of the studies were conducted in Medicaid populations in North Carolina or Alabama; populations overlapped for studies conducted in the same state. The studies did not directly address the key question because they were not designed to determine the referral source or effects of dental referral from primary care versus no referral. In addition, although all studies controlled for confounders (including demographic factors, socioeconomic factors, and risk factors for caries), findings are susceptible to confounding by indication related to the need for dental services. All studies were rated fair-quality (Appendix B6).

Two new studies compared children enrolled in North Carolina Medicaid who had preventive oral health visits from a primary care clinician versus a dentist (Appendix B5).^74,75^ In both analyses, children who received oral health visits from a primary care clinician were less likely to receive caries-related treatment compared with those who received oral health visits from a dentist, likely because those who saw a dentist had greater dental health needs. In the larger study (n=41,453), the likelihood of receiving any caries-related treatment between 3 to 5 years of age was 26.7 percent among children who received preventive oral health visits from a primary care clinician, 51.8 percent among children who received preventive oral health visits from a dentist, and 47.6 percent among children who received preventive health visits from both.^74^ However, among children at risk for caries, another analysis (n=5235) found receiving preventive health visits from a primary care clinician associated with higher likelihood of untreated decayed teeth than receiving preventive health visits from a dentist (OR 2.05, 95% CI, 1.28 to 3.30).^75^

Two new studies conducted among children enrolled in Alabama Medicaid reported similar results (Appendix B5).^73,76^ One study (n=9732) found children who had at least one preventive dental visit by a dentist were more likely to receive any caries-related treatment (20.6% vs. 11.3%, p<0.001) than those without a preventive dental visit.^73^ In the other study, children with at least one preventive dental visit by a dentist had more restorative dental visits (difference 11.1%, p<0.05) and emergency dental visits (difference 1.9%, p<0.05) than those without a preventive visit.^76^

Two studies compared children with a first earlier versus later preventive dental visit. A study included in the prior USPSTF report evaluated children enrolled in North Carolina Medicaid (n=19,888) (Appendix B5).^71^ It found having a first tertiary (dental caries present at baseline) preventive dental visit after 18 months of age associated with increased risk of subsequent dental procedures between 43 and 72 months of age compared with having an earlier (before 18 months of age) first visit (incidence density ratio ranged from 1.1 to 1.4). Among children without dental disease at baseline, there was no difference in risk of subsequent dental procedures by timing of initial preventive dental visit. A subsequent, new study of children also enrolled in North Carolina Medicaid (n=11,394) found a first preventive visit by 37 to 48 or 49 to 60 months of age associated with higher dmft index when assessed in kindergarten compared with first visit by 24 months of age, a finding likely related to children with more severe dental issues receiving earlier preventive visits.^72^ However, a later first visit was associated with decreased likelihood of having untreated caries.

## Key Question 4 How Effective Are Preventive Interventions (Dietary Fluoride Supplementation, Topical Fluoride Application, Silver Diamine Fluoride, or Xylitol) in Preventing Dental Caries in Children Younger Than Age 5 Years?

### Dietary Fluoride Supplementation

#### Summary

- We identified no new trials published since the 2004 USPSTF review.
- One randomized and four nonrandomized studies included in the 2004 review found dietary fluoride supplementation in settings with water fluoridation levels below 0.6 ppm F associated with decreased caries incidence versus no fluoridation.

#### Evidence

We identified no trials published since the 2004 USPSTF review of the effectiveness of fluoride supplementation on preventing dental caries in children younger than 5 years old. One randomized trial^77^ and four nonrandomized trials (in 5 publications)^78–82^ included in the 2004 USPSTF review found dietary fluoride supplementation in settings with water fluoridation levels below 0.6 ppm F associated with decreased caries incidence versus no fluoridation.^7^ The randomized trial (n=140, fluoridation <0.1 ppm F) found use of 0.25 mg fluoride drops or chews associated with decreased incidence of caries versus no fluoride supplementation in Taiwanese children with cleft lip who were 2 years of age at enrollment.^77^ The percent reduction in caries incidence ranged from 52 to 72 percent for dmft and from 51 to 81 percent for dmfs. In the nonrandomized trials (N=2,273), the reduction in caries incidence versus no fluoride supplementation ranged from mean dmft reduction of 32% to 69%.^78–82^ Two of the nonrandomized trials with extended followup found dietary fluoride supplementation associated with decreased caries incidence at 7 to 10 years of age (reductions ranged from 33% to 80%).^78,82^

### Topical Fluoride Application

#### Summary

- Based on 15 trials (5 trials in the prior USPSTF review and 10 new trials), topical fluoride (administered as fluoride varnish in all trials except for one) was associated with decreased caries increment (13 trials, N=5733, mean difference −0.94, 95% CI, −1.74 to −0.34, I^2^=86%) and decreased likelihood of incident caries (12 trials, N=8177, RR 0.80, 95% CI, 0.66 to 0.95, I^2^=79%; absolute risk difference [ARD] -7%, 95% CI, -12% to -2%) versus placebo or no varnish. Almost all trials were conducted in children at higher risk of caries.
- No trial evaluated effects of topical fluoride on quality of life, function, or other noncaries outcomes.

#### Evidence

The 2014 USPSTF review^3,4^ included three randomized trials^83–85^ that found fluoride varnish in children younger than 5 years of age more effective than no varnish (reduction in caries increment 18% to 59% and absolute mean reduction in the number of surfaces of 1.0 to 2.4). The trials enrolled children at high-risk of caries, based on low socioeconomic status, inadequate community fluoridation, or high baseline caries incidence. Two of the trials^83,84^ were conducted in Aboriginal communities in Canada or Australia and one trial^85^ was conducted in disadvantaged children in San Francisco. Results were consistent with findings from the 2004 USPSTF review,^7^ which found fluoride varnish associated with a percent reduction in incident caries lesions that ranged from 37 to 63 percent (absolute reduction in the mean number of cavities per child of 0.67 to 1.24 per year), based on three trials (two randomized^50,86^ and one with alternate allocation^61^). One other randomized trial^47^ in the 2014 USPSTF review evaluated topical fluoride administered as acidulated phosphate fluoride foam rather than as a varnish; fluoride foam was associated with decreased risk of caries versus placebo (dmfs increment 3.8 vs. 5.0, p=0.03; reduction in caries increment 24%). Meta-analysis on the effects of topical fluoride on caries incidence was not conducted for the prior USPSTF review.

Five trials (N=2616) previously reviewed by the USPSTF on topical fluoride versus no varnish or placebo were carried forward for this update.^47,83–86^ As indicated above, four trials evaluated fluoride varnish and one trial evaluated fluoride administered as a foam. Eight trials of fluoride varnish included in prior USPSTF reviews were excluded due to poor-quality (non-randomized, including use of alternating allocation),^60,61,63,65^ age older than 5 years,^50^ evaluation of topical fluoride for treatment of existing caries,^52^ or comparisons of different frequencies of varnish application, without a no varnish or placebo control.^53,57^

Ten additional trials (in 12 publications) of topical fluoride (N=6925) versus no treatment or placebo were added for this update (Table 1, Appendix B7).^87–98^ All of the new trials evaluated fluoride varnish.

Table 1 Pooled Analyses of Mean Change in Number of Caries at Followup, Topical Fluoride vs. Placebo or No Topical Fluoride

| Number of trials | MD (95% CI) | I^2^ | p^*^
All trials | 13^47,83–87,90–92,94–96,98^ | −0.94 (−1.74 to −0.34) | 86% | --
Fluoride type | | | | 0.57
- 5% NaF varnish | 10^83–86,90,92,94–96,98^ | −0.62 (−1.35 to −0.16) | 75%
- Other varnish | 2^87,91^ | −2.24 (−8.56 to 3.98) | 83%
- Foam | 1^47^ | −1.20 (−2.24 to −0.16) | Not applicable
Quality | | | | 0.13
- Good-quality trials | 3^90,92,96^ | 0.08 (−0.28 to 0.27) | 0%
- Fair-quality trials | 10^47,83–87,91,94,95,98^ | −1.33 (−2.36 to −0.54) | 78%
Fluoridation status | | | | 0.54
- Adequate | 2^85,98^ | −1.19 (−2.81 to −0.29) | 0%
- Not adequate | 11^47,83,84,86,87,90–92,94–96^ | −0.85 (−1.81 to −0.16) | 87%
Cluster RCT | | | | 0.27
- Yes | 3^47,83,84^ | −1.63 (−3.04 to −0.64) | 0%
- No | 10^85–87,90–92,94–96,98^ | −0.72 (−1.66 to −0.09) | 86
Setting | | | | 0.94
- Preschool | 5^47,87,91,92,95^ | −1.04 (−2.90 to 0.57) | 88%
- Other | 8^83–86,90,94,96,98^ | −0.89 (−1.86 to −0.21) | 80%
Mean age | | | | 0.93
- <2 years old | 4^85,90,91,94^ | −1.26 (−3.24 to 0.74) | 98%
- ≥2 years old | 9^47,83,84,86,87,92,95,96,98^ | −0.89 (−1.70 to −0.30) | 50%
High-risk of caries | | | | 0.34
- Yes | 12^47,83–87,90–92,94–96^ | −0.81 (−1.64 to −0.24) | 84%
- No | 1^98^ | −2.29 (−3.95 to −0.63) | Not applicable
Caries free at baseline | | | | 0.33
- Yes | 5^85,90,94,95,98^ | −0.43 (−1.24 to 0.06) | 74%
- No | 8^47,83,84,86,87,91,92,96^ | −1.40 (−2.74 to −0.29) | 74%
High human development index | | | | 0.22
- Yes | 7^85–87,90,92,95,98^ | −0.43 (−1.16 to 0.06) | 64%
- No | 6^47,83,84,91,94,96^ | −1.62 (−3.26 to −0.33) | 81%
Additional oral health measures used | | | | 0.07
- Yes | 10^83–85,87,90,92,94–96,98^ | −0.53 (−1.18 to −0.10) | 71%
- No | 3^47,86,91^ | −2.57 (−5.45 to 0.03) | 62%
Duration of followup | | | | 0.35
- 1 year | 2^87,94^ | −0.09 (−0.73 to 0.71) | 0%
- 2 years | 11^47,83–87,90–92,95,96^ | −0.95 (−1.87 to −0.28) | 84%
- 3 years | 1^98^ | −2.29 (−3.95 to −0.63) | Not applicable
Application Frequency | | | | 0.06
- Every 3 months | 1^91^ | −4.90 (−7.14 to −2.66) | Not applicable
- Every 4 months | 1^94^ | −0.12 (−0.60 to 0.36) | Not applicable
- Every 6 months | 11^47,83–87,90,92,95,96,98^ | −0.73 (−1.40 to −0.24) | 70%
- Every 12 months | 1^85^ | −1.00 (−1.72 to −0.28) | Not applicable

* p value for interaction.

Abbreviations: CI=confidence interval; MD=mean difference; NaF=sodium fluoride; RCT=randomized controlled trial.

Across all 15 trials (previously reviewed by the USPSTF and added for this update), sample sizes ranged from 123 to 2536 (total N=9541) (Table 1, Appendix B7). One trial was conducted in the United States,^85^ six in Europe,^86–89,91,92,97,98^ one in Brazil,^96^ one in Chile,^95^ two in China,^47,90^ two in Iran,^93,94^ and two in Aboriginal communities in Australia and Canada.^83,84^ Trials conducted in Kosovo, Iran, China, and the Aboriginal communities were not classified as “very high” on the human development index; the other trials were conducted in very high human development index countries. The mean age of enrolled children was 1 year to younger than 2 years in six trials and 2 years to younger than 5 years in nine trials; one trial^83^ did not report mean age but enrolled children 6 months to 5 years of age and was grouped with the trials of children 2 years to younger than 5 years. Five trials^47,87,91,92,95^ were conducted in preschool or daycare settings and the others were conducted in clinics. Seven trials enrolled children who were caries-free at baseline; five trials reported the proportion of children with caries at baseline, ranging from 17 to 100 percent,^83,84,87,92,96^ two trials reported mean baseline dmfs of 1.1 to 4.79,^86,91^ and one trial reported mean baseline dmft of 1.6 to 1.7.^47^ The trials with the highest proportion of children with caries at baseline (72% and 100%) were conducted in Aboriginal communities in Canada and Australia.^83,84^ Two trials were conducted in communities with adequate fluoridation (defined as ≥0.7 ppm) of drinking water.^85,97,98^ All trials except for one evaluated children classified as being at higher risk, based on low socioeconomic status, high community prevalence of caries, high baseline caries burden, or low rates of oral health behaviors (e.g., tooth brushing with fluoride toothpaste).

Five trials were cluster randomized^47,83,84,87–89^ and the rest were individually randomized. Fluoride varnish was most commonly administered as 5 percent sodium fluoride varnish; single trials evaluated 1.5 percent ammonium fluoride,^91^ 0.2 ml 0.9 difluorosilane fluoride varnish,^87^ or 1.23 percent acidulated phosphate fluoride foam.^47^ Topical fluoride was administered every 6 months, with the exception of two trials which administered varnish every 3 or 4 months.^91,94^ One trial evaluated fluoride varnish every 6 or 12 months.^85^ Topical fluoride was administered by a dental health professional in all trials in which this information was reported. Three trials^47,86,91^ did not describe provision of oral health education; in the other trials, oral health education was provided in addition to the randomized intervention. The duration of followup ranged from 1 to 3 years. The trials focused on effects of topical fluoride on caries increment (reported as a continuous outcomes for number of incident caries surfaces or teeth) or on likelihood of a child developing incident caries (reported as a dichotomous outcome). No trial evaluated effects of fluoride varnish on quality of life, function, or other non-caries health outcomes.

Three trials were rated good-quality^90,92,96^ and the rest were rated fair-quality (Appendix B4). Methodological limitations in the fair-quality trials included unclear randomization or allocation concealment methods, open-label design, or high attrition.

In a meta-analysis, topical fluoride was associated with decreased caries increment versus placebo or no topical fluoride at 1 to 3 years followup (13 trials, N=5733, mean difference −0.94, 95% CI, −1.74 to −0.34, I^2^=86%; Figure 3).^47,83–87,90–92,94–96,98^ All trials reported caries increment as dmfs except for three, which only reported dmft. Statistical heterogeneity was substantial (I^2^=86%). Results consistently favored topical fluoride in analyses stratified according to use of cluster randomization, application frequency, classification as very high human development index setting, preschool setting, mean age (<2 years vs. ≥2 years), enrollment restricted to caries-free children at baseline, adequate community water fluoridation, provision of additional oral health measures, risk of bias, or duration of followup (1 vs. 2 vs. 3 years) (Table 1). Stratification on these factors had little effect on statistical heterogeneity and no statistically significant interactions between these factors and effects on caries increment were observed. Results were also similar when the trial^47^ that evaluated fluoride foam or the trial^97,98^ that was not conducted in a high-risk population was excluded from the analysis.

Figure 3 Pooled Analysis of Topical Fluoride vs. Placebo or No Topical Fluoride on Mean Change in Number of Caries at Followup, by Fluoridation Status

*Studies adjusted for clustering design or other confounding variables.

^†^Range of age.

Abbreviations: CI=confidence interval; DMFS=decayed, missing, and filled surfaces; DMFT=decayed, missing, and filled teeth; ICDAS=International Caries Detection and Assessment System.

This figure titled “Pooled Analysis of Topical Fluoride Versus Placebo or No Topical Fluoride on Mean Change in Number of Caries at Followup, by Fluoridation Status” is a forest plot reporting mean change in number of caries at followup for topical fluoride versus placebo or no topical fluoride, and the plot is stratified by community water fluoridation status. Data for Figure 3 is presented in Table 1. The mean difference for the subgroup of 11 studies without adequate fluoridation status is −0.85 (95% CI, −1.81 to −0.16) with an I-squared value of 87.2%. The mean difference for the subgroup of 2 studies with adequate fluoridation status is −1.19 (95% CI, −2.81 to −0.29) with an I-squared value of 0.0%. The mean difference for all studies is −0.94 (95% CI, −1.74 to −0.34) with an I-squared value of 85.7%. This figure is described further in Chapter 3 Results under the Key Question 4 section titled Topical Fluoride Application.

Topical fluoride was also associated with decreased likelihood of incident caries versus placebo or no topical fluoride (12 trials, N=8177, RR 0.80, 95% CI, 0.66 to 0.95; ARD -7%, 95% CI, -12% to -2%; Figure 4). Statistical heterogeneity was high (I^2^=79%). Definitions for incident caries included any caries lesion or development of ICDAS 5 to 6 (distinct dentine cavity) lesions (Table 2, Appendix B7). Results were similar when the trial of fluoride foam^47^ or the trial conducted in a nonhigh-risk population^97,98^ was excluded from the analysis (Table 2). There were no statistically significant interactions between use of cluster design, very high human development index setting, varnish frequency, preschool setting, all children caries-free at baseline, adequate community fluoridation, provision of additional oral health measures, risk of bias, or duration of followup, and statistical heterogeneity remained present in the stratified analyses (Table 2). There was a statistically significant interaction between age and effects of fluoride varnish on likelihood of incident caries (p for interaction=0.008). In trials in which the mean age was younger than 2 years, fluoride varnish was associated with decreased likelihood of incident caries (5 trials, N=3669, RR 0.60, 95% CI, 0.39 to 1.03, I^2^=49%),^85,89–91,93^ but there was no effect in trials in which the mean age of children was 2 years or older (7 trials, N=4508, RR 0.92, 95% CI, 0.81 to 1.01, I^2^=42%).^47,83,87,92,95,96,98^

Figure 4 Pooled Analysis of Topical Fluoride vs. Placebo or No Topical Fluoride on Caries Development at Followup, by Fluoridation Status

*Studies adjusted for clustering design or other confounding variables.

^†^Range of age.

Abbreviations: CI=confidence interval; DMFS=decayed, missing, and filled surfaces; DMFT=decayed, missing, and filled teeth; ICDAS=International Caries Detection and Assessment System.

This figure titled “Pooled Analysis of Topical Fluoride Versus Placebo or No Topical Fluoride on Caries Development at Followup, by Fluoridation Status” is a forest plot reporting risk of caries development at followup for topical fluoride versus placebo or no topical fluoride, and the plot is stratified by community water fluoridation status. Data for Figure 4 is presented in Table 2. The risk ratio for the subgroup of 10 studies without adequate fluoridation status is 0.83 (95% CI, 0.68 to 1.00) with an I-squared value of 75.4%. The risk ratio for the subgroup of 2 studies with adequate fluoridation status is 0.68 (95% CI, 0.33 to 1.33) with an I-squared value of 76.2%. The risk ratio for all studies is 0.80 (95% CI, 0.66 to 0.95) with an I-squared value of 79.3%. This figure is described further in Chapter 3 Results under the Key Question 4 section titled Topical Fluoride Application.

Table 2 Pooled Analyses of Risk of Caries Development at Followup, Topical Fluoride vs. Placebo or No Topical Fluoride

| Number of trials | RR (95% CI) | I^2^ | p^*^
All trials | 12^47,83,85,87,89–93,95,96,98^ | 0.80 (0.66 to 0.95) | 79% | --
Fluoride type | | | | 0.79
- 5% NaF varnish | 11^83,85,87,89–93,95,96,98^ | 0.84 (0.69 to 0.99) | 65%
- Other varnish | 2^87,91^ | 0.69 (0.27 to 1.71) | 90%
- Foam | 1^47^ | 0.80 (0.54 to 1.19) | Not applicable
Quality | | | | 0.49
- Good-quality trials | 3^90,92,96^ | 0.85 (0.71 to 1.08) | 0%
- Fair-quality trials | 9^47,83,85,87,89,91,93,95,98^ | 0.77 (0.60 to 0.96) | 84%
Fluoridation status | | | | 0.43
- Adequate | 2^85,98^ | 0.68 (0.33 to 1.33) | 76%
- Not adequate | 10^47,83,87,89–93,95,96^ | 0.83 (0.68 to 1.00) | 75%
Cluster RCT | | | | 0.37
- Yes | 3^47,83,89^ | 1.04 (0.74 to 1.17) | 0%
- No | 9^85,87,90–93,95,96,98^ | 0.76 (0.60 to 0.95) | 78%
Setting | | | | 0.63
- Preschool | 5^47,87,91,92^ | 0.77 (0.58 to 1.01) | 83%
- Other | 7^83,85,89,90,93,95,96,98^ | 0.83 (0.61 to 1.08) | 74%
Mean age | | | | 0.008
- <2 years old | 5^85,89–91,93^ | 0.60 (0.39 to 1.03) | 49%
- ≥2 years old | 7^47,83,87,92,95,96,98^ | 0.92 (0.81 to 1.01) | 42%
High-risk of caries | | | | 0.73
- Yes | 11^47,83,85,87,89–93,95,96^ | 0.79 (0.64 to 0.96) | 80%
- No | 1^98^ | 0.87 (0.75 to 1.02) | Not applicable
Caries free at baseline | | | | 0.77
- Yes | 6^85,89,90,93,95,98^ | 0.77 (0.57 to 1.04) | 48%
- No | 6^47,83,87,91,92,96^ | 0.82 (0.62 to 1.05) | 86%
High human development index | | | | 0.57
- Yes | 7^85,87,89,90,92,95,98^ | 0.84 (0.69 to 1.00) | 48%
- No | 5^47,83,91,93,96^ | 0.74 (0.47 to 1.07) | 79%
Additional oral health measures used | | | | 0.11
- Yes | 10^83,85,87,89,90,92,93,95,96,98^ | 0.86 (0.73 to 1.00) | 64%
- No | 2^47,91^ | 0.59 (0.31 to 1.18) | 59%
Duration of followup | | | | 0.68
- 1 year | 3^85,87,93^ | 0.71 (0.27 to 1.29) | 58%
- 2 years | 9^47,83,85,87,90–92,95,96^ | 0.79 (0.63 to 0.99) | 84%
- 3 years | 2^89,98^ | 0.87 (0.67 to 1.07) | 0%
Application Frequency | | | | 0.07
- Every 3 months | 1^91^ | 0.46 (0.35 to 0.61) | Not applicable
- Every 6 months | 11^47,83,85,87,89,90,92,93,95,96,98^ | 0.88 (0.74 to 0.98) | 52%
- Every 12 months | 1^85^ | 0.60 (0.40 to 0.91) | Not applicable

* p value for interaction.

Abbreviations: CI=confidence interval; NaF=sodium fluoride; RCT=randomized controlled trial; RR=relative risk.

### Xylitol

#### Summary

- One fair-quality trial (n=115) included in the prior USPSTF review found xylitol tablets associated with lower dmfs increment versus no xylitol in children 2 years of age (mean reduction 0.42), but the difference was not statistically significant.
- One small (n=44), fair-quality trial included in the prior USPSTF review found xylitol wipes associated with markedly decreased risk of having incident caries versus placebo wipes in children 6 to 35 months of age (5% vs. 32%, RR 0.14, 95% CI, 0.02 to 1.07), but the difference was not statistically significant.
- No new trials of xylitol versus no xylitol were identified.

#### Evidence

The 2014 USPSTF review included three trials of xylitol versus no xylitol;^64,99,100^ however, one of the trials was poor-quality (non-randomized)^64^ and excluded from this update. The other two trials were carried forward (Appendix B8); both were rated fair-quality. Methodological limitations included unclear randomization and/or allocation concealment, not blinding care providers or patients, and differences in attrition between groups (Appendix B4).

One trial (n=115) compared xylitol tablets versus no xylitol in Swedish children 2 years of age.^100^ Baseline caries prevalence was 6 percent and the proportion of children that brushed their teeth one to two times a day was 79 percent; water is not fluoridated in Sweden. Xylitol was administered as one 0.5 mg tablet at bedtime for 6 months, followed by two tablets daily. Xylitol was associated with lower dmfs increment versus no xylitol after 2 years, but the difference was not statistically significant (mean percent reduction 52%, mean dmfs reduction 0.42).

The other, smaller (n=44) trial compared xylitol wipes versus placebo wipes in U.S. (San Francisco) children 6 to 35 months of age (mean 17.3 months).^99^ Most children attending the clinic at which recruitment took place were of low socioeconomic status. The proportion of children with caries at baseline was 7 percent, the proportion that brushed their teeth daily was 68 percent, and the proportion that used fluoride toothpaste was 32 percent. The San Francisco water supply is generally fluoridated to 1.0 mg/l. Xylitol was administered as a topical wipe to the teeth three times per day for 1 year. Xylitol wipes were associated with markedly decreased risk of having incident caries versus placebo, though the difference was not statistically significant (5% [1/22] vs. 32% [7/22], RR 0.14, 95% CI 0.02 to 1.07). In an on-treatment analysis of 37 children who completed the study, xylitol was associated with decreased risk of incident caries versus placebo (5% vs. 40%, p=0.03) and deceased dmfs increment (0.05 vs. 0.53, p=0.01); dmfs increment was not reported in the intention-to-treat population.

### Silver Diamine Fluoride

We identified no trial meeting inclusion criteria of SDF versus placebo or no SDF for prevention of caries in children younger than 5 years of age. One trial^101^ was excluded because of non-English language, but a systematic review^102^ noted that methods and results were reported poorly and excluded the trial from meta-analysis. Evidence on SDF for prevention of caries in children 5 years of age or older is addressed in the Contextual Question.

## Key Question 5 What Are the Harms of Specific Oral Health Interventions to Prevent Dental Caries in Children Younger Than Age 5 Years (Parental or Caregiver/Guardian Oral Health Education, Referral to a Dental Health Care Professional, and Preventive Interventions)?

### Summary

- The prior USPSTF review included a systematic review of 19 studies which found an association between early childhood ingestion of systemic fluoride and enamel fluorosis of the permanent dentition. Studies were observational and had methodological shortcomings, including use of retrospective recall to determine exposures.
- Four new trials (N=4141) reported no differences between fluoride varnish versus placebo or no varnish in risk of fluorosis or the likelihood of any adverse event. Two studies reported children did not like the smell of the fluoride varnish and one study reported that a few children vomited due to the smell, texture, or taste.

### Evidence

#### Dietary Fluoride Supplementation

No trial reported risk of dental fluorosis associated with early childhood ingestion of dietary fluoride supplements.

The prior USPSTF included a systematic review of 19 observational studies on the association between early childhood intake of fluoride supplements and risk of fluorosis, based on searches conducted through June 2006 (Appendix B9 and B10).^46^ Early childhood exposures were based on retrospective parental recall in 15 studies and on supplement use recorded at the time of exposure in four studies. Fluorosis was assessed at 8 to 14 years of age. The prevalence of fluorosis ranged from 10 to 67 percent. The review found intake of fluoride supplements prior to 7 years of age (primarily before 3 years of age) associated with increased risk of mild to moderate fluorosis. The ORs for dental fluorosis ranged from 1.1 to 10.8 in the studies that relied on retrospective recall and ranged from 4.2 to 15.6 in the studies that recorded supplement use at the time of exposure. We identified no new study on the association between early childhood intake of dietary fluoride supplements and risk of enamel fluorosis.

#### Topical Fluoride Application

The prior report included one trial of fluoride varnish that reported one child with an allergy to lanolin experienced an adverse event.^83^ The other studies did not report adverse events or reported that no adverse events were detected.

Four new trials (in 6 publications, N=4141) reported adverse events associated with fluoride varnish versus placebo or no varnish (Appendix B4 and B7).^87–89,97,98,103^

One trial (n=181) that followed children for 4 years reported no differences in the risk of fluorosis associated with the use of fluoride varnish compared with placebo (27% vs. 35%, p=0.44).^103^ There was also no difference in esthetically objectionable fluorosis (4.8% vs. 8.3%, p=0.48). No other trial reported risk of fluorosis. However, the degree of systemic exposure following application of fluoride varnish is believed to be low.

One trial (n=1096) reported no difference in the rate of adverse events between fluoride varnish and no fluoride varnish (7.2% vs. 5.9%; RR 1.22, 95% CI, 0.80 to 1.85).^97,98^ Two trials (N=2864) reported child complaints about varnish odor,^87,89^ with one reporting a few children vomited directly after application.^88,89^

#### Xylitol

Trials of xylitol did not report rates of diarrhea, and either did not report adverse events or stated none were reported.^99,100^

## Contextual Question. 1 How Effective Is Silver Diamine Fluoride in Preventing Dental Caries in Children Age 5 Years or Older?

SDF has primarily been evaluated as a treatment for arresting existing cavitated caries lesions. Systematic reviews have found SDF effective for arresting caries in primary teeth of children, though methodological limitations have been noted.^104,105^ Evidence on the effectiveness of SDF for preventing caries in children is very limited. As described in the Results, we identified no trials on the effectiveness of SDF in preventing dental caries in children younger than 5 years of age. One trial (n=704) conducted in the Philippines allocated first graders in six schools based on class registration number to single application of SDF (administered by school nurses) or atraumatic restorative treatment (ART) sealants (administered by dentists).^106^ Children in two other schools served as no-treatment controls. The proportion of children with D3 caries at baseline was 13.3 percent. All of the schools were supposed to provide an ongoing oral health care program that included daily school-based tooth brushing with fluoride toothpaste, but three schools were not in compliance with the program. Therefore, analyses were stratified according to school compliance with the tooth brushing program. There were no statistically significant differences between SDF versus controls in caries increment in children in the brushing schools (hazard ratio [HR] 1.16, 95% CI, 0.51 to 2.63) or nonbrushing schools (HR 0.71, 95% CI 0.45 to 1.11), though estimates were imprecise. Staining and other harms were not reported.

We identified no other completed trials of SDF for preventing dental caries in children older than 5 years of age. Two similarly designed ongoing trials in the United States are currently in progress, with expected completion in 2023.^107,108^ Both are cluster randomized trials in elementary school children and compare a single application of SDF (administered by dental hygienists or registered nurses) versus glass ionomer sealants (administered by dental hygienists). All children will receive toothbrushes, fluoride toothpaste, and oral hygiene instruction. The trial will evaluate caries arrest after 2 years and prevalence of new caries after 4 years. The primary difference between trials is that one is focused on children in low-income rural settings^108^ and in the other trial the primary study population is low-income urban Hispanic/Latino children.^107^

One other randomized trial (n=452) of 6 year old children found 38 percent SDF every 6 months associated with fewer new decayed surfaces in primary teeth and first permanent molars versus no SDF at 36 months (0.29 vs. 1.43 and 0.37 vs. 1.06, respectively).^109^ However, applicability of this trial to prevention is uncertain, as SDF was used for caries arrest in deciduous teeth and baseline caries status in first permanent molars was unclear.