# Chapter 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^45^ the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for this review. Investigators created two analytic frameworks with the key questions and the patient populations, interventions, and outcomes reviewed (Figures 1 and 2). Screening and preventive interventions were addressed in a single analytic framework in the prior USPSTF review. For this update, screening and preventive interventions have been split into separate analytic frameworks to more clearly distinguish treatment of children with existing caries identified on screening (screening analytic framework) from treatment of children without caries to prevent the development of future caries (interventions to prevent dental caries analytic framework).

Figure 1 Analytic Framework: Screening for Dental Caries in Children Younger Than Age 5 Years^*^ * The numbers in the analytic framework correspond to the Key Question numbers on page 9 in the report.

^†^Interventions are provided to children found to have caries on screening.

This figure titled “Analytic Framework: Screening for Dental Caries in Children Younger Than Age 5 Years” is an analytic framework that depicts the events that children ages 0 to younger than 5 years may experience during a clinician office visit. The figure shows that children may undergo an oral screening and risk factor assessment, which may cause adverse effects. This leads them to being identified at either average risk for dental caries or at increased risk for dental caries. Children at either risk level may experience interventions. It is noted that interventions are provided to children found to have caries on screening, which is not addressed in this analytic framework. The outcomes of interest for children at either risk level are decreased dental caries and associated complications.

Figure 2 Analytic Framework: Interventions to Prevent Dental Caries in Children Younger Than Age 5 Years^*^ * The numbers in the analytic framework correspond to the Key Question numbers on page 9 in the report.

^†^Interventions are provided to children without caries.

This figure titled “Analytic Framework: Interventions to Prevent Dental Caries in Children Younger Than Age 5 Years” is an analytic framework that depicts the events that children ages 0 to younger than 5 years may experience during a clinician office visit. The figure shows that children may undergo a risk factor assessment. This will lead to them being identified at either average risk for dental caries or at increased risk for dental caries. Children at either risk level may experience the following interventions, which it is noted are provided to children without caries: parental or caregiver/guardian oral health education; referral to a dental health care professional; or preventive interventions, any of which may cause adverse effects. The outcomes of interest for children at either risk level are decreased dental caries and associated complications.

### Key Questions

#### Screening for Dental Caries in Children Younger Than Age 5 Years

1. How effective is oral screening (including risk assessment) performed by a primary care clinician in preventing dental caries in children younger than age 5 years?
2. How accurate is screening performed by a primary care clinician in identifying children younger than age 5 years who:
  a. Have cavitated or noncavitated caries lesions?
  b. Are at increased risk for future dental caries?
3. What are the harms of oral health screening performed by a primary care clinician in children younger than age 5 years?

#### Interventions to Prevent Dental Caries in Children Younger Than Age 5 Years

1. How accurate is screening performed by a primary care clinician in identifying children younger than age 5 years who are at increased risk of future dental caries^*^?
2. How effective is parental or caregiver/guardian oral health education provided by a primary care clinician in preventing dental caries in children younger than age 5 years?
3. How effective is referral by a primary care clinician to a dental health care professional in preventing dental caries in children younger than age 5 years?
4. How effective are preventive interventions (dietary fluoride supplementation, topical fluoride application, silver diamine fluoride, or xylitol) in preventing dental caries in children younger than age 5 years?
5. What are the harms of specific oral health interventions to prevent dental caries in children younger than age 5 years (parental or caregiver/guardian oral health education, referral to a dental health care professional, and preventive interventions)?

### Contextual Question

One Contextual Question was also requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology.

1. How effective is silver diamine fluoride in preventing dental caries in children age 5 years or older?

## Strategies

We searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews (through April, 2021), and Ovid MEDLINE (2013 through April, 2021) for relevant studies and systematic reviews. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles. Ongoing surveillance was conducted to identify major studies published since April 2021 that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on July 23, 2021 and identified no studies affecting review conclusions.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies on the basis of inclusion and exclusion criteria developed for each key question (Appendix A2). Articles were selected for full review if they were about dental caries in preschool children (younger than 5 years old), were relevant to a key question, and met the pre-defined inclusion criteria. We restricted inclusion to English-language articles and excluded studies only published as abstracts. Studies of non-human subjects were also excluded, and studies had to report original data. We included an update^46^ to a systematic review^28^ included in the prior USPSTF report on risk of fluorosis; otherwise, inclusion was restricted to primary studies and systematic reviews were used as source of potentially eligible studies.

For all key questions, we included studies of children younger than 5 years of age, including those with dental caries at baseline. We focused on studies of screening or diagnostic accuracy performed in primary care settings for identifying caries or children at increased risk of caries. For preventive treatments, we included studies of primary care feasible treatments (not requiring extensive dental specific training) administered in primary care or non-primary care settings (e.g., daycare or preschool), but noted the setting and whether the treatment was administered by persons with dental training. Interventions were parental or caregiver education, referral to a dentist by a primary care clinician, and preventive treatments including dietary fluoride supplementation, topical fluoride application (varnish, foam, or gel), xylitol, and SDF; the comparison for each was no intervention or placebo. Antimicrobial rinses and antimicrobial varnishes, which were included in the prior USPSTF review, were not included in this update because they are not widely used in children or not available in the United States. Outcomes were decreased incidence of dental caries, morbidity, quality of life, function, and associated harms, including dental fluorosis. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists the included studies, and Appendix A5 lists the excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

For studies meeting inclusion criteria, we created data abstraction forms to summarize characteristics of study populations, interventions, comparators, outcomes, study designs, settings (including human development index classification, preschool or daycare, and community fluoridation level) and methods. One investigator conducted data abstraction, which was reviewed for completeness and accuracy by another team member.

Predefined criteria were used to assess the quality of individual controlled trials, systematic reviews, and observational studies by using criteria developed by the USPSTF; studies were rated as “good,” “fair,” or “poor” per USPSTF criteria, depending on the seriousness of the methodological shortcomings (Appendix A6).^45^ For each study, quality assessment was performed by two team members. Disagreements were resolved by consensus.

## Data Synthesis

We performed a random effects meta-analysis using the profile likelihood model to summarize the effects of topical fluoride versus placebo or no fluoride on likelihood of developing caries (dichotomous outcome) or caries burden (continuous outcome, measured based on the number of decayed, missing, or filled teeth [dmft] or surfaces [dmfs]). Effects on caries burden were based on mean difference in followup caries index if available; otherwise difference in change from baseline caries index (caries increment) was used. Adjusted differences were utilized when reported. For caries burden, we used dmfs when available and otherwise used dmft. Data for dentin caries were used if available; otherwise data for any (enamel or dentin) caries were used. We combined arms of comparable interventions within the same study in the primary analysis, so each study was represented once in a meta-analysis, in order to avoid overweighting. For cluster randomized trials, we used treatment differences that accounted for the intracluster correlation, if reported. Otherwise, we corrected for clustering using the intracluster correlation by calculating the design effect and the effective sample sizes before combining with individually randomized trials. If the intracluster correlation was not reported, we imputed it based on the intracluster correlation reported in the other cluster trials. We conducted prespecified study-level subgroup analyses on the following factors: use of cluster design (yes or no), varnish frequency (every 4, 6, or 12 months), trial conducted in very high human development index (HDI) setting (yes or no, based on a United Nations Development Programme HDI score of 0.800 or higher for the country or geographic setting), trial conducted in preschool or daycare setting (yes or no), high-risk population (yes or no; high-risk defined as high baseline caries, high community caries burden, low socioeconomic status, or low rates of oral health behaviors [e.g., brushing with fluoridated toothpaste]), mean age (<2 vs. ≥2 years), enrollment restricted to caries-free children at baseline (yes or no), adequate water fluoridation (yes or no; adequate fluoridation defined as ≥0.7 parts per million [ppm] F), use of additional oral health measures (yes or no; additional oral health measures defined as education and/or provision of toothbrush and toothpaste), followup duration (1 vs. <1 year), and risk of bias (fair vs. good). We also conducted a sensitivity analysis excluding a trial^47^ that used acidulated phosphate fluoride foam instead of fluoride varnish.

For all meta-analyses, statistical heterogeneity was assessed using the Cochran Q-test and I^2^ statistic.^48^ All meta-analyses were conducted using Stata/SE 16.1 (StataCorp, College Station, TX).

For all key questions, the overall quality of evidence was determined using the approach described in the USPSTF Procedure Manual.^45^ Evidence was rated “good”, “fair”, or “poor” based on study quality, consistency of results between studies, precision of estimates, study limitations, risk of reporting bias, and applicability.^45^

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and USPSTF members participated in developing the scope of the work and reviewed draft reports, but the authors are solely responsible for the content.

## Expert Review and Public Comment

The draft Research Plan was posted for public comment on the USPSTF website from September 19 to October 16, 2019. The comments were reviewed and the Research Plan was revised by adding a footnote to clarify that in the screening analytic framework interventions are provided to children found to have caries on screening and in the prevention analytic framework interventions are provided to children without caries; changed “dentist” to “dental health care professional”; and revised the exclusion criteria to clarify that dental clinics providing interventions not available in primary care clinics are excluded from the review (interventions that can be provided in primary care practices are included even if they were administered in other settings). Also, the Research Plan was revised to clarify that information regarding the skill level or training of primary care clinicians participating in studies of screening and preventive interventions would be abstracted, and effects of skill level/training on effectiveness analyzed (data permitting).

A draft version of this report has been reviewed by content experts and representatives of Federal partners (Appendix A7), USPSTF members, and AHRQ Project Officers, and edits were made for clarity. The draft report was posted for public comment from May 11 to June 7, 2021, and minor edits were made for clarity, prior to finalization.

* This is the same question as Screening Key Question 2b.