# Chapter 1 Introduction and Background

## Purpose

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2014 recommendation on the prevention of dental caries in children younger than 5 years of age.^1^ In 2014, the USPSTF recommended that primary care clinicians prescribe oral fluoride supplementation starting at age 6 months for children whose water supply is deficient in fluoride (B recommendation) and that primary care clinicians apply fluoride varnish to the primary teeth of all infants and children starting at the age of primary tooth eruption (B recommendation).^2^ The recommendation was based on evidence from randomized trials that fluoride varnish is more effective than placebo or no varnish in preventing caries, and evidence previously reviewed by the USPSTF on the effectiveness of oral fluoride.^3,4^ The USPSTF found insufficient evidence to assess the balance of benefits and harms of routine screening examinations for dental caries performed by primary care clinicians in children younger than 5 years of age (I statement). The 2014 recommendation expanded on the 2004 USPSTF recommendation, which also recommended fluoride supplementation and found insufficient evidence on screening by primary care clinicians, but did not address use of fluoride varnish.^5^

## Condition Background

### Condition Definition

Dental caries, or tooth decay, is a common chronic disease that can cause pain and diminished function and quality of life throughout one’s lifespan.^6^ Caries lesions form in teeth through a complex interaction among cariogenic, acid-producing bacteria in combination with fermentable carbohydrates and other dietary, genetic, behavioral, social, and cultural factors.^7–9^

Children are susceptible to caries as soon as the first teeth appear, which usually occurs at about 6 months of age. Early childhood caries is defined as the presence of one or more decayed (noncavitated or cavitated), missing (due to caries), or filled tooth surfaces in any primary tooth in a preschool-age child between birth and 71 months of age.^10^ Early childhood caries is often measured using the dmfs index for decayed, missing, or filled primary tooth surfaces, and dmft for decayed, missing, or filled primary teeth. In a particular child, the number of dmfs can be higher than the number of dmft because one tooth may have more than one affected surface. Over the years the dental research and practice communities have developed and used different dental caries classification systems to describe the degree of decay, such as describing the progression of decay through the tooth tissues from the dentin to the pulp (d_1_-d_4_ lesions), the International Caries Detection and Assessment System (ICDAS)^11^ and the American Dental Association Caries Classification System.^12^ The American Dental Association Council on Scientific Affairs has published a comparative overview of these classifications.^11^

### Prevalence and Burden of Disease/Illness

Dental caries is the most common chronic disease of children in the United States.^13,14^ The National Health and Nutrition Examination Study (NHANES) found that among 2 to 5 year olds, the prevalence of dental caries in primary teeth increased from approximately 24 percent between 1988 to 1994 to 28 percent between 1999 to 2004, with a subsequent decrease in caries prevalence to approximately 23 percent in 2011 to 2016.^6,15,16^ In 2011 to 2016, approximately 10 percent of children 2 to 5 years of age had untreated dental caries and in 2011 to 2014, approximately 4.6 percent had severe caries (defined as 3 or more decayed surfaces).

Dental caries disproportionately affects minority and economically disadvantaged children. NHANES data indicate that in 2011 to 2016, the prevalence of caries in children 2 to 5 years of age was 34 percent in those living in households below the federal poverty guidelines, compared with 16 percent in children from households at 200 percent or greater of the federal poverty guidelines; the proportion with untreated caries was 17 percent versus 6.02 percent.^6^ The prevalence of caries among children aged 2 to 5 years was higher in Mexican American children (33%) and black non-Hispanic children (28%) than white non-Hispanic children (18%). Dental caries were also more likely to be untreated in black non-Hispanic (15%) and Mexican American (15%) than white non-Hispanic children (6.7%).^15^

Early childhood caries is associated with pain and loss of teeth, as well as impaired growth, decreased weight gain, and negative effects on quality of life.^7,17^ Filling placement or extractions of carious teeth can be traumatic experiences for young children, and occasionally result in serious complications. Early childhood caries is also associated with failure to thrive and can affect appearance, self-esteem, speech, and school performance, and is associated with future caries in both the primary and permanent dentitions.^18^ A systematic review found poor oral health associated with significantly increased risk of poor academic performance (pooled odds ratio [OR] 1.5, 95% confidence interval [CI], 1.20 to 1.83) and school absenteeism (pooled OR 1.43, 95% CI, 1.24 to 1.63).^19^ Premature loss of primary molars due to early childhood caries can result in loss of arch space, leading to crowding of the permanent teeth, affecting esthetics and potentially requiring orthodontic correction.^7^ In 2000, the U.S. Surgeon General estimated that over 50 million school hours are lost each year nationally due to dental related concerns.^14^ In the state of North Carolina, a study based on 2008 data estimated that more than 4 million school hours are lost each year due to poor oral health status, with over 700,000 of these hours lost due to dental pain or infection.^19^

### Etiology and Natural History

Dental caries is a disease process during which various strains of bacteria colonize the tooth surface and metabolize dietary carbohydrates (especially refined sugars) to produce lactic and other acids, resulting in demineralization of teeth.^7,20^ In children ages 12 to 30 months, caries typically initially affects the maxillary primary incisors and first primary molars, reflecting the pattern of eruption. Dental caries first manifests as white spot lesions, which are small areas of demineralization under the enamel surface. At this stage, the caries lesion is usually reversible, if appropriate preventive action is taken (e.g., change in dietary behaviors or application of fluoride varnish). If oral conditions do not improve, demineralization progresses, and eventually results in irreversible cavities, with a loss of the normal tooth shape and contour. Continued progression of the caries process leads to pulpitis (inflammation due to bacterial infection of the dental pulp, or soft tissue in the center of a tooth) and tooth loss, and can be associated with complications such as facial cellulitis and systemic infections.^20,21^

### Risk Factors

Risk factors for dental caries in young children are multifactorial comprising biological as well as non-biological factors/social determinants of health. Biological factors include high levels of cariogenic bacterial colonization, low saliva flow rates, developmental defects of tooth enamel, and high maternal levels of cariogenic bacteria. Non-biological/social determinants of health factors include, frequent exposure to dietary sugar and refined carbohydrates, inappropriate bottle feeding (e.g., child put to sleep with a bottle containing something other than water), low socioeconomic status, previous caries, maternal caries, , and poor maternal oral hygiene.^20,22^ Other risk factors include lack of access to dental care, low community water fluoride levels, inadequate tooth brushing/use of fluoride-containing toothpastes, and lack of parental knowledge regarding oral health.^14^

### Rationale for Screening/Screening Strategies

Screening for dental caries and caries risk factors in young children prior to school entry could identify caries lesions at an earlier and reversible stage and lead to interventions to treat existing caries lesions, prevent progression of caries lesions, and reduce incidence of future lesions, including lesions in the permanent dentition. Screening strategies typically include oral health risk assessment and visual examination to identify high-risk children, including those already with caries. Primary care clinicians can play an important role in screening for dental caries because many young children routinely see a primary care clinician starting shortly after birth, but do not see a dental health care professional until they are older.^23^ Approximately three-quarters of children under 6 years of age did not have even one visit to a dental health care professional in the previous year, though the proportion with a visit increased from 21 percent in 1996 to 25 percent in 2004.^24^ Access to dental care is impacted by many factors, including social determinants of health and shortages in dental health care professionals treating young children, particularly for children who are not insured or who are publicly insured.^25^ Once children enter school, there are additional opportunities for screening and treatment.^26^

### Preventive Interventions

In young children at risk for dental caries, interventions to prevent development of caries lesions focus on reducing the burden of bacteria, reducing the intake of refined sugars, and increasing the resistance of teeth to caries development.^7,22^ Strategies to reduce the burden of bacteria include the use of fluoride, parental counseling to improve oral hygiene, xylitol, and topical antimicrobials such as chlorhexidine or povidone-iodine.^3,4^ Educational and behavioral interventions can also address reduced intake of refined sugars through changes in diet and feeding practices. Children with caries or at risk of caries can also be referred for needed dental care.

Use of fluorides primarily focuses on promoting remineralization of the enamel. Fluoride exposure can be topical (fluoride dentifrices, rinses, gels, foams, varnishes) or systemic (dietary fluoride supplements).^7,22^ Fluoridated water has topical as well as systemic effects. The main effect, however, is now believed to be topical. Fluoride is incorporated into the biofilm (dental plaque), saliva and tooth enamel and increases tooth resistance to acid decay, acts as a reservoir for remineralization of caries lesions, and inhibits cariogenic bacteria.^7,21^ A potential harm of excessive systemic fluoride exposure is enamel fluorosis, a visible change in enamel opacity due to altered mineralization. The severity of enamel fluorosis depends on the dose, duration and timing of fluoride intake, and is most strongly associated with cumulative intake during enamel development; risk of fluorosis is related to exposure from birth to 6 to 8 years of age, though children are most susceptible between 15 to 30 months of age.^27,28^ Mild fluorosis manifests as small opaque white streaks or specks in the tooth enamel.^29^ Severe fluorosis results in discoloration and pitted or rough enamel.^21^ In 1999 to 2004, the prevalence of severe enamel fluorosis in the United States was estimated at less than 1 percent.^29,30^

Topical fluoride is typically applied as a varnish with a small brush in young children. Unlike fluoride gels, which are more commonly used in older, school-aged children, fluoride varnish does not require specialized dental devices or equipment and can be applied quickly by both dental professional and non-dental health professionals in a variety of settings without the risk of the child swallowing large amounts, which can cause transient gastric irritation.^7,31^ Compared with other topical fluoride application methods (such as acidulated phosphate fluoride or sodium fluoride gel), systemic exposure to fluoride is low following application of fluoride varnish.^32,33^ The varnish results in prolonged contact time between the fluoride and the tooth surface, which maintains a higher level of the calcium fluoride in the biofilm; later the released fluoride promotes remineralization. Fluoride varnish is typically available in the United States as 5 percent sodium fluoride (2.26% F). Fluoride varnish is cleared for marketing by the U.S. Food and Drug Administration (FDA) as a cavity liner and tooth desensitizer; its use for prevention of caries is off-label.^34^

Silver diamine fluoride (SDF) is a topical medication that is noninvasive, relatively inexpensive, and easy to apply.^35^ The most common concentration is 38 percent, though it has been evaluated in 10 percent to 38 percent formulations. SDF was cleared for marketing by the FDA in 2014 as a desensitizing agent in adults, similar to fluoride varnish 20 years earlier;^36^ it has long been used in other parts of the world to arrest progression of existing caries lesions and avoid restorative treatment. SDF works by the combined effects of silver and fluoride on promoting remineralization, as a short-term germicide, and inhibits enzymes involved in collagen degradation, all of which result in an arrest of the carious process;^35,37^ SDF is also being evaluated for preventing future caries in school-age children.^38,39^ A potential disadvantage of SDF is cosmetic concerns, due to the permanent dark discoloration of active caries lesions by the silver component. However, SDF will not discolor healthy enamel, caries lesions themselves cause discoloration, and in young children discoloration would impact primary (non-permanent) teeth. Based on its potential as a caries treatment, SDF has been granted “breakthrough therapy” designation by the FDA, providing the opportunity for expedited approval for this indication, and a number of clinical trials of SDF for treating caries are in progress.

Xylitol is a naturally occurring sugar that cannot be metabolized by the oral microflora and thus has the potential to reduce levels of caries-forming mutans streptococci in the plaque and saliva.^40^ In young children, xylitol can be administered as a syrup or topically via wipes. In older children, xylitol can also be administered in gum, lozenges, or snack foods. FDA allows foods (including chewing gums) that contain xylitol to make the following statement: “Xylitol may reduce the risk of tooth decay”.^41^ Other topical antimicrobials such as chlorhexidine varnish or gel and povidone-iodine rinses are not commonly used in the United States in young children or are not available, as in the case of chlorhexidine varnish. Neither chlorhexidine nor povidone iodine has been approved by FDA to be used for caries reduction or prevention.^42^

### Current Clinical Practice/Recommendations of Other Groups

Since the publication of the Surgeon General’s Report on Oral Health in 2000,^14^ many organizations (see below) have emphasized the importance of preventive oral health care for young children, particularly in the primary care setting. The American Academy of Pediatrics (AAP) has developed an oral health risk assessment tool for use in primary care settings starting at the 6 month visit, along with suggested interventions for children at risk.^43^ The American Academy of Pediatric Dentistry (AAPD) developed the Caries-risk Assessment Tool (CAT), designed for use by dental and non-dental personnel.^44^ Although the vast majority of pediatricians agree with recommendations on oral health screening, only about half report examining the teeth of more than half of their 0 to 3 year old patients, and few (4%) reported regularly applying fluoride varnish.^25^ Data on rates of SDF use in primary care settings are not available.