# Appendix B Evidence Tables and Quality Tables

Appendix B1 Diagnostic Accuracy Studies for the Prevention of Dental Caries

Author, year^*^ | Screening test | Reference standard | Country Setting Screener | Population | Sample size Proportion with condition | Definition of a positive screening exam | Proportion unexaminable by screening test | Analysis of screening failures | Proportion who underwent reference standard and included in analysis | Sensitivity | Specificity | Positive predictive value | Negative predictive value | AUC (95% CI) | Quality rating
Prior review
Pierce et al., 2002 | Primary care pediatrician exam following 2 hours of training | Pediatric dentist exam | United States Pediatric group practice Primary care pediatrician | Children <36 months of age with erupted teeth participating in the “Into the Mouths of Babes” program. Excluded if they had received fluoride varnish and oral screening within 3 months or were very ill | n=258 children Cavitated lesions: 9.7% (mean 0.3/child) | Identification of a cavitated lesion Identification of need for referral | Appears to be none | Not applicable | Appears to be all | Patient-level analysis: 0.76 (19/25), 95% CI, 0.55 to 0.91; Tooth-level analysis: 0.49 (39/80), 95% CI, 0.37 to 0.60; Need for referral: 0.63 (17/27), 95% CI, 0.42 to 0.81 | Patient-level analysis: 0.95 (222/233), 95% CI, 0.92 to 0.98; Tooth-level analysis: 0.99 (3210/3235), 95% CI, 0.99 to 0.99; Need for referral: 0.98 (225/231), 95% CI, 0.95 to 0.99 | Patient-level analysis: 0.63 (19/30), 95% CI, 0.48 to 0.76; 0.83 (25/30) if precavitated lesions re-classified as true-positives; Tooth-level analysis: 0.61 (39/64), 95% CI, 0.50 to 0.71 Need for referral: 0.74 (17/23), 95% CI, 0.55 to 0.87 | Patient-level analysis: 0.97 (222/228), 95% CI, 0.95 to 0.99; Tooth-level analysis: 0.99 (3210/3251), 95% CI, 0.98 to 0.99; Need for referral: 0.96 (225/235), 95% CI, 0.93 to 0.97 | NR | Good
Serwint et al., 1993 | Pediatrician exam (not primary care provider) following 4 hours of training | Pediatric dentist exam | United States General pediatric clinic Pediatrician | Children 18 to 36 months of age, mother primary caretaker. Excluded for developmental delay or facial abnormalities | n=110 children Nursing caries (caries involving ≥1 teeth including the maxillary central or lateral incisors or the primary molars but sparing the mandibular incisors): 20% (22/110) | Identification of nursing caries | Not reported | Not reported | 55% (61/110) | 1.0 (n/N not calculable) | 0.87 (n/N not calculable) | Not calculable | Not calculable | NR | Fair
Current review
MacRitchie et al., 2012 | DCRAM | Dental exam following criteria developed for the Dundee selective threshold methods for caries detection. | Scotland Setting unclear, likely home-based Screening by nurse ‘health visitor’ | Children born and resident in Dundee, Scotland, in 1 complete calendar year and followed longitudinally for 4 years. | n=1681; Any d_1_ at year 1: 3%; Any d_3_ at year 1: 0.4%; Any d_1_ at year 4: 49%; Any d_3_ at year 4: 33% | At age 4 years: d_1_mft ≥1 or ≥3 d_3_mft ≥1 or ≥3 | Appears to be none | Not applicable | 99.8% | d_1_mft >0: 0.67; d_3_mft >0: 0.53; d_1_mft ≥3: 0.69; d_3_mft ≥3: 0.65 | d_1_mft >0: 0.57; d_3_mft >0: 0.77; d_1_mft ≥3: 0.60; d_3_mft ≥3: 0.69 | NR | NR | NR | Fair

* See Appendix A4 for full citations of included studies.

Abbreviations: AUC=area under the curve; DCRAM=Dundee Caries Risk Assessment Model; CI=confidence interval; NR=not reported.

Appendix B2 Quality Ratings for Diagnostic Accuracy Studies

Author, year^*^ | Representative spectrum | Random or consecutive sample | Screening test adequately described | Screening cutoffs predefined | Credible reference standard | Reference standard applied to all screened patients | Same reference standard applied to all patients | Reference standard and screening examination interpreted independently | Reference standard assessed by blinded assessor | Screening test assessed by blinded assessor | High rate of uninterpretable results, noncompliance with screening test, or attrition | Analysis includes patients with uninterpretable results or noncompliance | Quality rating
MacRitchie, 2012 | Yes | Yes | Yes | No | Yes | Yes (99%) | Yes | Yes | Unclear | Unclear | No | No | Fair
Serwint, 1993 | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair
Pierce, 2002 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Not applicable | Good

* See Appendix A4 for full citations of included studies.

Appendix B3 Trials of Educational Interventions for the Prevention of Dental Caries

Author, year^*^ | Study Design | Interventions | Baseline population characteristics | Eligibility criteria | Number approached, eligible, enrolled, analyzed | Country Setting | Sponsor | Duration of followup | Confounders adjusted for in analysis | Outcomes | Adverse events/harms | Attrition | Quality rating | Comments
Current report
Basir et al., 2017 | RCT | A. 2 brief in-person sessions (1 individual, 1 group; ≤30 minutes each), text message reminders every 2 weeks for 6 months, and pamphlet containing tips on the promotion of educational items and the need for oral health care for their children; B. Usual well baby visit care without an oral health component | A vs. B; Mean child age (SD): 1.5 (0.6) years; Mean maternal age (SD): 31 (6.7) years; Female: 50%; Race/ethnicity: NR; No prior dental visit: 71% vs. 73%; Education >high school: 90%; Caries at baseline: NR; Toothbrushing: NR | Mothers of children age 12 to 36 months without caries and with ≥8 completely erupted teeth, 4 maxillary anteriors, and 4 mandibular anteriors | Approached: 140; Eligible: 107 Enrolled: 104 (52 vs. 52); Analyzed: 104 (52 vs. 52) | Iran Maternal-child health wards Water fluoridation: NR | No external funding | 6 months | NA | A vs. B; Caries incidence (WHO criteria, including white spot lesions non-cavitated and categorized as D1): 13.5% (7/52) vs. 34.7% (17/49); RR 0.39 (95% CI, 0.18 to 0.85) | Not reported | Unclear | Fair | Fig 1 show all pts were analyzed at followup but that math doesn’t work for the reported caries incidence (35% of 52=18). I calculated the N based on an n=17 and incidence of 35%.

* See Appendix A4 for full citations of included studies.

Abbreviations: CI=confidence interval; NA=not applicable; NR=not reported; RCT=randomized controlled trial; RR=relative risk; SD=standard deviation; WHO=World Health Organization.

Appendix B4 Quality Ratings of Randomized, Controlled Trials of Topical Fluoride

Author, year^*^ | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Outcome assessors masked? | Care provider masked? | Patient masked? | Intention-to-treat (ITT) analysis | Patients with missing data analyzed? | Acceptable levels of overall attrition and between-group differences in attrition? | Post-randomization exclusions | Avoidance of selective outcomes reporting | Adjusted for cluster correlation? | Quality rating
Agouropoulos et al., 2014 | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No/Yes | No | Yes | NA | Fair
Anderson et al., 2016; Anderson et al., 2017 | Unclear | No | Yes | No | No | No | Yes | No | No/Yes | No | Yes | Yes | Fair
Basir et al., 2017 | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes/Yes | No | Yes | NA | Fair
Frostell et al., 1991 | NR | NR | NR | Unclear | No | No | Unclear | No | Unclear | No | Yes | NA | Fair
Jiang et al., 2005 | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | No | Yes/Yes | No | Yes | Yes | Fair
Jiang et al., 2014 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes/Yes | No | Yes | NA | Good
Latifi-Xhemajli et al., 2019 | Yes | Unclear | Yes | Yes | No | No | Yes | No | Yes/Yes | No | Yes | NA | Fair
Lawrence et al, 2008 | Yes | Unclear | Yes | Unclear | No | No | Yes | No | Yes/Yes | No | Yes | Yes | Fair
McMahon et al., 2020 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes/Yes | No | Yes | NA | Good
Memarpour et al, 2015 | Yes | Unclear | Yes | Yes | No | No | Yes | No | Yes/Yes | No | Yes | NA | Fair
Memarpour et al, 2016 | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | No | Yes/Yes | No | Yes | NA | Fair
Muñoz‐Millán, 2018 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No/Yes | No | Yes | NA | Fair
Oliveira et al., 2014; dos Santos et al., 2016 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes/Yes | No | Yes | NA | Good
Oscarson et al., 2006 | NR | NR | Yes | Yes | No | No | Yes | No | Yes/Yes | No | Yes | NA | Fair
Slade et al, 2011 | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes/Yes | No | Yes | Yes | Fair
Tickle et al., 2016 Tickle et al., 2017 | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | No | Yes/Yes | No | Yes | NA | Fair
Weintraub et al., 2006 | Yes | Yes | Yes | Yes | No | Yes | Yes | No | No/Yes | No | Yes | NA | Fair
Zhan et al., 2012 | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes/No (10% vs. 23%) | No | Yes | NA | Fair

* See Appendix A4 for full citations of included studies.

Abbreviations: NA=not applicable; NR=not reported.

Appendix B5 Cohort Studies of Dental Referral From a Primary Care Clinician for the Prevention of Dental Caries

Author, year^*^ | Type of study | Interventions | Population characteristics | Eligibility criteria | Number approached, eligible, enrolled, analyzed | Country | Sponsor | Duration of followup | Confounders adjusted for in analysis | Outcomes | Adverse events/harms | Attrition | Quality rating
Prior Report
Beil et al., 2012 | Cohort | A: First preventive dental visit by age 18 months; B: First preventive dental visit after age 18 months | A vs. B; Female: 46% vs. 48-51%; Non-white race: 67% vs. 66-67%; Number of well-child visits: 1.8 vs. 1.4-1.7; Percent of population in county under 18 months of age enrolled in Medicaid: 30% vs. 31-33%; Dentists per capita in county: 5.1 vs. 4.5-4.9 | Children enrolled in North Carolina Medicaid prior to first birthday, enrolled for at least 12 months, with a paid claim for dental care (1999-2006); Excluded if they received dental services in medical office as part of the Into the Mouths of Babes fluoride varnish program. | Approached: 165,383; Eligible: 19,888; Enrolled: 19,888; Analyzed: 19,888 | United States | AHRQ and NIDCR | Through 72 months of age | Age, race/ethnicity, caregiver employment, caregiver education, language spoken at home, diet score, hygiene score, tooth monitoring score | Subsequent dental treatment, first preventive visit at 18-24, 25-30, 31-36, or 37-42 months vs. <18 months (reference); [underlined: Primary or secondary preventive visit:] Incidence density ratio 0.98 (0.87-1.1), 1.1 (0.94-1.2), 1.1 (0.96-1.2), and 1.1 (0.95-1.2); [underlined: Tertiary preventive visit: Incidence density ratio] 1.2 (1.0-1.4), 1.2 (1.1-1.4), 1.1 (0.99-1.3), and 1.4 (1.2-1.6) | Not reported | None reported | Fair
Current Report
Beil et al., 2014 | Cohort | A: First preventive dental visit by age 24 months; B: First preventive dental visit at age 24 to 36 months; C: First preventive dental visit at age 37 to 48 months; D: First preventive dental visit at 49 to 60 months | A vs. B vs. C vs. D; Female: 47.5% vs. 50.6% vs. 49.5% vs. 48.2%; White: 42.0% vs. 38.7% vs. 36.6% vs. 39.2%; Black: 44.0% vs. 48.4% vs. 51.6% vs. 46.0%; Hispanic: 11.6% vs. 11.4% vs. 9.7% vs. 12.1%; Other race: 2.4% vs. 1.5% vs. 2.0% vs. 2.7%; Mean (SD) number of well-child visits: 1.68 (1.13) vs. 1.34 (1.11) vs. 1.24 (1.12) vs. 1.15 (1.09); Medicaid enrollees under age 18 years in county of residence: 34.8% vs. 34.7% vs. 36.0% vs. 35.8%; Mean (SD) number of dentists per 10,000 population: 4.11 (2.04) vs. 4.10 (2.01) vs. 3.83 (1.97) vs. 3.79 (1.91) | Children enrolled in North Carolina Medicaid prior to first birthday, still enrolled after turning 1 year, and did not receive preventive dental services in a medical office (2005-2006) | Approached: NR; Eligible: 11,394; Enrolled: 11,394; Analyzed: 11,394 | United States | AHRQ and NIDCR | Up to 5 years of age (assessment in kindergarten) | Child-level: gender, race, number of well-child visits from age 12 to 24 months, and whether child was continuously enrolled in Medicaid County-level: % of population under age 18 enrolled in Medicaid, metropolitan status, and number of dentists per 10,000 population | A vs. B vs. C vs. D; Any with untreated caries among those with caries (n=6749): 41.3% vs. 33.9% vs. 38.8% vs. 42.2%, p<0.01 for B vs. others; B vs. C vs. D (reference A); Adjusted IRR (95% CI) for dmft index: 0.98 (0.90 to 1.07) vs. 0.88 (0.81 to 0.95) vs. 0.75 (0.69 to 0.82); p<0.05 for A vs. C and D; Adjusted OR (95% CI) for having any untreated dental disease among children with any dental disease (n=6749): 0.71 (0.56 to 0.90) vs. 0.82 (0.66 to 1.03) vs. 0.97 (0.77 to 1.22), p<0.01 for A vs. B | Not reported | None reported | Fair
Blackburn et al, 2017 | Cohort | A: ≥1 preventive dental visit delivered by dental health care professional; B: No preventive dental visits | A vs. B; Female: 50.9% vs. 50.7%; Black: 44.0% vs. 43.4%; White: 37.6% vs. 38.3%; Hispanic: 16.3% vs. 16.5%; Other race: 2.0% vs. 1.8% | Children enrolled in Alabama’s Medicaid program from birth for 3 or more years (2008-2012) | Approached: NR; Eligible: NR; Enrolled: 9732; Analyzed: 9732 | United States | Lister Hill Center for Health Policy at the University of Alabama at Birmingham School of Public Health | 3 years | Propensity score matching of health services utilization, race, rural-urban community, age, fluoridation level | A vs. B; Received any caries-related treatment visit: 20.6% vs. 11.3%, p<0.001; Any annual dental visit: 80.1% vs. 42.8%, p<0.001; Received fluoride varnish during the first 2 years of life: 84.3% vs. NA; Number of fluoride varnishes received, mean (SD): 1.1 (0.7) vs. NA; Difference in number of annual caries-related visits: 0.15 (95% CI, 0.11 to 0.16); Difference in caries-related expenditures: −0.01 (95% CI, −0.13 to 0.12); Different in annual dental expenditures: 0.03 (95% CI, −0.06 to 0.13) | Not reported | None reported | Fair
Kranz, et al., 2014a | Cohort | A: Received ≥2 preventive oral health visits from a PCC; B: Received ≥2 preventive oral health visits from a dental health care professional; C: Received ≥2 preventive oral health visits from a PCC and a dental health care professional | A vs. B vs. C; Female: 48.4% vs. 50% vs. 46.6%; White: 39.4% vs. 34.4% vs. 36.4%; Black: 41.6% vs. 42.1% 42.7%; Hispanic: 7.0% vs. 14.2% vs. 11.9%; Mean (SD) number of well-child visits before age 3 years: 5.0 (1.4) vs. 4.0 (2.2) vs. 4.9 (1.6); Medicaid eligible people under 18 years old per 10,000 people: 511.2 (SD 144.0) vs. 417.7 (SD 123.5) vs. 452.8 (SD 124.4); Mean (SD) number of dentists per 10,000 people: 3.3 (1.4) 4.6 (1.7) vs. 3.8 (1.7) | Children enrolled in North Carolina Medicaid prior to first birthday, still enrolled after turning 1 year, and received preventive dental services before the age of 3 years (2005-2006) | Approached: NR; Eligible: 5235; Enrolled: 5235; Analyzed: 5235 | United States | AHRQ and NIDCR | Up to 3 years of age | Propensity score matching of sex, race, Hispanic ethnicity, total number of months enrolled in Medicaid, number of well-child visits, indicators of special heal care needs, receipt of caries-related treatment, whether any preventive oral health services were received in a federally qualified health center, health department, or rural health clinic, proportion of population with access to fluoridated public drinking water, rural or urban status, number of dentists, pediatricians, and family practice physicians per 10,000, and Medicaid-eligible children younger than 18 years | A vs. B vs. C; Received any caries-related treatment before age 3 years: 24.0% vs. 39.2% vs. 31.0%; A vs. C (reference B); OR (95% CI) of >0 dmft: 1.06 (0.78 to 1.46) vs. 0.77 (0.52 to 1.14); IRR (95% CI) of expected number of dmft for children at risk for dmft (n=2521): 0.95 (0.82 to 1.09) vs. 0.94 (0.82 to 1.08); OR (95% CI) of untreated decayed teeth of those at risk for dmft (n=2521): 2.05 (1.28 to 3.30) vs. 1.34 (0.82 to 2.19), p<0.01 for A vs. B | Not reported | None reported | Fair
Kranz, et al., 2014b | Cohort | A: Received preventive oral health visits from a PCC; B: Received preventive oral health visits from a dental health care professional; C: Received preventive oral health visits from a PCC and a dental health care professional | A vs. B vs. C; Age: 3-5 years overall; Female: 48.7% vs. 48.9% vs. 47.2%; White: 37.8% vs. 29.4% vs. 33.8%; Black: 39.1% vs. 39.3% vs. 39.0%; Hispanic: 12.6% vs. 20.1% vs. 18.2%; Mean (SD) number of well-child visits before age 3 years: 4.8 (1.3) vs. 3.9 (1.9) vs. 4.6 (1.4); Medicaid eligible people <18 years old per 10,000 people: 0.2 (SD 0.1) vs. 0.2 (SD 0.1) vs. 0.2 (SD 0.1); Mean (SD) number of dentists per 10,000 people: 43.6 (1.6) vs. 5.2 (1.8) vs. 4.3 (1.9) | Children enrolled in North Carolina Medicaid prior to first birthday, enrolled for ≥12 months before age 3 years, enrolled for ≥7 months after turning 3 years, with >1 visit to PCPs, dentists, or both before age 3 years (2000-2006) | Approached: NR; Eligible: 41,453; Enrolled: 41,453; Analyzed: 41,453 | United States | AHRQ and NIDCR | Up to 5 years of age | Child-level: sex, race, Hispanic ethnicity, months enrolled in Medicaid per year, number of well-child visits, indicators of special health care needs, whether any preventive oral health services were received in a public clinic, year that treatment was received; County-level: proportion of population with access to fluoridated drinking water; rural or urban status; and the number of dentists, pediatricians, and family practice physicians, and Medicaid-eligible children under 18 years per 10,000 population | A vs. B vs. C; Received any caries-related treatment between ages 3 to 5 years: 26.7% vs. 51.8% vs. 47.6% | Not reported | None reported | Fair
Sen et al., 2016 | Cohort | A: ≥1 preventive dental visit; B: No preventive dental visits | A vs. B; Age, mean (SD), years: 4.5 (0.7) vs. 4.0 (0.8); Female: 49.5% vs. 47.6%; White: 67.2% vs. 72.5%; Black: 23.6% vs. 17.3%; Other race: 9.2% vs. 10.2%; Well-child visits by 3 years, mean (SD) per child: 6.1 (3.7) vs. 6.6 (3.7) | Children enrolled in Alabama’s CHIP program from birth to 4 years old (1998-2012) | Approached: NR; Eligible: NR; Enrolled: 4774; Analyzed: 4774 | United States | Alabama Department of Public Health and Alabama Children’s Health Insurance Program | 3 years | Propensity score matching of health services utilization, race, rural-urban community, age, fluoridation level | A vs. B; Difference in number of restorative dental visits (adjusted): 11.1%, p<0.001; Difference in number of emergency dental visits (adjusted): 1.9%, p<0.05 | Not reported | None reported | Fair

* See Appendix A4 for full citations of included studies.

Abbreviations: AHRQ=Agency for Healthcare Research and Quality; CHIP=Children’s Health Insurance Program; CI=confidence interval; IRR=incidence rate ratio; NIDCR=National Institute of Dental and Craniofacial Research; NA=not applicable; NR=not reported; OR=odds ratio; PCC=primary care clinician; SD=standard deviation.

Appendix B6 Quality Ratings of Included Cohort Studies

Author, year^*^; Country | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria (inception cohort)? | Were the groups comparable at baseline on key prognostic factors (e.g., by restriction or matching)? | Did the study use accurate methods for ascertaining exposures and potential confounders (i.e., age, sex, other medications)? | Were outcome assessors and/or data analysts blinded to exposure being studied? | Did the article report attrition or missing data? | Is there important differential loss to followup or overall high loss to followup or missing data? | Were appropriate confounders analyzed (i.e., age, sex, other medications)? | Were outcomes pre-specified and defined, and ascertained using accurate methods? | Quality rating
Beil et al., 2012; United States | Yes | Yes | Unclear | Unclear | Yes | No | Yes | Yes | Fair
Beil et al., 2014; United States | Yes | Yes | Unclear | Unclear | Yes | No | Yes | Yes | Fair
Blackburn et al, 2017; United States | Yes | Yes | Unclear | Unclear | Yes | No | Yes | Yes | Fair
Kranz, et al., 2014a; United States | Yes | Yes | Unclear | Unclear | Yes | No | Yes | Yes | Fair
Kranz, et al., 2014b; United States | Yes | Mostly | Unclear | Unclear | Yes | No | Yes | Yes | Fair
Sen et al, 2016; United States | Yes | Yes | Unclear | Unclear | Yes | No | Yes | Yes | Fair

* See Appendix A4 for full citations of included studies.

Appendix B7 Trials of Topical Fluoride for the Prevention of Dental Caries

Author, year^*^ | Type of study | Interventions | Baseline population characteristics | Eligibility criteria | Number approached, eligible, enrolled, analyzed | Country Setting | Sponsor | Duration of followup | Outcomes | Adverse events/harms | Attrition | Quality rating
Prior Report
Frostell et al., 1991 | RCT | A: Duraphat treatment twice a year; B: No treatment; Most children were exposed to fluoride toothpaste and some use fluoride tablets and mouth rinse solutions.; Interventionist: NR | Age: 4 years; Female: NR; Race: NR; Mean dmfs_1_: 4.79 | 4 year old children; Excluded: Those who developed ≥10 caries between 3 and 4 years of age. | Approached: NR; Eligible: NR; Enrolled: 206; Analyzed: 206 (113 vs. 93) | Sweden; Suburban areas; Fluoridation status NR | Swedish Sugar Company, Swedish Odonatological Patents Revenue Research Fund | 2 years | A vs. B; Mean dmfs_1_: 2.26 vs. 3.60, p<0.01; Mean dmfs_2_: 2.86 vs. 4.10, p=NS; Mean dmft_1_: 1.09 vs. 1.32, p=NS | NR | NR | Fair
Jiang et al., 2005 | Cluster RCT (15 clusters) | A: 0.6 to 0.8 g of 1.23% acidulated phosphate fluoride foam applied every 6 months, max 4 applications; B: Placebo foam; No oral health education described; Interventionist: 2 dental health care professionals and 2 assistants | Age, mean (SD): 3.6 (0.6) years; Female: 46%; Race: NR; dmft, mean (SD): 1.6 (2.5); dmfs, mean (SD): 2.6 (4.3); Use of fluoride toothpaste: 22%; Daily toothbrushing: 46% | Children 3 to 4 years of age; Excluded: Not reported | Approached: NR; Eligible: NR; Enrolled: 392 (209 vs. 183); Analyzed: 318 (167 vs. 151) at 2 years | China; Recruitment setting: Kindergarten; Water fluoridation status: 0.1 to 0.3 ppm | National Key Technologies R&D Program of the Tenth-five Year Plan, Ministry of Science and Technology China | 2 years | A vs. B; dmfs increase >0: 61.7% (103/167) vs. 73.5% (111/151); RR 0.84 (95% CI, 0.72 to 0.98); dmfs increase ≥6: 28.1% (47/167) vs. 35.1% (53/151), RR 0.80 (95% CI, 0.58 to 1.11); dmfs increase ≥11: 11.4% (19/167) vs. 17.2% (26/151), RR 0.66 (95% CI, 0.38 to 1.14); dmfs increment (SD): 3.8 (0.9) vs. 5.0 (1.0); p=0.03; reduction in caries increment 24% | No adverse events detected | A vs. B: 20% (42/209) vs. 17% (32/183) | Fair
Lawrence et al., 2008 | Cluster RCT (20 clusters) | A: 0.3 to 0.5 ml 5% sodium fluoride varnish (Duraflor) applied every 6 months; B: No fluoride varnish; All children: Parental oral health education at baseline, 12 and 24 months; Interventionist: dental health care professionals | Age, mean (SD): 2.5 (1.2) years; Female: 51%%; Race: 100% aboriginal dmft, mean (SD): 7.0 (6.2) dmft >0: 72%; Daily toothbrushing: NR | Children 6 month to 5 years of age, with at least one primary tooth; Excluded: No teeth, stainless steel crowns only, ulcerative gingivitis, stomatitis or allergy to colophony component. | Approached: 1,793; Eligible: 1,275; Enrolled: 1,275 (915 vs. 360); Analyzed: 1,146 (818 vs. 328) | Canada; Recruitment setting: Rural Aboriginal communities; Water fluoridation status: No fluoridation | Institute of Aboriginal Peoples’ Health/Canadian Institutes of Health Research; Toronto Hospital for Sick Children Foundation | 2 years | A vs. B; Incident caries:^†^ 71.5% (595/832) vs. 75.3% (247/328), adjusted OR 0.72 (95% CI, 0.42 to 1.25); -caries free at baseline:^‡^ 44.4% (157/354) vs. 57.9% (73/126); adjusted OR 0.63 (95% CI, 0.33 to 1.1; -0 to 1 years:^‡^ 61.1% (209/342) vs. 69.4% (84/121), adjusted OR 0.52 (95% CI, 0.23 to 1.19); -2 to 3 years:^‡^ 75.5% (336/445) vs. 82.0% (132/161), adjusted OR 0.52 (95% CI, 0.24 to 1.10); dmfs increment, adjusted mean (SD):^†^ 11.0 (15.0) vs. 13.5 (15.0); adjusted mean difference −2.4 (SE 2.0), p=0.24, prevented fraction 18%; -caries free at baseline, adjusted mean (SD):^‡^ 4.3 (8.5) vs. 6.1 (9.4); adjusted mean difference: −1.7 (SE 1.3), p=0.18; -0 to 1 year, adjusted mean (SD): 8.1 (10.5) vs. 11.2 (14.1); adjusted mean difference −3.9 (SE 2.4), p=0.10; -2 to 3 years: 13.6 (16.0) vs. 16.6 (17.5); adjusted mean difference −3.7 (SE 3.0), p=0.22 | One child allergic to lanolin experienced an adverse event | A vs. B: 11% (96/915) vs. 9% (32/360) | Fair
Slade et al., 2011 | Cluster RCT (30 clusters) | A: 0.25 ml 5% sodium fluoride varnish (Duraphat) every 6 months, parental oral health education and provision of toothbrush and toothpaste (low concentration fluoride); B: No interventions Interventionist: dental health care professionals | Age, mean: 2.8 years; Female: 49%; Race: All aboriginal; dmfs >0: 62.5%; d_3_mfs, mean: 4.7; Daily toothbrushing: NR | Aboriginal identity, 18 to 48 months of age; Excluded: Asthma | Approached: 685; Eligible: 666; Enrolled: 666 (344 vs. 322); Analyzed: 666 (344 vs. 322) | Australia; Recruitment setting: Rural Aboriginal communities; Water fluoridation status: See population characteristics; Water fluoride concentration <0.6 ppm: 87% | Australian National Health and Medical Research Council | 2 years | A vs. B; dmfs increment, adjusted mean (SD): 7.3 (10.4) vs. 9.6 (10.1), difference −2.3 (95% CI, −3.7 to −0.8), prevented fraction 24%; -effect of additional 1 ppm F: −4.3 (95% CI, −7.0 to −1.6); -effect of age (years): −0.3 (95% CI, −0.3 to −0.2) | No adverse events detected | A vs. B: 19% (60/322) vs. 18% (63/344) | Fair
Weintraub et al., 2006 | RCT | A: 0.1 mL 5% sodium fluoride varnish (Duraphat) applied at 6 month intervals with 4 intended applications; B: 0.1 mL 5% sodium fluoride varnish (Duraphat) applied once per year with 2 intended applications; C: No fluoride varnish (gauze dipped in varnish, then folded and dry area applied to teeth); All children: Parental oral health education annually; Interventionist: dental health care professionals | Age, mean (SD): 1.8 (0.6) years; Female: 53%; Hispanic: 47%; Asian: 46%; Other race/ethnicity: 7%; dmfs: 0 (excluded); Daily toothbrushing: NR | 6 to 44 months if age, 4 erupted maxillary incisors, caries-free without demineralized white spots; Excluded: Medical problems or medications affecting oral health e.g. cleft lip/palate | Approached: NR; Eligible: NR; Enrolled: 376 (126 vs. 124 vs. 126); Analyzed: 280 (87 vs. 93 vs. 100) | U.S.; Recruitment setting: Family dental center and public health center serving primarily low-income, underserved Hispanic and Chinese populations; Water fluoridation status: ~1 ppm | National Institute of Dental and Craniofacial Research; the National Center for Minority Health and Health Disparities; UCSF Department of Preventive and Restorative Dental Sciences | 2 years | A vs. B vs. C; Incident caries (d_2_mfs >0): 13.2% (11/83) vs. 15.1% (13/86) vs. 29.3% (27/92) at 12 months, RR 0.45 (95% CI, 0.24 to 0.83) A vs. C and RR 0.52 (95% CI, 0.28 to 0.93) for B vs. C; 17.3% (14/81) vs. 28.0% (23/82) vs. 46.7% (42/90) at 24 months, RR 0.37 (95% CI 0.22 to 0.63) for A vs. C and 0.60 (95% CI 0.40 to 0.91) for B vs. C; d_2_mfs, mean (SD): 0.7 (2.1) vs. 0.7 (1.8) vs. 1.7 (3.1); p<0.01 for A vs. C and B vs. C | No adverse events detected | A vs. B vs. C: 31% (39/126) vs. 25% (31/124) vs. 21% (26/126) | Fair
Current Report
Agouropoulos et al., 2014 | Cluster RCT (10 clusters) | A: 0.2 ml 0.9% diflurosilane (1000 ppm fluoride) at 6 month intervals; B: Placebo varnish without fluoride at 6 month intervals; All children: Supervised toothbrushing at school with fluoride toothpaste, parental oral health education, and toothbrushing instructions; Interventionist: dental health care professionals | Age, mean (SD): 3.4 (0.8) years; Female: 49.6%; Race: NR; dmfs, mean (SD): 2.8 (6.4); Caries: 37.5%; Daily toothbrushing: NR | Children ages 2 to 5 years attending one of the preselected public preschools.; Excluded: Born outside of Greece, antibiotics within the last 2 weeks | Approached: NR; Eligible: 424; Enrolled: 409 (216 vs. 193); Analyzed: 328 (181 vs. 162) | Greece; Recruitment setting: Public preschools located in medium and low socioeconomic areas of Athens, Greece; Water fluoridation: NR (no fluoridated water in Greece) | “Live.Learn.Laugh” programme by FDI/Unilever and by Ivoclar-Vivadent | 2 years | A vs. B; Caries prevalence (dmfs>0): 63.0% (110/174) vs. 64.8% (100/154) at 1 year, RR 0.97 (95% CI, 0.83 to 1.14); 64.8% (113/174) vs. 65.8% (101/154) at 2 years, RR 0.99 (95% CI, 0.85 to 1.16) dmfs, mean (SD): 5.2 (9.2) vs. 4.9 (8.0) at 1 year; 5.8 (9.5) vs. 5.5 (8.8) at 2 years; Caries increment (change in dmfs), mean (SD): 2.1 (4.5) vs. 2.3 (4.7) from baseline to 1 year; 0.8 (2.2) vs. 1.1 (2.3) from 1 to 2 years; 2.9 (5.3) vs. 3.0 (5.2) from baseline to 2 years | No serious adverse events were noted, in some cases, the smell of the varnish was unpleasant to the younger children | A vs. B: 19.5% (42/216) vs. 20.2% (39/193) | Fair
Anderson et al., 2016; Same as Anderson et al., 2017 | Cluster RCT (23 clusters) | A: 0.25 ml sodium fluoride varnish (5.65 mg Duraphat) on the buccal surface of teeth every 6 months; B: No fluoride varnish; All children: Parental oral health education, toothpaste, and toothbrush at 12, 24, and 36 months; Interventionist: examiner, not specified, or dental assistant | Age: 1 year; Female: 51.5%; Race: NR; ICDAS 1-6: 5.2%; ICDAS 3-6: 0.6%; ICDAS 5-6: 0.2%; Daily toothbrushing: 55.1% | All children born in 2010 and living in the selected areas.; Excluded: Not reported | Approached: NR; Eligible: 4847; Enrolled: 3403; Analyzed: 2536 (1231 vs. 1305) | Sweden; Recruitment setting: Dental clinics located in areas with a multicultural population and families predominantly of medium or low socioeconomic status; Water fluoridation: No added fluoride (concentration “close to zero”) | Stockholm County Council and Karolinska Institute | 2 years | A vs. B; [underlined: Scores at 24 months]; ICDAS 1-2: 6.8% (83/1223) vs. 6.2% (90/1452), RR 1.09 (95% CI 0.82 to 1.46); ICDAS 3-6: 3.4% (42/1223) vs. 4.3% (63/1452), RR 0.79 (95% CI 0.54 to 1.16); ICDAS 5-6: 2.5% (30/1223) vs. 2.5% (37/1452), RR 0.96 (95% CI 0.60 to 1.55); ICDAS 1-6: 10.2% (125/1223) vs. 10.5% (153/1452), RR 0.96 (95% CI 0.77 to 1.20); [underlined: Scores at 36 months]; ICDAS 1-2: 11.5% (141/1231) vs. 9.6% (125/1305), RR 1.20 (95% CI 0.95 to 1.50); ICDAS 3-6: 10.4% (128/1231) vs. 13.7% (179/1305), RR 0.76 (95% CI 0.61 to 0.94); ICDAS 5-6: 6.1% (75/1231) vs. 7.6% (99/1305), RR 0.80 (95% CI 0.60 to 1.07); ICDAS 1-6: 21.9% (269/1231) vs. 23.3% (304/1305), RR 0.94 (95% CI 0.81 to 1.08) | No serious adverse events were noted, a few children vomited directly after application due to the smell, texture, or taste of the varnish | A vs. B: 25.5% (421/1652) vs. 25.5% (446/1751) | Fair
Anderson et al., 2017; Same as Anderson et al., 2016 | Cluster RCT (23 clusters) | A: 0.25 ml sodium fluoride varnish (Duraphat) on the buccal surface of teeth every 6 months; B: No fluoride varnish; All children: Parental oral health education, toothpaste, and toothbrush at 12, 24, and 36 months; Interventionist: examiner, not specified, or dental assistant | Age: 1 year old; Female: 53%; Race: NR; ICDAS 3-6 score: 3%; Daily toothbrushing: 50% | Children enrolled in “Stop Caries Stockholm” (see Anderson et al., 2016) who developed caries between 1 and 3 years of the study period. | Approached: NR; Eligible: 3403; Enrolled: 801; Analyzed: 664 (314 vs. 350) | Sweden; Recruitment setting: Dental clinics located in areas with a multicultural population and families predominantly of medium or low socioeconomic status; Water fluoridation: NR | Stockholm County Council and Karolinska Institute | 3 years | A vs. B; No progression of caries between 12 and 24 months: 71.1% vs. 76.8%, p=0.002; No progression of caries between 24 and 36 months: 79.0% vs. 79.0%, p=0.912; Progression from a healthy or initial stage occlusal surface (ICDAS 0 to 2) to a moderate to an extensive decayed surface (ICDAS 3 to 6): 6.0% vs. 7.3%, p=0.17 | NR | A vs. B: 26.3% (112/426) vs. 6.7% (25/375) | Fair
Jiang et al., 2014 | RCT | A. 5% sodium fluoride varnish (Clinpro White Varnish) at 6 month intervals, also hands-on training on brushing child’s teeth at baseline and toothbrush provided at 6 month intervals; B: Hands-on training on brushing child’s teeth at baseline; toothbrush provided and toothpaste without fluoride (placebo) administered at 6 month intervals; C. No additional intervention; All children: Parental health education at baseline; Interventionist: dental health care professionals | Age, mean (SD): 1.3 (0.3) years; Female: 56%; Race: NR; dmft, mean (SD): 0.03 (0.24); Daily toothbrushing: 12% | Children 8 to 23 months of age; Excluded: Major systemic disease or on long-term medication; not cooperative and refused examination | Approached: 512; Eligible: 483; Enrolled: 450 (149 vs. 152 vs. 149); Analyzed: 415 (137 vs. 144 vs. 134) | China; Recruited from parenting education centers and child day care centers; Water fluoridation: 0.5 ppm | Hong Kong Research Grant Council | 2 years | A vs. B vs. C; Incident cavitated caries lesions: 10.2% (14/137) vs. 6.9% (10/144) vs. 8.2% (11/134); RR 0.68 (95% CI, 0.31 to 1.48) for A vs. B, RR 1.24 (95% CI, 0.59 to 2.64) for A vs. C, RR 0.85 (95% CI, 0.37 to 1.93) for B vs. C; RR 1.48 (95% CI, 0.83 to 2.64) for A vs. B, RR 1.47 (95% CI, 0.82 to 2.64), RR 0.99 (95% CI, 0.52 to 1.88) for B vs. C; Incident cavitated and noncavitated caries lesions: 17.5% (24/137) vs. 11.8% (17/144) vs. 11.9% (16/134); RR dmfs, mean (SD): 0.2 (0.9) vs. 0.1 (0.5) vs. 0.2 (1.0); MD −0.1 (95% CI, −0.27 to 0.07) for A vs. B, MD 0.00 (95% CI, −0.23 to 0.23) for A vs. C, MD −0.1 (95% CI, −0.29 to 0.09) for B vs. C | NR | 8% (23/301) | Good
Latifi-Xhemajli et al., 2019 | RCT | A: 1.5% (7700 ppm) ammonium fluoride (Fluor Protector S) applied every 3 months for 2 years; B: Usual care (control group had no F-varnish applied, unless their parents were advised for their child’s basic oral health care); Interventionist: 2 pediatric dental health care professionals | Age, mean: 21 months; Female: NR; Race: NR; dmfs, mean (SD): 1.1 (2.9); Daily toothbrushing: NR | Children 6 to 30 months with parental permission. | Approached: NR; Eligible: NR; Enrolled: 504 (255 vs. 249); Analyzed: 427 (218 vs. 209) | Kosovo; Recruited from 11 preschools in the Pristina area; Water fluoridation: NR | None | 2 years | A vs. B at endpoint; dmfs, mean (SD): 5.2 (10.5) vs. 10.1 (12.9), p<0.001; dmfs >0: 30.6% vs. 60.0%; RR 1.81 (95% CI, 1.49 to 2.20); ICDAS 5-6: 22.0% vs. 47.7%; RR 1.49 (95% CI, 1.29 to 1.73) | NR | 15.3% (77/504) | Fair
McMahon et al., 2020 | RCT | A: Duraphat 50 mg/mL applied every 6 months; B: Placebo varnish applied every 6 months; All children: daily supervised toothbrushing; Interventionist: dental health care professionals | Age, mean: 3.53 years (SD 0.24); Female: 50%; Race: NR; Caries at baseline: 17%; Mean d_3_mfs: 1.1 (SD 3.5); SIMD 1 (most deprived): 21% | 3 year old children attending their first year of education in nursery schools.; Excluded: Those with contraindications for fluoride varnish, history of bronchial asthma requiring hospitalization, history of allergic episodes requiring hospital admission, showing signs of distress on the day of baseline inspection, or showing signs of verbal or nonverbal reluctance. | Approached: 1,916; Eligible: 1284; Enrolled: 1284 (643 vs. 641); Analyzed: 1150 (577 vs. 573) | Scotland; Recruited from 4 NHS Health Board areas; Water fluoridation: NR | Scottish Government | 2 years | A vs. B; Mean d_3_mfs: 3.5 (5.9) vs. 3.5 (4.9); Worse d_3_mft: 27% (155/577) vs. 32% (181/573), OR 0.80 (95% CI, 0.62 to 1.03); Worse d_3_mfs: 29% (165/577) vs. 34% (193/573), OR 0.79 (95% CI, 0.61 to 1.01); Worse d_3_t: 21% (119/577) vs. 26% (147/573), OR 0.75 (95% CI, 0.57 to 0.99); Worse mt: 5% (28/577) vs. 4% (21/573), OR 1.34 (95% CI, 0.75 to 2.39); Worse ft: 9% (52/577) vs. 11% (65/573), OR 0.77 (95% CI, 0.53 to 1.14); Extraction: 2% (11/577) vs. 1% (8/573), OR 1.37 (95% CI, 0.55 to 3.44); Fillings: 10% (55/577) vs. 11% (61/573), OR 0.88 (95% CI, 0.60 to 1.30); Pulpotomy: 1% (4/577) vs. 1% (3/573), OR 1.33 (95% CI, 0.30 to 5.95); Preformed metal crowns: 2% (13/577) vs. 2% (10/573), OR 1.30 (95% CI, 0.56 to 2.98); Extraction of deciduous teeth: 0% (1/577) vs. 0% (0/573); NNT to prevent 1 child from having a worsening of d_3_mft: 21 | NR | A vs. B: 10% (66/643) vs. 11% (68/641) | Good
Memarpour et al., 2015 | RCT | A: 5% (22,600 ppm) sodium fluoride varnish (DuraShield) and parental oral health education every 4 months; B: Educational pamphlet and motivational oral health counseling every 4 months; C: CPP-ACP twice a day after teeth brushing and information on oral hygiene; D: Dental examination only Interventionist: dental health care professionals | Age, mean (SD): 1.8 (0.6) years; Female: NR; Race: NR; dmft: 0 (excluded); Daily toothbrushing: NR | Children 12 to 36 months, having lived since birth in towns with a similar water fluoridation level (<0.7 ppm) and at least 4 erupted maxillary primary incisors with at least 2 white spot lesions; Excluded: Those who showed signs of cavitated caries or who did not use any oral hygiene methods, fluoride-containing products, or other preventive measures at home or at dental clinics; history of systemic disease, congenital physical or mental disability, oral or dental anomalies or disabilities, a history of drug allergies, allergies to milk protein or benzoate preservatives. | Approached: NR; Eligible: 220; Enrolled: 140; Analyzed: 123 (32 vs. 31 vs. 29 vs. 30) | Iran; Recruitment setting: Public health care centers; Water fluoridation status: <0.7 ppm | Vice-Chancellor of Research of the Shiraz University of Medical Science | 12 months | A vs. B vs. C vs. D dmft at 12 months, mean (SD): 0.3 (0.90) vs. 0.42 (0.99) vs. 0.17 (0.53) vs. 2.0 (2.0); p<0.001 for C vs. others | NR | A vs. B vs. C vs. D: 82.9% (29/35) vs. 88.6% (31/35) vs. 85.7% (30/35) vs. 91.4% (32/35) | Fair
Memarpour et al., 2016 | RCT | A. 5% sodium fluoride varnish at 6 month intervals; parental oral health education and training on proper toothbrushing at baseline; B: Placebo varnish at 6 month intervals; parental oral health education and training on proper toothbrushing at baseline; C. Placebo varnish at 6 month intervals without oral health education or training; Interventionist: dental health care professionals | Age, mean (SD): 1.7 (0.7) years; Female: 46%; Race: NR; Maternal high school diploma or higher: 55%; dmft: 0 (excluded); Daily toothbrushing: 0% | Children age 12 to 24 months; Excluded: Systemic diseases, drug allergies, congenital physical or mental disabilities, oral or dental anomalies or disabilities | Approached: NR; Eligible: NR; Enrolled: 300 (100 vs. 100 vs. 100); Analyzed: 260 (87 vs. 85 vs. 88) at 12 months | Iran; Public health care centers; Water fluoridation: <0.7 ppm | Shiraz University of Medical Sciences | 1 year | A vs. B vs. C; Incident caries (dmft >0); At 4 months: 1.0% (1/95) vs. 2.1% (2/97) vs. 3.1% (3/96); RR 1.96 (95% CI, 0.18 to 21.24) for A vs. B, RR 0.34 (95% CI, 0.04 to 3.18) for A vs. C, RR 0.66 (95% CI, 0.11 to 3.86) for B vs. C; At 8 months: 1.1% (1/93) vs. 3.2% (3/94) vs. 16.0% (15/94); RR 2.97 (95% CI, 0.31 to 28.02) for A vs. B, RR 0.07 (95% CI, 0.01 to 0.50) for A vs. C, RR 0.20 (95% CI, 0.06 to 0.67) for B vs. C; At 12 months: 1.1% (1/87) vs. 4.7% (4/85) vs. 33.0% (29/88); RR 4.09 (95% CI, 0.47 to 35.89) for A vs. B, RR 0.03 (95% CI, 0.005 to 0.25) for A vs. C, RR 0.14 (95% CI, 0.05 to 0.39) for B vs. C | NR | 13% (40/260) | Fair
Muñoz‐Millán et al., 2018 | RCT | A: 0.5 mL of fluoride varnish (Profluorid Varnish®) every 6 months; B: 0.5 mL innocuous placebo varnish every 6 months; All children: twice a year received a toothbrush and a tube of children’s 500 ppm fluoride toothpaste, and supervised daily toothbrushing; Interventionist: not described | Age, mean (SD): 32.9 (6.2) months; Female: 54%; Race: NR; Daily toothbrushing: 100% -Brushing ≥2/day: 72%; Good to fair oral hygiene index: 58%; Visible plaque: 76% | 2 to 3 year old children without cavitated carious lesions or previous dental treatments; Excluded: Children with systemic diseases, disabilities or developmental enamel defects, and those with temporary residences. | Approached: NR; Eligible: NR; Enrolled: 275; Analyzed: 275 (131 vs. 144) | Chile; Mainly low SES, rural preschools; Fluoridation status: none | Comision Nacional de Investigacion | 24 months | A vs. B; Incidence of caries: 45% (59/131) vs. 55.5% (80/144) , p=0.081; Mean (95% CI) incremental caries difference: −0.5 (−1.1 to 0.1); Mean (SD) dmft: 1.6 (2.0) vs. 2.1 (2.6); Preventive fraction: 18.9% (95% CI, −2.9% to 36.2%) | None reported by parents | A vs. B 32% (42/131) vs. 30% (44/144) | Fair
Oliveira et al., 2014; dos Santos et al., 2016 | RCT | A: 5% (22,600 ppm) sodium fluoride varnish at 6 month intervals; B: Placebo varnish; All children: Parental oral health education, free toothpaste and toothbrush at baseline; Interventionist: trained undergraduate or graduate dental students | Age, mean (SD): 2.4 (0.9) years; Female: 47%; Race: NR; d_2_mfs, mean (SD): 0.9 (2.1); d_3_mfs, mean (SD): 0.8 (1.9); Caries: 23.5%; Daily toothbrushing: 80% | 1 to 4 years of age; Excluded: Fluoride application in the previous 6 months, >10 dental surfaces with dentine caries lesions, dental abscess, or systemic disease that could be aggravated by a dental problem. | Approached: NR; Eligible: 310; Enrolled: 200; Analyzed: 181 (89 vs. 92); 123 in nested-cohort (63 vs. 60) | Brazil; Low-income families recruited at a pediatric ambulatory clinic located in a public health center; “Access to fluoridated water”, fluoridation status otherwise not reported | Colgate-Palmolive provided free supplies | 24 months, 4 years for nested-cohort | A vs. B; Children with new dentine caries lesions: 35.9% (32/89) vs. 46.7% (43/92); RR 0.77 (95% CI 0.54 to 1.09), ARD 11% (95% CI −3.5 to 25.0%); d_2_mfs, mean (SD): 2.0 (4.0) vs. 2.8 (4.2); difference −0.8 (95% CI, −1.9 to 0.4); d_3_mfs, mean (SD): 1.8 (3.9) vs. 2.5 (4.0); difference −0.7 (95% CI, −2.0 to 0.4) | 2 complaints reported; 1 child’s mother was bothered by the color of the child’s teeth after fluoride varnish application and 1 child’s mother reported the child complained of a burning sensation in her mouth on the first day of placebo varnish application; No withdrawals due to AEs, and of 11 (8 vs. 3) children with asthma at baseline none reported any Aes; [underlined: Followup for subgroup evaluated at 4 years (n=123)]; Fluorosis: 27% (17/63) vs. 35% (21/60); p=0.44; Esthetically objectionable fluorosis: 4.8% (3/63) vs. 8.3% (5/60); p=0.48 | A vs. B: 11% (11/100) vs. 8% (8/100) | Good
Tickle et al., 2016; Tickle et al., 2017 | RCT | A: 22,600 ppm fluoride varnish at 6 month intervals; also provided toothbrush and 50 mL tube of 1,450 ppm fluoride toothpaste; B: No fluoride intervention; All children: Parental oral health education every 6 months; Interventionist: dental health care professionals | Age, mean (SD): 3.1 (0.53) years; Female: 54%; Race: NR; dmft: 0 (excluded); Daily toothbrushing: NR | 2 to 3 years of age; Excluded: Dentin caries, history of fillings or extractions due to caries, fissure sealants on primary molar teeth, and/or a history of severe allergic reactions requiring hospitalization. | Approached: 2455; Eligible: 1248; Enrolled: 1248; Analyzed: 1096 (549 vs. 547) | Ireland; National Health Services dental practices in Norther Ireland; Fluoridation status not reported (national policy of mandatory water fluoridation at 0.6 to 0.8 ppm) | National Institute for Health Research Health Technology Assessment program | 3 years | A vs. B; Converted from caries free to caries active: 34% (187/549) vs. 39% (213/547); adjusted OR 0.81 (95% CI, 0.64 to 1.04); p=0.11; d_3_mfs affected by caries in children who developed caries, mean (SD): 7.18 (7.99) vs. 9.61 (8.75); adjusted mean difference −2.29 (95% CI, −3.96 to −0.63); p=0.007; Teeth extraction, among those developing caries: 11.2% (11/187) vs. 13.1% (28/547) | A vs. B; Any AE: 7.2% (45/624) vs. 5.9% (37/624); RR 1.22 (95% CI 0.80 to 1.85) | A vs. B: 12% (75/624) vs. 12% (77/624) | Fair

* See Appendix A4 for full citations of included studies.

† Restricted to aboriginal children, including 14 non-randomized children who received fluoride varnish.

‡ Includes 102 non-randomized children (88 nonaboriginal) who received fluoride varnish (or subgroup from this population).

Abbreviations: AE=adverse event; CI=confidence interval; CPP-ACP=casein phosphopeptide-amorphous calcium phosphate; ICDAS=international caries detection and assessment system; MD=mean difference; NR=not reported; NS=not significant; OR=odds ratio; RCT=randomized controlled trial; RR=relative risk; SD=standard deviation; SE=standard error; UCSF=University of California, San Francisco.

Appendix B8 Trials of Xylitol for the Prevention of Dental Caries

Author, year^*^ | Type of study | Interventions | Population characteristics | Eligibility criteria | Number approached, eligible, enrolled, analyzed | Country Setting | Sponsor | Duration of followup | Outcomes | Adverse events/harms | Attrition | Quality rating
Prior report
Oscarson et al., 2006 | RCT | A: One 0.48 gram xylitol tablet at bedtime after brushing for 6 months; then one tablet twice daily to age 3 years and 6 months; B: No tablets | Age: 25 vs. 25 months; Female: 49% vs. 46% (p>0.05); Non-white: NR Seldom/irregular tooth-brushing: 7% vs. 3% (p>0.05); High (>100 CFU) mutans streptococci counts: 11% vs. 6% (p>0.05); Daily sugary soft drinks: 17% vs. 27% (p>0.05); Daily sugars sweets: 0% vs. 2% (p>0.05) | Healthy 2 year old children.; Excluded: Children with severe disabilities or uncooperative for oral exam | Number approached: NR; Number eligible: NR; Number enrolled: 132 (66 vs. 66); Number analyzed: 115 (55 vs. 63) | Sweden Recruitment setting: Public dental clinic Water fluoridation status: Not reported | County of Vasterbotten, The Patent Revenue Fund for Dental Prophylaxis and Swedish Dental Society | 2 years | A vs. B; Dental caries: 18% (10/55) vs. 25% (16/63), OR 0.65 (95% CI 0.27 to 1.59); dmfs, mean: 0.38 vs. 0.80 (p>0.05) Absolute reduction in caries increment: 0.42; Reduction in caries increment: 52% | A vs. B; Withdrawals due to adverse events: NR | A vs. B: 16.7% (11/66) vs. 4.5% (3/66) | Fair
Zhan et al., 2012 | RCT | A: Xylitol wipes, two at a time, three times per day (estimated daily dosage 4.2 g) every 3 months; B: Placebo wipes | Age: 6 to 35 months vs. 6 to 35 months; Female: 36% vs. 40%; Non-white: 90% vs. 95%; Brush teeth daily: 68% vs. 68%; Use fluoride toothpaste: 36% vs. 27% | Mothers with healthy children aged 6 to 35 months; mothers were primary care givers (>8 hours daily) and with minimum of one active caries lesion within a year; no children with oral or systemic diseases; no mothers or children who took antibiotics or other medication affecting oral flora in previous 3 months. | Number approached: 82; Number eligible: 57; Number enrolled: 44 (22 vs. 22); Number analyzed: 44 (22 vs. 22) ITT; 37 (20 vs. 17) on-treatment analysis | United States Recruitment setting: University pediatric clinic Water fluoridation status: Not reported | California Society of Pediatric Dentistry Foundation, a Graduate Scientific Research Award from American Academy of Pediatric Dentistry, and NIH/NIDCR grant U54 DEO19285 | 1 year | A vs. B; Mean new decayed surfaces: 0.05 vs. 0.53 (p=0.01); New caries lesions at 1 year: 5% vs. 40% (p=0.03); NNT 3; ITT analysis of new caries lesions at 1 year: 5% vs. 32%; RR 0.14 (95% CI 0.02 to 1.07); NNT 4; Absolute reduction in caries increment: 0.48; Reduction in caries increment: 91% | None | A vs. B 9% (2/22) vs. 23% (5/22) | Fair

* See Appendix A4 for full citations of included studies.

Abbreviations: CFU=colony-forming unit; CI=confidence interval; ITT=intention to treat; NIDCR=National Institute of Dental and Craniofacial Research; NIH=National Institutes of Health; NNT=number needed to treat; NR=not reported; OR=odds ratio; RCT=randomized controlled trial; RR=relative risk.

Appendix B9 Systematic Review of Fluorosis Due to Fluoride Supplements

Author, year* | Databases searched, date of last search | Number and type of studies | Methods for rating methodological quality of primary studies | Methods for synthesizing results of primary studies | Number of patients (treatment and control) | Adverse events | Quality rating
Ismail and Hasson, 2008 | MEDLINE: 1966-June 2006; Cochrane: up to 2nd quarter 2006; EMBASE: 1974-2006 | 5 observational studies | Cochrane Handbook of Systematic Reviews | Qualitative analyses only, due to high heterogeneity of subjects, outcomes, and duration of followup | Not reported | 5 observational studies reported fluorosis outcomes associated with early childhood use of fluoride supplementation; - All studies found an association between fluoride supplementation in early childhood and risk of fluorosis; - 1 study (n=383) found OR increased by 84% per year of use of fluoride supplements (95% CI, 1.4 to 2.5); - 1 study (n=188) OR 10.3 in children started on fluoride supplements within the first 2 years of life (95% CI, 1.9 to 61.6); - Largest study (n=3978) found slightly increased risk that ranged | Good

Appendix B10 Quality Ratings of Systematic Reviews

Author, year* | 1. Did the research questions and inclusion criteria for the review include the components of PICO? | 2. Did the report of the review contain an explicit statement that the review methods were established prior to the conduct of the review and did the report justify any significant deviations from the protocol? (Critical Domain) | 3. Did the review authors explain their selection of the study designs for inclusion in the review? | 4. Did the review authors use a compre-hensive literature search strategy? (Critical Domain) | 5. Did the review authors perform study selection in duplicate? | 6. Did the review authors perform data extraction in duplicate? | 7. Did the review authors provide a list of excluded studies and justify the exclusions? (Critical Domain) | 8. Did the review authors describe the included studies in adequate detail? | 9a. Did the review authors use a satisfactory technique for assessing the ROB in individual studies that were included in the review? (Critical Domain) [underlined: RCTs] | 9b. Did the review authors use a satisfactory technique for assessing the RoB in individual studies that were included in the review? (Critical Domain) [underlined: NRSI] | 10. Did the review authors report on the sources of funding for the studies included in the review? | 11a. If meta-analysis was performed did the review authors use appropriate methods for statistical combination of results? (Critical Domain) | 11b. If meta-analysis was performed did the review authors use appropriate methods for statistical combination of results? (Critical Domain) [underlined: NRSI] | 12. If meta-analysis was performed, did the review authors assess the potential impact of RoB in individual studies on the results of the meta-analysis or other evidence synthesis? | 13. Did the review authors account for RoB in individual studies when interpreting/discussing the results of the review? (Critical Domain) | 14. Did the review authors provide a satisfactory explanation for, and discussion of, any hetero-geneity observed in the results of the review? | 15. If they performed quantitative synthesis did the review authors carry out an adequate investigation of publication bias (small study bias) and discuss its likely impact on the results of the review? (Critical Domain) | 16. Did the review authors report any potential sources of conflict of interest, including any funding they received for conducting the review? | Overall rating
Ismail and Hasson, 2008 | Yes | Yes | Yes | Yes | Not reported | Not reported | No | Yes | Yes | Yes | No | Not applicable | Not applicable | Not applicable | No | No | No | Yes | Good