# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Database: OVID MEDLINE®

Search Strategy:

1. exp Dental Caries/ (43963)
2. limit 1 to (“newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)”) (8321)
3. limit 2 to yr=“2014 -Current” (1368)
4. limit 3 to (meta analysis or “systematic review”) (36)
5. from 4 keep 11,13,18,20-22,24,31 (8)
6. limit 3 to randomized controlled trial (121)
7. from 6 keep 1,3-4,6-9,13,19,22,24-26,29,34,38,42-43,46,48-49,52,56,58-59,61,63-64,66,68,72-74,77,79,83-85,92-94,101,107-108,112,115-117 (48)
8. 5 or 7 (56)

### Database: EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

1. dental caries.mp. [mp=title, short title, abstract, full text, keywords, caption text] (113)
2. limit 1 to full systematic reviews (87)
3. 2 and prevention.mp. [mp=title, short title, abstract, full text, keywords, caption text] (62)
4. 3 and children.mp. [mp=title, short title, abstract, full text, keywords, caption text] (51)
5. from 4 keep 1,6,8,23,30,32-35,41-42 (11)

## Appendix A2 Inclusion and Exclusion Criteria

Category | Included | Excluded
Populations | Asymptomatic children younger than age 5 years | Animal studies, adults, children older than preschool age (≥5 years), and children who are symptomatic for dental caries
Interventions | KQs 1–3 (screening) and KQ 1 (preventive interventions): Oral screening and risk factor assessment performed by a primary care clinician; KQs 2, 3, 5 (preventive interventions): Parent/caregiver/guardian oral health education and/or referral to dental health care provider; KQs 4, 5 (preventive interventions): Preventive interventions: oral fluoride supplementation, topical fluoride application, silver diamine fluoride, or xylitol (including xylitol given to the child or mother) | KQs 1–3 (screening) and KQ 1 (preventive interventions): Community- or school-based screening interventions; KQs 2, 3 (preventive interventions): Education or referral not performed in primary care settings; education or referral for existing caries; KQs 4, 5 (preventive interventions): Interventions not available for preschool children or not available in the United States; treatment for existing caries
Comparisons | No intervention or placebo | Active treatment
Outcomes | KQs 1, 3 (screening) and KQs 2–5 (preventive interventions): Dental caries, morbidity, quality of life, and function; KQ 2 (screening) and KQ 1 (preventive interventions): Diagnostic accuracy and measures of risk prediction; KQ 3 (screening) and KQ 5 (preventive interventions): Dental fluorosis, tooth staining, emotional stress, acute toxicity, and other associated complications | Cost effectiveness
Setting | Applicable to U.S. primary care practice | Schools; dental clinics providing interventions not available in primary care settings
Study Design | KQ 1 (screening) and KQs 2–4 (preventive interventions): Randomized, controlled trials; nonrandomized, controlled clinical trials; and cohort studies; KQ 2 (screening) and KQ 1 (preventive interventions): Studies of diagnostic accuracy or risk prediction; KQ 3 (screening) and KQ 5 (preventive interventions): Randomized, controlled trials; nonrandomized, controlled clinical trials; cohort studies or case-control studies (if data from randomized trials are lacking); and systematic reviews | KQs 1, 2 (screening) and KQs 1–4 (preventive interventions): Case-control studies; uncontrolled intervention studies; All KQs: Opinions, editorials, or case reports
Study Quality | Good or fair quality | Poor quality

## Appendix A3 Literature Flow Diagram

Abbreviations: CQ=contextual question; KQ=key question.

*Identified from reference lists, hand searching, suggested by experts, etc.

^†^We included 36 publications of 33 studies. See Appendix A5 for the list of excluded studies and Appendix A2 for the list of exclusion criteria.

^‡^Studies that provided data and contributed to the body of evidence were considered ‘included’.

^§^Studies may have contributed data for more than one key question.

The literature flow diagram depicts the search and selection of articles. The diagram shows that 2674 citations were reviewed that were identified through literature database searches and other sources such as reference lists, hand searching, and suggestions from experts. 368 full text articles were reviewed for relevance to Key Questions and the Contextual Question after we excluded 2306 abstracts that did not meet inclusion criteria. Additionally, 34 full text articles were reviewed from the prior reviews’ included articles. From the full text articles reviewed, 17 full text articles from the prior reviews’ included studies were excluded for the follow reasons: 4 for ineligible population, 1 for ineligible intervention, 4 for active comparison, and 8 for poor quality study. Also from the full text articles reviewed, 349 articles were excluded for the following reasons: 19 for background information only, 139 for ineligible population, 55 ineligible intervention, 24 for ineligible outcome, 2 for ineligible setting, 80 for ineligible publication type, 1 for not applicable to U.S. population, 8 for foreign language, 13 for outdated and/or non-systematic review, 5 for ineligible comparison, and 3 used for Contextual Question only. We included a total of 33 studies in 36 publications that provided data and contributed to the body of evidence. Studies may have contributed data for more than one Key Question. For the screening Key Questions, 0 articles addressed Key Question 1, 3 articles addressed Key Question 2, and 0 articles addressed Key Question. For the prevention Key Questions, 1 article addressed Key Question 1, 1 article addressed Key Question 2, 6 articles addressed Key Question 3, 22 studies in 24 articles addressed Key Question 4, and 6 studies in 8 articles addressed Key Question 5.

## Appendix A4 List of Included Studies

1 Agouropoulos A, Twetman S, Pandis N, . Caries-preventive effectiveness of fluoride varnish as adjunct to oral health promotion and supervised tooth brushing in preschool children: a double-blind randomized controlled trial. J Dent. 2014 Oct;42(10):1277–83. doi: 10.1016/j.jdent.2014.07.020. PMID: 25123352.25123352
2 Anderson M, Dahllof G, Soares FC, . Impact of biannual treatment with fluoride varnish on tooth-surface-level caries progression in children aged 1-3 years. J Dent. 2017 Oct;65:83–8. doi: 10.1016/j.jdent.2017.07.009. PMID: 28739318.28739318
3 Anderson M, Dahllof G, Twetman S, . Effectiveness of early preventive intervention with semiannual fluoride varnish application in toddlers living in high-risk areas: A stratified cluster-randomized controlled trial. Caries Res. 2016;50(1):17–23. doi: 10.1159/000442675. PMID: 26795957.26795957
4 Basir L, Rasteh B, Montazeri A, . Four-level evaluation of health promotion intervention for preventing early childhood caries: a randomized controlled trial. BMC Public Health. 2017 10 02;17(1):767. doi: 10.1186/s12889-017-4783-9. PMID: 28969655.28969655
5 Beil H, Rozier RG, Preisser JS, . Effect of early preventive dental visits on subsequent dental treatment and expenditures. Med Care. 2012;50(9):749–56. doi: 10.1097/MLR.0b013e3182551713. PMID: 22525611.22525611
6 Beil H, Rozier RG, Preisser JS, . Effects of early dental office visits on dental caries experience. Am J Public Health. 2014;104(10):1979–85. doi: 10.2105/AJPH.2013.301325.24134364
7 Blackburn J, Morrisey MA, Sen B. Outcomes associated with early preventive dental care among Medicaid-enrolled children in Alabama. JAMA Pediatr. 2017;171(4):335–41. doi: 10.1001/jamapediatrics.2016.4514.28241184
8 Dos Santos AP, Malta MC, de Marsillac MW, . Fluoride varnish applications in preschoolers and dental fluorosis in permanent incisors: results of a nested-cohort study within a clinical trial. Pediatr Dent. 2016 Oct 15;38(5):414–8. PMID: 28206898.28206898
9 Frostell G, Birkhed D, Edwardsson S, . Effect of partial substitution of invert sugar for sucrose in combination with Duraphat treatment on caries development in preschool children: the Malmo Study. Caries Res. 1991;25(4):304–10. doi: 10.1159/000261381. PMID: 1913770.1913770
10 Hamberg L. Controlled trial of fluoride in vitamin drops for prevention of caries in children. Lancet. 1971 Feb 27;1(7696):441–2. PMID: 4100412.4100412
11 Hennon DK, Stookey GK, Muhler JC. Prophylaxis of dental caries: Relative effectiveness of chewable fluoride preparations with and without added vitamins. J Pediatr. 1972;80(6):1018–21. PMID: 5026023.5026023
12 Hu D, Wan H, Li S. The caries-inhibiting effect of a fluoride drop program: a 3-year study on Chinese kindergarten children. Chin J Dent Res. 1998;1(3):17–20. PMID: 10557167.10557167
13 Ismail AI, Hasson H. Fluoride supplements, dental caries and fluorosis: a systematic review. J Am Dent Assoc. 2008;139(11):1457–68. doi: 10.14219/jada.archive.2008.0071. PMID: 18978383.18978383
14 Jiang EM, Lo EC, Chu CH, . Prevention of early childhood caries (ECC) through parental toothbrushing training and fluoride varnish application: a 24-month randomized controlled trial. J Dent. 2014 Dec;42(12):1543–50. doi: 10.1016/j.jdent.2014.10.002. PMID: 25448437.25448437
15 Jiang H, Bian Z, Tai BJ, . The effect of a bi-annual professional application of APF foam on dental caries increment in primary teeth: 24-month clinical trial. J Dent Res. 2005;84(3):265–8. doi: 10.1177/154405910508400311. PMID: 15723868.15723868
16 Kranz AM, Rozier RG, Preisser JS, . Preventive services by medical and dental providers and treatment outcomes. J Dent Res. 2014;93(7):633–8. doi: 10.1177/0022034514536731.24891593
17 Kranz AM, Rozier RG, Preisser JS, . Comparing medical and dental providers of oral health services on early dental caries experience. Am J Public Health. 2014 Jul;104(7) doi: 10.2105/ajph.2014.301972. PMID: 24832418.24832418
18 Latifi-Xhemajli B, Begzati A, Veronneau J, . Effectiveness of fluoride varnish four times a year in preventing caries in the primary dentition: a 2 year randomized controlled trial. Community Dent Health. 2019 Aug 29;36(2):190–4. doi: 10.1922/CDH_4453Begzati05. PMID: 31436925.31436925
19 Lawrence HP, Binguis D, Douglas J, . A 2-year community-randomized controlled trial of fluoride varnish to prevent early childhood caries in Aboriginal children. Community Dent Oral Epidemiol. 2008;36(6):503–16. doi: 10.1111/j.1600-0528.2008.00427.x. PMID: 18422711.18422711
20 Lin YT, Tsai CL. Comparative anti-caries effects of tablet and liquid fluorides in cleft children. J Clin Dent. 2000 2000;11(4):104–6. PMID: 11460274.11460274
21 MacRitchie HM, Longbottom C, Robertson M, . Development of the Dundee Caries Risk Assessment Model (DCRAM)--risk model development using a novel application of CHAID analysis. Community Dent Oral Epidemiol. 2012 Feb;40(1):37–45. doi: 10.1111/j.1600-0528.2011.00630.x. PMID: 21838824.21838824
22 Margolis FJ, Macauley J, Freshman E. The effects of measured doses of fluoride. A five-year preliminary report. Am J Dis Child. 1967;113(6):670–2. PMID: 4381737.4381737
23 Margolis FJ, Reames HR, Freshman E, . Flouride. Ten-year prospective study of deciduous and permanent dentition. Am J Dis Child. 1975;129(7):794–800. PMID: 1096595.1096595
24 McMahon AD, Wright W, Anopa Y, . Fluoride Varnish in Nursery Schools: A Randomised Controlled Trial - Protecting Teeth @3. Caries Res. 2020 Sep 10;54(3):274–82. doi: 10.1159/000509680. PMID: 32911474.32911474
25 Memarpour M, Dadaein S, Fakhraei E, . Comparison of oral health education and fluoride varnish to prevent early childhood caries: A randomized clinical trial. Caries Res. 2016;50(5):433–42. doi: 10.1159/000446877. PMID: 27504845.27504845
26 Memarpour M, Fakhraei E, Dadaein S, . Efficacy of fluoride varnish and casein phosphopeptide-amorphous calcium phosphate for remineralization of primary teeth: a randomized clinical trial. Med Princ Pract. 2015;24(3):231–7. doi: 10.1159/000379750. PMID: 25895964.25895964
27 Munoz-Millan P, Zaror C, Espinoza-Espinoza G, . Effectiveness of fluoride varnish in preventing early childhood caries in rural areas without access to fluoridated drinking water: A randomized control trial. Community Dent Oral Epidemiol. 2018 02;46(1):63–9. doi: 10.1111/cdoe.12330. PMID: 28850712.28850712
28 Oliveira BH, Salazar M, Carvalho DM, . Biannual fluoride varnish applications and caries incidence in preschoolers: a 24-month follow-up randomized placebo-controlled clinical trial. Caries Res. 2014;48(3):228–36. doi: 10.1159/000356863. PMID: 24481085.24481085
29 Oscarson P, Lif Holgerson P, Sjöström I, . Influence of a low xylitol-dose on mutans streptococci colonisation and caries development in preschool children. Eur Arch Paediatr Dent. 2006;7(3):142–7. doi: 10.1007/bf03262555. PMID: 17140543.17140543
30 Pierce KM, Rozier RG, Vann WF, Jr. Accuracy of pediatric primary care providers’ screening and referral for early childhood caries. Pediatrics. 2002;109(5):E82. doi: 10.1542/peds.109.5.e82. PMID: 11986488.11986488
31 Sen B, Blackburn J, Kilgore ML, . Preventive Dental Care and Long-Term Dental Outcomes among ALL Kids Enrollees. Health Serv Res. 2016;51(6):2242–57. doi: 10.1111/1475-6773.12469.26927421
32 Serwint JR, Mungo R, Negrete VF, . Child-rearing practices and nursing caries. Pediatrics. 1993;92(2):233–7. PMID: 8337022.8337022
33 Slade GD, Bailie RS, Roberts-Thomson K, . Effect of health promotion and fluoride varnish on dental caries among Australian Aboriginal children: results from a community-randomized controlled trial. Community Dent Oral Epidemiol. 2011;39(1):29–43. doi: 10.1111/j.1600-0528.2010.00561.x. PMID: 20707872.20707872
34 Tickle M, O’Neill C, Donaldson M, . A randomised controlled trial to measure the effects and costs of a dental caries prevention regime for young children attending primary care dental services: the Northern Ireland Caries Prevention In Practice (NIC-PIP) trial. Health Technol Assess. 2016 09;20(71):1–96. doi: 10.3310/hta20710. PMID: 27685609.27685609
35 Tickle M, O’Neill C, Donaldson M, . A randomized controlled trial of caries prevention in dental practice. J Dent Res. 2017 Jul;96(7):741–6. doi: 10.1177/0022034517702330. PMID: 28375708.28375708
36 Weintraub JA, Ramos-Gomez F, Jue B, . Fluoride varnish efficacy in preventing early childhood caries. J Dent Res. 2006;85(2):172–6. doi: 10.1177/154405910608500211. PMID: 16434737.16434737
37 Zhan L, Cheng J, Chang P, . Effects of xylitol wipes on cariogenic bacteria and caries in young children. J Dent Res. 2012;91(7 Suppl):85S–90S. doi: 10.1177/0022034511434354. PMID: 22699675.22699675

## Appendix A5 List of Excluded Studies With Reasons for Exclusion

Exclusion key: 2: background information only; 3: contextual information only; 4: ineligible population; 5: ineligible intervention; 6: ineligible publication type; 7: ineligible outcome; 8: ineligible setting; 9: not applicable to U.S. population; 10: non-English paper; 11: outdated and/or non-systematic review; 12: ineligible comparison; 13: poor-quality study.

### Full-text papers excluded from the prior review

1 Alamoudi NM, Hanno AG, Masoud MI, . Effects of xylitol on salivary mutans streptococcus, plaque level, and caries activity in a group of Saudi mother-child pairs. An 18-month clinical trial. Saudi Med J. 2012;33(2):186–92. PMID: 22327761. Exclusion: 12.22327761
2 Autio-Gold JT, Courts F. Assessing the effect of fluoride varnish on early enamel carious lesions in the primary dentition. J Am Dent Assoc. 2001;132(9):1247–53. PMID: 1665349. Exclusion: 4.11665349
3 Chu CH, Lo ECM, Lin HC. Effectiveness of silver diamine fluoride and sodium fluoride varnish in arresting dentin caries in Chinese pre-school children. J Dent Res. 2002;81(11):767–70. doi: 10.1177/0810767. PMID: 12407092. Exclusion: 412407092
4 Davies GM, Duxbury JT, Boothman NJ, . Challenges associated with the evaluation of a dental health promotion programme in a deprived urban area. Community Dent Health. 2007;24(2):117–21. PMID: 17615828. Exclusion: 13.17615828
5 Davies GM, Duxbury JT, Boothman NJ, . A staged intervention dental health promotion programme to reduce early childhood caries. Community Dent Health. 2005;22(2):118–22. PMID: 15984138. Exclusion: 13.15984138
6 Du MQ, Tai BJ, Jiang H, . A two-year randomized clinical trial of chlorhexidine varnish on dental caries in Chinese preschool children. J Dent Res. 2006;85(6):557–9. doi: 10.1177/154405910608500615. PMID: 16723655. Exclusion: 4.16723655
7 Grodzka K, Augustyniak L, Budny J, . Caries increment in primary teeth after application of Duraphat fluoride varnish. Community Dent Oral Epidemiol. 1982 Apr;10(2):55–9. doi: 10.1111/j.1600-0528.1982.tb00362.x. PMID: 6952970. Exclusion: 13.6952970
8 Holm AK. Effect of fluoride varnish (Duraphat) in preschool children. Community Dent Oral Epidemiol. 1979 Oct;7(5):241–5. doi: 10.1111/j.1600-0528.1979.tb01225.x. PMID: 295702. Exclusion: 13.295702
9 Kovari H, Pienihäkkinen K, Alanen P. Use of xylitol chewing gum in daycare centers: a follow-up study in Savonlinna, Finland. Acta Odontol Scand. 2003;61(6):367–70. doi: 10.1080/00016350310007806. PMID: 14960009. Exclusion: 12.14960009
10 Kressin NR, Nunn ME, Singh H, . Pediatric clinicians can help reduce rates of early childhood caries: effects of a practice based intervention. Med Care. 2009;47(11):1121–8. doi: 10.1097/MLR.0b013e3181b58867. PMID: 19786919. Exclusion: 13.19786919
11 Lopez L, Berkowitz R, Spiekerman C, . Topical antimicrobial therapy in the prevention of early childhood caries: a follow-up report. Pediatr Dent. 2002 May-Jun;24(3):204–6. PMID: 12064491. Exclusion: 5.12064491
12 Milgrom P, Ly KA, Tut OK, . Xylitol pediatric topical oral syrup to prevent dental caries: a double-blind randomized clinical trial of efficacy. Arch Pediatr Adolesc Med. 2009;163(7):601–7. doi: 10.1001/archpediatrics.2009.77. PMID: 19581542. Exclusion: 12.19581542
13 Petersson LG, Twetman S, Pakhomov GN. The efficiency of semiannual silane fluoride varnish applications: a two-year clinical study in preschool children. J Public Health Dent. 1998 Winter;58(1):57–60. doi: 10.1111/j.1752-7325.1998.tb02991.x. PMID: 9608447. Exclusion: 13.9608447
14 Seki M, Karakama F, Kawato T, . Effect of xylitol gum on the level of oral mutans streptococci of preschoolers: block-randomised trial. Int Dent J. 2011;61(5):274–80. doi: 10.1111/j.1875-595X.2011.00073.x. PMID: 21995376. Exclusion: 13.21995376
15 Twetman S, Petersson LG, Pakhomov GN. Caries incidence in relation to salivary mutans streptococci and fluoride varnish applications in preschool children from low- and optimal fluoride areas. Caries Res. 1996;30(5):347–53. PMID: 8877088. Exclusion: 13.8877088
16 Weinstein P, Riedy C, Kaakko T, . Equivalence between massive versus standard fluoride varnish treatments in high caries children aged 3-5 years. Eur J Paediatr Dent. 2001;2(2):91–6. Exclusion: 4.
17 Weinstein P, Spiekerman C, Milgrom P. Randomized equivalence trial of intensive and semiannual applications of fluoride varnish in the primary dentition. Caries Res. 2009;43(6):484–90. doi: 10.1159/000264686. PMID: 20016179. Exclusion: 12.20016179

### Full-text papers excluded from update searches

1 Agouropoulos A, Birpou E, Twetman S, . Validation of Three Caries Risk Assessment Tools for Preschool Children From Areas with High Caries Prevalence. Pediatr Dent. 2019 Sep 15;41(5):391–9. PMID: 31648671. Exclusion: 5.31648671
2 Ahovuo-Saloranta A, Forss H, Hiiri A, . Pit and fissure sealants versus fluoride varnishes for preventing dental decay in the permanent teeth of children and adolescents. Cochrane Database Syst Rev. 2016 Jan 18(1):CD003067. doi: 10.1002/14651858.CD003067.pub4. PMID: 26780162. Exclusion: 4.26780162
3 Ahovuo-Saloranta A, Forss H, Walsh T, . Sealants for preventing dental decay in the permanent teeth. Cochrane Database Syst Rev. 2013 Mar 28(3):CD001830. doi: 10.1002/14651858.CD001830.pub4. PMID: 23543512. Exclusion: 4.23543512
4 Ahovuo-Saloranta A, Forss H, Walsh T, . Pit and fissure sealants for preventing dental decay in permanent teeth. Cochrane Database Syst Rev. 2017 07 31;7:CD001830. doi: 10.1002/14651858.CD001830.pub5. PMID: 28759120. Exclusion: 4.28759120
5 Al Dehailan L, Martinez-Mier EA. Prevention program including fluoride varnish and 1450-ppm fluoride toothpaste targeting young children in clinical setting in UK did not Stop sental caries from developing but slowed lesion progression. J Evid Based Dent Pract. 2019 06;19(2):207–9. doi: 10.1016/j.jebdp.2019.05.013. PMID: 31326059. Exclusion: 6.31326059
6 Al-Batayneh OB, Bani Hmood EI, Al-Khateeb SN. Assessment of the effects of a fluoride dentifrice and GC Tooth Mousse on early caries lesions in primary anterior teeth using quantitative light-induced fluorescence: a randomised clinical trial. Eur Arch Paediatr Dent. 2020 Feb;21(1):85–93. doi: 10.1007/s40368-019-00451-7. PMID: 31134470. Exclusion: 5.31134470
7 Alamoudi NM, Hanno AG, Almushayt AS, . Early prevention of childhood caries with maternal xylitol consumption. Saudi Med J. 2014 Jun;35(6):592–7. PMID: 24888659. Exclusion: 5.24888659
8 Alamoudi NM, Hanno AG, Sabbagh HJ, . Impact of maternal xylitol consumption on mutans streptococci, plaque and caries levels in children. J Clin Pediatr Dent. 2012 Winter;37(2):163–6. doi: 10.17796/jcpd.37.2.261782tq73k4414x. PMID: 23534323. Exclusion: 4.23534323
9 Alayadi H, Sabbah W, Bernabe E. Effectiveness of school dental screening on dental visits and untreated caries among primary schoolchildren: study protocol for a cluster randomised controlled trial. Trials. 2018 Apr 13;19(1):224. doi: 10.1186/s13063-018-2619-2. PMID: 29653545. Exclusion: 6.29653545
10 Alrashdi M, Mendez MJC, Farokhi MR. A randomized clinical trial preventive outreach targeting dental caries and oral-health-related quality of life for refugee children. International journal of environmental research and public health. 2021;18(4):1–10. PMID: CN-02245225. Exclusion: 4.
11 Alves APS, Rank R, Vilela JER, . Efficacy of a public promotion program on children’s oral health. J Pediatr (Rio J). 2018 Sep - Oct;94(5):518–24. doi: 10.1016/j.jped.2017.07.012. PMID: 28958799. Exclusion: 6.28958799
12 American Academy of Pediatric D. Guideline on fluoride therapy. Pediatr Dent. 2013 Sep-Oct;35(5):E165–8. PMID: 24290545. Exclusion: 6.24290545
13 American Academy Of Pediatric Dentistry. Guideline on periodicity of examination, preventive dental services, anticipatory guidance/counseling, and oral treatment for infants, children, and adolescents. Pediatr Dent. 2013 Sep-Oct;35(5):E148–56. PMID: 24290543. Exclusion: 6.24290543
14 American Academy of Pediatric Dentistry. Periodicity of examination, preventive dental services, anticipatory guidance/counseling, and oral treatment for infants, children, and adolescents. Pediatr Dent. 2017;39:188–96. Exclusion: 2.29179356
15 Anonymous. Systematic review and meta-analysis of randomised controlled trials on the effectiveness of school-based dental screening versus no screening on improving oral health in children. Br Dent J. 2017 May 12;222(9):675. doi: 10.1038/sj.bdj.2017.403. PMID: 28496244. Exclusion: 6.28496244
16 Anttonen V, Halunen I, Päkkilä J, . A practice-based study on the effect of a short sucrose/xylitol exposure on survival of primary teeth caries free. Int J Paediatr Dent. 2012;22(5):356–62. doi: 10.1111/j.1365-263X.2011.01205.x. PMID: 22211678. Exclusion: 4.22211678
17 Autio-Gold J. Recommendations for fluoride varnish use in caries management. Dent Today. 2008 Jan;27(1):64–7. PMID: 18240633. Exclusion: 2.18240633
18 B T. A two-year study of 40% chlorhexidine varnish on the prevention of dental caries. J Oral Sci Res. 2003;19:521–3. Exclusion: 10.
19 Bader JD, Rozier RG, Lohr KN, . Physicians’ roles in preventing dental caries in preschool children: a summary of the evidence for the U.S. Preventive Services Task Force. Am J Prev Med. 2004 May;26(4):315–25. PMID: 15110059. Exclusion: 2.15110059
20 Bader JD, Vollmer WM, Shugars DA, . Results from the Xylitol for adult caries trial (X-ACT). J Am Dent Assoc. 2013 Jan;144(1):21–30. doi: 10.14219/jada.archive.2013.0010. PMID: 23283923. Exclusion: 4.23283923
21 Bakhshandeh A, Ekstrand K. Infiltration and sealing versus fluoride treatment of occlusal caries lesions in primary molar teeth. 2-3 years results. Int J Paediatr Dent. 2015 Jan;25(1):43–50. doi: 10.1111/ipd.12096. PMID: 24460688. Exclusion: 5.24460688
22 Batra M, Shah AF, Virtanen JI. Integration of oral health in primary health care through motivational interviewing for mothers of young children: A pilot study. J Indian Soc Pedod Prev Dent. 2018 Jan-Mar;36(1):86–92. doi: 10.4103/JISPPD.JISPPD_19_17. PMID: 29607846. Exclusion: 6.29607846
23 Bawden JW. Fluoride varnish: a useful new tool for public health dentistry. J Public Health Dent. 1998;58(4):266–9. PMID: 10390707. Exclusion: 2.10390707
24 Baygin O, Tuzuner T, Kusgoz A, . Antibacterial effects of fluoride varnish compared with chlorhexidine plus fluoride in disabled children. Oral Health Prev Dent. 2014;12(4):373–82. doi: 10.3290/j.ohpd.a32129. PMID: 24914426. Exclusion: 4.24914426
25 Berger C, Bachman J, Casalone GG, . An oral health program for children. Nurse Pract. 2014 Feb 15;39(2):48–53. doi: 10.1097/01.NPR.0000441912.47395.46. PMID: 24441318. Exclusion: 6.24441318
26 Bidwell J. Fluoride mouthrinses for preventing dental caries in children and adolescents. Public Health Nurs. 2018 01;35(1):85–7. doi: 10.1111/phn.12364. PMID: 28944499. Exclusion: 4.28944499
27 Birpou E, Agouropoulos A, Twetman S, . Validation of different Cariogram settings and factor combinations in preschool children from areas with high caries risk. Int J Paediatr Dent. 2019 Jul;29(4):448–55. doi: 10.1111/ipd.12476. PMID: 30735595. Exclusion: 5.30735595
28 Birungi N, Fadnes LT, Okullo I, . Effect of breastfeeding promotion on early childhood caries and breastfeeding duration among 5 year old children in Eastern Uganda: a cluster randomized trial. PLoS ONE. 2015;10(5). Exclusion: 5.
29 Bock NC, Seibold L, Heumann C, . Changes in white spot lesions following post-orthodontic weekly application of 1.25 per cent fluoride gel over 6 months-a randomized placebo-controlled clinical trial. Part II: clinical data evaluation. Eur J Orthod. 2017;39(2):144–52. doi: 10.1093/ejo/cjw061. PMID: 27702807. Exclusion: 4.27702807
30 Brambilla E, Felloni A, Gagliani M, . Caries prevention during pregnancy: results of a 30-month study. J Am Dent Assoc. 1998;129(7):871–7. doi: 10.14219/jada.archive.1998.0351. PMID: 9685762. Exclusion: 4.9685762
31 Brannemo I, Dahllof G, Cunha Soares F, . Impact of an extended postnatal home visiting programme on oral health among children in a disadvantaged area of Stockholm, Sweden. Acta Paediatr. 2020 Jul 04;04:04. doi: 10.1111/apa.15457. PMID: 32623798. Exclusion: 5.32623798
32 Braun PA, Quissell DO, Henderson WG, . A cluster-randomized, community-based, tribally delivered oral health promotion trial in Navajo head start children. J Dent Res. 2016 Oct;95(11):1237–44. doi: 10.1177/0022034516658612. PMID: 27439724. Exclusion: 5.27439724
33 Brignardello-Petersen R. There seem to be no differences between the benefits of resin-based sealants with and without fluoride in cooperative children at high risk of developing caries. J Am Dent Assoc. 2018 10;149(10) doi: 10.1016/j.adaj.2018.03.026. PMID: 29907258. Exclusion: 6.29907258
34 Brignardello-Petersen R. Accuracy for predicting caries in preschool-aged children seems to vary across risk assessment tools. J Am Dent Assoc. 2020 Apr;151(4) doi: 10.1016/j.adaj.2019.11.003. PMID: 32057404. Exclusion: 6.32057404
35 Bruen BK, Steinmetz E, Bysshe T, . Potentially preventable dental care in operating rooms for children enrolled in Medicaid. J Am Dent Assoc. 2016 09;147(9):702–8. doi: 10.1016/j.adaj.2016.03.019. PMID: 27158078. Exclusion: 6.27158078
36 Bulut G, Bulut H. Zero to five years: First dental visit. Eur J Paediatr Dent. 2020 Dec;21(4):326–30. doi: 10.23804/ejpd.2020.21.04.13. PMID: 33337911. Exclusion: 7.33337911
37 Burgette JM, Mestre Y, Martin B, . Success rates of pediatric dental referrals made by public health dental hygiene practitioners. J Public Health Dent. 2020 Nov 19;19:19. doi: 10.1111/jphd.12428. PMID: 33210783. Exclusion: 4.33210783
38 Cabral RN, Faber J, Otero SAM, . Retention rates and caries-preventive effects of two different sealant materials: a randomised clinical trial. Clin Oral Investig. 2018 Dec;22(9):3171–7. doi: 10.1007/s00784-018-2416-z. PMID: 29524027. Exclusion: 4.29524027
39 Cabral RN, Hilgert LA, Faber J, . Caries risk assessment in schoolchildren--a form based on Cariogram software. J Appl Oral Sci. 2014 Sep-Oct;22(5):397–402. doi: 10.1590/1678-775720130689. PMID: 25466473. Exclusion: 4.25466473
40 Cagetti MG, Campus G, Milia E, . A systematic review on fluoridated food in caries prevention. Acta Odontol Scand. 2013 May-Jul;71(3-4):381–7. doi: 10.3109/00016357.2012.690447. PMID: 22827733. Exclusion: 5.22827733
41 Cahen PM, Frank RM, Turlot JC, . Comparative unsupervised clinical trial on caries inhibition effect of monofluorophosphate and amine fluoride dentifrices after 3 years in Strasbourg, France. Community Dent Oral Epidemiol. 1982 Oct;10(5):238–41. doi: 10.1111/j.1600-0528.1982.tb00386.x. PMID: 6754242. Exclusion: 4.6754242
42 Camm J. Creative diagnosis. Pediatr Dent. 2014 Sep-Oct;36(5):373. PMID: 25303502. Exclusion: 6.25303502
43 Campus G, Cagetti MG, Sacco G, . Caries risk profiles in Sardinian schoolchildren using Cariogram. Acta Odontol Scand. 2009;67(3):146–52. doi: 10.1080/00016350902740498. PMID: 19253062. Exclusion: 4.19253062
44 Campus G, Cagetti MG, Sale S, . Cariogram validity in schoolchildren: a two-year follow-up study. Caries Res. 2012;46(1):16–22. doi: 10.1159/000334932. PMID: 22222621. Exclusion: 4.22222621
45 Campus G, Cagetti MG, Sale S, . Six months of high-dose xylitol in high-risk caries subjects--a 2-year randomised, clinical trial. Clin Oral Investig. 2013 Apr;17(3):785–91. doi: 10.1007/s00784-012-0774-5. PMID: 22791282. Exclusion: 4.22791282
46 Cao H-Z, Wang S, Pan Y. [An investigation of the clinical effect of the 0.3% Triclosan varnish on caries prevention of primary teeth]. Shanghai Kou Qiang Yi Xue. 2007 2007/02//;16(1):8–10. PMID: 17377691. Exclusion: 10.17377691
47 Cardoso Cde A, Lacerda B, Mangueira DF, . Mechanisms of action of fluoridated acidic liquid dentifrices against dental caries. Arch Oral Biol. 2015 Jan;60(1):23–8. doi: 10.1016/j.archoralbio.2014.08.016. PMID: 25244615. Exclusion: 5.25244615
48 Carey CM. Focus on fluorides: update on the use of fluoride for the prevention of dental caries. J Evid Based Dent Pract. 2014 Jun;14 Suppl:95–102. doi: 10.1016/j.jebdp.2014.02.004. PMID: 24929594. Exclusion: 6.24929594
49 Cartes-Velasquez R, Araya C, Flores R, . A motivational interview intervention delivered at home to improve the oral health literacy and reduce the morbidity of Chilean disadvantaged families: a study protocol for a community trial. BMJ Open. 2017;7(7) doi: 10.1136/bmjopen-2016-011819. Exclusion: 6.
50 Cassol DV, Duarte ML, Pintor AVB, . Iodoform Vs Calcium Hydroxide/Zinc Oxide based pastes: 12-month findings of a Randomized Controlled Trial. Pesqui Odontol Bras. 2019 Feb 11;33:e002. doi: 10.1590/1807-3107bor-2019.vol33.0002. PMID: 30758402. Exclusion: 5.30758402
51 Celeste RK, Luz PB. Independent and additive effects of different sources of fluoride and dental fluorosis. Pediatr Dent. 2016;38(3):233–8. PMID: 27306248. Exclusion: 4.27306248
52 Ceyhan D, Akdik C, Kirzioglu Z. An educational programme designed for the evaluation of effectiveness of two tooth brushing techniques in preschool children. Eur J Paediatr Dent. 2018;19(3):181–6. doi: 10.23804/ejpd.2018.19.03.03. PMID: 30063148 Exclusion: 2.30063148
53 Chaffee BW, Cheng J, Featherstone JD. Baseline caries risk assessment as a predictor of caries incidence. J Dent. 2015 May;43(5):518–24. doi: 10.1016/j.jdent.2015.02.013. PMID: 25731155. Exclusion: 7.25731155
54 Chaffee BW, Feldens CA, Vitolo MR. Cluster-randomized trial of infant nutrition training for caries prevention. J Dent Res. 2013 Jul;92(7 Suppl):29S–36S. doi: 10.1177/0022034513484331. PMID: 23690364. Exclusion: 4.23690364
55 Chandak S, Bhondey A, Bhardwaj A, . Comparative evaluation of the efficacy of fluoride varnish and casein phosphopeptide - Amorphous calcium phosphate in reducing Streptococcus mutans counts in dental plaque of children: An in vivo study. J Int Soc Prev Community Dent. 2016 Sep-Oct;6(5):423–9. doi: 10.4103/2231-0762.192936. PMID: 27891308. Exclusion: 7.27891308
56 Chandran T, Ravindranath NS, Kumari D, . Oral health education intervention among preschoolers: a randomized controlled trial. Indian J Public Health Res Dev. 2019;10(9):363–8. Exclusion: 5.
57 Chen KJ, Gao SS, Duangthip D, . The caries-arresting effect of incorporating functionalized tricalcium phosphate into fluoride varnish applied following application of silver nitrate solution in preschool children: study protocol for a randomized, double-blind clinical trial. Trials. 2018 Jul 04;19(1):352. doi: 10.1186/s13063-018-2741-1. PMID: 29973256. Exclusion: 6.29973256
58 Chen X, Liu X. Clinical comparison of Fuji VII and a resin sealant in children at high and low risk of caries. Dent Mater J. 2013;32(3):512–8. doi: 10.4012/dmj.2012-300. PMID: 23719016. Exclusion: 4.23719016
59 Cheng JK, Faniyan A, Chan Yuen J, . Changes in oral health behaviors associated with a nursing intervention in primary care. Glob Pediatr Health. 2019;6:2333794X19845923. doi: 10.1177/2333794X19845923. PMID: 31192280. Exclusion: 6.31192280
60 Cheng LL. Limited evidence suggests fluoride mouthrinse may reduce dental caries in children and adolescents. J Am Dent Assoc. 2017 04;148(4):263–6. doi: 10.1016/j.adaj.2017.02.002. PMID: 28238359. Exclusion: 4.28238359
61 Chestnutt IG. Are fluoride-containing sealants more effective than non-fluoride sealants? Evid Based Dent. 2019;20(1):12–3. doi: 10.1038/s41432-019-0019-4. PMID: 30903118 Exclusion: 6.30903118
62 Chi DL. Topical fluoride varnish every 6 months is not more effective than placebo varnish at preventing dental caries in preschoolers in Brazil. J Evid Based Dent Pract. 2014 Sep;14(3):142–4. doi: 10.1016/j.jebdp.2014.07.009. PMID: 25234217. Exclusion: 6.25234217
63 Chi DL, Tut O, Milgrom P. Cluster-randomized xylitol toothpaste trial for early childhood caries prevention. J Dent Child (Chic). 2014 Jan-Apr;81(1):27–32. PMID: 24709430. Exclusion: 5.24709430
64 Chi DL, Zegarra G, Vasquez Huerta EC, . Milk sweetened with xylitol: A proof-of-principle caries prevention randomized Clinical Trial. J Dent Child (Chic). 2016 Sep 15;83(3):152–60. PMID: 28327266. Exclusion: 5.28327266
65 Chi LY, Lin PY, Wang J, . Can government-supported preventive fluoride varnish application service reduce pulp-involved primary molars? J Public Health Dent. 2019 Apr 23;23:23. doi: 10.1111/jphd.12319. PMID: 31016749. Exclusion: 6.31016749
66 Chong LY, Clarkson JE, Dobbyn-Ross L, . Slow-release fluoride devices for the control of dental decay. Cochrane Database Syst Rev. 2018 03 01;3:CD005101. doi: 10.1002/14651858.CD005101.pub4. PMID: 29495063. Exclusion: 4.29495063
67 Chou R, Cantor A, Zakher B, . Preventing dental caries in children <5 years: systematic review updating USPSTF recommendation. Pediatrics. 2013 Aug;132(2):332–50. doi: 10.1542/peds.2013-1469. PMID: 23858419. Exclusion: 2.23858419
68 Chou R, Cantor A, Zakher B, . Prevention of Dental Caries in Children Younger Than 5 Years Old: Systematic Review to Update the U.S. Preventive Services Task Force Recommendation. Evidence Synthesis No. 104. AHRQ Publication No. 12-05170-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2014. Exclusion: 2.
69 Christian B, Calache H, Adams G, . A methodological study to assess the measurement properties (reliability and validity) of a caries risk assessment tool for young children. J Dent. 2020 Apr;95 doi: 10.1016/j.jdent.2020.103324. PMID: 32200008. Exclusion: 5.32200008
70 Clasen AB, Ogaard B, Sønju T. A comparison of the anticaries effect on the primary dentition of two dentifrices containing 250 ppm and 1450 ppm fluoride. Int J Paediatr Dent. 1995 Mar;5(1):3–8. doi: 10.1111/j.1365-263x.1995.tb00154.x. PMID: 17252658. Exclusion: 4.17252658
71 Colvara BC, Faustino-Silva DD, Meyer E, . Motivational interviewing in preventing early childhood caries in primary healthcare: A community-based randomized cluster trial. J Pediatr. 2018 10;201:190–5. doi: 10.1016/j.jpeds.2018.05.016. PMID: 29885752. Exclusion: 12.29885752
72 Contreras V, Toro MJ, Elias-Boneta AR, . Effectiveness of silver diamine fluoride in caries prevention and arrest: a systematic literature review. Gen Dent. 2017 May-Jun;65(3):22–9. PMID: 28475081. Exclusion: 3.28475081
73 Crystal YO, Marghalani AA, Ureles SD, . Use of Silver diamine fluoride for dental caries management in children and adolescents, including those with special health care needs. Pediatr Dent. 2017 Sep 15;39(5):135–45. PMID: 29070149. Exclusion: 5.29070149
74 Crystal YO, Niederman R. Silver diamine fluoride treatment considerations in children’s caries management. Pediatr Dent. 2016 Nov 15;38(7):466–71. PMID: 28281949. Exclusion: 6.28281949
75 Crystal YO, Niederman R. Evidence-based dentistry update on silver diamine fluoride. Dent Clin North Am. 2019 Jan;63(1):45–68. doi: 10.1016/j.cden.2018.08.011. PMID: 30447792. Exclusion: 3.30447792
76 Cuevas J, Chi DL. SBIRT-Based Interventions to Improve Pediatric Oral Health Behaviors and Outcomes: Considerations for Future Behavioral SBIRT Interventions in Dentistry. Curr Oral Health Rep. 2016 Sep;3(3):187–92. PMID: 27857880. Exclusion: 11.27857880
77 Cunha-Cruz J, Milgrom P, Shirtcliff RM, . Population-centered Risk- and Evidence-based Dental Interprofessional Care Team (PREDICT): study protocol for a randomized controlled trial. Trials. 2015 Jun 20;16:278. doi: 10.1186/s13063-015-0786-y. PMID: 26091669. Exclusion: 6.26091669
78 Cury JA, de Oliveira BH, dos Santos AP, . Are fluoride releasing dental materials clinically effective on caries control? Dent Mater. 2016 Mar;32(3):323–33. doi: 10.1016/j.dental.2015.12.002. PMID: 26777115. Exclusion: 6.26777115
79 Cury JA, Tenuta LM. Evidence-based recommendation on toothpaste use. Pesqui Odontol Bras. 2014;28 Spec No:1–7. doi: 10.1590/S1806-83242014.50000001. PMID: 24554097. Exclusion: 6.24554097
80 Cvikl B, Moritz A, Bekes K. Pit and fissure sealants-A comprehensive review. Dent J (Basel). 2018 Jun 12;6(2):12. doi: 10.3390/dj6020018. PMID: 29895726. Exclusion: 6.29895726
81 Daher A, Abreu MH, Costa LR. Recognizing preschool children with primary teeth needing dental treatment because of caries-related toothache. Community Dent Oral Epidemiol. 2015 Aug;43(4):298–307. doi: 10.1111/cdoe.12154. PMID: 25656813. Exclusion: 4.25656813
82 Daher A, Versloot J, Leles CR, . Screening preschool children with toothache: validation of the Brazilian version of the Dental Discomfort Questionnaire. Health Qual Life Outcomes. 2014 Mar 04;12:30. doi: 10.1186/1477-7525-12-30. PMID: 24593691. Exclusion: 7.24593691
83 Dahlberg D, Hiott DB, Wilson CC. Implementing pediatric fluoride varnish application in a rural primary care medical office: A feasibility study. J Pediatr Health Care. 2019 Aug 31;31:31. doi: 10.1016/j.pedhc.2019.06.002. PMID: 31477489. Exclusion: 7.31477489
84 Dahm KT, Dalsbo TK, Kirkehei I, . Knowledge Centre for the Health Services at The Norwegian Institute of Public Health (NIPH). 2015 from Norwegian Knowledge Centre for the Health Services (NOKC) No 11;NIPH Systematic Reviews:Executive Summaries. PMID: 2851039528510395. Exclusion: 11.
85 Daniel SJ, Kumar S. Comparison of dental hygienists and dentists: clinical and teledentistry identification of dental caries in children. Int. 2017 Nov;15(4):e143–e8. doi: 10.1111/idh.12232. PMID: 27256722. Exclusion: 8.27256722
86 Dasanayake AP, Caufield PW, Cutter GR, . Transmission of mutans streptococci to infants following short term application of an iodine-NaF solution to mothers’ dentition. Community Dent Oral Epidemiol. 1993;21(3):136–42. doi: 10.1111/j.1600-0528.1993.tb00738.x. PMID: 8348786. Exclusion: 4.8348786
87 Dasanayake AP, Wiener HW, Li Y, . Lack of effect of chlorhexidine varnish on Streptococcus mutans transmission and caries in mothers and children. Caries Res. 2002 Jul-Aug;36(4):288–93. doi: 10.1159/000063922. PMID: 12218279. Exclusion: 4.12218279
88 Davies GM, Worthington HV, Ellwood RP, . A randomised controlled trial of the effectiveness of providing free fluoride toothpaste from the age of 12 months on reducing caries in 5-6 year old children. Community Dent Health. 2002;19(3):131–6. PMID: 12269458. Exclusion: 4.12269458
89 Davies K, Armitage CJ, Lin YL, . Development of an implementation intention-based intervention to change children’s and parent-carers’ behaviour. Pilot feasibility stud. 2018;4:20. doi: 10.1186/s40814-017-0171-6. PMID: 28725453. Exclusion: 6.28725453
90 de Almeida Baldini Cardoso C, Mangueira DF, Olympio KP, . The effect of pH and fluoride concentration of liquid dentifrices on caries progression. Clin Oral Investig. 2014 Apr;18(3):761–7. doi: 10.1007/s00784-013-1031-2. PMID: 23873319. Exclusion: 5.23873319
91 De Amorim RG, Leal SC, Bezerra ACB, . Association of chlorhexidine and fluoride for plaque control and white spot lesion remineralization in primary dentition. Int J Paediatr Dent. 2008 2008/11/01;18(6):446–51. doi: 10.1111/j.1365-263X.2008.00914.x. Exclusion: 4.18489576
92 de Moura MS, de Carvalho MM, Silva MC, . The impact of a dental program for maternal and infant health on the prevalence of dental fluorosis. Pediatr Dent. 2013;35(7):519–22. PMID: 24553275. Exclusion: 4.24553275
93 de Oliveira BH, Dos Santos AP. Semiannual Fluoride Applications in Low-Risk Toddlers May Not Be More Effective Than Toothbrushing Instruction and Dietary Counseling in Controlling Dental Caries. J Evid Based Dent Pract. 2016 12;16(4):246–8. doi: 10.1016/j.jebdp.2016.11.006. PMID: 27938699. Exclusion: 6.27938699
94 de Sousa FSO, Dos Santos APP, Nadanovsky P, . Fluoride varnish and dental caries in preschoolers: A systematic review and meta-analysis. Caries Res. 2019;53(5):502–13. doi: 10.1159/000499639. PMID: 31220835. Exclusion: 11.31220835
95 Deery C. Strong evidence for the effectiveness of resin based sealants. Evid Based Dent. 2013 Sep;14(3):69–70. doi: 10.1038/sj.ebd.6400945. PMID: 24071670. Exclusion: 6.24071670
96 Dooley D, Moultrie NM, Heckman B, . Oral health prevention and toddler well-child care: routine integration in a safety net system. Pediatrics. 2016 Jan;137(1):e20143532. doi: 10.1542/peds.2014-3532. PMID: 26647374. Exclusion: 5.26647374
97 dos Santos AP, Nadanovsky P, de Oliveira BH. A systematic review and meta-analysis of the effects of fluoride toothpastes on the prevention of dental caries in the primary dentition of preschool children. Community Dent Oral Epidemiol. 2013 Feb;41(1):1–12. doi: 10.1111/j.1600-0528.2012.00708.x. PMID: 22882502. Exclusion: 11.22882502
98 dos Santos AP, Nadanovsky P, de Oliveira BH. A systematic review and meta-analysis of the effects of fluoride toothpastes on the prevention of dental caries in the primary dentition of preschool children. Evid Based Dent. 2014; 1: 5. Evid Based Dent. 2014 Sep;15(3):67. doi: 10.1038/sj.ebd.6401035. PMID: 25343385. Exclusion: 6.25343385
99 Douglas GV, Ramsdale MP, Vinall-Collier K, . Using high fluoride concentration products in public policy: A rapid review of current guidelines for high fluoride concentration products. Caries Res. 2016;50 Suppl 1:50–60. doi: 10.1159/000443409. PMID: 27100106. Exclusion: 6.27100106
100 Douglass JM, Clark MB. Integrating oral health into overall health care to prevent early childhood caries: Need, evidence, and solutions Pediatr Dent. 2015 May-Jun;37(3):266–74. PMID: 26063555. Exclusion: 11.26063555
101 Duane B. Xylitol and caries prevention. Evid Based Dent. 2015 Jun;16(2):37–8. doi: 10.1038/sj.ebd.6401088. PMID: 26114781. Exclusion: 6.26114781
102 Duangthip D, Fung MHT, Wong MCM, . Adverse effects of silver diamine fluoride treatment among preschool children. J Dent Res. 2018 04;97(4):395–401. doi: 10.1177/0022034517746678. PMID: 29237131. Exclusion: 4.29237131
103 Dumas SA, Weaver KE, Park SY, . Accuracy of visible plaque identification by pediatric clinicians during well-child care. Clin Pediatr (Phila). 2013 Jul;52(7):645–51. doi: 10.1177/0009922813483876. PMID: 23572449. Exclusion: 5.23572449
104 Elkhadem A, Wanees S. Limited evidence suggests standard fluoride toothpaste reduces caries potential in preschool children. Evid Based Dent. 2014 Mar;15(1):5. doi: 10.1038/sj.ebd.6400979. PMID: 24763164. Exclusion: 6.24763164
105 ElSalhy M, Alsumait A, Lai H, . Identifying a potential summary measure for overall caries level in children examined with the international caries detection and assessment system. Caries Res. 2018 01;51(6):568–75. doi: 10.1159/000479389. PMID: 29024927. Exclusion: 4.29024927
106 Englander HR, Mellberg JR, Engler WO. Observations on dental caries in primary teeth after frequent fluoride toplications in a program involving other preventives. J Dent Res. 1978 Sep-Oct;57(9-10):855–60. doi: 10.1177/00220345780570090101. PMID: 281356. Exclusion: 6.281356
107 Estai M, Kanagasingam Y, Huang B, . The efficacy of remote screening for dental caries by mid-level dental providers using a mobile teledentistry model. Community Dent Oral Epidemiol. 2016 10;44(5):435–41. doi: 10.1111/cdoe.12232. PMID: 27111291. Exclusion: 4.27111291
108 Estai M, Winters J, Kanagasingam Y, . Validity and reliability of remote dental screening by different oral health professionals using a store-and-forward telehealth model. Br Dent J. 2016 Oct 07;221(7):411–4. doi: 10.1038/sj.bdj.2016.733. PMID: 27713449. Exclusion: 4.27713449
109 Falony G, Honkala S, Runnel R, . Long-term effect of erythritol on dental caries development during childhood: A posttreatment survival analysis. Caries Res. 2016;50(6):579–88. doi: 10.1159/000450762. PMID: 27806364. Exclusion: 4.27806364
110 Fan X, Li X, Wan H, . Clinical investigation of the anticaries efficacy of a 1.14% sodium monofluorophosphate (SMFP) calcium carbonate-based dentifrice: a two-year caries clinical trial on children in China. J Clin Dent. 2008 2008;19(4):134–7. PMID: 19278083. Exclusion: 4.19278083
111 Featherstone JDB, Chaffee BW. The Evidence for Caries Management by Risk Assessment (CAMBRA). Adv Dent Res. 2018 02;29(1):9–14. doi: 10.1177/0022034517736500. PMID: 29355423. Exclusion: 6.29355423
112 Feldens CA, Vítolo MR, Drachler MdL. A randomized trial of the effectiveness of home visits in preventing early childhood caries. Community Dent Oral Epidemiol. 2007;35(3):215–23. doi: 10.1111/j.1600-0528.2006.00337.x. PMID: 17518968. Exclusion: 5.17518968
113 Ferro R, Besostri A, Giuca MR, . The Italian perspective on fluoride intake in children and adolescents. Eur J Paediatr Dent. 2014 Mar;15(1):55–8. PMID: 24745594. Exclusion: 6.24745594
114 Fontana M, Catt D, Eckert GJ, . Xylitol: effects on the acquisition of cariogenic species in infants. Pediatr Dent. 2009 May-Jun;31(3):257–66. PMID: 19552232. Exclusion: 4.19552232
115 Fontana M, Eckert GJ, Keels MA, . Fluoride use in health care settings: association with children’s caries risk. Adv Dent Res. 2018 02;29(1):24–34. doi: 10.1177/0022034517735297. PMID: 29355412. Exclusion: 6.29355412
116 Gao X, Di Wu I, Lo EC, . Validity of caries risk assessment programmes in preschool children. J Dent. 2013 Sep;41(9):787–95. doi: 10.1016/j.jdent.2013.06.005. PMID: 23791698. Exclusion: 5.23791698
117 Gao X, Hsu CY, Loh T, . Role of microbiological factors in predicting early childhood caries. Pediatr Dent. 2014 Jul-Aug;36(4):348–54. PMID: 25198002. Exclusion: 5.25198002
118 Gao XL, Hsu CY, Xu Y, . Building caries risk assessment models for children. J Dent Res. 2010 Jun;89(6):637–43. doi: 10.1177/0022034510364489. PMID: 20400721. Exclusion: 9.20400721
119 Gao XL, Lo EC, Chu CH, . Caries risk assessment programmes for Hong Kong children. Hong Kong Med. 2015 Dec;21 Suppl 6:42–6. PMID: 26645883. Exclusion: 7.26645883
120 Garcia RI, Gregorich SE, Ramos-Gomez F, . Absence of Fluoride Varnish-Related Adverse Events in Caries Prevention Trials in Young Children, United States. Prev Chronic Dis. 2017 02 16;14:E17. doi: 10.5888/pcd14.160372. PMID: 28207379. Exclusion: 11.28207379
121 Garg A, Madan M, Dua P, . Validating the Usage of Cariogram in 5- and 12-year-old School-going Children in Paonta Sahib, Himachal Pradesh, India: A 12-month Prospective Study. Int J Clin Pediatr Dent. 2018 Mar-Apr;11(2):110–5. doi: 10.5005/jp-journals-10005-1495. PMID: 29991863. Exclusion: 4.29991863
122 Ghazal TS, Levy SM, Childers NK, . Dental Caries in High-risk, School-age African American Children in Alabama: A Six-year Prospective. Pediatr Dent. 2016;38(3):224–30. PMID: 27306247. Exclusion: 4.27306247
123 Gimenez T, Bittar DG, Piovesan C, . Influence of examiner experience on clinical performance of visual inspection in detecting and assessing the activity status of caries lesions. Oper Dent. 2013 Nov-Dec;38(6):583–90. doi: 10.2341/12-067-C. PMID: 23617691. Exclusion: 4.23617691
124 Gnaedinger EA. Fluoride varnish application, a quality improvement project implemented in a rural pediatric practice. Public Health Nurs. 2018 11;35(6):534–40. doi: 10.1111/phn.12522. PMID: 29888506. Exclusion: 6.29888506
125 Gold J. Fluoride varnish with community-based oral health promotion may reduce surface-level caries risk in preschool children. J Evid Based Dent Pract. 2013 Jun;13(2):55–7. doi: 10.1016/j.jebdp.2013.04.003. PMID: 23773467. Exclusion: 6.23773467
126 Gold J. Erythritol may reduce dental caries in high-risk school children. J Evid Based Dent Pract. 2014 Dec;14(4):185–7. doi: 10.1016/j.jebdp.2014.10.007. PMID: 25488868. Exclusion: 4.25488868
127 Gold J. Consumption of Xylitol Gummy Bears May not Provide Additional Caries Prevention for School Children. J Evid Based Dent Pract. 2016 Mar;16(1):70–2. doi: 10.1016/j.jebdp.2016.01.032. PMID: 27132564. Exclusion: 6.27132564
128 Goodwin M, Emsley R, Kelly M, . The CATFISH study protocol: an evaluation of a water fluoridation scheme. BMC Oral Health. 2016 Feb 01;16:8. doi: 10.1186/s12903-016-0169-0. PMID: 26831505. Exclusion: 6.26831505
129 Gotjamanos T. Safety issues related to the use of silver fluoride in paediatric dentistry. Aust Dent J. 1997 Jun;42(3):166–8. PMID: 9241926. Exclusion: 4.9241926
130 Gotjamanos T, Afonso F. Unacceptably high levels of fluoride in commercial preparations of silver fluoride. Aust Dent J. 1997 Feb;42(1):52–3. PMID: 9078648. Exclusion: 4.9078648
131 Green E. A clinical evaluation of two methods of caries prevention in newly-erupted first permanent molars. Aust Dent J. 1989 Oct;34(5):407–9. doi: 10.1111/j.1834-7819.1989.tb00696.x. PMID: 2818298. Exclusion: 4.2818298
132 Gruner D, Paris S, Schwendicke F. Probiotics for managing caries and periodontitis: Systematic review and meta-analysis. J Dent. 2016 May;48:16–25. doi: 10.1016/j.jdent.2016.03.002. PMID: 26965080. Exclusion: 5.26965080
133 Guedes RS, Piovesan C, Ardenghi TM, . Validation of Visual Caries Activity Assessment: A 2-yr Cohort Study. J Dent Res. 2014 Jul;93(7 Suppl):101S–7S. doi: 10.1177/0022034514531017. PMID: 24713370. Exclusion: 5.24713370
134 Gugnani N, Gugnani S. Remineralisation and arresting caries in children with topical fluorides. Evid Based Dent. 2017 06 23;18(2):41–2. doi: 10.1038/sj.ebd.6401234. PMID: 28642564. Exclusion: 6.28642564
135 Günay H, Dmoch-Bockhorn K, Günay Y, . Effect on caries experience of a long-term preventive program for mothers and children starting during pregnancy. Clin Oral Investig. 1998;2(3):137–42. doi: 10.1007/s007840050059. PMID: 9927915. Exclusion: 4.9927915
136 Hallas D, Fernandez JB, Lim LJ, . OHEP: an oral health education program for mothers of newborns. J Pediatr Health Care. 2015 Mar-Apr;29(2):181–90. doi: 10.1016/j.pedhc.2014.11.004. PMID: 25547319. Exclusion: 7.25547319
137 Hanno AG, Alamoudi NM, Almushayt AS, . Effect of xylitol on dental caries and salivary Streptococcus mutans levels among a group of mother-child pairs. J Clin Pediatr Dent. 2011 Fall;36(1):25–30. doi: 10.17796/jcpd.36.1.d4g77616714w3372. PMID: 22900440. Exclusion: 4.22900440
138 Hansel Petersson G, Twetman S, Bratthall D. Evaluation of a computer program for caries risk assessment in schoolchildren. Caries Res. 2002 Sep-Oct;36(5):327–40. doi: 10.1159/000065963. PMID: 12399693. Exclusion: 4.12399693
139 Hanwatkar P, Gajendra S, Veazie P, . Fluoride Varnish: Knowledge, Preferences and Practices of General and Pediatric Dentists. N Y State Dent J. 2017 Mar;83(2):37–42. PMID: 29920030. Exclusion: 6.29920030
140 Harrison R, Benton T, Everson-Stewart S, . Effect of motivational interviewing on rates of early childhood caries: a randomized trial. Pediatr Dent. 2007 Jan-Feb;29(1):16–22. PMID: 18041508. Exclusion: 5.18041508
141 Harrison RL, Veronneau J, Leroux B. Effectiveness of maternal counseling in reducing caries in Cree children. J Dent Res. 2012;91(11):1032–7. doi: 10.1177/0022034512459758. PMID: 22983408. Exclusion: 4.22983408
142 Harrison RL, Wong T. An oral health promotion program for an urban minority population of preschool children. Community Dent Oral Epidemiol. 2003;31(5):392–9. doi: 10.1034/j.1600-0528.2003.00001.x. PMID: 14667011. Exclusion: 6.14667011
143 Hashizume LN, Mathias TC, Cibils DM, . Effect of the widespread use of fluorides on the occurrence of hidden caries in children. Int J Paediatr Dent. 2013 Jan;23(1):72–6. doi: 10.1111/j.1365-263X.2012.01231.x. PMID: 22348554. Exclusion: 4.22348554
144 Hatefnia E, Alinasab A, Ghorbani M. Impact of theory-based educational intervention on promotion of caries-prevention behaviors in iranian mothers with 3-6-year-old children. Biomedical research (india). 2017;28(5):1969–74. Exclusion: 7.
145 Heavey E. Open wide: Oral health in primary care. Nursing. 2014 Mar;44(3):59–62. doi: 10.1097/01.NURSE.0000441882.95371.8c. PMID: 24531586. Exclusion: 6.24531586
146 Hebbal M, Ankola A, Metgud S. Caries risk profile of 12 year old school children in an Indian city using Cariogram. Med Oral Patol Oral Cir Bucal. 2012 Nov 1;17(6):e1054–61. doi: 10.4317/medoral.17880. PMID: 22926464. Exclusion: 4.22926464
147 Hedayati-Hajikand T, Lundberg U, Eldh C, . Effect of probiotic chewing tablets on early childhood caries--a randomized controlled trial. BMC Oral Health. 2015 Sep 24;15(1):112. doi: 10.1186/s12903-015-0096-5. PMID: 26403472. Exclusion: 5.26403472
148 Henshaw MM, Borrelli B, Gregorich SE, . Randomized Trial of Motivational Interviewing to Prevent Early Childhood Caries in Public Housing. JDR Clin Trans Res. 2018 Oct;3(4):353–65. doi: 10.1177/2380084418794377. PMID: 30238060. Exclusion: 8.30238060
149 Herndon JB, Tomar SL, Catalanotto FA. Effect of training pediatricians and family physicians in early childhood caries prevention. J Pediatr. 2015 Apr;166(4):1055–61.e1. doi: 10.1016/j.jpeds.2014.12.040. PMID: 25662286. Exclusion: 5.25662286
150 Hinze ES, Casamassimo PS, Seale NS, . Relative value of oral health in well-child care: a survey of pediatricians in Texas and Ohio. J Dent Child (Chic). 2014 May-Aug;81(2):84–90. PMID: 25198951. Exclusion: 6.25198951
151 Hodge P. Mouthwashes: Do They Work and Should We Use Them? Part 2: Anticaries, Antihalitosis and Dry Mouth Relief Efficacy of Mouthwashes. Dent Update. 2016 Sep;43(7):631–2, 4–6, 9–40. PMID: 29148673. Exclusion: 4.29148673
152 Hofmeyr GJ, Lawrie TA, Atallah AN, . Calcium supplementation during pregnancy for preventing hypertensive disorders and related problems. Cochrane Database Syst Rev. 2018 10 01;10:CD001059. doi: 10.1002/14651858.CD001059.pub5. PMID: 30277579. Exclusion: 4.30277579
153 Holgerson PL, Twetman S, Stecksen-Blicks C. Validation of an age-modified caries risk assessment program (Cariogram) in preschool children. Acta Odontol Scand. 2009;67(2):106–12. doi: 10.1080/00016350802714734. PMID: 19152150. Exclusion: 4.19152150
154 Holley MA, Wiley LA, Marass AD. Watch Me Grow: A Well-Child Examination Protocol to Improve Preventive Care in Dominican Children. J Pediatr Health Care. 2019 May - Jun;33(3):263–9. doi: 10.1016/j.pedhc.2018.09.003. PMID: 30472029. Exclusion: 4.30472029
155 Holmes R, Howe D, Landes DP. Oral health education and disease prevention in primary dental care: insight from a pilot intervention targeting children aged 0-7 years in northeast England. Community Dent Health. 2013 Sep;30(3):134–7. PMID: 24151785. Exclusion: 4.24151785
156 Holt RD, Morris CE, Winter GB, . Enamel opacities and dental caries in children who used a low fluoride toothpaste between 2 and 5 years of age. Int Dent J. 1994 1994/08//;44(4):331–41. PMID: 7822059. Exclusion: 4.7822059
157 Hom JM, Lee JY, Silverman J, . State Medicaid Early and Periodic Screening, Diagnosis, and Treatment guidelines: adherence to professionally recommended best oral health practices. J Am Dent Assoc. 2013 Mar;144(3):297–305. PMID: 23449906. Exclusion: 6.23449906
158 Hong M, Vuong C, Herzog K, . Sealed primary molars are less likely to develop caries. J Am Dent Assoc. 2019 08;150(8):641–8. doi: 10.1016/j.adaj.2019.04.011. PMID: 31352965. Exclusion: 4.31352965
159 Honkala S, Runnel R, Saag M, . Effect of erythritol and xylitol on dental caries prevention in children. Caries Res. 2014;48(5):482–90. doi: 10.1159/000358399. PMID: 24852946. Exclusion: 4.24852946
160 Horst JA, Heima M. Prevention of Dental Caries by Silver Diamine Fluoride. Compend Contin Educ Dent. 2019 Mar;40(3):158–63; quiz 64. PMID: 30829497. Exclusion: 4.30829497
161 Horst JA, Tanzer JM, Milgrom PM. Fluorides and Other Preventive Strategies for Tooth Decay. Dent Clin North Am. 2018 04;62(2):207–34. doi: 10.1016/j.cden.2017.11.003. PMID: 29478454. Exclusion: 2.29478454
162 Hou J, Gu Y, Zhu L, . Systemic review of the prevention of pit and fissure caries of permanent molars by resin sealants in children in China. J Investig Clin Dent. 2017 Feb;8(1) doi: 10.1111/jicd.12183. PMID: 26272130. Exclusion: 4.26272130
163 Hultquist AI, Brudin L, Bagesund M. Early childhood caries risk assessment in 1-year-olds evaluated at 6-years of age. Acta Odontol Scand. 2020 Jul 22:1–9. doi: 10.1080/00016357.2020.1795247. PMID: 32697607. Exclusion: 4.32697607
164 Ijaz S. Low quality evidence for effectiveness of fluoridated milk. Evid Based Dent. 2015 Dec;16(4):99. doi: 10.1038/sj.ebd.6401126. PMID: 26680513. Exclusion: 6.26680513
165 Innes NP, Clarkson JE, Douglas GVA, . Child caries management: A randomized controlled trial in dental practice. J Dent Res. 2020;99(1):36–43. doi: 10.1177/0022034519888882. PMID: 31771385. Exclusion: 5.31771385
166 Ismail A, Razak IA, Ab-Murat N. The impact of anticipatory guidance on early childhood caries: a quasi-experimental study. BMC Oral Health. 2018;18(1):126-. doi: 10.1186/s12903-018-0589-0. Exclusion: 6.30053849
167 Isokangas P, Söderling E, Pienihäkkinen K, . Occurrence of dental decay in children after maternal consumption of xylitol chewing gum, a follow-up from 0 to 5 years of age. J Dent Res. 2000;79(11):1885–9. doi: 10.1177/00220345000790111201. PMID: 11145360. Exclusion: 4.11145360
168 Jackson EB. Outcomes of a quality improvement project examining early childhood caries and improving identification of at risk patients in a pediatric medical home setting. J Pediatr Nurs. 2015 Jul-Aug;30(4):543–9. doi: 10.1016/j.pedn.2014.10.020. PMID: 25448475. Exclusion: 7.25448475
169 Jamieson L, Bradshaw J, Lawrence H, . Fidelity of Motivational Interviewing in an Early Childhood Caries Intervention Involving Indigenous Australian Mothers. J Health Care Poor Underserved. 2016;27(1A):125–38. PMID: 27763436. Exclusion: 7.27763436
170 Jamieson L, Smithers L, Hedges J, . Follow-up of intervention to prevent dental caries among indigenous children in australia: A secondary analysis of a randomized clinical trial. JAMA Netw Open. 2019 Nov 01;2(11) doi: 10.1001/jamanetworkopen.2019.15611. PMID: 31774519. Exclusion: 4.31774519
171 Jamieson L, Smithers L, Hedges J, . Dental Disease Outcomes Following a 2-Year Oral Health Promotion Program for Australian Aboriginal Children and Their Families: A 2-Arm Parallel, Single-blind, Randomised Controlled Trial. EClinicalMedicine. 2018 Jul;1:43–50. doi: 10.1016/j.eclinm.2018.05.001. PMID: 31193658. Exclusion: 4.31193658
172 Jamieson LM, Smithers LG, Hedges J, . Follow-up of an intervention to reduce dental caries in indigenous Australian children: A secondary analysis of a randomized clinical trial. JAMA Netw Open. 2019 Mar 01;2(3):e190648. doi: 10.1001/jamanetworkopen.2019.0648. PMID: 30874781. Exclusion: 4.30874781
173 Janakiram C, Deepan Kumar CV, Joseph J. Xylitol in preventing dental caries: A systematic review and meta-analyses. Journal of Natural Science Biology & Medicine. 2017 Jan-Jun;8(1):16–21. doi: 10.4103/0976-9668.198344. PMID: 28250669. Exclusion: 2.28250669
174 Jiang M, Xie QY, Wong MCM, . Association between dental conditions, sliver diamine fluoride application, parental satisfaction, and oral health-related quality of life of preschool children. Clin Oral Investig. 2020 Sep 07;07:07. doi: 10.1007/s00784-020-03542-8. PMID: 32895767. Exclusion: 4.32895767
175 Jiang S, McGrath C, Lo EC, . Motivational interviewing to prevent early childhood caries: a randomized controlled trial. J Dent. 2020;97(103349) doi: 10.1016/j.jdent.2020.103349. PMID: 32330548. Exclusion: 5.32330548
176 Jordan KH, McGwin G, Childers NK. Overestimation of Early Childhood Caries Using the dmfs Index. Pediatr Dent. 2020 May 15;42(3):208–11. PMID: 32522324. Exclusion: 5.32522324
177 Jorgensen MR, Twetman S. A systematic review of risk assessment tools for early childhood caries: is there evidence? Eur Arch Paediatr Dent. 2020 Apr;21(2):179–84. doi: 10.1007/s40368-019-00480-2. PMID: 31559535. Exclusion: 4.31559535
178 Joury E, Alghadban M, Elias K, . Impact of providing free preventive dental products without health workers’ counselling on infants’ tooth-brushing and bottle-feeding termination practices: a randomised controlled trial. Community Dent Health. 2016 Sep;33(3):213–7. doi: 10.1922/CDH_3841Joury05. PMID: 28509517. Exclusion: 6.28509517
179 Joury E, Bernabe E, Sabbah W, . Systematic review and meta-analysis of randomised controlled trials on the effectiveness of school-based dental screening versus no screening on improving oral health in children. J Dent. 2017 Mar;58:1–10. doi: 10.1016/j.jdent.2016.11.008. PMID: 27884719. Exclusion: 4.27884719
180 Joury E, Khairallah M, Sabbah W, . Inequalities in the frequency of free sugars intake among Syrian 1-year-old infants: a cross-sectional study. BMC Oral Health. 2016 Sep 8;16(1):94. doi: 10.1186/s12903-016-0287-8. PMID: 27608712. Exclusion: 6.27608712
181 Kalhan TA, Un Lam C, Karunakaran B, . Caries risk prediction models in a medical health care setting. J Dent Res. 2020 Apr 20 doi: 10.1177/0022034520913476. PMID: 32311276. Exclusion: 5.32311276
182 Karasz A, Bonuck K. Reducing pediatric caries and obesity risk in South Asian immigrants: randomized controlled trial of common health/risk factor approach. BMC Public Health. 2018 05 31;18(1):680. doi: 10.1186/s12889-018-5317-9. PMID: 29855352. Exclusion: 6.29855352
183 Kavvadia K, Agouropoulos A, Gizani S, . Caries risk profiles in 2- to 6-year-old Greek children using the Cariogram. Eur J Dent. 2012 Oct;6(4):415–21. PMID: 23077422. Exclusion: 7.23077422
184 Keightley AJ, Taylor GD. Fluoride varnish applications and caries incidence in pre-schoolers. Evid Based Dent. 2014 Sep;15(3):83–4. doi: 10.1038/sj.ebd.6401045. PMID: 25343395. Exclusion: 6.25343395
185 Kemparaj U, Chavan S, Shetty NL. Caries risk assessment among school children in davangere city using cariogram. Int J Prev Med. 2014 May;5(5):664–71. PMID: 24932401. Exclusion: 4.24932401
186 Kilinc G, Uzuner N, Karaman O. Effect of dental care programme and fluoridation in the prevention of dental caries in asthmatic children. JPMA J Pak Med Assoc. 2016 11;66(11):1378–84. PMID: 27812052. Exclusion: 4.27812052
187 Kramer MS, Chalmers B, Hodnett ED, . Promotion of Breastfeeding Intervention Trial (PROBIT): a randomized trial in the Republic of Belarus. JAMA. 2001;285(4):413–20. doi: 10.1001/jama.285.4.413. PMID: 11242425. Exclusion: 5.11242425
188 Kranz AM, Lee J, Divaris K, . North Carolina physician-based preventive oral health services improve access and use among young Medicaid enrollees. Health Aff (Millwood). 2014 Dec;33(12):2144–52. doi: 10.1377/hlthaff.2014.0927. PMID: 25489032. Exclusion: 6.25489032
189 Laitala ML, Alanen P, Isokangas P, . Long-term effects of maternal prevention on children’s dental decay and need for restorative treatment. Community Dent Oral Epidemiol. 2013 Dec;41(6):534–40. doi: 10.1111/cdoe.12057. PMID: 23786466. Exclusion: 5.23786466
190 Lalloo R, Kroon J, Tut O, . Effectiveness, cost-effectiveness and cost-benefit of a single annual professional intervention for the prevention of childhood dental caries in a remote rural Indigenous community. BMC Oral Health. 2015 Aug 29;15:99. doi: 10.1186/s12903-015-0076-9. PMID: 26318162. Exclusion: 6.26318162
191 Lapinleimu H, Viikari J, Jokinen E, . Prospective randomised trial in 1062 infants of diet low in saturated fat and cholesterol. Lancet. 1995;345(8948):471–6. doi: 10.1016/s0140-6736(95)90580-4. PMID: 7861873. Exclusion: 5.7861873
192 Lebrun-Harris LA, Canto MT, Vodicka P. Preventive oral health care use and oral health status among US children: 2016 National Survey of Children’s Health. J Am Dent Assoc. 2019 Apr;150(4):246–58. doi: 10.1016/j.adaj.2018.11.023. PMID: 30922456. Exclusion: 2.30922456
193 Lenkkeri AM, Pienihäkkinen K, Hurme S, . The caries-preventive effect of xylitol/maltitol and erythritol/maltitol lozenges: results of a double-blinded, cluster-randomized clinical trial in an area of natural fluoridation. Int J Paediatr Dent. 2012 May;22(3):180–90. doi: 10.1111/j.1365-263X.2011.01182.x. PMID: 21951305. Exclusion: 4.21951305
194 Leverett DH, Adair SM, Vaughan BW, . Randomized clinical trial of the effect of prenatal fluoride supplements in preventing dental caries. Caries Res. 1997;31(3):174–9. doi: 10.1159/000262394. PMID: 9165186. Exclusion: 4.9165186
195 Levey C, Innes N, Schwendicke F, . Outcomes in randomised controlled trials in prevention and management of carious lesions: a systematic review. Trials. 2017;18(1). Exclusion: 2.
196 Lewis CW. Fluoride and dental caries prevention in children. Pediatr Rev. 2014 Jan;35(1):3–15. doi: 10.1542/pir.35-1-3. PMID: 24385561. Exclusion: 6.24385561
197 Li X, Zhong Y, Jiang X, . Randomized clinical trial of the efficacy of dentifrices containing 1.5% arginine, an insoluble calcium compound and 1450 ppm fluoride over two years. J Clin Dent. 2015;26(1):7–12. PMID: 26054185. Exclusion: 4.26054185
198 Li Y, Tanner A. Effect of Antimicrobial Interventions on the Oral Microbiota Associated with Early Childhood Caries. Pediatr Dent. 2015 May-Jun;37(3):226–44. PMID: 26063552. Exclusion: 2.26063552
199 Lima TJ, Ribeiro CCC, Tenuta LMA, . Low-Fluoride Dentifrice and Caries Lesion Control in Children with Different Caries Experience: A Randomized Clinical Trial. Caries Res. 2008;42(1):46–50. doi: 10.1159/000111749. Exclusion: 12.18042987
200 Lin HK, Fang CE, Huang MS, . Effect of maternal use of chewing gums containing xylitol on transmission of mutans streptococci in children: a meta-analysis of randomized controlled trials. Int J Paediatr Dent. 2016 Jan;26(1):35–44. doi: 10.1111/ipd.12155. PMID: 25684114. Exclusion: 7.25684114
201 Liu BY, Lo EC, Li CM. Effect of silver and fluoride ions on enamel demineralization: a quantitative study using micro-computed tomography. Aust Dent J. 2012 Mar;57(1):65–70. doi: 10.1111/j.1834-7819.2011.01641.x. PMID: 22369560. Exclusion: 4.22369560
202 Llodra JC, Rodriguez A, Ferrer B, . Efficacy of silver diamine fluoride for caries reduction in primary teeth and first permanent molars of schoolchildren: 36-month clinical trial. J Dent Res. 2005 Aug;84(8):721–4. PMID: 16040729. Exclusion: 3.16040729
203 Lo EC, Chu CH, Lin HC. A community-based caries control program for pre-school children using topical fluorides: 18-month results. J Dent Res. 2001 Dec;80(12):2071–4. doi: 10.1177/00220345010800120901. PMID: 11808764. Exclusion: 4.11808764
204 Maguire A. ADA clinical recommendations on topical fluoride for caries prevention. Evid Based Dent. 2014 Jun;15(2):38–9. doi: 10.1038/sj.ebd.6401019. PMID: 24971851. Exclusion: 6.24971851
205 Makinen KK, Jarvinen KL, Anttila CH, . Topical xylitol administration by parents for the promotion of oral health in infants: a caries prevention experiment at a Finnish Public Health Centre. Int Dent J. 2013 Aug;63(4):210–24. doi: 10.1111/idj.12038. PMID: 23879257. Exclusion: 6.23879257
206 Marghalani AA, Guinto E, Phan M, . Effectiveness of Xylitol in Reducing Dental Caries in Children. Pediatr Dent. 2017 Mar 15;39(2):103–10. PMID: 28390459. Exclusion: 2.28390459
207 Marinho CCV, Higgins PTJ, Logan S, . Fluoride toothpastes for preventing dental caries in children and adolescents. Cochrane Database Syst Rev. 2009(1). Exclusion: 4.
208 Marinho CCV, Higgins PTJ, Logan S, . Topical fluoride (toothpastes, mouthrinses, gels or varnishes) for preventing dental caries in children and adolescents. Cochrane Database Syst Rev. 2009 or 2003(1). Exclusion: 11.
209 Marinho CCV, Higgins PTJ, Sheiham A, . Combinations of topical fluoride (toothpastes, mouthrinses, gels, varnishes) versus single topical fluoride for preventing dental caries in children and adolescents. Cochrane Database Syst Rev. 2009(1). Exclusion: 4.
210 Marinho VC, Chong LY, Worthington HV, . Fluoride mouthrinses for preventing dental caries in children and adolescents. Cochrane Database Syst Rev. 2016 Jul 29;7:CD002284. doi: 10.1002/14651858.CD002284.pub2. PMID: 27472005. Exclusion: 4.27472005
211 Marinho VC, Worthington HV, Walsh T, . Fluoride gels for preventing dental caries in children and adolescents. Cochrane Database Syst Rev. 2015 Jun 15(6):CD002280. doi: 10.1002/14651858.CD002280.pub2. PMID: 26075879. Exclusion: 2.26075879
212 Marinho VC, Worthington HV, Walsh T, . Fluoride varnishes for preventing dental caries in children and adolescents. Cochrane Database Syst Rev. 2013 Jul 11(7):CD002279. doi: 10.1002/14651858.CD002279.pub2. PMID: 23846772. Exclusion: 2.23846772
213 Masoud MI, Allarakia R, Alamoudi NM, . Long-term clinical and bacterial effects of xylitol on patients with fixed orthodontic appliances. Prog Orthod. 2015;16(1). Exclusion: 4.
214 Medeiros PB, Otero SA, Frencken JE, . Effectiveness of an oral health program for mothers and their infants. Int J Paediatr Dent. 2015;25(1):29–34. doi: 10.1111/ipd.12094. PMID: 24393627. Exclusion: 4.24393627
215 Megalaa N, Thirumurugan K, Kayalvizhi G, . A comparative evaluation of the anticaries efficacy of herbal extracts (Tulsi and Black myrobalans) and sodium fluoride as mouthrinses in children: A randomized controlled trial. Indian J Dent Res. 2018 Nov-Dec;29(6):760–7. doi: 10.4103/ijdr.IJDR_790_16. PMID: 30589005. Exclusion: 4.30589005
216 Mei ML, Zhao IS, Ito L, . Prevention of secondary caries by silver diamine fluoride. Int Dent J. 2016 Apr;66(2):71–7. doi: 10.1111/idj.12207. PMID: 26689611. Exclusion: 4.26689611
217 Mejare I, Axelsson S, Dahlen G, . Caries risk assessment. A systematic review. Acta Odontol Scand. 2014 Feb;72(2):81–91. doi: 10.3109/00016357.2013.822548. PMID: 23998481. Exclusion: 6.23998481
218 Milgrom P, Horst JA, Ludwig S, . Topical silver diamine fluoride for dental caries arrest in preschool children: A randomized controlled trial and microbiological analysis of caries associated microbes and resistance gene expression. J Dent. 2018 01;68:72–8. doi: 10.1016/j.jdent.2017.08.015. PMID: 28866468. Exclusion: 4.28866468
219 Milgrom P, Tut O, Rothen M, . Efficacy evaluation of an anti-caries varnish: protocol for a phase II randomised controlled trial. BMJ Open. 2017 06 30;7(6):e017866. doi: 10.1136/bmjopen-2017-017866. PMID: 28667230. Exclusion: 6.28667230
220 Milgrom P, Tut O, Rothen M, . Addition of Povidone-Iodine to Fluoride Varnish for Dental Caries: A Randomized Clinical Trial. JDR Clin Trans Res. 2020 May 21:2380084420922968. doi: 10.1177/2380084420922968. PMID: 32437626. Exclusion: 4.32437626
221 Mohammadi TM, Hajizamani A, Hajizamani HR, . Fluoride varnish effect on preventing dental caries in a sample of 3-6 years old children. Journal of International Oral Health. 2015 Jan;7(1):30–5. PMID: 25709364. Exclusion: 4.25709364
222 Moyer VA, Force USPST. Prevention of dental caries in children from birth through age 5 years: US Preventive Services Task Force recommendation statement. Pediatrics. 2014 Jun;133(6):1102–11. doi: 10.1542/peds.2014-0483. PMID: 24799546. Exclusion: 2.24799546
223 Muhoozi GKM, Atukunda P, Diep LM, . Nutrition, hygiene, and stimulation education to improve growth, cognitive, language, and motor development among infants in Uganda: A cluster-randomized trial. Matern Child Nutr. 2018;14(2):e12527–e. doi: 10.1111/mcn.12527. PMID: 28925580. Exclusion: 5.28925580
224 Muthu MS, Ankita S, Renugalakshmi A, . Impact of Pharmacological Interventions in Expectant Mothers Resulting in Altered Mutans Streptococci Levels in their Children. Pediatr Dent. 2015 Sep-Oct;37(5):422–8. PMID: 26531084. Exclusion: 4.26531084
225 N T. Studies on topical application of Ag (NH3)2F for the control of interproximal caries in human primary molars: 3. Clinical trial of Ag(NH3)2F on interproximal caries in human primary molars. Jpn J Pediatr Dent. 1981;19(3):537–45. Exclusion: 10.
226 Nakai Y, Shinga-Ishihara C, Kaji M, . Xylitol gum and maternal transmission of mutans streptococci. J Dent Res. 2010;89(1):56–60. doi: 10.1177/0022034509352958. PMID: 19948944. Exclusion: 4.19948944
227 Nguyen TM, Christian B, Koshy S, . A Validation and Cost-Analysis Study of a Targeted School-Based Dental Check-Up Intervention: Children’s Dental Program. Children (Basel). 2020 Nov 26;7(12):26. doi: 10.3390/children7120257. PMID: 33256020. Exclusion: 4.33256020
228 Nguyen Y, Ueno M, Zaitsu T, . Caries arresting effect of silver diamine fluoride in vietnamese preschool children. International Journal of Clinical Preventive Dentistry. 2017 09/30;13:147–54. doi: 10.15236/ijcpd.2017.13.3.147. Exclusion: 4.
229 Nicol P, Anthonappa R, King N, . Caries burden and efficacy of a referral pathway in a cohort of preschool refugee children. Aust Dent J. 2015 Mar;60(1):73–9. doi: 10.1111/adj.12269. PMID: 25721281. Exclusion: 5.25721281
230 Nicolae A, Levin L, Wong PD, . Identification of early childhood caries in primary care settings. Paediatr Child Health. 2018 Apr;23(2):111–5. doi: 10.1093/pch/pxx155. PMID: 29686495. Exclusion: 6.29686495
231 O’Malley L, Adair P, Burnside G, . An evaluation of a storybook targeting parental attitudes, intention, and self-efficacy to change their child’s oral health behavior. Health Psychol. 2017;36(2):152–9. Exclusion: 7.27831705
232 O’Neill C, Worthington HV, Donaldson M, . Cost-Effectiveness of Caries Prevention in Practice: A Randomized Controlled Trial. J Dent Res. 2017 Jul;96(8):875–80. doi: 10.1177/0022034517708968. PMID: 28521109. Exclusion: 7.28521109
233 Oliveira BH, Rajendra A, Veitz-Keenan A, . The effect of silver diamine fluoride in preventing caries in the primary dentition: A systematic review and meta-analysis. Caries Res. 2019;53(1):24–32. doi: 10.1159/000488686. PMID: 29874642. Exclusion: 4.29874642
234 Paek AE, Li Y, Wang Z, . Caries outcome following an intensive fluoride varnish treatment regimen for children at high risk for early childhood caries. Int J Paediatr Dent. 2018 May;28(3):291–9. doi: 10.1111/ipd.12353. PMID: 29314344. Exclusion: 4.29314344
235 Paige CJ, Shahid SK. Developing and implementing a fluoride varnish programme for young children in Bradford, UK. Community Dent Health. 2014 Mar;31(1):5–8. PMID: 24741886. Exclusion: 4.24741886
236 Palit M, Hegde SK, Bhat SS. Effectiveness of mouthrinse formulated from aqueous extract of terminalia chebula on salivary streptococcus mutans count and pH among 8- to 12-year-old school children of karnataka: A randomized clinical trial. Int J Clin Pediatr Dent. 2016 Oct-Dec;9(4):349–54. doi: 10.5005/jp-journals-10005-1390. PMID: 28127168. Exclusion: 4.28127168
237 Park JS, Kruger E, Nicholls W, . Comparing the outcomes of gold-standard dental examinations with photographic screening by mid-level dental providers. Clin Oral Investig. 2019 May;23(5):2383–7. doi: 10.1007/s00784-018-2700-y. PMID: 30302610. Exclusion: 4.30302610
238 Park S, Momany ET, Jones MP, . The effects of medical well baby visits in promoting earlier first dental visits for children. JDR Clin Trans Res. 2018;3(1):91–100. doi: 10.1177/2380084417728237. Exclusion: 5.29276779
239 Perala SR, Bhupathiraju P. Efficacy of Four Fluoride Mouth Rinses on Streptococcus mutans in High Caries Risk Children - A Randomized Controlled Trial. J Clin Diagn Res. 2016 Sep;10(9):ZC56–ZC60. PMID: 27790581. Exclusion: 4.27790581
240 Pesaressi E, Villena RS, Bronkhorst EM, . Dental caries in three-year-old preschool children in Lima, Peru assessed according to the CAST instrument. Acta Odontol Latinoam. 2020 Sep 01;33(2):90–7. PMID: 32920610. Exclusion: 7.32920610
241 Petersson GH, Fure S, Twetman S, . Comparing caries risk factors and risk profiles between children and elderly. Swed Dent J. 2004;28(3):119–28. PMID: 15506689. Exclusion: 5.15506689
242 Petersson GH, Isberg PE, Twetman S. Caries risk assessment in school children using a reduced Cariogram model without saliva tests. BMC Oral Health. 2010 Apr 19;10:5. doi: 10.1186/1472-6831-10-5. PMID: 20403163. Exclusion: 4.20403163
243 Petersson GH, Isberg PE, Twetman S. Caries risk profiles in schoolchildren over 2 years assessed by Cariogram. Int J Paediatr Dent. 2010 Sep 1;20(5):341–6. doi: 10.1111/j.1365-263X.2010.01064.x. PMID: 20642470. Exclusion: 4.20642470
244 Petersson LG, Birkhed D, Gleerup A, . Caries-preventive effect of dentifrices containing various types and concentrations of fluorides and sugar alcohols. Caries Res. 1991;25(1):74–9. doi: 10.1159/000261346. PMID: 2070385. Exclusion: 5.2070385
245 Petersson LG, Koch G, Rasmusson CG, . Effect on caries of different fluoride prophylactic programs in preschool children. A two year clinical study. Swed Dent J. 1985 1985;9(3):97–104. PMID: 3895545. Exclusion: 4.3895545
246 Pieper K, Winter J, Krutisch M, . Prevention in kindergartens with 500 ppm fluoride toothpaste-a randomized clinical trial. Clin Oral Investig. 2016 Jul;20(6):1159–64. doi: 10.1007/s00784-015-1604-3. PMID: 26395351. Exclusion: 5.26395351
247 Pitchika V, Kokel CJ, Andreeva J, . Effectiveness of a new fluoride varnish for caries prevention in pre-school children. J Clin Pediatr Dent. 2013;38(1):7–12. doi: 10.1111/cdoe.12330. PMID: 24579275. Exclusion: 6.24579275
248 Plonka KA, Pukallus ML, Barnett A, . A controlled, longitudinal study of home visits compared to telephone contacts to prevent early childhood caries. Int J Paediatr Dent. 2013 Jan;23(1):23–31. doi: 10.1111/j.1365-263X.2011.01219.x. PMID: 22251427. Exclusion: 5.22251427
249 Plonka KA, Pukallus ML, Holcombe TF, . Randomized controlled trial: a randomized controlled clinical trial comparing a remineralizing paste with an antibacterial gel to prevent early childhood caries. Pediatr Dent. 2013 Jan-Feb;35(1):8–12. PMID: 23635884. Exclusion: 5.23635884
250 Plutzer K, Spencer AJ. Efficacy of an oral health promotion intervention in the prevention of early childhood caries. Community Dent Oral Epidemiol. 2008;36(4):335–46. doi: 10.1111/j.1600-0528.2007.00414.x. PMID: 19145720. Exclusion: 4.19145720
251 Pukallus ML, Plonka KA, Barnett AG, . A randomised, controlled clinical trial comparing chlorhexidine gel and low-dose fluoride toothpaste to prevent early childhood caries. Int J Paediatr Dent. 2013 May;23(3):216–24. doi: 10.1111/j.1365-263X.2012.01248.x. PMID: 22713081. Exclusion: 5.22713081
252 Pukallus ML, Plonka KA, Holcombe TF, . A randomized controlled trial of a 10 percent CPP-ACP cream to reduce mutans streptococci colonization. Pediatr Dent. 2013;35(7):550–5. PMID: 24553281. Exclusion: 5.24553281
253 Punathil S, Pulayath CV, Ismail SP, . Assessment of Enamel Surface Microhardness with different Fluoride Varnishes-An In Vitro Study. J Contemp Dent Pract. 2018 Nov 01;19(11):1317–21. PMID: 30602634. Exclusion: 6.30602634
254 Quissell DO, Bryant LL, Braun PA, . Preventing caries in preschoolers: successful initiation of an innovative community-based clinical trial in Navajo Nation Head Start. Contemp Clin Trials. 2014 Mar;37(2):242–51. doi: 10.1016/j.cct.2014.01.004. PMID: 24469238. Exclusion: 6.24469238
255 Ramesh K, Kunjappan S, Ramesh M, . Comparative evaluation of predictive value of three caries activity tests-snyder, lactobacillus count and cariostat in mixed dentition children with and without caries. J Pharm Bioallied Sci. 2013 Jun;5(Suppl 1):S63–8. doi: 10.4103/0975-7406.113299. PMID: 23946580. Exclusion: 4.23946580
256 Ramos-Gomez FJ, Gansky SA, Featherstone JDB, . Mother and youth access (MAYA) maternal chlorhexidine, counselling and paediatric fluoride varnish randomized clinical trial to prevent early childhood caries. Int J Paediatr Dent. 2012;22(3):169–79. doi: 10.1111/j.1365-263X.2011.01188.x. PMID: 21999806. Exclusion: 4.21999806
257 Razeghi S, Amiri P, Mohebbi SZ, . Impact of health promotion interventions on early childhood caries Prevention in Children Aged 2-5 Years Receiving Dental Treatment Under General Anesthesia. Front Public Health. 2020;8:6. doi: 10.3389/fpubh.2020.00006. PMID: 32175299. Exclusion: 12.32175299
258 Richards D. Fluoride gel effective at reducing caries in children. Evid Based Dent. 2015 Dec;16(4):108–9. doi: 10.1038/sj.ebd.6401131. PMID: 26680518. Exclusion: 6.26680518
259 Richards D. Caries prevention - little evidence for use of chlorhexidine varnishes and gels. Evid Based Dent. 2015 Jun;16(2):43–4. doi: 10.1038/sj.ebd.6401091. PMID: 26114784. Exclusion: 6.26114784
260 Richards D. The effectiveness of silver diamine fluoride in arresting caries. Evid Based Dent. 2017 10 27;18(3):70. doi: 10.1038/sj.ebd.6401250. PMID: 29075024. Exclusion: 6.29075024
261 Richards D. No evidence that fluoride supplements taken during pregnancy prevent caries. Evid Based Dent. 2018 10;19(3):73. doi: 10.1038/sj.ebd.6401320. PMID: 30361671. Exclusion: 6.30361671
262 Riedy CA, Weinstein P, Mancl L, . Dental attendance among low-income women and their children following a brief motivational counseling intervention: A community randomized trial. Social science & medicine (1982). 2015;144:9–18. doi: 10.1016/j.socscimed.2015.09.005. PMID: 26372934. Exclusion: 4.26372934
263 Riggs E, Kilpatrick N, Slack-Smith L, . Interventions with pregnant women, new mothers and other primary caregivers for preventing early childhood caries. Cochrane Database Syst Rev. 2019;2019(11) doi: 10.1002/14651858.CD012155.pub2. Exclusion: 6.
264 Riggs E, Kilpatrick N, Slack-Smith L, . Interventions with pregnant women, new mothers and other primary caregivers for preventing early childhood caries. Cochrane Database Syst Rev. 2020(4) doi: 10.1002/14651858.CD012155.pub2. PMID: 31745970. Exclusion: 11.31745970
265 Riley P, Lamont T. Triclosan/copolymer containing toothpastes for oral health. Cochrane Database Syst Rev. 2013 Dec 05(12):CD010514. doi: 10.1002/14651858.CD010514.pub2. PMID: 24310847. Exclusion: 4.24310847
266 Riley P, Moore D, Ahmed F, . Xylitol-containing products for preventing dental caries in children and adults. Cochrane Database Syst Rev. 2015 Mar 26(3):CD010743. doi: 10.1002/14651858.CD010743.pub2. PMID: 25809586. Exclusion: 11.25809586
267 Ritter AV, Bader JD, Leo MC, . Tooth-surface-specific effects of xylitol: randomized trial results. J Dent Res. 2013;92(6):512–7. doi: 10.1177/0022034513487211. PMID: 23589387. Exclusion: 4.23589387
268 Ritwik P. Inconclusive caries-preventive results with chlorhexidine varnish in children and adolescents. J Am Dent Assoc. 2014 Aug;145(8):856–8. doi: 10.14219/jada.2014.29. PMID: 25082935. Exclusion: 6.25082935
269 Robertson LD, Phipps KR, Oh J, . Using chlorhexidine varnish to prevent early childhood caries in American Indian children. J Public Health Dent. 2013 Winter;73(1):24–31. doi: 10.1111/j.1752-7325.2012.00348.x. PMID: 22731632. Exclusion: 5.22731632
270 Rolnick SJ, Jackson JM, DeFor TA, . Fluoride Varnish Application in the Primary Care Setting. A Clinical Study. J Clin Pediatr Dent. 2015;39(4):311–4. doi: 10.17796/1053-4628-39.4.311. PMID: 26161600. Exclusion: 6.26161600
271 Ruff RR, Sischo L, Chinn CH, . Development and validation of the Child Oral Health Impact Profile - Preschool version. Community Dent Health. 2017 Sep;34(3):176–82. doi: 10.1922/CDH_4110Ruff07. PMID: 28872813. Exclusion: 5.28872813
272 Saengtipbovorn S. Efficacy of motivational interviewing in conjunction with caries risk assessment (MICRA) programmes in improving the dental health status of preschool children: a randomised controlled trial. Oral Health Prev Dent. 2017;15(2):123–9. doi: 10.3290/j.ohpd.a37924. PMID: 28322356. Exclusion: 12.28322356
273 Salas-Lopez EK, Pierdant-Perez M, Hernandez-Sierra JF, . Effect of Silver Nanoparticle-Added Pit and Fissure Sealant in the Prevention of Dental Caries in Children. J Clin Pediatr Dent. 2017;41(1):48–52. doi: 10.17796/1053-4628-41.1.48. PMID: 28052214. Exclusion: 4.28052214
274 Sanguino SM, Dhepyasuwan N, Church A, . Oral Health Promotion During Well Visits. Clin Pediatr (Phila). 2017 Sep;56(10):894–901. doi: 10.1177/0009922817709552. PMID: 28516799. Exclusion: 5.28516799
275 Sankeshwari R, Ankola A, Bhat K, . Evaluation of Physical Parameters of Novel Licorice Varnish Versus Fluoride and Combination Varnish: An In-Vitro Study. Acta Med Acad. 2018 Nov;47(2):176–85. doi: 10.5644/ama2006-124.229. PMID: 30585069. Exclusion: 4.30585069
276 Sato R SY. Clinical application of silver ammonia fluoride (Saforide) to children. Nippon Dental Review. 1970;332:66–7. Exclusion: 10.
277 Savage MF, Lee JY, Kotch JB, . Early preventive dental visits: effects on subsequent utilization and costs. Pediatrics. 2004 Oct;114(4):e418–23. doi: 10.1542/peds.2003-0469-F. PMID: 15466066. Exclusion: 7.15466066
278 Schroth RJ, Rothney J, Sturym M, . A systematic review to inform the development of a Canadian caries risk assessment tool for use by primary healthcare providers. Int J Paediatr Dent. 2021 Jan 26;26:26. doi: 10.1111/ipd.12776. PMID: 33497015. Exclusion: 7.33497015
279 Seifo N, Al-Yaseen W, Innes N. The efficacy of silver diamine fluoride in arresting caries in children. Evid Based Dent. 2018 Jun;19(2):42–3. doi: 10.1038/sj.ebd.6401301. PMID: 29930376. Exclusion: 6.29930376
280 Senneby A, Mejare I, Sahlin NE, . Diagnostic accuracy of different caries risk assessment methods. A systematic review. J Dent. 2015 Dec;43(12):1385–93. doi: 10.1016/j.jdent.2015.10.011. PMID: 26493112. Exclusion: 6.26493112
281 Shahid M. Regular supervised fluoride mouthrinse use by children and adolescents associated with caries reduction. Evid Based Dent. 2017 03;18(1):11–2. doi: 10.1038/sj.ebd.6401217. PMID: 28338040. Exclusion: 6.28338040
282 Shinga-Ishihara C, Nakai Y, Milgrom P, . Xylitol carryover effects on salivary mutans streptococci after 13 months of chewing xylitol gum. Caries Res. 2012;46(6):519–22. doi: 10.1159/000341221. PMID: 22890503. Exclusion: 4.22890503
283 Shirzad M, Taghdisi MH, Dehdari T, . Oral health education program among pre-school children: an application of health-promoting schools approach. Health Promot Perspect. 2016;6(3):164–70. Exclusion: 4.27579261
284 Sintes JL, Elías-Boneta A, Stewart B, . Anticaries efficacy of a sodium monofluorophosphate dentifrice containing xylitol in a dicalcium phosphate dihydrate base. A 30-month caries clinical study in Costa Rica. Am J Dent. 2002 Aug;15(4):215–9. PMID: 12572637. Exclusion: 4.12572637
285 Sintes JL, Escalante C, Stewart B, . Enhanced anticaries efficacy of a 0.243% sodium fluoride/10% xylitol/silica dentifrice: 3-year clinical results. Am J Dent. 1995 Oct;8(5):231–5. PMID: 8634157. Exclusion: 4.8634157
286 Sitthisettapong T, Phantumvanit P, Huebner C, . Effect of CPP-ACP Paste on Dental Caries in Primary Teeth: A Randomized Trial. J Dent Res. 2012 2012/09/01;91(9):847–52. doi: 10.1177/0022034512454296. Exclusion: 5.22805294
287 Skeie MS, Klock KS. Dental caries prevention strategies among children and adolescents with immigrant - or low socioeconomic backgrounds- do they work? A systematic review. BMC Oral Health. 2018 02 07;18(1):20. doi: 10.1186/s12903-018-0478-6. PMID: 29415706. Exclusion: 4.29415706
288 Slade GD, Grider WB, Maas WR, . Water fluoridation and dental caries in U.S. children and adolescents. J Dent Res. 2018 09;97(10):1122–8. doi: 10.1177/0022034518774331. PMID: 29900806. Exclusion: 2.29900806
289 Smith NH, Lutz T, Maupome G, . Long-term effects of a toddler-focused caries prevention programme among Northwestern US tribal children: The TOTS-to-Tweens study. Community Dent Oral Epidemiol. 2021 Jun;49(3):284–90. doi: 10.1111/cdoe.12600. PMID: 33274563. Exclusion: 5.33274563
290 Söderling E, Isokangas P, Pienihäkkinen K, . Influence of maternal xylitol consumption on acquisition of mutans streptococci by infants. J Dent Res. 2000;79(3):882–7. doi: 10.1177/00220345000790031601. PMID: 10765964. Exclusion: 4.10765964
291 Söderling E, Isokangas P, Pienihäkkinen K, . Influence of maternal xylitol consumption on mother-child transmission of mutans streptococci: 6-year follow-up. Caries Res. 2001 May-Jun;35(3):173–7. doi: 10.1159/000047452. PMID: 11385196. Exclusion: 4.11385196
292 Steel K. How effective is the application of topical fluoride varnish in preventing dental caries in children? a literature review. Prim Dent J. 2014 Aug;3(3):74–6. PMID: 25198645. Exclusion: 11.25198645
293 Stojkovic B, Igic M, Jevtovic Stoimenov T, . Can Salivary Biomarkers Be Used as Predictors of Dental Caries in Young Adolescents? Med Sci Monit. 2020 Jun 10;26:e923471. doi: 10.12659/MSM.923471. PMID: 32518218. Exclusion: 4.32518218
294 Strickland M, Duda P, Merdad HE, . The clinical performance of chairside caries risk assessment kits. Quintessence Int. 2017;48(2):161–71. doi: 10.3290/j.qi.a37152. PMID: 27834421. Exclusion: 4.27834421
295 Sudhanthar S, Lapinski J, Turner J, . Improving oral health through dental fluoride varnish application in a primary care paediatric practice. BMJ Open Qual. 2019;8(2):e000589. doi: 10.1136/bmjoq-2018-000589. PMID: 31259286. Exclusion: 7.31259286
296 Sun P, Chen W, Yi X, . [A comparative study on early childhood caries detection by using international caries detection and assessment system-II and WHO criteria]. Chung Hua Kou Chiang Hsueh Tsa Chih. 2018 Nov 09;53(11):725–9. doi: 10.3760/cma.j.issn.1002-0098.2018.11.002. PMID: 30419651. Exclusion: 10.30419651
297 Sundell AL, Ullbro C, Koch G. Evaluation of preventive programs in high caries active preschool children. Swed Dent J. 2013;37(1):23–9. PMID: 23721034. Exclusion: 4.23721034
298 Sundell AL, Ullbro C, Marcusson A, . Comparing caries risk profiles between 5- and 10- year-old children with cleft lip and/or palate and non-cleft controls. BMC Oral Health. 2015 Jul 25;15:85. doi: 10.1186/s12903-015-0067-x. PMID: 26208495. Exclusion: 4.26208495
299 Taipale T, Pienihakkinen K, Alanen P, . Administration of Bifidobacterium animalis subsp. lactis BB-12 in early childhood: a post-trial effect on caries occurrence at four years of age. Caries Res. 2013;47(5):364–72. doi: 10.1159/000348424. PMID: 23571819. Exclusion: 12.23571819
300 Takahashi R, Ota E, Hoshi K, . Fluoride supplementation (with tablets, drops, lozenges or chewing gum) in pregnant women for preventing dental caries in the primary teeth of their children. Cochrane Database Syst Rev. 2017 10 23;10:CD011850. doi: 10.1002/14651858.CD011850.pub2. PMID: 29059464. Exclusion: 11.29059464
301 Teng F, Yang F, Huang S, . Prediction of Early Childhood Caries via Spatial-Temporal Variations of Oral Microbiota. Cell Host Microbe. 2015 Sep 09;18(3):296–306. doi: 10.1016/j.chom.2015.08.005. PMID: 26355216. Exclusion: 7.26355216
302 Teo TK, Ashley PF, Louca C. An in vivo and in vitro investigation of the use of ICDAS, DIAGNOdent pen and CarieScan PRO for the detection and assessment of occlusal caries in primary molar teeth. Clin Oral Investig. 2014 Apr;18(3):737–44. doi: 10.1007/s00784-013-1021-4. PMID: 23793456. Exclusion: 4.23793456
303 Thorild I, Lindau B, Twetman S. Effect of maternal use of chewing gums containing xylitol, chlorhexidine or fluoride on mutans streptococci colonization in the mothers’ infant children. Oral Health Prev Dent. 2003;1(1):53–7. PMID: 15643749. Exclusion: 4.15643749
304 Thorild I, Lindau B, Twetman S. Salivary mutans streptococci and dental caries in three-year-old children after maternal exposure to chewing gums containing combinations of xylitol, sorbitol, chlorhexidine, and fluoride. Acta Odontol Scand. 2004 2004/01/01;62(5):245–50. doi: 10.1080/00016350410001676. Exclusion: 4.15841810
305 Thorild I, Lindau B, Twetman S. Caries in 4-year-old children after maternal chewing of gums containing combinations of xylitol, sorbitol, chlorhexidine and fluoride. European archives of paediatric dentistry : official journal of the European Academy of Paediatric Dentistry. 2006;7(4):241–5. doi: 10.1007/bf03262559. PMID: 17164069. Exclusion: 4.17164069
306 Thorild I, Lindau B, Twetman S. Long-term effect of maternal xylitol exposure on their children’s caries prevalence. Eur Arch Paediatr Dent. 2012 2012/12/01;13(6):305–7. doi: 10.1007/BF03320831. Exclusion: 4.23235130
307 Timms L, Deery C. Fluoride varnish and dental caries in preschoolers: a systematic review and meta-analysis. Evid Based Dent. 2020 Mar;21(1):18–9. doi: 10.1038/s41432-020-0074-x. PMID: 32221488. Exclusion: 6.32221488
308 Tomasin L, Pusinanti L, Zerman N. The role of fluoride tablets in the prophylaxis of dental caries. A literature review. Ann Stomatol (Roma). 2015 Jan-Mar;6(1):1–5. PMID: 26161245. Exclusion: 4.26161245
309 Treide A, Treide B. The anticaries effectiveness of newly developed fluoride-containing gels following 3 years of clinical use in preschool children. Stomatologie der DDR. 1988;38(10):708–12. Exclusion: 10.3269091
310 Trieu A, Mohamed A, Lynch E. Silver diamine fluoride versus sodium fluoride for arresting dentine caries in children: a systematic review and meta-analysis. Sci Rep. 2019 Feb 14;9(1):2115. doi: 10.1038/s41598-019-38569-9. PMID: 30765785. Exclusion: 11.30765785
311 TubertJeannin S, Auclair C, Amsallem E, . Fluoride supplements (tablets, drops, lozenges or chewing gums) for preventing dental caries in children. Cochrane Database Syst Rev. 2011(12) doi: 10.1002/14651858.CD011850.pub2. PMID: 29059464. Exclusion: 4.29059464
312 Turska-Szybka A, Gozdowski D, Twetman S, . Clinical Effect of Two Fluoride Varnishes in Caries-Active Preschool Children: A Randomized Controlled Trial. Caries Res. 2021;55(2):137–43. doi: 10.1159/000514168. PMID: 33706305. Exclusion: 4.33706305
313 Twetman S. Caries risk assessment in children: how accurate are we? Eur Arch Paediatr Dent. 2016 Feb;17(1):27–32. doi: 10.1007/s40368-015-0195-7. PMID: 26189019. Exclusion: 4.26189019
314 Twetman S, Petersson GH, Bratthall D. Caries risk assessment as a predictor of metabolic control in young Type 1 diabetics. Diabet Med. 2005 Mar;22(3):312–5. doi: 10.1111/j.1464-5491.2005.01419.x. PMID: 15717880. Exclusion: 4.15717880
315 Ulu Guzel KG, Akyildiz M, Dogusal G, . Evaluation of oral health status of children in pretreatment and after treatment for 18 month. Cent Eur J Public Health. 2018 Sep;26(3):199–203. doi: 10.21101/cejph.a5079. PMID: 30419622. Exclusion: 4.30419622
316 Urquhart O, Tampi MP, Pilcher L, . Nonrestorative Treatments for Caries: Systematic Review and Network Meta-analysis. J Dent Res. 2019 Jan;98(1):14–26. doi: 10.1177/0022034518800014. PMID: 30290130. Exclusion: 4.30290130
317 Verlinden DA, Schuller AA, Verrips GHW, . Effectiveness of a short web-based film targeting parental oral health knowledge in a well-child care setting. Eur J Oral Sci. 2020;128(3):226–32. doi: 10.1111/eos.12700. PMID: 32396668. Exclusion: 7.32396668
318 Vilhena FV, Olympio KP, Lauris JR, . Low-fluoride acidic dentifrice: a randomized clinical trial in a fluoridated area. Caries Res. 2010;44(5):478–84. doi: 10.1159/000320364. PMID: 20861632. Exclusion: 4.20861632
319 Villavicencio J, Villegas LM, Arango MC, . Effects of a food enriched with probiotics on Streptococcus mutans and Lactobacillus spp. salivary counts in preschool children: a cluster randomized trial. J Appl Oral Sci. 2018 May 14;26:e20170318. doi: 10.1590/1678-7757-2017-0318. PMID: 29768525. Exclusion: 5.29768525
320 Wagle M, Acharya G, Basnet P, . Knowledge about preventive dentistry versus self-reported competence in providing preventive oral healthcare - a study among Nepalese dentists. BMC Oral Health. 2017 Apr 12;17(1):76. doi: 10.1186/s12903-017-0366-5. PMID: 28403843. Exclusion: 5.28403843
321 Wagner Y, Greiner S, Heinrich-Weltzien R. Evaluation of an oral health promotion program at the time of birth on dental caries in 5-year-old children in Vorarlberg, Austria. Community Dent Oral Epidemiol. 2014 Apr;42(2):160–9. doi: 10.1111/cdoe.12072. PMID: 24033742. Exclusion: 6.24033742
322 Wagner Y, Heinrich-Weltzien R. Evaluation of an interdisciplinary preventive programme for early childhood caries: findings of a regional German birth cohort study. Clin Oral Investig. 2016 Nov;20(8):1943–52. PMID: 26662355. Exclusion: 6.26662355
323 Wagner Y, Heinrich-Weltzien R. Evaluation of a regional German interdisciplinary oral health programme for children from birth to 5 years of age. Clin Oral Investig. 2017 Jan;21(1):225–35. doi: 10.1007/s00784-016-1781-8. PMID: 26979442. Exclusion: 6.26979442
324 Walsh T, Oliveira-Neto JM, Moore D. Chlorhexidine treatment for the prevention of dental caries in children and adolescents. Cochrane Database Syst Rev. 2015 Apr 13(4):CD008457. doi: 10.1002/14651858.CD008457.pub2. PMID: 25867816. Exclusion: 4.25867816
325 Walsh T, Worthington HV, Glenny AM, . Fluoride toothpastes of different concentrations for preventing dental caries. Cochrane Database Syst Rev. 2019 03 04;3:CD007868. doi: 10.1002/14651858.CD007868.pub3. PMID: 30829399. Exclusion: 4.30829399
326 Wang Y, Hays R, Marcus M, . Development of a parents’ short form survey of their children’s oral health. Int J Paediatr Dent. 2019 May;29(3):332–44. doi: 10.1111/ipd.12453. PMID: 30481390. Exclusion: 7.30481390
327 Wang Y, Li J, Sun W, . Effect of non-fluoride agents on the prevention of dental caries in primary dentition: A systematic review. PLoS ONE. 2017;12(8):e0182221. doi: 10.1371/journal.pone.0182221. PMID: 28787448. Exclusion: 4.28787448
328 Watt RG, Tull KI, Hardy R, . Effectiveness of a social support intervention on infant feeding practices: randomised controlled trial. J Epidemiol Community Health. 2009;63(2):156–62. doi: 10.1136/jech.2008.077115. PMID: 19141661. Exclusion: 7.19141661
329 Weinstein P, Harrison R, Benton T. Motivating mothers to prevent caries: Confirming the beneficial effect of counseling. J Am Dent Assoc. 2006 2006/06/01/;137(6):789–93. doi: 10.14219/jada.archive.2006.0291. Exclusion: 5.16803808
330 Weyant RJ, Tracy SL, Anselmo TT, . Topical fluoride for caries prevention: executive summary of the updated clinical recommendations and supporting systematic review. J Am Dent Assoc. 2013 Nov;144(11):1279–91. doi: 10.14219/jada.archive.2013.0057. PMID: 24177407. Exclusion: 2.24177407
331 Winter GB, Holt RD, Williams BF. Clinical trial of a low-fluoride toothpaste for young children. Int Dent J. 1989 Dec;39(4):227–35. PMID: 2691402. Exclusion: 5.2691402
332 Wright JT, Tampi MP, Graham L, . Sealants for Preventing and Arresting Pit-and-fissure Occlusal Caries in Primary and Permanent Molars. Pediatr Dent. 2016;38(4):282–308. PMID: 27557916. Exclusion: 4.27557916
333 Wright JT, Tampi MP, Graham L, . Sealants for preventing and arresting pit-and-fissure occlusal caries in primary and permanent molars: A systematic review of randomized controlled trials-a report of the American Dental Association and the American Academy of Pediatric Dentistry. J Am Dent Assoc. 2016 08;147(8):631–45.e18. doi: 10.1016/j.adaj.2016.06.003. PMID: 27470524. Exclusion: 4.27470524
334 Wright W, Turner S, Anopa Y, . Comparison of the caries-protective effect of fluoride varnish with treatment as usual in nursery school attendees receiving preventive oral health support through the Childsmile oral health improvement programme - the Protecting Teeth@3 Study: a randomised controlled trial. BMC Oral Health. 2015 Dec 18;15:160. doi: 10.1186/s12903-015-0146-z. PMID: 26681191. Exclusion: 6.26681191
335 Wu S, Zhang T, Liu Q, . Effectiveness of fluoride varnish on caries in the first molars of primary schoolchildren: a 3-year longitudinal study in Guangxi Province, China. Int Dent J. 2020 Apr;70(2):108–15. doi: 10.1111/idj.12528. PMID: 31705529. Exclusion: 4.31705529
336 Xiao J, Alkhers N, Kopycka-Kedzierawski DT, . Prenatal oral health care and early childhood caries prevention: A systematic review and meta-analysis. Caries Res. 2019;53(4):411–21. doi: 10.1159/000495187. PMID: 30630167. Exclusion: 11.30630167
337 Xuan SY, Yuan JW, Wang J, . [A 2-year cohort study on the caries risk assessment of 3-year-old caries-free children using Cariostat caries activity test]. Chung Hua Kou Chiang Hsueh Tsa Chih. 2017 Nov 09;52(11):667–71. doi: 10.3760/cma.j.issn.1002-0098.2017.11.004. PMID: 29972945. Exclusion: 10.29972945
338 Yates C, Duane B. Maternal xylitol and mutans streptococci transmission. Evid Based Dent. 2015 Jun;16(2):41–2. doi: 10.1038/sj.ebd.6401090. PMID: 26114783. Exclusion: 6.26114783
339 Yee R, Holmgren C, Mulder J, . Efficacy of silver diamine fluoride for Arresting Caries Treatment. J Dent Res. 2009 Jul;88(7):644–7. doi: 10.1177/0022034509338671. PMID: 19641152. Exclusion: 4.19641152
340 Yeung AC, Chong L-Y, Glenny A-M. Fluoridated milk for preventing dental caries. Cochrane Database Syst Rev. 2018(5). Exclusion: 6.
341 Yeung SST, Argaez C. CADTH Rapid Response Reports. Silver Diamine Fluoride for the Prevention and Arresting of Dental Caries or Hypersensitivity: A Review of Clinical Effectiveness, Cost-Effectiveness and Guidelines. Ottawa (ON): Canadian Agency for Drugs and Technologies in Health; 2017. Exclusion: 6.
342 Yoshida S OM, Mori S, Baba H. Evaluation of topical application of diamine silver fluoride to pit and fissure of primary molars. J Gifu Dent Soc. 1976;4:35–41. Exclusion: 10.
343 You W, Hao A, Li S, . Deep learning-based dental plaque detection on primary teeth: a comparison with clinical assessments. BMC Oral Health. 2020 May 13;20(1):141. doi: 10.1186/s12903-020-01114-6. PMID: 32404094. Exclusion: 5.32404094
344 Zanata RL, Navarro MFdL, Pereira JC, . Effect of caries preventive measures directed to expectant mothers on caries experience in their children. Braz Dent J. 2003;14(2):75–81. doi: 10.1590/s0103-64402003000200001. PMID: 12964648. Exclusion: 4.12964648
345 Zhan L, Featherstone JD, Lo J, . Clinical efficacy and effects of xylitol wipes on bacterial virulence. Adv Dent Res. 2012 Sep;24(2):117–22. doi: 10.1177/0022034512449835. PMID: 22899693. Exclusion: 7.22899693
346 Zhou N, Wong HM, McGrath C. Social story-based oral health promotion for preschool children with special healthcare needs: A 24-month randomized controlled trial. Community Dent Oral Epidemiol. 2020 Jun 23;23:23. doi: 10.1111/cdoe.12554. PMID: 32578261. Exclusion: 5.32578261
347 Zhou N, Wong HM, Wen YF, . Efficacy of caries and gingivitis prevention strategies among children and adolescents with intellectual disabilities: a systematic review and meta-analysis. J Intellect Disabil Res. 2019 Jun;63(6):507–18. doi: 10.1111/jir.12576. PMID: 30575187. Exclusion: 4.30575187
348 Zukanovic A. Caries risk assessment models in caries prediction. Acta Med Acad. 2013 Nov;42(2):198–208. doi: 10.5644/ama2006-124.87. PMID: 24308399. Exclusion: 7.24308399

## Appendix A6 Criteria for Assessing Internal Validity of Individual Studies^*^

### Systematic Reviews

Criteria:

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

Definition of ratings based on above criteria:

Good:: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions.
Fair:: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies.
Poor:: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies.

### Case-Control Studies

Criteria:

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls, with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

Definition of ratings based on above criteria:

Good:: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80%; accurate diagnostic procedures and measurements applied equally to cases and controls; and appropriate attention to confounding variables.
Fair:: Recent, relevant, and without major apparent selection or diagnostic workup bias, but response rate less than 80% or attention to some but not all important confounding variables.
Poor:: Major selection or diagnostic workup bias, response rate less than 50%, or inattention to confounding variables.

### RCTs and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  ○ For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ For cohort studies: consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs

Definition of ratings based on above criteria:

Good:: Meets all criteria: comparable groups are assembled initially and maintained throughout the study (followup greater than or equal to 80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair:: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
Poor:: Studies are graded “poor” if any of the following fatal flaws exists: groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of ratings based on above criteria:

Good:: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (greater than 100) of broad-spectrum patients with and without disease.
Fair:: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
Poor:: Has a fatal flaw, such as: uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients.

## Appendix A7 Expert and Federal Reviewers

### Expert Reviewers

- Edward Chin Man Lo, BDS, MDS, PhD
  Professor, Division of Applied Oral Sciences & Community Dental Care
  Faculty of Dentistry at The University of Hong Kong
- David M. Kroll, MD, MPH
  Medical Director
  Connecticut Children’s Care Network
- Steven M. Levy, DDS, MPH
  Professor of Research, Department of Preventive & Community Dentistry
  College of Dentistry and Dental Clinics
  The University of Iowa
- Hugh Silk, MD, MPH
  Professor
  University of Massachusetts Medical School
- Margherita Fontana, DDS, PhD
  Professor of Dentistry
  University of Michigan School of Dentistry

### Federal Reviewers

- Erin M. Abramsohn, DrPH, MPH
  Office of the Associate Director for Policy and Strategy
  Centers for Disease Control and Prevention
- Darien Weatherspoon, DDS, MPH
  National Institutes of Health/National Institute of Dental and Craniofacial Research
- Frederick Hyman, DDS, MPH
  Dental Officer
  U.S. Food and Drug Administration
- Benyam Hailu, MD, MPH
  Medical Officer
  National Institute on Minority Health and Health Disparities

* Reference: U.S. Preventive Services Task Force Procedure Manual. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual/procedure-manual-appendix-vi-criteria-assessing-internal-validity-individual-studies. Accessed on August 9, 2021.