# References

1 U.S. Department of Health and Human Services, Public Health Service, Office of the Surgeon General. The Surgeon General's Call to Action to Prevent and Decrease Overweight and Obesity. Rockville, Md: U.S. Government Printing Office, Washington; 2001.
2 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Alexandria, Virginia: International Medical Publishing, Inc.;1996:219–229.
3 NHLBI Obesity Education Initiative. Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults: the Evidence Report. Bethesda, MD: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Heart, Lung, and Blood Institute. 1998;NIH Publication No. 98-4083.
4 Lapidus L, Bengtsson C, Larsson B, Pennert K, Rybo E, Sjostrom L. Distribution of adipose tissue and risk of cardiovascular disease and death: a 12 year follow up of participants in the population study of women in Gothenburg, Sweden. BMJ (Clin Res Ed). 1984;289:1257-1261.
5 Lee I M, Manson J E, Hennekens C H, Paffenbarger R S Jr. Body weight and mortality. A 27-year follow-up of middle-aged men. J Am Med Assoc. 1993;270:2823-2828.
6 Despres J P, Moorjani S, Lupien P J, Tremblay A, Nadeau A, Bouchard C. Regional distribution of body fat, plasma lipoproteins, and cardiovascular disease. Arteriosclerosis. 1990;10:497-511. [pmid: 2196040].
7 National Center for Health Statistics. Health, United States, 2001. With Urban and Rural Health Chartbook, Hyattsville, MD: National Center for Health Statistics; 2001.
8 National Center for Health Statistics. Prevalence of Overweight and Obesity Among Adults: United States, 1999. Available at: www.cdc.gov/nchs/products/pubs/pubd/hestats/obese/obese99.htm. Accessed June 15, 2002.
9 Dietz W H. Overweight and precursors of type 2 diabetes mellitus in children and adolescents. J Pediatr. 2001;138:453-454. [pmid: 11295702].
10 Strauss R S, Pollack H A. Epidemic increase in childhood overweight, 1986-1998. J Am Med Assoc. 2001;286:2845-1848.
11 Mokdad A H, Serdula M K, Dietz W H, Bowman B A, Marks J S, Koplan J P. The continuing epidemic of obesity in the United States. J Am Med Assoc. 2000;284:1650-1651.
12 Must A, Spadano J, Coakley E H, Field A E, Colditz G, Dietz W H. The disease burden associated with overweight and obesity. J Am Med Assoc. 1999;282:1523-1529.
13 Radimer K L, Subar A F, Thompson F E. Nonvitamin, nonmineral dietary supplements: issues and findings from NHANES III. J Am Diet Assoc. 2000;100:447-454. [pmid: 10767902].
14 Roe DA, Eickwort KR. Relationships between obesity and associated health factors with unemployment among low income women. J Am Med Womens Assoc. 1976;31:193–194, 198–199, 203–204.
15 Sorkin J D, Muller D, Andres R. Body mass index and mortality in Seventh-day Adventist men. A critique and re-analysis. Int J Obes Relat Metab Disord. 1994;18:752-754. [pmid: 7866475].
16 Manson J E, Willett W C, Stampfer M J, et al. Body weight and mortality among women. N Engl J Med. 1995;333:677-685. [pmid: 7637744].
17 Laara E, Rantakallio P. Body size and mortality in women: a 29 year follow up of 12,000 pregnant women in northern Finland. J Epidemiol Community Health. 1996;50:408-414. [pmid: 8882224]. [pmcid: 1060311].
18 Shaper A G, Wannamethee S G, Walker M. Body weight: implications for the prevention of coronary heart disease, stroke, and diabetes mellitus in a cohort study of middle aged men. BMJ. 1997;314:1311-1317. [pmid: 9158466]. [pmcid: 2126570].
19 Chyou P H, Burchfiel C M, Yano K, et al. Obesity, alcohol consumption, smoking, and mortality. Ann Epidemiol. 1997;7:311-317. [pmid: 9177115].
20 Wannamethee S G, Shaper A G, Walker M, Ebrahim S. Lifestyle and 15-year survival free of heart attack, stroke, and diabetes in middle-aged British men. Arch Intern Med. 1998;158:2433-2440. [pmid: 9855381].
21 Huang Z, Willett W C, Manson J E, et al. Body weight, weight change, and risk for hypertension in women. Ann Intern Med. 1998;128:81-88. [pmid: 9441586].
22 Durazo-Arvizu R A, McGee D L, Cooper R S, Liao Y, Luke A. Mortality and optimal body mass index in a sample of the US population. Am J Epidemiol. 1998;147:739-749. [pmid: 9554415].
23 Calle E E, Thun M J, Petrelli J M, Rodriguez C, Heath C W J. Body-mass index and mortality in a prospective cohort of U.S. adults. N Engl J Med. 1999;341:1097-1105. [pmid: 10511607].
24 Rosengren A, Wedel H, Wilhelmsen L. Body weight and weight gain during adult life in men in relation to coronary heart disease and mortality. A prospective population study. Eur Heart J. 1999;20:269-277. [pmid: 10099921].
25 Folsom A R, Kushi L H, Anderson K E, et al. Associations of general and abdominal obesity with multiple health outcomes in older women: the Iowa Women's Health Study. Arch Intern Med. 2000;160:2117-2128. [pmid: 10904454].
26 Song Y M, Sung J. Body mass index and mortality: a twelve-year prospective study in Korea. Epidemiol. 2001;12:173-179.
27 Kim K S, Owen W L, Williams D, Adams-Campbell L L. A comparison between BMI and Conicity index on predicting coronary heart disease: the Framingham Heart Study. Ann Epidemiol. 2000;10:424-431. [pmid: 11018345].
28 Stevens J, Cai J, Pamuk E R, Williamson D F, Thun M J, Wood J L. The effect of age on the association between body-mass index and mortality. N Engl J Med. 1998;338:1-7. [pmid: 9414324].
29 Heiat A, Vaccarino V, Krumholz H M. An evidence-based assessment of federal guidelines for overweight and obesity as they apply to elderly persons. Arch Intern Med. 2001;161:1194-1203. [pmid: 11343442].
30 Stevens J. Obesity and mortality in Africans-Americans. Nutr Rev. 2000;58:346-353. [pmid: 11140906].
31 Weight cycling. National Task Force on the Prevention and Treatment of Obesity. JAMA. 1994;272:1196–1202.
32 Williamson D F. “Weight cycling” and mortality: how do the epidemiologists explain the role of intentional weight loss?. J Am Coll Nutr. 1996;15:6-13. [pmid: 8632117].
33 Reynolds M W, Fredman L, Langenberg P, Magaziner J. Weight, weight change, mortality in a random sample of older community-dwelling women. J Am Geriatr Soc. 1999;47:1409-1414. [pmid: 10591233].
34 Williamson D F, Pamuk E R. The association between weight loss and increased longevity. A review of the evidence. Ann Intern Med. 1993;119:731-736. [pmid: 8363207].
35 Olson M B, Kelsey S F, Bittner V, et al. Weight cycling and high-density lipoprotein cholesterol in women: evidence of an adverse effect: a report from the NHLBI-sponsored WISE study. Women's Ischemia Syndrome Evaluation Study Group. J Am Coll Cardiol. 2000;36:1565-1571. [pmid: 11079659].
36 Field A E, Wing R R, Manson J E, Spiegelman D L, Willett W C. Relationship of a large weight loss to long-term weight change among young and middle-aged US women. Int J Obes Relat Metab Disord. 2001;25:1113-1121. [pmid: 11477495].
37 Guagnano M T, Ballone E, Pace-Palitti V, et al. Risk factors for hypertension in obese women. The role of weight cycling. Eur J Clin Nutr. 2000;54:356-360. [pmid: 10745288].
38 Petersmarck K A, Teitelbaum H S, Bond J T, Bianchi L, Hoerr S M, Sowers M F. The effect of weight cycling on blood lipids and blood pressure in the Multiple Risk Factor Intervention Trial Special Intervention Group. Int J Obes Relat Metab Disord. 1999;23:1246-1255. [pmid: 10643680].
39 Carmody T P, Brunner R L, St Jeor S T. Hostility, dieting, and nutrition attitudes in overweight and weight- cycling men and women. Int J Eat Disord. 1999;26:37-42. [pmid: 10349582].
40 Simkin-Silverman L R, Wing R R, Plantinga P, Matthews K A, Kuller L H. Lifetime weight cycling and psychological health in normal-weight and overweight women. Int J Eat Disord. 1998;24:175-183. [pmid: 9697016].
41 Singh R B, Rastogi S S, Verma R, et al. Randomised controlled trial of cardioprotective diet in patients with recent acute myocardial infarction: results of one year follow up. BMJ. 1992;304:1015-1019. [pmid: 1586782]. [pmcid: 1881705].
42 Wolf A M, Colditz G A. Current estimates of the economic cost of obesity in the United States. Obes Res. 1998;6:97-106. [pmid: 9545015].
43 Birmingham C L, Muller J L, Palepu A, Spinelli J J, Anis A H. The cost of obesity in Canada. Can Med Assoc J. 1999;160:483-488. [pmid: 10081464]. [pmcid: 1230073].
44 Thompson D, Edelsberg J, Colditz G A, Bird A P, Oster G. Lifetime health and economic consequences of obesity. Arch Intern Med. 1999;159:2177-2183. [pmid: 10527295].
45 Galuska D A, Will J C, Serdula M K, Ford E S. Are health care professionals advising obese patients to lose weight?. JAMA. 1999;282:1576-1578. [pmid: 10546698].
46 Douketis J D, Feightner J W, Attia J, Feldman W F. Periodic health examination, 1999 update: 1. Detection, prevention and treatment of obesity. Canadian Task Force on Preventive Health Care. Can Med Assoc J. 1999;160:513-525. [pmid: 10081468]. [pmcid: 1230077].
47 NHS Centre for Reviews and Dissemination University of York. The prevention and treatment of obesity. Eff Health Care. 1997;3:1-12.
48 Colditz G A, Willett W C, Rotnitzky A, Manson J E. Weight gain as a risk factor for clinical diabetes mellitus in women. Ann Intern Med. 1995;122:481-486. [pmid: 7872581].
49 Willett W C, Manson J E, Stampfer M J, et al. Weight, weight change, and coronary heart disease in women. Risk within the ‘normal’ weight range. JAMA. 1995;273:461-465. [pmid: 7654270].
50 Harris R P, Helfand M, Woolf S H, et al. Current methods of the U.S. Preventive Services Task Force. A review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
51 Arterburn D, Noel PH. Effects of drug treatment for obesity in adults. BMJ Clin Evid. 2001;412–419.
52 Wadden T A, Berkowitz R I, Sarwer D B, Prus-Wisniewski R, Steinberg C. Benefits of lifestyle modification in the pharmacologic treatment of obesity: a randomized trial. Arch Intern Med. 2001;161:218-227. [pmid: 11176735].
53 Gray D S, Fujioka K. Use of relative weight and Body Mass Index for the determination of adiposity. J Clin Epidemiol. 1991;44:545-550. [pmid: 2037859].
54 Deurenberg P, Weststrate J A, Seidell J C. Body mass index as a measure of body fatness: age- and sex-specific prediction formulas. Br J Nutr. 1991;65:105-114. [pmid: 2043597].
55 Wang J, Thornton J C, Russell M, Burastero S, Heymsfield S, Pierson R N Jr. Asians have lower body mass index (BMI) but higher percent body fat than do whites: comparisons of anthropometric measurements. Am J Clin Nutr. 1994;60:23-28. [pmid: 8017333].
56 Deurenberg P, Yap M, van Staveren W A. Body mass index and percent body fat: a meta analysis among different ethnic groups. Int J Obes Relat Metab Disord. 1998;22:1164-1171. [pmid: 9877251].
57 Gurrici S, Hartriyanti Y, Hautvast J G, Deurenberg P. Relationship between body fat and body mass index: differences between Indonesians and Dutch Caucasians. Eur J Clin Nutr. 1998;52:779-783. [pmid: 9846588].
58 Deurenberg P, van der Kooy K, Hulshof T, Evers P. Body mass index as a measure of body fatness in the elderly. Eur J Clin Nutr. 1989;43:231-236. [pmid: 2661215].
59 Kramer H, Berkowitz R I, Hammer L D. Methodological difficulties in studies of obesity. I: Measurement Issues. Ann Behav Med. 1990;12:112-118.
60 National Task Force on the Prevention and Treatment of Obesity. Long-term Pharmacotherapy in the management of obesity. JAMA. 1996;276:1907-1915. [pmid: 8968018].
61 Lee C D, Blair S N, Jackson A S. Cardiorespiratory fitness, body composition, and all-cause and cardiovascular disease mortality in men. Am J Clin Nutr. 1999;69:373-380. [pmid: 10075319].
62 Liese A D, Mayer-Davis E J, Tyroler H A, et al. Development of the multiple metabolic syndrome in the ARIC cohort: joint contribution of insulin, BMI, and WHR. Atherosclerosis risk in communities. Ann Epidemiol. 1997;7:407-416. [pmid: 9279450].
63 Baik I, Ascherio A, Rimm E B, et al. Adiposity and mortality in men. Am J Epidemiol. 2000;152:264-271. [pmid: 10933273].
64 Rexrode K M, Carey V J, Hennekens C H, et al. Abdominal adiposity and coronary heart disease in women. JAMA. 1998;280:1843-1848. [pmid: 9846779].
65 Kuller L H, Simkin-Silverman L R, Wing R R, Meilahn E N, Ives D G. Women's Healthy Lifestyle Project: A randomized clinical trial: results at 54 months. Circ. 2001;103:32-37.
66 Tuomilehto J, Lindstrom J, Eriksson J G, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344:1343-1350. [pmid: 11333990].
67 Rothacker D Q, Staniszewski B A, Ellis P K. Liquid meal replacement vs traditional food: a potential model for women who cannot maintain eating habit change. J Am Diet Assoc. 2001;101:345-347. [pmid: 11269616].
68 Jones D W, Miller M E, Wofford M R, et al. The effect of weight loss intervention on antihypertensive medication requirements in the Hypertension Optimal Treatment (HOT) study. Am J Hypertens. 1999;12:1175-1180. [pmid: 10619579].
69 Stevens V J, Obarzanek E, Cook N R, et al. Long-term weight loss and changes in blood pressure: results of the Trials of Hypertension Prevention, phase II. Ann Intern Med. 2001;134:1-11. [pmid: 11187414].
70 Swinburn B A, Woollard G A, Chang E C, Wilson M R. Effects of reduced-fat diets consumed ad libitum on intake of nutrients, particularly antioxidant vitamins. J Am Diet Assoc. 1999;99:1400-1405. [pmid: 10570677].
71 Jakicic J M, Winters C, Lang W, Wing R R. Effects of intermittent exercise and use of home exercise equipment on adherence, weight loss, and fitness in overweight women: a randomized trial. JAMA. 1999;282:1554-1560. [pmid: 10546695].
72 Leermakers E A, Perri M G, Shigaki C L, Fuller P R. Effects of exercise-focused versus weight-focused maintenance programs on the management of obesity. Addict Behav. 1999;24:219-227. [pmid: 10336103].
73 Sbrocco T, Nedegaard R C, Stone J M, Lewis E L. Behavioral choice treatment promotes continuing weight loss: preliminary results of a cognitive-behavioral decision-based treatment for obesity. J Consult Clin Psychol. 1999;67:260-266. [pmid: 10224737].
74 Fogelholm M, Kukkonen-Harjula K, Nenonen A, Pasanen M. Effects of walking training on weight maintenance after a very-low-energy diet in premenopausal obese women: a randomized controlled trial. Arch Intern Med. 2000;160:2177-2184. [pmid: 10904461].
75 Jeffery R W, French S A. Preventing weight gain in adults: design, methods and one year results from the Pound of Prevention study. Int J Obes Relat Metab Disord. 1997;21:457-464. [pmid: 9192229].
76 Wing R R, Anglin K. Effectiveness of a behavioral weight control program for blacks and whites with NIDDM. Diabetes Care. 1996;19:409-413. [pmid: 8732700].
77 Lindholm L H, Ekbom T, Dash C, Eriksson M, Tibblin G, Schersten B. The impact of health care advice given in primary care on cardiovascular risk. CELL Study Group. BMJ. 1995;310:1105-1109. [pmid: 7742677]. [pmcid: 2549500].
78 Imperial Cancer Research Fund OXCHECK Study Group. Effectiveness of health checks conducted by nurses in primary care: final results of the OXCHECK study. BMJ. 1995;310:1099-1104. [pmid: 7742676]. [pmcid: 2549499].
79 Knowler W C, Barrett-Connor E, Fowler S E, et al. Diabetes Prevention Program Research Group. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346(6):393-403. [pmid: 11832527]. [pmcid: 1370926].
80 Ashley J M, St Jeor S T, Schrage J P, et al. Weight control in the physician's office. Arch Int Med. 2001;161:1599-604. [pmid: 11434791].
81 Bemelmans W J, Broer J, de Vries J H, Hulshof K F, May J F, Meyboom-De Jong B. Impact of Mediterranean diet education versus posted leaflet on dietary habits and serum cholesterol in a high risk population for cardiovascular disease. Public Health Nutr. 2000;3:273-283. [pmid: 10979147].
82 Arterburn D, Noel P H. Extracts from ‘Clinical Evidence’. Obesity. BMJ. 2001;322:1406-1409. [pmid: 11397749]. [pmcid: 1120474].
83 James W P, Astrup A, Finer N, et al. Effect of sibutramine on weight maintenance after weight loss: a randomised trial. STORM Study Group. Sibutramine Trial of Obesity Reduction and Maintenance. Lancet. 2000;356:2119-2125. [pmid: 11191537].
84 Fujioka K, Seaton T B, Rowe E, et al. Weight loss with sibutramine improves glycaemic control and other metabolic parameters in obese patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2000;2:175-187. [pmid: 11220553].
85 Gokcel A, Karakose H, Ertorer E M, Tanaci N, Tutuncu N B, Guvener N. Effects of sibutramine in obese female subjects with type 2 diabetes and poor blood glucose control. Diabetes Care. 2001;24:1957-1960. [pmid: 11679464].
86 Smith IG, Goulder MA, On behalf of the Members of the Sibutramine Clinical Study 1047 T. Randomized placebo-controlled trial of long-term treatment with sibutramine in mild to moderate obesity. J Fam Pract. 2001;50:505–512
87 Wirth A, Krause J. Long-term weight loss with sibutramine: a randomized controlled trial. JAMA. 2001;286:1331-1339. [pmid: 11560538].
88 Dujovne CA, Zavoral JH, Rowe E, Mendel CM, The Silbutramine Study G. Effects of sibutramine on body weight and serum lipids: a double-blind, randomized, placebo-controlled study in 322 overweight and obese patients with dyslipidemia. Am Heart J. 2001;142:489–497.
89 Van Gaal L F, Broom J I, Enzi G, Toplak H. Efficacy and tolerability of orlistat in the treatment of obesity: a 6-month dose-ranging study. Orlistat Dose-Ranging Study Group. Eur J Clin Pharmacol. 1998;54:125-132. [pmid: 9626916].
90 Hill J O, Hauptman J, Anderson J W, et al. Orlistat, a lipase inhibitor, for weight maintenance after conventional dieting: a 1-y study. Am J Clin Nutr. 1999;69:1108-1116. [pmid: 10357727].
91 Karhunen L, Franssila-Kallunki A, Rissanen P, et al. Effect of orlistat treatment on body composition and resting energy expenditure during a two-year weight-reduction programme in obese Finns. Int J Obes Relat Metab Disord. 2000;24:1567-1572. [pmid: 11126207].
92 Micic D, Ivkovic-Lazar T, Dragojevic R, Jorga J, Stokic E, Hajdukovic Z. Orlistat, a gastrointestinal lipase inhibitor, in therapy of obesity with concomitant hyperlipidemia. Med Pregl. 1999;52:323-333. [pmid: 10624380].
93 Muls E, Kolanowski J, Scheen A, Van Gaal L, ObelHyx Study G. The effects of orlistat on weight and on serum lipids in obese patients with hypercholesterolemia: a randomized, double-blind, placebo-controlled, multicentre study. Int J Obes. 2001;25:1713-1721.
94 Rissanen A. Pharmacological intervention: the antiobesity approach. Euro J Clin Invest. 1998;28(Suppl 2):27-30.
95 Giugliano D, Quatraro A, Consoli G, et al. Metformin for obese, insulin-treated diabetic patients: improvement in glycaemic control and reduction of metabolic risk factors. Eur J Clin Pharmacol. 1993;44:107-112. [pmid: 8453955].
96 Rissanen P, Vahtera E, Krusius T, Uusitupa M, Rissanen A. Weight change and blood coagulability and fibrinolysis in healthy obese women. Int J Obes. 2001;25:212-218.
97 de Wit LT, Mathus-Vliegen L, Hey C, Rademaker B, Gouma DJ, Obertop H. Open versus laparoscopic adjustable silicone gastric banding: a prospective randomized trial for treatment of morbid obesity. Ann Surg. 1999;230:800–805; discussion 805–807.
98 Weiner R, Bockhorn H, Rosenthal R, Wagner D. A prospective randomized trial of different laparoscopic gastric banding techniques for morbid obesity. Surg Endosc. 2001;15:63-68. [pmid: 11178766].
99 Sjostrom L, Larsson B, Backman L, et al. Swedish obese subjects (SOS). Recruitment for an intervention study and a selected description of the obese state. Int J Obes Relat Metab Disord. 1992;16:465-479. [pmid: 1322873].
100 Torgerson J S, Sjostrom L. The Swedish Obese Subjects (SOS) study--rationale and results. Int J Obes Relat Metab Disord. 2001;25(Suppl 1):S2-S4. [pmid: 11466577].
101 Pories WJ, Swanson MS, MacDonald KG, et al. Who would have thought it? An operation proves to be the most effective therapy for adult-onset diabetes mellitus. Ann Surg. 1995;222:339–350; discussion 350–352.
102 Long S D, O'Brien K, MacDonald K G, et al. Weight loss in severely obese subjects prevents the progression of impaired glucose tolerance to type II diabetes. A longitudinal interventional study. Diabetes Care. 1994;17:372-375. [pmid: 8062602].
103 Brolin R E, Bradley L J, Wilson A C, Cody R P. Lipid risk profile and weight stability after gastric restrictive operations for morbid obesity. J Gastrointest Surg. 2000;4:464-469. [pmid: 11077320].
104 Sjostrom C D, Lissner L, Wedel H, Sjostrom L. Reduction in incidence of diabetes, hypertension and lipid disturbances after intentional weight loss induced by bariatric surgery: the SOS Intervention Study. Obes Res. 1999;7:477-484. [pmid: 10509605].
105 Sjostrom C D, Peltonen M, Sjostrom L. Blood pressure and pulse pressure during long-term weight loss in the obese: the Swedish Obese Subjects (SOS) Intervention Study. Obes Res. 2001;9:188-195. [pmid: 11323444].
106 Andres R, Muller D C, Sorkin J D. Long-term effects of change in body weight on all-cause mortality. A review. Ann Intern Med. 1993;119:737-743. [pmid: 8363208].
107 Williamson D F, Pamuk E, Thun M, Flanders D, Byers T, Heath C. Prospective study of intentional weight loss and mortality in never- smoking overweight US white women aged 40–64 years. Am J Epidemiol. 1995;141:1128-1141. [pmid: 7771451].
108 Melissas J, Christodoulakis M, Spyridakis M, et al. Disorders associated with clinically severe obesity: significant improvement after surgical weight reduction. South Med J. 1998;91:1143-1148. [pmid: 9853727].
109 Bloomston M, Zervos E E, Camps M A, Goode S E, Rosemurgy A S. Outcome following bariatric surgery in super versus morbidly obese patients: does weight matter?. Obes Surg. 1997;7:414-419. [pmid: 9730495].
110 Balsiger B M, Poggio J L, Mai J, Kelly K A, Sarr M G. Ten and more years after vertical banded gastroplasty as primary operation for morbid obesity. J Gastrointest Surg. 2000;4:598-605. [pmid: 11307094].
111 Davila-Cervantes A, Ganci-Cerrud G, Gamino R, Gallegos-Martinez J, Gonzalez-Barranco J, Herrera M F. Open vs. laparoscopic vertical banded gastroplasty: a case control study with a 1-year follow-up. Obes Surg. 2000;10:409-412. [pmid: 11054244].
112 Alper D, Ramadan E, Vishne T, et al. Silastic ring vertical gastroplasty- long-term results and complications. Obes Surg. 2000;10:250-254. [pmid: 10929157].
113 Choi Y, Frizzi J, Foley A, Harkabus M. Patient satisfaction and results of vertical banded gastroplasty and gastric bypass. Obes Surg. 1999;9:33-35. [pmid: 10065578].
114 Papakonstantinou A, Alfaras P, Komessidou V, Hadjiyannakis E. Gastrointestinal complications after vertical banded gastroplasty. Obes Surg. 1998;8:215-217. [pmid: 9730397].
115 Baltasar A, Bou R, Arlandis F, et al. Vertical banded gastroplasty at more than 5 years. Obes Surg. 1998;8:29-34. [pmid: 9562483].
116 Stoner J, Stoner P, Sytsma J. 42-month preliminary follow-up of the silastic ring vertical banded gastroplasty. Obes Surg. 1997;7:513-515. [pmid: 9730510].
117 Yashkov YI, Timoshin AD, Oppel TA. Vertical banded gastroplasty: first experience in Russia. Obes Surg. 1997;7:317–320; discussion 321.
118 Goulding S T, Hovell B C. Anaesthetic experience of vertical banded gastroplasty. Br J Anaesth. 1995;75:301-306. [pmid: 7547048].
119 Lundell L, Ruth M, Olbe L. Vertical banded gastroplasty or gastric banding for morbid obesity: effects on gastro-oesophageal reflux. Eur J Surg. 1997;163:525-531. [pmid: 9248987].
120 Schauer P R, Ikramuddin S, Gourash W, Ramanathan R, Luketich J. Outcomes after laparoscopic Roux-en-Y gastric bypass for morbid obesity. Ann Surg. 2000;232:515-529. [pmid: 10998650]. [pmcid: 1421184].
121 Nguyen NT, Ho HS, Palmer LS, Wolfe BM. A comparison study of laparoscopic versus open gastric bypass for morbid obesity. J Am Coll Surg. 2000;191:149–155; discussion 155–157.
122 Choban P S, Onyejekwe J, Burge J C, Flancbaum L. A health status assessment of the impact of weight loss following Roux-en-Y gastric bypass for clinically severe obesity. J Am Coll Surg. 1999;188:491-497. [pmid: 10235576].
123 Jones K B. Roux-en-Y gastric bypass: an effective antireflux procedure in the less than morbidly obese. Obes Surg. 1998;8:35-38. [pmid: 9562484].
124 Crampton N A, Izvornikov V, Stubbs R S. Silastic ring gastric bypass: results in 64 patients. Obes Surg. 1997;7:489-494. [pmid: 9730506].
125 Freeman J B, Kotlarewsky M, Phoenix C. Weight loss after extended gastric bypass. Obes Surg. 1997;7:337-344. [pmid: 9730521].
126 Oh CH, Kim HJ, Oh S. Weight loss following transected gastric bypass with proximal Roux-en-Y. Obes Surg. 1997;7:142–147; discussion 148.
127 Abu-Abeid S, Szold A. Laparoscopic management of Lap-Band erosion. Obes Surg. 2001;11:87-89. [pmid: 11361174].
128 Nowara H A. Egyptian experience in laparoscopic adjustable gastric banding (technique, complications and intermediate results). Obes Surg. 2001;11:70-75. [pmid: 11361172].
129 De Luca M, de Werra C, Formato A, et al. Laparotomic vs laparoscopic lap-band: 4-year results with early and intermediate complications. Obes Surg. 2000;10:266-268. [pmid: 10929160].
130 Suter M, Bettschart V, Giusti V, Heraief E, Jayet A. A 3-year experience with laparoscopic gastric banding for obesity. Surg Endosc. 2000;14:532-536. [pmid: 10890959].
131 Wiesner W, Schob O, Hauser R S, Hauser M. Adjustable laparoscopic gastric banding in patients with morbid obesity: radiographic management, results, and postoperative complications. Radiology. 2000;216:389-394. [pmid: 10924559].
132 Holeczy P, Novak P, Kralova A. Complications in the first year of laparoscopic gastric banding: is it acceptable?. Obes Surg. 1999;9:453-455. [pmid: 10605902].
133 Dargent J. Laparoscopic adjustable gastric banding: lessons from the first 500 patients in a single institution. Obes Surg. 1999;9:446-452. [pmid: 10605901].
134 Suter M, Giusti V, Heraief E, Jayet C, Jayet A. Early results of laparoscopic gastric banding compared with open vertical banded gastroplasty. Obes Surg. 1999;9:374-380. [pmid: 10484296].
135 Abu-Abeid S, Szold A. Results and complications of laparoscopic adjustable gastric banding: an early and intermediate experience. Obes Surg. 1999;9:188-190. [pmid: 10340776].
136 Miller K, Hell E. Laparoscopic adjustable gastric banding: a prospective 4-year follow-up study. Obes Surg. 1999;9:183-187. [pmid: 10340775].
137 Forsell P, Hallerback B, Glise H, Hellers G. Complications following Swedish adjustable gastric banding: a long-term follow-up. Obes Surg. 1999;9:11-16. [pmid: 10065574].
138 Doherty C, Maher J W, Heitshusen D S. Prospective investigation of complications, reoperations, and sustained weight loss with an adjustable gastric banding device for treatment of morbid obesity. J Gastrointest Surg. 1998;2:102-108. [pmid: 9841975].
139 Forestieri P, Meucci L, De Luca M, Formato A, De Werra C, Chiacchio C. Two years of practice in adjustable silicone gastric banding (LAP-BAND): evaluation of variations of body mass index, percentage ideal body weight and percentage excess body weight. Obes Surg. 1998;8:49-52. [pmid: 9562487].
140 Forsell P, Hellers G. The Swedish Adjustable Gastric Banding (SAGB) for morbid obesity: 9 year experience and a 4-year follow-up of patients operated with a new adjustable band. Obes Surg. 1997;7:345-351. [pmid: 9730522].
141 Horchner R, Tuinebreijer W. Improvement of physical functioning of morbidly obese patients who have undergone a Lap-Band operation: one-year study. Obes Surg. 1999;9:399-402. [pmid: 10484301].
142 Doldi S B, Micheletto G, Lattuada E, Zappa M A, Bona D, Sonvico U. Adjustable gastric banding: 5-year experience. Obes Surg. 2000;10:171-173. [pmid: 10782180].