# Acknowledgments

This study was supported by Contract 290-97-0011 from the Agency of Healthcare Research and Quality (Task No. 3). We acknowledge at AHRQ the continuing support of Jacqueline Besteman, JD, MA, Director for the Evidence-based Practice Center program; David Atkins, MD, MPH, Chief Medical Officer of the AHRQ Center for Practice and Technology Assessment; and Jean Slutsky, PA, MSPH, the Task Order Officer for this project. We would also like to acknowledge the guidance and assistance from our US Preventive Services Task Force liaisons, Janet Allan, PhD, RN, CS, FAAN and Mark Johnson, MD, MPH.

The investigators deeply appreciate the contributions of Loraine Monroe at RTI, for superior secretarial assistance. In addition, we are indebted to Timothy S. Carey, MD, MPH, Co-Director of the RTI-UNC Evidence-based Practice Center at the University of North Carolina Cecil G. Sheps Center for Health Services Research.

We also owe our thanks to the following external peer reviewers, who provided constructive feedback and insightful suggestions for improvement of this systematic evidence review: David Arterburn, MD, University of Washington, Seattle, WA; James D. Douketis, MD, McMaster University, Hamilton, Onatario, Canada; Evelyn L. Lewis-Clark, MD Bowie, MD, representing the American Academy of Family Physicians; F. Xavier Pi-Sunyer, MD, MPH, St Luke's/Roosevelt Hospital Center, New York, NY; Walter J. Pories, MD, East Carolina School of Medicine, Greenville, NC; Bruce A. Reeder, University of Saskatchewan, Saskatoon, Canada and representing the Canadian Task Force on Preventive Health Care; and Vincenza Snow, MD, American College of Physicians-American Society of Internal Medicine, Philadelphia, PA.